# Chapter 2 Methods

## Scope and Purpose

This review was commissioned to support the USPSTF in considering a recommendation on preventive services for food insecurity in primary care settings.

## Key Questions and Analytic Framework

We followed USPSTF procedures and methods to define study inclusion and exclusion criteria (Appendix A Table 1) and developed an Analytic Framework (Figure 1) and five key questions (KQs) to guide the literature search, data abstraction, and data synthesis.

Figure 1 Analytic Framework

* Intermediate outcomes include behavioral, physiologic, decision-making, patient participation, and healthcare utilization outcomes.

Figure 1 is the analytic framework that depicts the Key Questions addressed in the systematic review. The figure illustrates how assessment for food insecurity may impact health outcomes (KQ1), may lead to detection of food insecurity (KQ2), and may lead to harms or unintended consequences of assessment (KQ3). Additionally, the figure illustrates how interventions for food insecurity may impact health outcomes (KQ4) and have harms or unintended consequences (KQ5). Finally, the figure illustrates that food insecurity status may impact intermediate outcomes (KQ4a) or health outcomes (KQ4b), and that intermediate outcomes may also impact health outcomes (KQ4b). This figure is discussed in the Methods section.

1. Does identifying food insecurity in healthcare improve health outcomes?
2. What is the performance of risk assessment or screening tools to identify food insecurity?
3. What are the harms or unintended consequences of assessment for food insecurity?
4. What is the effect of healthcare-related interventions to address food insecurity on food security, intermediate outcomes, or health outcomes?
  a. What are the effects of improvements in food security outcomes on intermediate and health outcomes?
  b. What are the effects of improvements in intermediate outcomes on health outcomes?
5. What are the harms or unintended consequences of healthcare-related interventions to address food insecurity?

## Data Sources and Searches

This review builds upon the work of a 2021 technical brief conducted for the USPSTF^11^ on screening and interventions for social risk factors and a 2019 scoping review by De Marchis and colleagues addressing screening for food insecurity in healthcare settings.^99^ We evaluated the studies included in these reports, comparing them with this review’s inclusion and exclusion criteria, and conducted bridge searches to capture any new studies relevant to screening or interventions for social risk factors that include food insecurity. We bridged from the existing searches by searching MEDLINE via Ovid, CINAHL via EBSCO, and the Cochrane Central Registry of Controlled Trials for relevant studies published beginning January 1, 2017 (for screening studies, bridging from the De Marchis review) and June 1, 2018 (for intervention studies, bridging from the technical brief) and ending on August 21, 2023. A research librarian developed and executed the search, which was peer reviewed by a second research librarian (Appendix A). We limited all searches to articles published in English.

In addition to database searches, we examined the reference lists of other previously published reviews, meta-analyses, and primary studies to identify potential studies for inclusion. We also reviewed the literature in the Patient-Centered Outcomes Research Institute Evidence Map on Social Needs Interventions to Improve Health Outcomes.^100^ We supplemented our searches with news and table-of-content alerts such as those produced by the USPSTF Scientific Resource Center LitWatch activity.^101^ We conducted ongoing surveillance for relevant literature through April 3, 2024. One new study showing high sensitivity and specificity of the Abbreviated Child and Adult Food Security Scale was identified; however, it did not substantively change the review’s interpretation of findings or conclusions and is not addressed further.^102^ We managed literature search results using version X9 of Endnote® (Thomson Reuters, New York, NY), a bibliographic management software database.

## Study Selection

Two reviewers independently reviewed the title and abstract of each identified article using DistillerSR (DistillerSR, Inc, Ottawa, Canada) to determine whether the study might meet our a priori inclusion criteria for aim, population, intervention, comparator, outcomes, setting, and study design. Two reviewers then independently evaluated full-text articles of all potentially relevant studies against the complete inclusion criteria. We resolved disagreements about the abstract and/or full-text review disposition by discussion. A list of included studies is available in Appendix B and excluded studies can be found in Appendix C.

The review was limited to U.S.-based studies because other economically developed nations have very different social benefits and social welfare structures, as well as different structures and resourcing of food accessibility for lower-income households. For all KQs other than KQ2 (performance of screening tools), some part of each study had to have occurred in a healthcare setting (e.g., case-finding, recruitment, referral, intervention) and included screening conducted in a clinical setting or identified through a healthcare delivery or payment system (e.g., health plan data) and interventions or programs integrated into, associated with, or referred from healthcare. For KQ2 (performance of screening tools), we included studies that did not have a healthcare connection but did have large, nationally representative U.S. samples after finding two such studies based on U.S. census data. We applied no age restrictions for any KQ. We excluded studies limited to participants who were undergoing cancer treatment, had other acute medical or psychiatric conditions, or had severe malnutrition or known nutritional deficiencies. In addition, we excluded studies if one of these groups comprised more than 50 percent of the study sample. However, we included studies that were limited to participants with chronic medical conditions such as diabetes and hypertension.

For KQ1 (benefits of screening) and KQ3 (harms of screening), we included both randomized clinical trials (RCTs) and nonrandomized studies of interventions (NRSIs) comparing a group that was systematically screened for food insecurity with a group that was not systematically or universally screened for food insecurity. We allowed naturalistic screening in individual cases as part of usual care in the control groups. KQ1 and KQ3 studies may include interventions to address food insecurity for those screening positive. For studies that screened for multiple social needs (e.g., housing, transportation, financial need), we included only food security–related outcomes because improvements in other outcomes could be due to changes in other social needs entirely independent of screening for food insecurity. For studies that screened for multiple social needs, we required reporting of baseline and followup measures of food insecurity. We required at least 12 weeks of followup after the baseline assessment for KQ1 but applied no restrictions for KQ3, on the assumption that short-term harms could be clinically meaningful. For KQ1, outcomes included food and nutrition security, access to food, behavioral outcomes (e.g., dietary intake, substance use), physiologic outcomes (e.g., blood pressure, lipid levels, glucose or insulin-related measures), healthcare-related decision-making outcomes, health-related patient participation outcomes (e.g., medication compliance, attendance at medical appointments), healthcare utilization outcomes (e.g., emergency department visits, hospitalizations), and health outcomes (i.e., outcomes directly felt by patients, such as quality of life, mental health, cardiovascular events, and developmental outcomes in children). We included any harms to study participants identified by the studies for KQ3.

For KQ2 (performance of screening tools), we included studies that compared either a brief screener or risk assessment tool with a longer, more detailed assessment of food insecurity, such as the USDA food security surveys.^103^ The screener could involve a brief (e.g., 1- to 2-minute) set of questions asked directly of the study participant or use medical records to identify patients at higher risk. For inclusion, we required that studies report one or more measures of test accuracy (sensitivity, specificity) or test discrimination (for risk assessment tools), or sufficient data to calculate them.

For KQ4 (benefits of interventions) and KQ5 (harms of interventions), we included randomized trials, NRSIs with a control comparison group, and pre-post studies without contemporaneous comparison groups.

Included interventions had to have elements specifically designed to reduce food insecurity, such as directly providing food or food vouchers, referrals to local food resources, or assistance signing up for government or other food assistance programs. We limited KQ4a and 4b to studies included in KQ4.

For KQ4 (benefits of interventions) studies with interventions that primarily or exclusively addressed food insecurity, we required that samples either 1) include 50 percent or more with food insecurity at baseline or 2) reported results separately for participants with food insecurity at baseline. For interventions that addressed other social and health needs in addition to food insecurity, the percent with food insecurity had to be reported at baseline and followup.

We extracted only outcomes related to food security for studies with components that addressed risk factors other than food insecurity. Other components, such as housing, transportation, nutrition education, and healthcare, could directly impact intermediate and health outcomes such as blood pressure or quality of life. Thus, we felt it could be misleading to ascribe improvements in these outcomes to the food-related components of the intervention. The full list of relevant outcomes was abstracted for KQ4 interventions that only addressed food insecurity. We included any harms reported by the KQ4 studies for KQ5 (harms of interventions). We required at least 12 weeks of followup after the baseline assessment for KQ4 but applied no restrictions for KQ5, on the assumption that short-term harms could be clinically meaningful.

## Quality Assessment and Data Abstraction

Two reviewers independently assessed the methodological quality of each study by applying predefined study-design specific criteria (Appendix A Table 2).^101^ For screening accuracy evidence (KQ2) we used the Quality Assessment of Diagnostic Accuracy Studies (QUADAS)-2.^104^ For RCT and NRSI evidence, we applied signaling questions from the Cochrane Risk of Bias (RoB 2) tool^105^ and the Risk of Bias In Non-randomized Studies of Interventions (ROBINS-I) tool^106^, respectively, along with the USPSTF-design specific criteria.^101^ We used criteria developed by the National Heart, Lung, and Blood Institute to rate pre-post studies and multi-arm comparative effectiveness studies—which we treated as pre-post studies (see Study Selection).^107^ For pre-post studies, we used item 11 as a signaling question (“Were outcome measures of interest taken multiple times before the intervention and multiple times after the intervention?”). We rated studies as poor quality that did not use this design and conducted no further assessment of risk of bias. Disagreements about quality ratings were resolved by discussion. Each study was given a final quality rating of good (low risk of bias), fair (moderate risk of bias), or poor (high risk of bias). We rated studies based on the main outcome of interest to our review, and the quality rating reflected our confidence that the food security screening or intervention caused the changes in the relevant outcomes. As mentioned above, a study’s primary aim might have differed from the result extracted for this review, so a poor-quality rating does not necessarily reflect a high risk of bias for the study’s primary aim.

Good-quality studies were those that met nearly all the specified quality criteria for the outcome of interest to this review (e.g., comparable groups were assembled initially and maintained throughout the study, followup was approximately ≥85%, conservative data substitution methods were used in cases of missing data, no evidence of selective outcome or analysis reporting). Fair-quality studies did not meet all these criteria but did not have serious threats to their internal validity related to the design or execution of the study. Studies we rated as poor quality had several important limitations, including at least one of the following risks of bias: no control group to determine whether change differed from naturalistic rates or lack of repeated measures before and after the intervention to establish clear baseline and followup rates; very high attrition (generally >40%) or unknown attrition, differential attrition between intervention arms (generally >20%); lack of baseline comparability between groups without adjustment; unclear methods or differing methods between groups for ascertainment of outcomes; or issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting, inappropriate exclusion of participants from analyses, and questionable validity of randomization and allocation concealment procedures). Due to the lack of literature and the pilot nature of this review in addressing unmet social needs, we departed from usual USPSTF methods and included poor-quality studies in the evidence base for KQ4 and KQ5.

For all included studies, one reviewer extracted key elements into standardized abstraction forms in DistillerSR (Evidence Partners, Ottawa, Canada). A second reviewer checked the data for accuracy. For each study, we abstracted general characteristics (e.g., author, year, study design, setting), sample characteristics (e.g., age, race and ethnicity, socioeconomic characteristics), screening approach, intervention duration and components, and results. For intervention characteristics, we abstracted information on both food-related and non-food–related components. Food security–related components included provision of food (not medically tailored), medically tailored food, medically tailored prepared meals, food vouchers, community referrals, and support in completing applications for food assistance. Examples of non-food security components included those addressing housing, transportation, employment, education, utilities, language barriers, social isolation, interpersonal violence, childcare, and legal concerns. We considered nutrition or meal preparation education to be separate from food security unless we characterized it as minimal (e.g., electronic newsletters or print materials included in food boxes; optional food tastings, demonstrations, and information at food box pick-up sites).

## Data Synthesis and Analysis

We developed separate tables for each of the three broad bodies of evidence covered by this review: studies of food security screening (KQs 1 and 3), studies on the accuracy of the screening tools (KQ2), and studies on interventions to improve food security (KQs 4 and 5). The tables included study, population, intervention characteristics, and outcomes. We examined population characteristics to ascertain whether the evidence included traditionally marginalized or underrepresented groups that have a higher prevalence of food insecurity, such as Black, Hispanic, and American Indian/Alaska Native populations.

To synthesize findings on screening tool accuracy, we calculated sensitivity and specificity based on the 2-by-2 contingency table of true positives, false positives, true negatives, and false negatives if they were not reported. Most studies examined agreement between the full HFSS 18-item assessment tool and a subset of the items embedded in this tool, without separate administration of the screener and reference standard. We used the terms “sensitivity” and “specificity” but acknowledge the departure from the preferred method of independent administration.

For KQ4, we grouped interventions into three broad categories:

- Food security only: intervention focused only on food security (e.g., providing food or vouchers for food, referrals to local organizations that provide food, assistance with food-related benefits such as SNAP and WIC) and did not address other social needs.
- Food security + nutrition education: combined food security components with nutrition and food preparation education (beyond minimal approaches such as inserts in food boxes or demonstrations at food box pick-ups).
- Multidomain: multidomain interventions that assessed and addressed other social needs in addition to food insecurity, as needed.

Because intervention components addressing nutrition, medical needs or disease management, or other social needs could affect health and intermediate outcomes, only food security–related outcomes were reported for studies with the latter two intervention categories (food security + nutrition education, multidomain). The highest-level food security components were identified and categorized as: 1) food (e.g., food boxes, delivery of prepared meals), 2) vouchers (exchanged for food, or subsidies to increase purchasing power), 3) application support (e.g., patient navigation or help with identifying relevant resources and completing applications), and 4) referral only (information about local and federal food resources with no further support).

We conducted narrative synthesis of the evidence based on the created tables, since evidence was too sparse and heterogeneous for meta-analysis. For the outcome of percent with food insecurity, however, we calculated risk ratios (RRs) and 95 percent CIs comparing the intervention and control groups for traditional RCTs and NRSIs, “on-meal” and “off-meal” for a randomized crossover trial of meal provision, and post-intervention versus pre-intervention values for pre-post studies, consistent with another review on this topic.^80^ RRs are shown in a forest plot but not pooled, due to the heterogeneity in study design and other important features. All significance testing was 2-sided, and results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach,^108^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^109^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

We rated the domain of consistency as reasonably consistent, inconsistent, or not applicable (e.g., single study) and the domain of precision as reasonably precise, imprecise, or not applicable (e.g., no evidence). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body-of-evidence limitations field highlights important restrictions in answering the overall KQ (e.g., evidence of reporting bias, lack of replication of interventions, nonreporting of outcomes important to patients).

At least two independent reviewers rated the overall strength of evidence for each intervention type. We resolved discrepancies through consensus discussion with the full review team, consulting with outside reviewers as needed. We graded the overall strength of evidence as high, moderate, low, or insufficient. “High” indicated high confidence that the evidence reflected the true effect, and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicated moderate confidence that the evidence reflected the true effect, and that further research may change our confidence in the estimate of effect as well as the estimate. “Low” indicated low confidence that the evidence reflected the true effect, and that further research is likely to change our confidence in the estimate of effect as well as the estimate. A grade of “insufficient” indicated that evidence was either unavailable or did not permit an estimate of an effect.

## Contextual Questions

In addition to the systematically reviewed questions, we addressed contextual questions (CQs) to aid with the broader interpretation of the evidence. CQs are important considerations that may not be readily answerable from the KQ evidence. Seven CQs were prespecified in our Research Plan:

1. What risk assessment or screening tools are commonly used in clinical practice to identify food insecurity? What are the benefits and limitations of these tools (e.g., ease of administration)?
2. What factors inform the appropriate reassessment interval for food insecurity?
3. What are important moderators that affect the effectiveness or harms of food insecurity assessment and healthcare-related interventions?
4. What is the acceptability (e.g., satisfaction) of food insecurity assessment and healthcare-related interventions to patients and providers?
5. What is the uptake of services (e.g., rate of adoption, receipt of benefits) after food insecurity is identified?
6. What are the patient, provider, and health system facilitators and barriers to implementing assessment for food insecurity?
7. What are the patient, provider, health system, and community facilitators and barriers to implementing interventions to address food insecurity?

CQs were not systematically reviewed. Evidence for CQs was identified based on literature retrieved for the systematic search for KQs as well as targeted searches and scanning bibliographies of relevant articles. A best-evidence approach was used to identify the most recent, applicable, and robust evidence. CQs are addressed in the Introduction and Discussion section of this report.

## Expert Review and Public Comment

A draft Research Plan including the Analytic Framework, KQs, and inclusion and exclusion criteria was posted on the USPSTF website for public comment from February 22 to March 21, 2022. In response to public comment, the USPSTF added several outcomes to KQs 1 and 4, including food access, clinical decision making, and patient adherence. The USPSTF also made minor clarifying changes to the KQs, CQs, and inclusion criteria. A final Research Plan was posted to the USPSTF website on July 28, 2022.

The draft version of this report was reviewed by invited experts and individuals at USPSTF federal partner agencies. Experts were selected based on their expertise with both methodologic and content aspects of the review and were selected to obtain diverse informed perspectives. The revised draft of the report was posted for public comment on the USPSTF website from June 25, 2024, to July 22, 2024. The draft received several public comments, leading to minor editorial changes but no updates to the included evidence or report conclusions.

## USPSTF and AHRQ Involvement

We worked with USPSTF members at key points throughout this review, particularly when determining the scope and methods and developing the Analytic Framework and KQs. The USPSTF members approved the final Analytic Framework, KQs, and inclusion and exclusion criteria after revisions reflecting the public comment period. AHRQ staff provided oversight for the project, coordinated the review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.