# Chapter 1 Introduction

## Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to make a recommendation on Preventive Services for Food Insecurity.

## Condition Background

### Condition Definition

Food insecurity is generally defined as a household-level economic and social condition of limited or uncertain access to sufficient amounts of safe, nutritious food needed for an active and healthy life.^1,2^ Food insecurity, reflecting economic instability, may be long term or temporary. For some, it may occur following a specific event (e.g., loss of employment), while for others it may occur regularly (e.g., running out of money at the end of each month due to other competing expenses).^3^ Additionally, food insecurity can differ even among members of a household; for instance, adults are more likely to go without food to maintain the dietary patterns of the children in the household. Food insecurity differs from hunger, which is an individual-level physiological state that may result from food insecurity and is defined as insufficient caloric intake.^4^ The U.S. Department of Agriculture (USDA) divides food insecurity into two categories: “very low food security,” in which some household members reduce their food intake because of an inability to afford enough food, and “low food security,” indicating that at some point during the year households reduced the quality, variety, and desirability of their diets while maintaining normal eating patterns.^5^ Food security also is classified according to two categories: “marginal food security,” in which households had problems or anxiety at times, but did not substantially alter the quality, variety, or quantity of their intake, and “high food security,” in which households had no problems or anxiety about consistently accessing adequate food.^5^ Thus, food insecurity can be thought of as a continuum in which individuals may alter the amount of food they consume, their preferred variety of foods, or their food sources (e.g., food pantries), and, in extreme cases, go without.^3,6^

Food insecurity may lead to disrupted meal patterns and/or skipped meals, which can contribute to inadequate dietary intake, malnutrition, nutritional deficiency, or poor dietary quality.^3,7^ Recently, there has been an increased focus on nutrition insecurity, which goes beyond simply meeting caloric sufficiency to include access to nutritious foods. Nutrition insecurity can occur with or without food insecurity; for instance, one can consume sufficient calories without meeting nutritional recommendations for vegetables or protein. However, the concepts are often linked, as food insecurity can imply some degree of nutrition insecurity. A definition of food security that incorporates nutrition security includes consistent, equitable, and reliable access, availability, and affordability of foods that promote well-being.^8,9^ Another related term is food insufficiency, which refers to lack of adequate quantity of food in past week.^10^

Food insecurity is considered a key social risk factor—a measurable, intervenable, individual-level social and economic condition shaped by broader social and structural determinants of health such as house costs, wages, and the cost of higher education.^11–14^ Social needs are social risk factors that individuals prioritize as something they believe is important to address and would like assistance with.^12^ The Centers for Medicare & Medicaid Services (CMS) has identified five core social risk factors that community services can help with: food insecurity, housing instability, transportation needs, utility help needs, and interpersonal safety.^15^ These social risk factors are interconnected. For instance, a low income and unemployment are often directly connected to other risk factors, such as food insecurity, housing instability, and transportation issues.

### Historical Context

The concept of food insecurity has evolved over time. Fifty years ago, hunger was a prominent cause of disease in children in the United States.^8^ Since then, federal policies and programs, such as the Supplemental Nutrition Assistance Program (SNAP) (previously Food Stamps), National School Lunch and Breakfast Programs, Special Supplementation Nutrition Program for Women, Infants, and Children (WIC), and local hunger relief agencies have greatly reduced the issue of hunger, although food insecurity is still a concern for many families in the United States, and disparities in access to healthy and affordable food remain.

### Prevalence and Burden

#### Prevalence of Food Insecurity

According to the USDA Economic Research Service’s Current Population Survey (CPS), 12.8 percent (17.0 million) of households were food insecure in 2022, with 7.7 percent of households experiencing low food security and 5.1 percent of households experiencing very low food security.^16,17^ The 2022 prevalence of food insecurity (12.8%) is significantly higher than the prevalence measured from 2017 through 2020.^16^ The economic changes and fluctuations of government aid programs during and after the COVID-19 pandemic have also significantly impacted rates of food insecurity: in April 2020, the prevalence of food insecurity was reported to be as high as 20.4 percent,^18^ and while the USDA implemented a number of economic support programs in 2020, including some specific to food and nutrition assistance, many of those programs have since come to an end.^16^

The prevalence of food insecurity varies significantly by household type and is higher in households with children (17.3%), households with children younger than age 6 years (16.7%), households headed by a single woman (33.1%) or a single man (21.2%), and households with incomes below 185 percent of the poverty threshold (32.0%).^16,17^ While children are sometimes protected from substantial reductions in food intake even in households with very low food security, about 1.0 percent of all households with children in the United States (381,000 households) experienced very low food security: these households reported that children were hungry, skipped a meal, or didn’t eat for an entire day due to lack of money for food.^15–17^ People who identify as lesbian, gay, bisexual, or trans (LGBT) are also more than twice as likely to experience food insecurity as the general population, especially adults younger than age 35 years.^19,20^

Older adults are also at increased risk for food insecurity. Over the past two decades in the United States, food insecurity has increased by 45 percent in older adults.^21^ Adults with disabilities are also at high risk for food insecurity, primarily due to limited financial resources for food (i.e., limited income and employability along with high healthcare expenditures).^22^ Thirty-three percent of U.S. households with adults who are not in the labor force due to disability experience food insecurity, including 16.6 percent with very low food security, compared with 8.1 percent of households without an adult with disabilities.^23^

Working-age veterans have a 7.4 percent greater risk for food insecurity than nonveterans. From 2015 to 2019, 11.1 percent of working-age veterans lived in food insecure households, and 5.3 percent lived in households with very low food security.^24^ Food insecurity was substantially higher among disabled (33.6%), unemployed (20.0%), and female (13.5%) working-age veterans.

There are also significant differences by race and ethnicity. In 2022, 22.4 percent of Black non-Hispanic households and 20.8 percent of Hispanic households experienced food insecurity, compared with 9.3 percent of White households.^16^ While USDA data on other racial and ethnic groups are not available, data from other studies indicate that American Indian/Alaska Native groups are more than twice as likely as White populations to experience food insecurity.^25–32^ The factors contributing to these differences are complex and related to other social needs such as income, employment, housing, and access to transportation, which are ultimately shaped by broader social and structural determinants. However, there is an increasing acknowledgment in the literature that racial discrimination and structural racism play an important role in health inequities, including food insecurity,^26,33^ and people of color have a higher risk of food insecurity even when other social risk factors are removed.^26–31^ In addition to structural racism, one study has shown that the frequency of lifetime racial discrimination is significantly associated with increased odds of experiencing very low food security.^32^

#### Burden of Food Insecurity

Links between living in a household experiencing food insecurity and health outcomes are well documented, especially in children, among whom food insecurity is associated with birth defects, anemia, cognitive problems, aggression, anxiety, asthma, behavioral problems, depression, suicide ideation, obesity, and worse oral health.^34,35^ In young children (e.g., ages 4 to 36 months), food insecurity is associated with developmental problems,^36^ and persistent food insecurity in early childhood has been associated with lower health status later in childhood.^37^ Experiences of hunger during childhood have also been associated with poor health into late adolescence.^38^ The causal pathways of food insecurity and adverse health outcomes in children are not well understood.^39–42^

In adults, living in a household with food insecurity is associated with an increased risk of obesity and a number of health conditions, including diabetes, hypertension, cardiovascular disease, asthma, chronic obstructive pulmonary disease, arthritis, and kidney disease.^5,34,43–45^ The relative probability of chronic disease and hospitalization increases significantly when adults experience more severe levels of household food insecurity.^5,46^ Those experiencing food insecurity are also more likely to experience poor mental health, including psychological distress, depression, and anxiety.^39–41,47–49^

Food insecurity among adults may impact health outcomes directly or indirectly; however, in children, the mechanisms are not fully understood. Some theoretical pathways include: 1) food insecurity can contribute to stress, depression, drug and alcohol use, and poor overall mental health status, which increases risk of cardiovascular disease and other adverse health outcomes;^50^ 2) individuals experiencing food insecurity are more likely to have cost-related medical nonadherence;^51,52^ 3) food insecurity may lead to peripheral insulin resistance and stress-related increases in cortisol and other physiologic impacts of stress, which can increase the risk for diabetes; ^34,52,53^ 4) food insecurity may lead individuals to alter their diets in ways that increase the risk of or impair management of conditions affected by diet, and subsequently increase obesity, which may in turn increase the risk of chronic disease;^34^ and 5) food insecurity may alter gut microbiota and/or white blood cell count, causing inflammation that has been associated with health conditions such as diabetes and cardiovascular disease.^54,55^ Regarding mental health outcomes, food insecurity can be both a cause and effect: the transition to food insecurity is associated with a decline in mental health, but food insecurity can also precede depression outcomes.^3^

### Risk Factors

#### Related Risk Factors

At its core, food insecurity is an economic issue; therefore, poverty, underemployment or unemployment, lack of affordable housing, and related economic factors are all likely to be risk factors for food insecurity. In 2022, 36.7 percent of households with annual incomes below 185 percent of the poverty threshold were food insecure, compared with 6.8 percent of those at or above the threshold.^16^ Unemployment can contribute to challenges in meeting basic household food needs,^56^ and children with unemployed parents have higher rates of food insecurity than those with employed parents.^57^ However, the high cost of housing in the United States contributes to food insecurity as well; data from the 2021 U.S. census indicate that 25.4 percent of renter-occupied households spend more than 50 percent of their incomes on housing,^58^ leaving fewer resources to pay for food.

The presence of chronic conditions is also considered a risk factor for food insecurity. In a sample of 41,854 adults experiencing poverty, food insecurity was associated with higher probability of 10 chronic conditions—hypertension, coronary heart disease, hepatitis, stroke, cancer, asthma, diabetes, arthritis, chronic obstructive pulmonary disease, and kidney disease—and was associated with the total number of chronic conditions reported.^5^ In a national sample of older adults, approximately 54 percent of food insecure people had two or more chronic conditions.^21^ Functional limitations is also a risk factor for food insecurity among older adults; an analysis of National Health and Nutrition Examination Survey data found that older adults with four or more physical limitations were more than twice as likely to report very low food security than older adults without limitations (adjusted odds ratio, 2.62 [95% confidence interval {CI}, 1.43 to 4.81]).^59^ Data from the Medical Expenditure Panel Survey indicate that the prevalence of food insecurity is much higher among adults with diabetes compared with those without diabetes (16% vs. 9%).^60^ Among Medicaid enrollees with insulin-dependent diabetes and diabetes-related eye or kidney complications, over 40 percent were food insecure.^60^ The pressure of limited income combined with increased healthcare expenditures, reduced employment opportunities, and increased stress related to chronic disease can all work together to increase the risk of food insecurity.^61^ Furthermore, for individuals with diet-related chronic disease such as diabetes, food insecurity can in turn exacerbate their health.

Neighborhood conditions can affect physical access to healthy foods, which may contribute to disparities. Low-income neighborhoods have fewer full-service supermarkets and more convenience stores.^62,63^ Residents are at higher risk for food insecurity in these neighborhoods, especially if public transportation options are limited.^64^ People with chronic diseases or disabilities and those residing in rural areas are less likely to have access to personal or public transportation, further limiting their access to food.^43,64,65^

### Rationale for Screening and Screening Strategies

Historically, the assessment of patients’ social needs has not been a routine part of preventive or primary care, but because food and nutrition security are so intertwined with health and health outcomes, some have argued that screening for food insecurity is an ethical imperative for clinicians and in healthcare.^66^ As a result, screening for unmet social needs is increasingly being linked with screening for health behaviors (e.g., smoking).

#### Commonly Used Tools to Identify Food Insecurity

The USDA’s Household Food Security Survey Module (HFSS) is the primary tool for the assessment of food insecurity in the United States.^67^ The HFSS includes a series of 10 questions for households with no children and 18 questions for households with children that elicit information on the household’s difficulty in meeting basic food needs due to lack of resources. These questions have been included as part of the Community Population Survey (distributed by the U.S. Census Bureau) since 1995. The 18-item scale has been further developed to incorporate subscales, including a 6-item set that measures food insecurity and hunger in states’ surveillance systems.^67^ Brief (1- or 2-item) screening tools to identify household food insecurity used in healthcare delivery settings are all derived from and validated against the HFSS (Table 1).^68^ The most frequently used and studied single-domain screening tool for food insecurity is the 2-item Hunger Vital Sign tool,^69–71^ which is available in one of the most widely used electronic health records systems (i.e., EPIC). Multiple social risk factors are often assessed via multidomain tools, rather than screening for food insecurity in isolation, and food or nutrition security are typically included in these tools (Appendix D Table 1). Evaluation of CMS’s Accountable Health Communities (AHC) Model found that tailoring social risk screening practices (e.g., timing, location, staff responsibility, mode of administration) to each clinical site’s workflows, staffing, and intake processes was important.^72^ Patients appear to prefer self-administered formats, and sparse evidence does not suggest a difference between formats specifically for the identification of food insecurity.^68,73^ ^74–76^ For more information see Appendix F, Contextual Questions, Contextual Question 1.

Table 1 Food +/− Nutrition Insecurity-Specific Assessment Tools

Name of Tool | Target population | Total # of questions
Hunger Vital Sign^70^ | Pediatrics | 2
U.S. Household Food Security Survey^67,103,181^ | Adults and children | 18
Short Form of the U.S. Household Food Security Survey^103^ | Adults | 6
U.S. Adult Food Security Survey^103^ | Adults | 10
U.S. Household Food Security Survey for Youth^103,182^ | Pediatrics (Ages 12 & older) | 9

Limited information is available to inform the appropriate reassessment interval for food insecurity. Food and nutrition insecurity may change over time, and research to date has not addressed the appropriate frequency of screening for food and nutrition insecurity.^68,73^ One study looking at food insecurity over the course of the first years of the COVID-19 pandemic found that children of caregivers who received social needs screenings and relevant referrals every 6 months had greater improvements in social needs than those who received routine annual well-child screenings and referrals,^77^ although the applicability to non-pandemic times is unclear. Furthermore, while the recall period for different screening tools varies from 30 days to 12 months, most screening tools do not assess the duration of food insecurity, and therefore cannot assess whether it is temporary or chronic.^78^ For more information see Appendix F, Contextual Questions, Contextual Question 2.

### Intervention Approaches

Interventions to address food and nutrition insecurity (Table 2) can include policies at the governmental or institutional level (e.g., WIC, SNAP, siting new grocery stores in underserved areas, fruit and vegetable gleaning initiatives), programs at the community level (e.g., community gardens, community kitchens for nutrition education) and at schools (e.g., school breakfast or lunch programs, farm-to-school programs, use of school-based health centers to connect families to community resources), and interventions directly embedded in healthcare (e.g., medically tailored meals or food prescriptions, food boxes or pantries linked to clinics). Other types of government programs provide monetary assistance that may not be specifically for food but can nonetheless address food and nutrition insecurity by offsetting other expenses (e.g., Medicaid expansion, child tax credit, federal safety net public assistance programs).

Table 2 Interventions to Address Food and Nutrition Insecurity^183^

Intervention target | Intervention | Description
HOUSEHOLD/INDIVIDUAL | Food or nutrition prescriptions | Provide prescriptions with healthy eating goals for patients and families, often accompanied by food subsidies or food supplies; most commonly prescribed foods are fruits and vegetables (i.e., produce prescriptions); can include partnerships with local farmers’ markets via FVRx programs or co-interventions like nutrition education
HOUSEHOLD/INDIVIDUAL | Food referrals | Passive (i.e., provide list of local resources) or active (i.e., provide navigation or directly links patients)
HOUSEHOLD/INDIVIDUAL | Medically tailored meals | Meals, usually delivered, tailored to severely ill individuals to meet specific medical and nutritional needs
HOUSEHOLD/INDIVIDUAL | Meal delivery programs | Deliver meals directly to participants’ residences; often targeted to those with limited mobility and/or transportation issues
COMMUNITY | Mobile produce markets | Support fresh food carts or vehicles that travel to neighborhoods on a set schedule to sell fresh fruits and vegetables
COMMUNITY | Farmers’ markets | Support multiple vendor markets where producers sell goods such as fresh fruit and vegetables, meat, dairy items, and prepared foods directly to consumers
COMMUNITY | Healthy food initiatives in food pantries | Combine hunger relief efforts with nutrition information and healthy eating opportunities, often with on-site cooking demonstrations, recipe tastings, produce display stands, etc.
COMMUNITY | Healthy food in convenience stores | Encourage convenience stores, corner stores, or gas station markets to carry fresh produce and other healthier food options
COMMUNITY | New grocery stores in underserved areas | Attract new grocery stores that sell a variety of fresh foods, baked goods, packaged, and frozen items to underserved areas via financing initiatives, tax incentives, or zoning regulation
COMMUNITY | Fruit & vegetable incentive programs | Offer participants with low incomes matching funds to purchase healthy foods, especially fresh fruits and vegetables; often called bonus dollars, market bucks, produce coupons, or nutrition incentives; may be tied to SNAP benefits
COMMUNITY | Community kitchens for nutrition education | Use existing kitchen spaces for community members to share knowledge, resources, and labor to prepare, cook, and consume food, often with nutrition education provided for participants experiencing food insecurity
COMMUNITY | Community kitchens for food processing | Establish shared kitchen spaces that support licensed, commercial food processing and connect specialty food processors, farmers, and others who produce value-added goods
COMMUNITY | Urban agriculture | Support food-producing and income-earning activities in urban environments (e.g., edible landscapes, front yard or rooftop gardens, window farming, hydroponics, livestock, etc.)
COMMUNITY | Food buying clubs & co-ops | Offer opportunities for group purchase and distribution of selected grocery items, generally at a reduced price
COMMUNITY | Food hubs | Support businesses or organizations that aggregate, distribute, and market local and regional food products (e.g., fresh fruits and vegetables, meat, dairy, grains, and prepared items)
COMMUNITY | Community supported agriculture (CSA) | Establish partnerships between farmers and consumers in which consumers purchase a share of a farm’s products in advance
COMMUNITY | Fruit & vegetable gleaning initiatives | Gather food left in fields after a primary harvest, food in fields where harvesting is not profitable, or excess produce from orchards, packing houses, urban agriculture sites, etc.
COMMUNITY | Food banks or pantries | Although the two terms are sometimes used interchangeably, “food banks” are organizations that distribute food to food pantries and other organizations that distribute food directly to households or individuals, while “food pantries” are local emergency food organizations that provide aid to food insecure households through the distribution of unprepared food for offsite consumption; food pantries typically rely on funding from local donors and labor from volunteers
GOVERNMENT | Supplemental Nutrition Assistance Program (SNAP) | SNAP provides benefits to eligible low-income individuals and families via an Electronic Benefits Transfer card, which can be used like a debit card to purchase eligible food in authorized retail food stores
GOVERNMENT | Special Supplemental Nutrition Program for Women, Infants, and Children (WIC) | Provides supplemental foods, healthcare referrals, and nutrition education for low-income pregnant, breastfeeding, and non-breastfeeding postpartum women, and to infants and children up to age 5 years who are found to be at nutritional risk
GOVERNMENT | WIC & Senior Farmers’ Market Nutrition Programs | Support Farmers’ Market Nutrition Programs, which provide WIC and Senior Nutrition Program participants with coupons for fresh, unprepared, locally grown fruits and vegetables
GOVERNMENT | Farm to school programs | Incorporate locally grown foods into school meals and snacks, often with visits from food producers, cooking classes, nutrition and waste reduction efforts, and school gardens
GOVERNMENT | School breakfast programs | Support programs to provide students with a nutritious breakfast in the cafeteria, from grab and go carts in hallways, or in classrooms
GOVERNMENT | Healthy school lunch initiatives | Modify the school lunch food environment by prominently displaying, marketing, and increasing the convenience of healthy foods and providing healthy options
GOVERNMENT | Electronic Benefit Transfer payment at farmers’ markets | Enable farmers’ markets to accept EBT, the electronic payment system of debit cards used to issue and redeem Supplemental Nutrition Assistance Program (SNAP) benefits

Abbreviations: CSA=community supported agriculture; EBT=electronic benefits transfer; FVRx=fruit and vegetable prescription; SNAP=Supplemental Nutrition Assistance Program; WIC=Supplemental Nutrition Program for Women, Infants, and Children

Commonly evaluated interventions tied to healthcare include referrals to community-based food banks and food pantries or enrollment in a formal program that a healthcare system runs in partnership with a food bank, a food pantry located in the healthcare setting, programs to increase access to fresh produce not in partnership with a food bank (e.g., food voucher and prescription programs for fruit and vegetables or other healthy foods, partnerships with local grocery stores or markets), subsidized community supported agriculture (CSA) shares, and SNAP enrollment (e.g., onsite benefits coordinator to assist with enrollment and application, referral to local food bank to assist with enrollment process).^68,79^ Other types of interventions in healthcare include meal delivery programs and medically tailored meals or groceries, often targeted to patients with diabetes (e.g., meals distributed, referral to food bank or pantry for medically appropriate foods with a “prescription,” medically tailored food box).^79,80^ These types of interventions aim to improve nutrition security as well as food insecurity, which may have important health benefits aside from adequate caloric intake. Many of these interventions also include targeted components specifically addressing nutrition insecurity, such as health education coaching, nutrition education, and/or cooking classes.

Some models of care directly link food insecurity assessments to staff-led interventions or an electronic screening platform that provides resources, referrals, and other assistance.^73^ In other models, designated staff (e.g., navigators, case managers, community health workers, social workers) respond to identified social needs. In published studies, referrals were typically provided by medical staff, while resources were typically provided by other staff (e.g., medical assistant, volunteers).

Because food insecurity assessments are often conducted as part of a broader screening for multiple social risk factors and social needs, interventions that follow may address social needs in addition to food security (e.g., financial security, housing, transportation). Thus, evaluations of interventions aimed at multiple social needs or delivered alongside medical co-interventions may not be able to isolate the benefit from intervening on food insecurity.

### Recent Recommendations and Current Clinical Practice in the United States

Several professional societies recommend that healthcare systems incorporate food insecurity screening and referral to food sources into their care programs (Appendix E Table 2). The American Academy of Family Physicians’ EveryONE Project™ initiative recommends that family physicians use a social risk screening instrument that includes food insecurity.^81^ Similarly, AARP developed a resource guide and toolkit for implementing food insecurity screening and referral for older patients in primary care.^82^ The American Academy of Nutrition and Dietetics,^83^ the American Academy of Pediatrics^84^ and the American Diabetes Association^85^ suggest using the 2-item Hunger Vital Sign screener to assess the possibility of food insecurity. The American College of Cardiology/American Heart Association,^86^ American College of Physicians,^87^ and American College of Obstetricians and Gynecologists^88^ do not endorse a particular screening tool. Regarding interventions, the Community Preventive Services Task Force (CPSTF) recommends fruit and vegetable incentive programs for households with lower incomes, which the CPSTF found to be effective in reducing household food insecurity and increasing fruit and vegetable consumption.^89^

Screening and interventions for food insecurity and other social needs are rapidly changing in current clinical practice. Estimates of screening for food insecurity range from 25 to 100 percent; a more precise estimate is challenging due to data limitations (e.g., heterogeneity in survey instruments, low response rates, reliance on self-report).^90^ Standards of practice for assessment have not been identified, and the likelihood of getting screened and screening positive for food insecurity varies for a host of reasons (e.g., screening tool, setting, type of visit, format/mode of delivery, timing of screening).^91^ Some healthcare systems use assessments as a means to measure prevalence and better understand the needs of their population, while others follow with referrals, clinical care, and additional services.^79^ For example, the Veterans Health Administration began screening for food insecurity in 2017, and to ensure regular screening instituted a 3-month reminder in the health record of every veteran who screened positive for food insecurity. Veterans with food insecurity are provided resource referrals such as food pantries, federal food assistance programs, and meal delivery programs.^92,93^

There are also important quality measures related to food insecurity, in the context of broader screening for social risk factors. The National Committee for Quality Assurance has a quality measure on social needs screening and intervention, which is the percentage of members screening for unmet food, housing, and transportation needs, and receiving a corresponding intervention for those who screening positive.^94^ CMS has similarly published a quality metric on screening for social drivers of health, which includes screening for food insecurity, housing instability, transportation needs, utility difficulties, and interpersonal safety.^95^

The Affordable Care Act (ACA) of 2010 requires nonprofit hospital systems to conduct community health needs assessments every 3 years and identify how community health funds could address identified needs.^79^ Healthcare organizations are also exploring new payment structures that could reimburse healthcare providers or social service organizations for programs that address social needs.^79^ In 2014, the National Academy of Medicine recommended a set of 11 core social and behavioral domains and measures for inclusion in patients’ health records.^96^ In 2017, CMS’s Innovation Center launched the AHC Model to ascertain whether connecting Medicare and Medicaid beneficiaries to community resources could improve health outcomes and reduce costs by addressing health-related social needs, of which food security was the most commonly identified.^72^ Some states have been approved for Section 1115 Medicaid waivers to test new approaches to address social determinants of health.^97^ For example, in Arkansas, Medicaid enrollees meeting certain requirements can receive nutrition counseling and education, including information on healthy meal preparation.^98^