# Appendix References

1 Sterne JA, Hernán MA, McAleenan A, . Assessing risk of bias in a non-randomized study. In: Higgins J, Thomas J, Chandler J, Cumpston M, Li T, Page M, ., editors. Cochrane handbook for systematic reviews of interventions 2019. p. 621–41.
2 Whiting P, Rutjes A, Westwood M, . QUADAS-2: A Revised Tool for the Quality Assessment of Diagnostic Accuracy Studies. Annals of Internal Medicine. 2011;155(8):529–36. PMID: 22007046. 10.7326/0003-4819-155-8-201110180-00009 22007046
3 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: USPSTF; 2021. PMID.
4 National Heart L, and Blood Institute. Quality assessment tool for studies with no control group. https://www.nhlbi.nih.gov/health-topics/study-quality-assessment-tools. Accessed Aug 28, 2023. PMID.
5 Lane WG, Dubowitz H, Feigelman S, . The Effectiveness of Food Insecurity Screening in Pediatric Primary Care. Int J Child Health Nutr. 2014;3(3):130–8. PMID: 28649292. 10.6000/1929-4247.2014.03.03.3 28649292
6 Makelarski JA, Abramsohn E, Benjamin JH, . Diagnostic Accuracy of Two Food Insecurity Screeners Recommended for Use in Health Care Settings. Am J Public Health. 2017;107(11):1812–7. PMID: 28933929. 10.2105/ajph.2017.304033 28933929
7 Gattu RK, Paik G, Wang Y, . The Hunger Vital Sign Identifies Household Food Insecurity among Children in Emergency Departments and Primary Care. Children (Basel). 2019;6(10). PMID: 31581751. 10.3390/children6100107 31581751
8 Gundersen C, Engelhard EE, Crumbaugh AS, . Brief assessment of food insecurity accurately identifies high-risk US adults. Public Health Nutr. 2017;20(8):1367–71. PMID: 28215190. 10.1017/S1368980017000180 28215190
9 Hager ER, Quigg AM, Black MM, . Development and validity of a 2-item screen to identify families at risk for food insecurity. Pediatrics. 2010;126(1):e26–32. PMID: 20595453. 10.1542/peds.2009-3146 20595453
10 Harrison C, Goldstein JN, Gbadebo A, . Validation of a 2-Item Food Insecurity Screen Among Adult General Medicine Outpatients. Population Health Management. 2021;24(4):509–14. PMID: 33021444. 10.1089/pop.2020.0183 33021444
11 Harle CA, Wu W, Vest JR. Accuracy of Electronic Health Record Food Insecurity, Housing Instability, and Financial Strain Screening in Adult Primary Care. JAMA. 2023;329(5):423–4. PMID: 36749341. 10.1001/jama.2022.23631 36749341
12 Radandt NE, Corbridge T, Johnson DB, . Validation of a Two-Item Food Security Screening Tool in a Dental Setting. J Dent Child (Chic). 2018;85(3):114–9. PMID: 30869587.30869587
13 Baer TE, Scherer EA, Fleegler EW, . Food Insecurity and the Burden of Health-Related Social Problems in an Urban Youth Population. J Adolesc Health. 2015;57(6):601–7. PMID: 26592328. 10.1016/j.jadohealth.2015.08.013 26592328
14 Blumberg SJ, Bialostosky K, Hamilton WL, . The effectiveness of a short form of the Household Food Security Scale. Am J Public Health. 1999;89(8):1231–4. PMID: 10432912. 10.2105/ajph.89.8.1231 10432912
15 Aiyer JN, Raber M, Bello RS, . A pilot food prescription program promotes produce intake and decreases food insecurity. Translational Behavioral Medicine. 2019;9(5):922–30. PMID: 31570927. 10.1093/tbm/ibz112 31570927
16 Berkowitz SA, Hulberg AC, Placzek H, . Mechanisms Associated with Clinical Improvement in Interventions That Address Health-Related Social Needs: A Mixed-Methods Analysis. Popul Health Manag. 2018. PMID: 30562141. 10.1089/pop.2018.0162 30562141
17 Berkowitz SA, Delahanty LM, Terranova J, . Medically Tailored Meal Delivery for Diabetes Patients with Food Insecurity: a Randomized Cross-over Trial. J Gen Intern Med. 2019;34(3):396–404. PMID: 30421335. 10.1007/s11606-018-4716-z 30421335
18 Byker Shanks C, Vanderwood K, Grocke M, . The UnProcessed Pantry Project (UP3): A Community-Based Intervention Aimed to Reduce Ultra-Processed Food Intake Among Food Pantry Clients. Fam Community Health. 2022;45(1):23–33. PMID: 34783688. 10.1097/FCH.0000000000000310 34783688
19 Cohen AJ, Richardson CR, Heisler M, . Increasing Use of a Healthy Food Incentive: A Waiting Room Intervention Among Low-Income Patients. American journal of preventive medicine. 2017;52(2):154–62. PMID: 28109458. 10.1016/j.amepre.2016.11.008 28109458
20 Cook M, Ward R, Newman T, . Food Security and Clinical Outcomes of the 2017 Georgia Fruit and Vegetable Prescription Program. Journal of Nutrition Education and Behavior. 2021;53(9):770–8. PMID: 34509277. 10.1016/j.jneb.2021.06.010 34509277
21 Fischer L, Bodrick N, Mackey ER, . Feasibility of a Home-Delivery Produce Prescription Program to Address Food Insecurity and Diet Quality in Adults and Children. Nutrients. 2022;14(10):10. PMID: 35631144. 10.3390/nu14102006 35631144
22 Freedman DA, Choi SK, Hurley T, . A farmers’ market at a federally qualified health center improves fruit and vegetable intake among low-income diabetics. Prev Med. 2013;56(5):288–92. PMID: 23384473. 10.1016/j.ypmed.2013.01.018 23384473
23 Gottlieb L, Hessler D, Long D, . Are acute care settings amenable to addressing patient social needs: A sub-group analysis. The American journal of emergency medicine. 2018;36(11):2108–9. PMID: 29576258. 10.1016/j.ajem.2018.03.034 29576258
24 Gottlieb LM, Adler NE, Wing H, . Effects of In-Person Assistance vs Personalized Written Resources About Social Services on Household Social Risks and Child and Caregiver Health. JAMA netw. 2020;3(3):e200701. PMID: 32154888. 10.1001/jamanetworkopen.2020.0701 32154888
25 Hager K, Du M, Li Z, . Impact of Produce Prescriptions on Diet, Food Security, and Cardiometabolic Health Outcomes: A Multisite Evaluation of 9 Produce Prescription Programs in the United States. Circ Cardiovasc Qual Outcomes. 2023;16(9):e009520. PMID: 37641928. 10.1161/circoutcomes.122.009520 37641928
26 Izumi BT, Martin A, Garvin T, . CSA Partnerships for Health: outcome evaluation results from a subsidized community-supported agriculture program to connect safety-net clinic patients with farms to improve dietary behaviors, food security, and overall health. Translational Behavioral Medicine. 2020;10(6):1277–85. PMID: 33421087. 10.1093/tbm/ibaa041 33421087
27 Jones LJ, VanWassenhove-Paetzold J, Thomas K, . Impact of a Fruit and Vegetable Prescription Program on Health Outcomes and Behaviors in Young Navajo Children. Current Developments in Nutrition. 2020;4(8). PMID: 32734135. 10.1093/cdn/nzaa109 32734135
28 Kempainen S, Cutts DB, Robinson-O’Brien R, . A Collaborative Pilot to Support Patients With Diabetes Through Tailored Food Box Home Delivery. Health Promot Pract. 2023:15248399221100792. PMID: 36627767. 10.1177/15248399221100792 36627767
29 Morales ME, Epstein MH, Marable DE, . Food Insecurity and Cardiovascular Health in Pregnant Women: Results From the Food for Families Program, Chelsea, Massachusetts, 2013-2015. Prev Chronic Dis. 2016;13:E152. PMID: 27809418. 10.5888/pcd13.160212 27809418
30 Orsega-Smith E S N, Cotugna N. . Local pediatricians partner with food bank to provide produce prescription program. J Hunger Environ Nutr. 2020;15(3):353–9. 10.1080/19320248.2019.1592051
31 Ranjit N, Aiyer JN, Toups JD, . Clinical outcomes of a large-scale, partnership-based regional food prescription program: results of a quasi-experimental study. BMC Res Notes. 2023;16(1):13. PMID: 36765390. 10.1186/s13104-023-06280-8 36765390
32 Renaud J, McClellan SR, DePriest K, . Addressing Health-Related Social Needs Via Community Resources: Lessons From Accountable Health Communities. Health Aff (Millwood). 2023 05 17 ed2023. p. 832–40. PMID: 37196207. 10.1377/hlthaff.2022.01507 37196207
33 Rivera RL, Adams M, Dawkins E, . Delivering Food Resources and Kitchen Skills (FoRKS) to Adults with Food Insecurity and Hypertension: A Pilot Study. Nutrients. 2023;15(6):17. PMID: 36986184. 10.3390/nu15061452 36986184
34 Saxe-Custack A, LaChance J, Hanna-Attisha M. Child Consumption of Whole Fruit and Fruit Juice Following Six Months of Exposure to a Pediatric Fruit and Vegetable Prescription Program. Nutrients. 2019;12(1):20. PMID: 31877635. 10.3390/nu12010025 31861789
35 Scher K, Sohaki A, Tang A, . A community partnership to evaluate the feasibility of addressing food insecurity among adult patients in an urban healthcare system. Pilot Feasibility Stud. 2022;8(1):59. PMID: 35264239. 10.1186/s40814-022-01013-3 35264239
36 Seligman HK, Lyles C, Marshall MB, . A pilot food bank intervention featuring diabetes-appropriate food improved glycemic control among clients in three states. Health affairs (Project Hope). 2015;34(11):1956–63. PMID: 26526255. 10.1377/hlthaff.2015.0641 26526255
37 Shankar KN, Dugas JN, Flacks J, . High touch, high trust: Using community health advocates and lawyers to address ED high utilizers. American Journal of Emergency Medicine. 2022;60:171–6. PMID: 36037733. 10.1016/j.ajem.2022.07.049 36037733
38 Singer C, Porta C. Improving patient well-being in the United States through care coordination interventions informed by social determinants of health. Health Soc Care Community. 2022;17:17. PMID: 35301764. 10.1111/hsc.13776 35301764
39 Slagel N, Newman T, Sanville L, . Effects of a Fruit and Vegetable Prescription Program With Expanded Education for Low-Income Adults. Health Education & Behavior. 2022;49(5):849–60. PMID: 35535592. 10.1177/10901981221091926 35535592
40 Wetherill MS, Chancellor McIntosh H, Beachy C, . Design and Implementation of a Clinic-Based Food Pharmacy for Food Insecure, Uninsured Patients to Support Chronic Disease Self-Management. J Nutr Educ Behav. 2018;50(9):947–9. PMID: 30064811. 10.1016/j.jneb.2018.05.014 30064811
41 Woo Baidal JA, Duong N, Goldsmith J, . Association of a primary care-based mobile food pantry with child body mass index: A propensity score matched cohort study. Pediatric Obesity. 2023;18(6):e13023. PMID: 36939408. 10.1111/ijpo.13023 36939408
42 Wu AW, Weston CM, Ibe CA, . The Baltimore Community-Based Organizations Neighborhood Network: Enhancing Capacity Together (CONNECT) Cluster RCT. American journal of preventive medicine. 2019;57(2):e31–e41. PMID: 31248746. 10.1016/j.amepre.2019.03.013 31248746
43 Xie J, Price A, Curran N, . The impact of a produce prescription programme on healthy food purchasing and diabetes-related health outcomes. Public Health Nutr. 2021/04/28 ed2021. p. 3945–55. PMID: 33902771. 10.1017/s1368980021001828 33902771
44 American Academy of Family Physicians. Social Needs Screening Tool. https://www.aafp.org/dam/AAFP/documents/patient_care/everyone_project/hops19-physician-form-sdoh.pdf. Accessed Oct 5, 2021. PMID.
45 Center for Health Care Strategies. AccessHealth Spartanburg: Social Determinants Screening Tool. https://www.chcs.org/media/AccessHealth-Social-Determinant-Screening_102517.pdf. Accessed Oct 5, 2021. PMID.
46 Billioux A, Verlander K, Anthony S, . Standardized screening for health-related social needs in clinical settings: the accountable health communities screening tool. NAM Perspectives. 2017. 10.31478/201705b
47 Centers for Medicare and Medicaid Services. The Accountable Health Communities Health-Related Social Needs Screening Tool. https://innovation.cms.gov/Files/worksheets/ahcm-screeningtool.pdf. Accessed Sept 28, 2021. PMID.
48 Arlington Screening Tool- Pilot Questions. https://sirenetwork.ucsf.edu/sites/default/files/2021-02/Arlington%2520Screening%2520Tool-%2520Final%2520version.pdf. Accessed Oct 5, 2021. PMID.
49 LaForge K, Gold R, Cottrell E, . How 6 Organizations Developed Tools and Processes for Social Determinants of Health Screening in Primary Care: An Overview. J Ambul Care Manage. 2018;41(1):2–14. PMID: 28990990. 10.1097/JAC.0000000000000221 28990990
50 Manchanda R, Gottlieb L. Upstream Risks Screening Tool and Guide V2.6. https://www.aamc.org/system/files/c/2/442878-chahandout1.pdf. Accessed 10/23/2019. PMID.
51 Berkowitz SA, Hulberg AC, Hong C, . Addressing basic resource needs to improve primary care quality: a community collaboration programme. BMJ Qual Saf. 2016;25(3):164–72. PMID: 26621916. 10.1136/bmjqs-2015-004521 26621916
52 Health Leads. Social Needs Screening Toolkit. https://healthleadsusa.org/resources/the-health-leads-screening-toolkit/. Accessed 10/23/2019. PMID.
53 Hassan A, Blood EA, Pikcilingis A, . Youths’ health-related social problems: concerns often overlooked during the medical visit. J Adolesc Health. 2013;53(2):265–71. 10.1016/j.jadohealth.2013.02.024 23643339
54 Steiner JF, Stenmark SH, Sterrett AT, . Food Insecurity in Older Adults in an Integrated Health Care System. J Am Geriatr Soc. 2018;66(5):1017–24. PMID: 29492953. 10.1111/jgs.15285 29492953
55 North Carolina Department of Health and Human Services. Using Standardized Social Determinants of Health Screening Questions to Identify and Assist Patients with Unmet Health-related Resource Needs in North Carolina. https://files.nc.gov/ncdhhs/documents/SDOH-Screening-Tool_Paper_FINAL_20180405.pdf. Accessed Oct 5, 2021. PMID.
56 Colvin JD, Bettenhausen JL, Anderson-Carpenter KD, . Multiple Behavior Change Intervention to Improve Detection of Unmet Social Needs and Resulting Resource Referrals. Acad Pediatr. 2016;16(2):168–74. PMID: 26183003. 10.1016/j.acap.2015.06.001 26183003
57 Gottlieb L, Hessler D, Long D, . A randomized trial on screening for social determinants of health: the iScreen study. Pediatrics. 2014;134(6):e1611–8. PMID: 25367545. 10.1542/peds.2014-1439 25367545
58 Pettignano R, Caley SB, Bliss LR. Medical-legal partnership: impact on patients with sickle cell disease. Pediatrics. 2011;128(6):e1482–8. PMID: 22084325. 10.1542/peds.2011-0082 22084325
59 Johnson KF, Brookover DL, Bradbrook K. Social health needs and promotive health factors scale for college students: Scale development and initial validation. J Am Coll Health. 2022;70(1):74–83. PMID: 32101095. 10.1080/07448481.2020.1725021 32101095
60 Taylor DR, Bernstein BA, Carroll E, . Keeping the Heat on for Children’s Health: A Successful Medical-Legal Partnership Initiative to Prevent Utility Shutoffs in Vulnerable Children. Journal of health care for the poor and underserved. 2015;26(3):676–85. PMID: 26320904. 10.1353/hpu.2015.0074 26320904
61 National Association of Community Health Centers I. PRAPARE: Protocol for Responding to and Assessing Patient Assets, Risks, and Experiences. http://www.nachc.org/wp-content/uploads/2016/09/PRAPARE_Paper_Form_Sept_2016.pdf. Accessed 10/23/2019. PMID.
62 SEEK Organization. SEEK Partent Questionnaire-R. https://seekwellbeing.org/seek-materials/. Accessed 10/23/2019. PMID.
63 Guo JW, Wallace AS, Luther BL, . Psychometric Evaluation of the Screener for Intensifying Community Referrals for Health. Eval Health Prof. 2022;45(3):270–6. PMID: 34235988. 10.1177/01632787211029360 34235988
64 Beck AF, Klein MD, Kahn RS. Identifying social risk via a clinical social history embedded in the electronic health record. Clin Pediatr (Phila). 2012;51(10):972–7. PMID: 22511197. 10.1177/0009922812441663 22511197
65 Klein MD, Beck AF, Henize AW, . Doctors and lawyers collaborating to HeLP children--outcomes from a successful partnership between professions. J Health Care Poor Underserved. 2013;24(3):1063–73. 10.1353/hpu.2013.0147 23974381
66 Bourgois P, Holmes SM, Sue K, . Structural Vulnerability: Operationalizing the Concept to Address Health Disparities in Clinical Care. Acad Med. 2017;92(3):299–307. PMID: 27415443. 10.1097/ACM.0000000000001294 27415443
67 Perrin E, Sheldrick R, Visco Z, . The Survey of Well-being of Young Children (SWYC) User’s Manual, v1.01. https://www.tuftschildrenshospital.org/-/media/Brochures/Floating-Hospital/SWYC/SWYC-Manual-v101-Web-Format-33016.ashx?la=en&hash=E0C2802F003ED312E9D5268374C540A112151FB3. Accessed Nov. 10, 2021. PMID.
68 Total Health Assessment Questionnaire for Medicare Members. https://sirenetwork.ucsf.edu/sites/sirenetwork.ucsf.edu/files/Medicare%20THA%20questionnaire%20v2%20%28rvd%2012-5-14%29%20with%20Sources.pdf. Accessed 10/23/2019. PMID.
69 Garg A, Toy S, Tripodis Y, . Addressing social determinants of health at well child care visits: a cluster RCT. Pediatrics. 2015;135(2):e296–304. PMID: 25560448. 10.1542/peds.2014-2888 25560448
70 Page-Reeves J, Kaufman W, Bleecker M, . Addressing Social Determinants of Health in a Clinic Setting: The WellRx Pilot in Albuquerque, New Mexico. J Am Board Fam Med. 2016;29(3):414–8. PMID: 27170801. 10.3122/jabfm.2016.03.150272 27170801
71 Pooler J, Levin M, Hoffman V, . Implementing Food Security Screening and Referral for Older Patients in Primary Care: A Resource Guide and Toolkit. http://www.advancingstates.org/sites/nasuad/files/FINAL%20Resource%20Guide%20HI%20Res_0.pdf. Accessed. PMID.
72 Holben DH, Marshall MB. Position of the Academy of Nutrition and Dietetics: Food Insecurity in the United States. J Acad Nutr Diet. 2017;117(12):1991–2002. PMID: 29173349. 10.1016/j.jand.2017.09.027 29173349
73 American Academy of Family Physicians. Social Determinants of Health: guide to social needs screening. https://www.aafp.org/dam/AAFP/documents/patient_care/everyone_project/hops19-physician-guide-sdoh.pdf2019. PMID.
74 Council on Community Pediatrics and Committee on Nutrition. Promoting Food Security for All Children. Pediatrics. 2015;136(5):e1431–e8. PMID: 26498462. 10.1542/peds.2015-3301 26498462
75 Arnett DK, Blumenthal RS, Albert MA, . 2019 ACC/AHA Guideline on the Primary Prevention of Cardiovascular Disease: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. J Am Coll Cardiol. 2019;74(10):e177–e232. PMID: 30894318. 10.1016/j.jacc.2019.03.010 30894318
76 Committee on Health Care for Underserved Women. Importance of social determinants of health and cultural awareness in the delivery of reproductive health care. OBSTETRICS AND GYNECOLOGY. Washington, DC: American College of Obstetricians and Gynecologists; 2018. PMID.
77 Serchen J, Atiq O, Hilden D. Strengthening Food and Nutrition Security to Promote Public Health in the United States: A Position Paper From the American College of Physicians. Annals of Internal Medicine. 2022;175(8):1170–1. PMID: 35759767. 10.7326/m22-0390 35759767
78 ElSayed NA, Aleppo G, Aroda VR, . Improving Care and Promoting Health in Populations: Standards of Care in Diabetes-2023. Diabetes Care. 2023;46(Supple 1):S10–s8. PMID: 36507639. 10.2337/dc23-S001 36507639
79 Task Force on Hunger Nutrition and Health. Ambitious, Actionable Recommendations to End Hunger, Advance Nutrition, and Improve Health in the United States. https://informingwhc.org/wp-content/uploads/2022/08/Informing_White_House_Conference_Task_Force_Report_Aug22.pdf. Accessed Jun 22, 2023. PMID.
80 National Research Council. Food Insecurity and Hunger in the United States: An Assessment of the Measure. In: Wunderlich G, Norwood J, editors. Washington, DC: National Academies Press; 2006. PMID. 10.17226/11578
81 De Marchis EH, Torres JM, Benesch T, . Interventions Addressing Food Insecurity in Health Care Settings: A Systematic Review. Ann Fam Med. 2019;17(5):436–47. PMID: 31501207. 10.1370/afm.2412 31501207
82 Byker Shanks C, Calloway EE, Parks CA, . Scaling up measurement to confront food insecurity in the USA. Translational Behavioral Medicine. 2020;10(6):1382–9. PMID: 33277900. 10.1093/tbm/ibaa112 33277900
83 Alley DE, Asomugha CN, Conway PH, . Accountable Health Communities--Addressing Social Needs through Medicare and Medicaid. The New England journal of medicine. 2016;374(1):8–11. PMID: 26731305. 10.1056/NEJMp1512532 26731305
84 Eder M, Henninger M, Durbin S, . Screening and Interventions for Social Risk Factors: Technical Brief to Support the US Preventive Services Task Force. Jama. 2021;326(14):1416–28. PMID: 34468710. 10.1001/jama.2021.12825 34468710
85 Henrikson NB, Blasi PR, Dorsey CN, . Psychometric and Pragmatic Properties of Social Risk Screening Tools: A Systematic Review. American journal of preventive medicine. 2019;57(6 Suppl 1):S13–S24. PMID: 31753276. 10.1016/j.amepre.2019.07.012 31753276
86 Moen M, Storr C, German D, . A Review of Tools to Screen for Social Determinants of Health in the United States: A Practice Brief. Population Health Management. 2020;23(6):422–9. PMID: 31910355. 10.1089/pop.2019.0158 31910355
87 Sandhu S, Xu J, Eisenson H, . Workforce Models to Screen for and Address Patients’ Unmet Social Needs in the Clinic Setting: A Scoping Review. J. 2021;12. PMID: 34053370. 10.1177/21501327211021021 34053370
88 RTI International. Accountable Health Communities (AHC) Model Evaluation: First Evaluation Report. https://innovation.cms.gov/data-and-reports/2020/ahc-first-eval-rpt: 2020. PMID.
89 Macias-Konstantopoulos W, Ciccolo G, Muzikansky A, . A pilot mixed-methods randomized controlled trial of verbal versus electronic screening for adverse social determinants of health. J Am Coll Emerg Physicians Open. 2022;3(1):e12678. PMID: 35224551. 10.1002/emp2.12678 35224551
90 Careyva BA, Hamadani R, Friel T, . A Social Needs Assessment Tool for an Urban Latino Population. J Community Health. 2018;43(1):137–45. PMID: 28707180. 10.1007/s10900-017-0396-6 28707180
91 Oldfield BJ, Casey M, DeCew A, . Screening for Social Determinants of Health Among Children: Patients’ Preferences for Receiving Information to Meet Social Needs and a Comparison of Screening Instruments. Population Health Management. 2021;24(1):141–8. PMID: 148473894. 10.1089/pop.2019.0211 32096695
92 Montez K, Brown CL, Garg A, . Trends in food insecurity rates at an academic primary care clinic: a retrospective cohort study. BMC Pediatrics. 2021;21(1):364. PMID: 34452604. 10.1186/s12887-021-02829-3 34452604
93 Courts KA, Hubbard RA, Kersten HB, . Stability of food insecurity status in paediatric primary care. Public Health Nutr. 2021;24(5):845–50. PMID: 32811587. 10.1017/S1368980020002281 32811587
94 Liese AD, Sharpe PA, Bell BA, . Persistence and transience of food insecurity and predictors among residents of two disadvantaged communities in South Carolina. Appetite. 2021;161:105128. PMID: 33513414. 10.1016/j.appet.2021.105128 33513414
95 Manian N, Wagner CA, Placzek H, . Relationship between intervention dosage and success of resource connections in a social needs intervention. Public Health. 2020;185:324–31. PMID: 32726729. 10.1016/j.puhe.2020.05.058 32726729
96 De Marchis EH, Torres JM, Fichtenberg C, . Identifying Food Insecurity in Health Care Settings: A Systematic Scoping Review of the Evidence. Fam Community Health. 2019;42(1):20–9. PMID: 30431466. 10.1097/FCH.0000000000000208 30431466
97 Orr CJ, Ravanbakht S, Flower KB, . Associations Between Food Insecurity and Parental Feeding Behaviors of Toddlers. Acad Pediatr. 2020;20(8):1163–9. PMID: 32492577. 10.1016/j.acap.2020.05.020 32492577
98 Thomas B, Fitzpatrick S, Sidani S, . Developing and Implementing a Food Insecurity Screening Initiative for Adult Patients Living With Type 2 Diabetes. Can. 2018;42(3):257–62. PMID: 28797890. 10.1016/j.jcjd.2017.06.004 28797890
99 Barnidge E, Krupsky K, LaBarge G, . Food Insecurity Screening in Pediatric Clinical Settings: A Caregivers’ Perspective. Matern Child Health J. 2020;24(1):101–9. PMID: 141192202. Language: English. Entry Date: 20200117. Revision Date: 20201231. Publication Type: Article. 10.1007/s10995-019-02785-6 31494801
100 Knowles M, Khan S, Palakshappa D, . Successes, Challenges, and Considerations for Integrating Referral into Food Insecurity Screening in Pediatric Settings. Journal of health care for the poor and underserved. 2018;29(1):181–91. PMID: 29503293. 10.1353/hpu.2018.0012 29503293
101 Bernhardt C, Hou S-I, King C, . Identifying Barriers to Effective Patient-Provider Communication About Food Insecurity Screenings in Outpatient Clinical Settings in Central Florida: A Mixed-Methods Study. J Public Health Manag Pract. 2022;28(2):E595–E602. PMID: 34608888. 10.1097/PHH.0000000000001449 34608888
102 Colvin JD, Bettenhausen JL, Anderson-Carpenter KD, . Caregiver Opinion of In-Hospital Screening for Unmet Social Needs by Pediatric Residents. Acad Pediatr. 2016;16(2):161–7. PMID: 26946270. 10.1016/j.acap.2015.06.002 26946270
103 O’Toole TP, Roberts CB, Johnson EE. Screening for Food Insecurity in Six Veterans Administration Clinics for the Homeless, June-December 2015. Prev Chronic Dis. 2017;14:E04. PMID: 28084988. 10.5888/pcd14.160375 28084988
104 Hamity C, Jackson A, Peralta L, . Perceptions and Experience of Patients, Staff, and Clinicians with Social Needs Assessment. The Permanente journal. 2018;22:18–105. PMID: 30285914. 10.7812/tpp/18-105 30285914
105 Kangovi S, Mitra N, Grande D, . Patient-centered community health worker intervention to improve posthospital outcomes: a randomized clinical trial. JAMA internal medicine. 2014;174(4):535–43. PMID: 24515422. 10.1001/jamainternmed.2013.14327 24515422
106 Real FJ, Beck AF, Spaulding JR, . Impact of a Neighborhood-Based Curriculum on the Helpfulness of Pediatric Residents’ Anticipatory Guidance to Impoverished Families. Matern Child Health J. 2016;20(11):2261–7. PMID: 27480423.27480423
107 Weintraub D, Rodgers MA, Botcheva L, . Pilot study of medical-legal partnership to address social and legal needs of patients. Journal of health care for the poor and underserved. 2010;21(2 Suppl):157–68. PMID: 20453383. 10.1353/hpu.0.0311 20453383
108 Schickedanz A, Sharp A, Hu YR, . Impact of Social Needs Navigation on Utilization Among High Utilizers in a Large Integrated Health System: a Quasi-experimental Study. J Gen Intern Med. 2019;34(11):2382–9. PMID: 31228054. 10.1007/s11606-019-05123-2 31228054
109 Frost K, Stafos A, Metcalf AL, . Knowledge and barriers related to food insecurity screening in healthcare settings. Public Health Nurs. 2022;39(4):770–7. PMID: 35020212. 10.1111/phn.13040 35020212
110 Greenthal E, Jia J, Poblacion A, . Patient experiences and provider perspectives on a hospital-based food pantry: a mixed methods evaluation study. Public Health Nutr. 2019;22(17):3261–9. PMID: 31486351. 10.1017/S1368980019002040 31486351
111 Tong ST, Liaw WR, Kashiri PL, . Clinician Experiences with Screening for Social Needs in Primary Care. J Am Board Fam Med. 2018;31(3):351–63. PMID: 29743219. 10.3122/jabfm.2018.03.170419 29743219
112 Garg A, Butz AM, Dworkin PH, . Improving the management of family psychosocial problems at low-income children’s well-child care visits: the WE CARE Project. Pediatrics. 2007;120(3):547–58. PMID: 17766528. 10.1542/peds.2007-0398 17766528
113 Klein MD, Kahn RS, Baker RC, . Training in social determinants of health in primary care: does it change resident behavior? Acad Pediatr. 2011;11(5):387–93. PMID: 21640683. 10.1016/j.acap.2011.04.004 21640683
114 Palakshappa D, Vasan A, Khan S, . Clinicians’ Perceptions of Screening for Food Insecurity in Suburban Pediatric Practice. Pediatrics. 2017;140(1). PMID: 28634247. 10.1542/peds.2017-0319 28634247
115 Fox CK, Cairns N, Sunni M, . Addressing food insecurity in a pediatric weight management clinic: A pilot intervention. J Pediatr Health Care. 2016;30(5):e11–5. PMID: 27321679. 10.1016/j.pedhc.2016.05.003 27321679
116 Smith S, Malinak D, Chang J, . Implementation of a food insecurity screening and referral program in student-run free clinics in San Diego, California. Prev Med Rep. 2017;5:134–9. PMID: 27990340.27990340
117 Arbour M, Fico P, Atwood S, . Benefits of a Universal Intervention in Pediatric Medical Homes to Identify and Address Health-Related Social Needs: An Observational Cohort Study. Acad Pediatr. 2022;18:18. PMID: 35863734. 10.1016/j.acap.2022.06.013 35863734
118 Fleegler EW, Lieu TA, Wise PH, . Families’ health-related social problems and missed referral opportunities. Pediatrics. 2007;119(6):e1332–41. PMID: 17545363. 10.1542/peds.2006-1505 17545363
119 Marpadga S, Fernandez A, Leung J, . Challenges and Successes with Food Resource Referrals for Food-Insecure Patients with Diabetes. Perm. 2019;23. PMID: 30939269. 10.7812/TPP/18-097 30939269
120 Chagin K, Choate F, Cook K, . A Framework for Evaluating Social Determinants of Health Screening and Referrals for Assistance. J. 2021:1–8. PMID: 154384667. Language: English. Entry Date: 20220120. Revision Date: 20220120. Publication Type: Article. 10.1177/21501327211052204
121 Woo Baidal JA, Meyer D, Partida I, . Feasibility of Food FARMacia: Mobile Food Pantry to Reduce Household Food Insecurity in Pediatric Primary Care. Nutrients. 2022;14(5). PMID: 35268034. 10.3390/nu14051059 35268034
122 Walker DM, DePuccio MJ, Hefner JL, . Utilization Patterns of a Food Referral Program: Findings from the Mid-Ohio Farmacy. J Am Board Fam Med. 2021;34(6):1174–82. PMID: 34772772. 10.3122/jabfm.2021.06.210036 34772772
123 Gottlieb LM, Hessler D, Long D, . Effects of Social Needs Screening and In-Person Service Navigation on Child Health: A Randomized Clinical Trial. Jama, Pediatr. 2016;170(11):e162521. PMID: 27599265. 10.1001/jamapediatrics.2016.2521 27599265
124 Selvaraj K, Korpics J, Osta AD, . Parent Perspectives on Adverse Childhood Experiences & Unmet Social Needs Screening in the Medical Home: A Qualitative Study. Acad Pediatr. 2022;22:22. PMID: 36007805. 10.1016/j.acap.2022.08.002 36007805
125 Runkle NK, Nelson DA. The Silence of Food Insecurity: Disconnections Between Primary Care and Community Organizations. J. 2021;8(1):31–8. PMID: 33511251. 10.17294/2330-0698.1765 33511251
126 Yaun JA, Rogers LW, Marshall A, . Whole Child Well-Child Visits: Implementing ACEs and SDOH Screenings in Primary Care. Clin Pediatr (Phila). 2022:99228221093279. PMID: 35499122. 10.1177/00099228221093279 35499122
127 Canavan CR, D’Cruze T, Kennedy MA, . Missed opportunities to improve food security for pregnant people: a qualitative study of prenatal care settings in Northern New England during the COVID-19 pandemic. BMC Nutr. 2022;8(1):8. PMID: 35067225. 10.1186/s40795-022-00499-7 35067225
128 Knight JK, Fritz Z. Doctors have an ethical obligation to ask patients about food insecurity: what is stopping us? J Med Ethics. 2021. PMID: 34261802. 10.1136/medethics-2021-107409 34261802
129 Nederveld AL, Duarte KF, Rice JD, . IMAGINE: A Trial of Messaging Strategies for Social Needs Screening and Referral. American journal of preventive medicine. 2022;63(3 Suppl 2):S164–S72. PMID: 35987528. 10.1016/j.amepre.2022.04.025 35987528
130 Gonzalez JV, Hartford EA, Moore J, . Food Insecurity in a Pediatric Emergency Department and the Feasibility of Universal Screening. The western journal of emergency medicine. 2021;22(6):1295–300. PMID: 34787554. 10.5811/westjem.2021.7.52519 34787554
131 Acquah OO, Honsvall Hoefler AM, Zoller I, . Improving Identification of Food-Insecure Patients in an Outpatient Clinic Setting. Primer. 2020;4:3. PMID: 32537603. 10.22454/PRiMER.2020.115304 32537603
132 Cohen DJ, Wyte-Lake T, Dorr DA, . Unmet information needs of clinical teams delivering care to complex patients and design strategies to address those needs. J Am Med Inform Assoc. 2020;27(5):690–9. PMID: 32134456. 10.1093/jamia/ocaa010 32134456
133 Fitzhugh CD, Pearsall MS, Tully KP, . Social Determinants of Health in Maternity Care: A Quality Improvement Project for Food Insecurity Screening and Health Care Provider Referral. Health Equity. 2021;5(1):606–11. PMID: 34909527. 10.1089/heq.2020.0120 34909527
134 Cohen AJ, Oatmen KE, Heisler M, . Facilitators and Barriers to Supplemental Nutrition Assistance Program Incentive Use: Findings From a Clinic Intervention for Low-Income Patients. American journal of preventive medicine. 2019;56(4):571–9. PMID: 30799161. 10.1016/j.amepre.2018.11.010 30799161
135 McWhorter JW, Danho MP, LaRue DM, . Barriers and Facilitators of Implementing a Clinic-Integrated Food Prescription Plus Culinary Medicine Program in a Low-Income Food Insecure Population: A Qualitative Study. J Acad Nutr Diet. 2022;122(8):1499–513. PMID: 34839026. 10.1016/j.jand.2021.11.016 34839026
136 Steeves-Reece AL, Totten AM, Broadwell KD, . Social Needs Resource Connections: A Systematic Review of Barriers, Facilitators, and Evaluation. American journal of preventive medicine. 2022;62(5):e303–e15. PMID: 35078672. 10.1016/j.amepre.2021.12.002 35078672
137 Poulos NS, Nehme EK, O’Neil MM, . Implementing food bank and healthcare partnerships: a pilot study of perspectives from charitable food systems in Texas. BMC Public Health. 2021;21(1):1–7. PMID: 153435659. Language: English. Entry Date: 20211215. Revision Date: 20211215. Publication Type: journal article. 10.1186/s12889-021-12031-w 33388037
138 Prado Junior JC, Medronho RdA. Spatial analysis of tuberculosis cure in primary care in Rio de Janeiro, Brazil. BMC Public Health. 2021;21(1):1–15. PMID: 152974103. Language: English. Entry Date: In Process. Revision Date: 20211103. Publication Type: journal article. Journal Subset: Biomedical. 10.1186/s12889-021-11834-1 33388037
139 Downer S, Berkowitz SA, Harlan TS, . Food is medicine: actions to integrate food and nutrition into healthcare. Bmj. 2020;369:m2482. PMID: 32601089. 10.1136/bmj.m2482 32601089
140 Ridberg RA, Yaroch AL, Nugent NB, . A Case for Using Electronic Health Record Data in the Evaluation of Produce Prescription Programs. J. 2022;13:21501319221101849. PMID: 35603984. 10.1177/21501319221101849 35603984
141 Harm HCW. Engaging the community to understand food needs: Including community stakeholders in the community health needs assessment process. https://foodcommunitybenefit.noharm.org/resources/community-health-needs-assessment/engaging-community-understand-food-needs. Accessed Aug 28, 2023. PMID.
142 Zack RM, Rodriguez Bronico JV, Babbin M, . Facilitators and Barriers to Patient Attendance at a Free Health Center Produce Market. American journal of preventive medicine. 2022;63(3 Suppl 2):S131–S43. PMID: 35987525. 10.1016/j.amepre.2022.03.034 35987525
143 Noseworthy J. The Future of Care - Preserving the Patient-Physician Relationship. The New England journal of medicine. 2019;381(23):2265–9. PMID: 31800995. 10.1056/NEJMsr1912662 31800995
144 Iott BE, Eddy C, Casanova C, . More than a Database: Understanding Community Resource Referrals within a Socio-Technical Systems Framework. AMIA Annu Symp Proc. 2020;2020:583–92. PMID: 33936432.33936432
145 Crook H, Zheng J, Bleser W, . How Are Payment Reforms Addressing Social Determinants of Health? Policy Implications and Next Steps. Duke-Margolis Center for Health Policy & Milbank Memorial Fund; 2021. PMID.