# Appendix G Ongoing Studies

Appendix G Table 1 Ongoing Studies

Study Name; Trial identifier | Design | Aim | Relevant Outcome(s) | Country | Estimated N | Status in 2023
Maximizing Nutrition Education to Meet Dietary and Food Security of Children and Parents; NCT05196763 (https://beta.clinicaltrials.gov/study/NCT05196763) | RCT | Determine effect of adult-focused direct SNAP-education intervention on child diet quality and household food insecurity. | Food insecurity, dietary quality | US | 300 | Recruiting; Estimated completion date: Dec. 2025
Healthy Food Prescription Incentive Program; NCT04725630 (https://beta.clinicaltrials.gov/study/NCT04725630) | RCT | Investigate impact of a healthy food prescription incentive program among adults who are experiencing food insecurity and persistent hyperglycemia. | HbA1c, diet quality, fruit & vegetable intake, blood lipid levels, waist circumference, BMI, food insecurity, medication adherence | Canada | 594 | Recruiting; Estimated completion date: Dec. 2023
Home Food Delivery for Diabetes Management in Patients of Rural Clinics; NCT04876053 (https://beta.clinicaltrials.gov/study/NCT04876053) | RCT | Evaluate impact of food delivery intervention among rural food insecure patients with type 2 diabetes. | HbA1c | US | 400 | Recruiting; Estimated completion date: Jun. 2025
Eat Well Produce Benefit for Diabetes and Food Insecurity; NCT05896644 (https://beta.clinicaltrials.gov/study/NCT05896644) | RCT | Assess impact of participation in a produce prescription program with diabetes education materials in diabetes patients at risk of food insecurity. | HbA1c, ED visits, outpatient visits, hospitalizations, BMI, cholesterol, medication adherence, blood pressure | US | 3000 | Recruiting; Estimated completion date: Dec. 2025
CommunityRx-Hunger; NCT04171999 (https://beta.clinicaltrials.gov/study/NCT04171999) | RCT | Evaluate impact of a hospital-based intervention to address food security and other health-related social needs among caregivers experiencing food insecurity. | Caregiver satisfaction | US | 660 | Not recruiting; Estimated completion date: Aug. 2023
Food As Medicine Study; NCT05407376 (https://beta.clinicaltrials.gov/study/NCT05407376) | RCT | Assess the effect of a produce prescription intervention for patients enrolled in Medicaid who experience consistently uncontrolled HbA1c. | Food insecurity, HbA1c, food-related self-management, diet quality, nutrition security | US | 450 | Not recruiting; Estimated completion date: Jun. 2023
Addressing Diabetes by Elevating Access to Nutrition (ADELANTE); NCT05228860 (https://beta.clinicaltrials.gov/study/NCT05228860) | RCT | To determine whether a multilevel intervention to improve household food insecurity and glycemic control is effective for Latino patients with diabetes. | Food insecurity, HbA1c, cholesterol, blood pressure, BMI, waist-height ratio, HRQoL, depression, anxiety, loneliness, dietary intake, diet-related behaviors, physical activity, nutrition security | US | 360 | Recruiting; Estimated completion date: Jun. 2027
addressInG iNcome securITy in Primary care (IGNITE); NCT02459184 (https://beta.clinicaltrials.gov/study/NCT02459184) | RCT | Evaluate the impact of an income-focused health promoter for adults living in poverty. | Food insecurity, QoL, HRQoL | Canada | 284 | Not recruiting; Estimated completion date: Jan. 2022
Intervening in Food Insecurity to Reduce and Mitigate (InFoRM) Childhood Obesity; NCT05586269 (https://beta.clinicaltrials.gov/study/NCT05586269) | Randomized crossover comparative effectiveness | Compare impact of a meal kit delivery intervention with a newsletter and pantry referral in families and children with food insecurity and obesity. | Food security, child BMI | US | 30 | Not recruiting; Estimated completion date: Dec. 2024
Delivering Food Resources & Kitchen Skills (FoRKS) to Adults With Food Insecurity and Hypertension; NCT05856591 (https://beta.clinicaltrials.gov/study/NCT05856591) | Randomized comparative effectiveness | Compare impact of a home-delivered foods and kitchen skills program with enhanced usual care on health and nutrition in adults with high blood pressure and food insecurity. | Blood pressure, HbA1c | US | 200 | Recruiting; Estimated completion date: July 2027
Indigenous Supported Agriculture “Go Healthy”; NCT05773833 (https://beta.clinicaltrials.gov/study/NCT05773833) | Randomized comparative effectiveness | Compare effects of an indigenous supported agriculture program vs. monetary compensation of equal value among Native Americans with overweight or obesity. | Food insecurity, diet quality, blood pressure, BMI, HbA1c | Osage Nation (US) | 400 | Recruiting; Estimated completion date: April 2025
Fresh RX: NHS 2020; NCT04845230 (https://beta.clinicaltrials.gov/study/NCT04845230) | Randomized comparative effectiveness | Compare impact of a program providing food delivery with or without integrative care services with facilitated referrals to food insecure pregnant women. | Food insecurity, physical and mental health, birth weight | US | 750 | Recruiting; Estimated completion date: Sept. 2026
Food As MedicinE for Diabetes (FAME-D); NCT04828785 (https://beta.clinicaltrials.gov/study/NCT04828785) | Randomized comparative effectiveness | Evaluate impact of a medically tailored meal intervention or usual care + monthly food subsidy for adults with food insecurity and type 2 diabetes mellitus. | Food insecurity, HbA1c, health-related quality of life, depressive symptoms, hypoglycemia | US | 200 | Recruiting; Estimated completion date: Jan. 2025
Fruit and Vegetable Rx (FVRx) + Home Plate; NCT04986046 (https://beta.clinicaltrials.gov/study/NCT04986046) | Randomized comparative effectiveness | Compare the impact of fruit and vegetable prescription vouchers with or without a cooking skills program among adults with type 2 diabetes and BMI ≥25. | Food insecurity, diet quality, caregiver mental health | US | 90 | Recruiting; Estimated completion date: Dec. 2023
Nourishing Beginnings: Addressing Food Insecurity During Pregnancy; NCT05341960 (https://beta.clinicaltrials.gov/study/NCT05341960) | Randomized comparative effectiveness | Compare effectiveness of a food delivery program vs. financial support and navigation during pregnancy among Medicaid eligible. | Food insecurity, maternal depression, infant birthweight, infant gestational age at birth | US | 124 | Recruiting; Estimated completion date: Jul. 2024
Linking Education, Produce Provision, and Community Referrals to Improve Diabetes Care (LINK); NCT05472441 (https://beta.clinicaltrials.gov/study/NCT05472441) | Randomized comparative effectiveness | Compare the effects of produce provision, diabetes education, and/or community referrals in individuals with type 2 diabetes experiencing food insecurity. | Food security, HbA1c | US | 568 | Recruiting; Estimated completion date: Oct. 2026
At-risk and vulNerable Individuals To Infection With COVID-19 and ProActive inTervention With intEgrated Health and Social Care (ANTICIPATE); NCT05197608 (https://beta.clinicaltrials.gov/study/NCT05197608) | Randomized comparative effectiveness | Compare the impact of an embedded System Navigator with a list of tailored community resources among at-risk and vulnerable patients age 60 years or older. | Social needs met, emotional distress, mortality, and hospitalizations | Canada | 180 | Not yet recruiting; Estimated completion date: Dec. 2022
The Good Food Rx: Food-as-medicine Program; NCT05541458 (https://beta.clinicaltrials.gov/study/NCT05541458) | Pre-post | Determine impact of nutritional food boxes partnered with nutrition education classes among adults with hypertension, elevated HbA1c, hyperlipidemia and/or obesity. | Blood pressure, HbA1c, cholesterol, body weight | US | 25 | Not recruiting; Estimated completion date: Apr. 2024
Feasibility and Impact of the FOOD4MOMS Produce Prescription Program Among Pregnant Latina Women; NCT05907616 (https://beta.clinicaltrials.gov/study/NCT05907616) | Pre-post | Evaluate impact of 10 months of produce provision with education sessions in pregnant Latina women. | Produce intake, household food insecurity | US | 150 | Not yet recruiting; Estimated completion date: July 2024

Abbreviations: BMI=body mass index; ED=emergency department; HbA1c=hemoglobin A1c; HRQoL=health-related quality of life; RCT=randomized controlled trial; SNAP=Supplemental Nutrition Assistance Program