# Appendix F Contextual Questions

## Contextual Question 1 What risk assessment or screening tools are commonly used in clinical practice to identify food insecurity? What are the benefits and limitations of these tools (e.g., ease of administration)?

Historically, the U.S. Department of Agriculture’s (USDA) Household Food Security Survey Module (HFSSM) has served as the primary tool for the assessment of food insecurity in the United States.^80^ The HFSSM includes a series of 10 questions for households with no children and 18 questions for households with children that elicit information on household difficulty in meeting basic food needs due to lack of resources. These questions have been included as part of the Community Population Survey (distributed by the U.S. Census Bureau) since 1995. The 18-item scale has been further developed to incorporate subscales, including a 6-item set that has been used to measure food insecurity and hunger in state surveillance systems.^80^ Brief (1- or 2-item) screening tools to identify household food insecurity used in healthcare delivery settings are all derived from and validated against the HFSSM (Table 2).^81^ The most frequently used and studied single domain screening tool for food insecurity is the 2-item Hunger Vital Sign tool.^6,^ ^7,^ ^9^ It is also currently available in one of the most widely used electronic health records systems (i.e., EPIC). These brief screening tools have primarily been validated in caregivers of young children.^81^ Screeners derived from the HFSSM focus on food insecurity because of the lack of financial resources and may therefore not capture other facets of food insecurity such as psychosocial aspects (e.g., self-efficacy), duration and transience, and trade-off behaviors individuals may employee to address financial hardship.^82^

Multiple social risk factors are often assessed using multidomain tools, rather than screening for food insecurity in isolation. For example, in 2017, the Centers for Medicare & Medicaid Services (CMS) developed a screening tool for use in clinical settings that focuses on a select number of social risk factors, including five core patient social risk factors: food insecurity, housing instability, transportation difficulties, utility needs, and interpersonal safety.^83^ Most of the commonly used multidomain screening tools include question(s) on screening for food +/− nutrition insecurity (Appendix E Table 1), and many of these tools have been used in intervention studies to identify people with social risk factors.^84^ However, gold standard methods were rarely reported or used in development of these tools, and few included reliability and validity testing with a representative sample, although many tools have pragmatic assessments to show favorable readability and ease of administration, including low cost.^85^

Overall, whether as part of a single or multidomain assessment tool, the questions targeting food or nutrition insecurity vary in the time frame of reference (e.g., previous 3 to 12 months, current concerns, next 2 months), types of questions asked (e.g., enough food, fruit and vegetable or healthy food intake, eligibility for or denial from Special Supplemental Nutrition Program for Women, Infants, and Children [WIC] or Supplemental Nutrition Assistance Program [SNAP] benefits), and mode of delivery (e.g., in person, electronically, by telephone, multiple modes).^84,^ ^86^ These tools can be administered by a variety of staff (e.g., case manager, community health worker, navigator, nurse).^87^ Self-administered assessments can be done on paper or electronically and be distributed by front desk staff or medical assistants at check-in or while rooming patients. In some models of care, staff are available to assist patients in completing questions.^87^ Evaluation of the Accountable Health Communities (AHC) model found that tailoring social risk screening practices (e.g., timing, location, staff responsibility, and mode of administration) to each clinical site’s workflows, staffing, and intake processes was important.^88^ Patients appear to prefer self-administered formats, and sparse evidence does not suggest a difference between formats specifically for the identification of food insecurity.^81,^ ^87^ ^89–91^

## Contextual Question 2 What factors inform the appropriate reassessment interval for food insecurity?

Limited information is available to inform the appropriate reassessment interval for food insecurity. Food and nutrition insecurity change over time, and research to date has not addressed the appropriate frequency of screening for food and nutrition insecurity.^81,^ ^87^ Furthermore, most screening tools do not assess the duration of food insecurity, and therefore cannot assess if it is temporary or chronic.^86^

One retrospective study in an academic pediatric primary care clinic over a 2-year period demonstrated that food insecurity is transitional. Among caregivers reporting food security in year 1, 7.7 percent screened positive for food insecurity in year 2. There was a significant decrease in the percentage of caregivers reporting food insecurity between years 1 and 2 in all racial and ethnic groups, with Black participants reporting the largest decrease.^92^ Similar findings were identified in a review of electronic health record food insecurity recordings, with 9.5 percent of patients transitioning between food security statuses (5.0% to food security and 4.5% to food insecurity). These transitions were most notable among families whose previous screen occurred more than a year before, compared with those screened 0 to 6 months prior (odds ratio [OR], 1.91 [95% CI, 1.05 to 3.47), leading the authors to believe that screening more often than annually may not substantially contribute to the identification of transitions in food security status.^93^ A cohort study among middle aged participants in South Carolina (primarily female, African American, and living in food deserts) found transient food security in 36 percent of households and 37 percent with persistent food insecurity over 3 years of repeated measurements. The only predictors of transient food security status were income less than $10,000 (compared with >$20,000) and fair, good, or poor self-reported health (compared with very good or excellent health).^94^

## Contextual Question 3 What are important moderators that affect the effectiveness or harms of food insecurity assessment and healthcare-related interventions?

Greater use of services and high initial need were associated with larger benefits of food security interventions among studies included in this review.

### Use of Intervention Services

Four of the included studies of interventions to improve food security noted that higher participation in the intervention was associated with more positive outcomes.^19,^ ^20,^ ^22,^ ^43^ One study that provided information to participants about Double Up Food Bucks (DUFB), a national program to double a portion of their SNAP benefits when used at participating farmers markets, along with a $10 farmers market voucher, found that greater use of the program was associated with greater increases in fruit and vegetable consumption.^19^ In this study, those who used the option to double their benefit three or more times increased fruit and vegetable consumption by 1.2 servings/day after 5 months (p<0.001 for change from baseline), versus a small increase among those using the program one or two times (~0.6 servings/day, estimated from a figure; p=0.039) and no change in those who did not use the program. Similarly, in a study of people with diabetes receiving up to $50 in vouchers for use at a farmers market, the odds of increasing fruit and vegetable consumption were higher for those who visited the farmers market more often (OR, 2.07 [95% CI, 1.09 to 3.95]).^22^ Finally, a study that provided $40/month in vouchers for fruits and vegetables at a local grocery store chain found that participants who used the vouchers more often (“frequent” vs. “sometimes” spenders) showed greater increases in expenditures on fruits and vegetables (3.3% increase in the full sample, 3.8% increase among those with diabetes) and greater fruit and vegetable diversity (2.5 more unique items per month in the full sample, 2.3 more unique items per month among those with diabetes), compared with their baseline use.^43^ This study also found that participants who were female and who were older were more likely to be “frequent” spenders.

This finding is consistent with a study of an intervention addressing a broad array of social needs that was not included in our review because it did not report food security outcomes.^95^ This study of patient navigation found that a higher number of contacts with the patient navigator was associated with greater resource connections, after adjusting for the patient and site characteristics and the number of needs. In-person contact, although received by only 25 percent of the patients in this study, was associated with the highest probability of optimal success (e.g., OR, 2.89 [95% CI, 2.71 to 3.08] for a result of “optimal success”). This was a study of broad social needs screening, and 31.8 percent of the sample had food-related needs.

### Acuity of Need

Two of our included studies found greater improvements among those with higher baseline need. The study cited above that provided information about DUFB found larger improvements in fruit and vegetable consumption among people with lower initial fruit and vegetable consumption (increase of 0.9 servings/day after 1.5 months among people consuming 0 to 3 servings/day at baseline vs. decrease of 0.5 servings/day among those consuming 4+ servings/day at baseline).^19^ Another study conducted qualitative interviews among participants of their multidomain patient navigation intervention and found that those with a positive response to the intervention tended to have higher acuity of need than those who did not have a positive response.^16^ In this study, 40.1 percent of the participants had screened positive for food insecurity.

### Other Potential Moderators

Finally, one study that offered parents $15 fruit and vegetable vouchers at every visit to a pediatrician found that the program had a consistent effect on change in mean daily intake of whole fruits across child or caregiver race and age, child gender, and caregiver education level among the full sample of participants with and without food insecurity (37.7% of families reported low or very low food security).^34^

## Contextual Question 4 What is the acceptability (e.g., satisfaction) of food insecurity assessment and healthcare-related interventions to patients and providers?

Acceptability of food insecurity assessment and interventions for both patients and providers is a key aspect of implementation. The many studies that have examined these issues generally report high levels of acceptability.

### Acceptability to Patients

Several studies have reported high levels of patient satisfaction with assessment of food insecurity in healthcare, with or without broader social needs assessment. A systematic review of assessment of food insecurity in healthcare found that between 66 and 88 percent of caregivers and between 80 and 84 percent of young adult patients found it acceptable to be asked about food insecurity during healthcare visits.^96^ However, there is some evidence that patients may experience some level of discomfort when being asked about food insecurity;^97,^ ^98^ and for caregivers of children, there is an additional layer of stigma, shame, and/or fear about being perceived as unable to care for their child.^99,^ ^100^ Acceptability may be affected by a patient’s preexisting relationship with the provider,^98^ provider communication and empathy,^99,^ ^101^ cultural sensitivity of healthcare providers,^101^ and whether the patient had been exposed to social needs screening before. While one study found that self-administered questionnaires yielded higher rates of social risk factors for sensitive topics, suggesting a greater willingness to self-disclose with a self-administered instrument, the yield for food insecurity was similar across modes of administration.^57^ Some studies have also suggested that social needs assessments may help to establish trust and rapport between patients and providers.^98,^ ^102,^ ^103^

Studies reporting the acceptability of healthcare-related interventions for food insecurity indicate that patients generally give positive feedback for such interventions, both broadly^16,^ ^21,^ ^37,^ ^104–106^ and when queried about specific components.^15,^ ^26,^ ^107^

### Acceptability to Providers

Several studies have reported that providers believe that social needs, including food insecurity, should be addressed in healthcare.^108–110^ A systematic review that examined acceptability of food insecurity screening found that between 80 and 89 percent of clinicians were willing to include food insecurity screening during patient encounters.^96^ In some cases, providers saw this type of assessment as an opportunity to build relationships with patients.^108,^ ^111^ Several studies reported low levels of provider discomfort around screening,^103,^ ^108,^ ^112,^ ^113^ though some reported provider concern about embarrassing patients or not being able to provide adequate resources.^103,^ ^114^

## Contextual Question 5 What is the uptake of services (e.g., rate of adoption, receipt of benefits) after food insecurity is identified?

Enrollment in federal food assistance programs and use of local services was highly variable following identification in healthcare settings (7.5% to 97%) but was higher with the assistance of navigators or other staff. Vouchers were associated with increased purchasing of produce at farmers markets, and most free food was eaten.

### Receipt of SNAP and WIC Benefits

We identified four studies that implemented screening for food insecurity (with or without other social needs) and reported on subsequent enrollment in government food assistance programs (SNAP or WIC).^5,^ ^69,^ ^115,^ ^116^ All four provided information and referrals for food resources, and three also provided support for completing applications for government assistance.^5,^ ^116^ The largest effect was seen in the included KQ1 trial, a randomized trial of screening for child maltreatment risk factors that offered referrals and application support for those screening positive for food insecurity. At 6-month followup, 97 percent of the intervention participants were receiving SNAP benefits, compared with 81 percent in the control group.^5^ Two pre-post studies that included application support along with referrals had lower levels of SNAP enrollment after screening. One of these reported that 20% of participants with food insecurity were enrolled in SNAP.^116^ The other, which referred those screening positive for food insecurity to a partnering food bank for SNAP enrollment assistance, found that 30 of the 40 participants agreed to the referral and three ultimately enrolled (7.5% of those screening positive).^115^ The final study we found was a randomized trial of broad social needs screening with referral to relevant resources but no application support. In this study, 11 percent of patients who screened positive for food insecurity had enrolled in SNAP or WIC benefits after 1 month, compared with 9 percent in the usual care group. The difference between groups was not statistically significant after adjustment for race, marital status, maternal employment, and followup time (adjusted OR, 0.9 [95% CI, 0.4 to 2.1]).^69^

### Use of Local Food Resources

Eight studies reported the proportion of participants who connected with local food resources.^69,^ ^116–122^ At the high end, 67 percent of clinic patients who reported being screened for food insecurity and receiving a referral reported that they had contacted a community agency.^118^ Rates were lower in pre-post studies that prospectively followed patients who had been screened and given referrals, but showed higher rates when staff helped facilitate connections with local resources. A pre-post study of a screening and referral program in a diabetes clinic affiliated with a safety-net hospital found that provision of information alone about community food resources resulted in low uptake (0% to 4%), even with individually tailored referrals. On the other hand, 31 percent of participants connected with local resources with personnel-guided, in-clinic enrollment to a food resource.^119^ Similarly, one of the studies included in our review that addressed multiple social domains found a greater reduction in the number of unmet social needs with active patient navigation compared with simply providing referral information.^123^ In another program in which a community health worker helped address social needs, 21.5% of participants newly connected with relevant resources in the year after screening.^117^ Yet another study found that 27 percent of cases of food insecurity that were accepted by a community organization were ultimately resolved, and rates of resolution did not differ by age (<65 vs. ≥65), race (White, Black), or gender (male, female).^120^

Four of these studies specifically describe use of food pantries, finding that 21 to 51 percent of participants visited a food pantry after receiving a referral.^69,^ ^116,^ ^121,^ ^122^ An RCT of broad social needs screening with referral to relevant resources found that 4 percent of intervention participants visited a food pantry, compared with 2 percent in the control group (adjusted OR, 2.2 [95% CI, 0.7 to 6.7]), or 23 percent in the intervention group versus 11 percent in the control group among those with food insecurity at baseline.^69^ Other studies found that 21 percent^116^ and 51 percent^122^ had visited a food pantry. The latter reported that those who visited a food pantry were more likely to be older, have diabetes, and have visited a food pantry before their referral.^122^ A separate study found that 29 percent of participants given a referral registered for a mobile food pantry, and that the demographic characteristics of the mobile pantry participants were similar to those of the target population, which was majority Hispanic and Spanish-speaking.^121^

### Use of Free Food and Vouchers

Five of the studies included in this review reported on whether vouchers were redeemed^15,^ ^19,^ ^22^ or free food was eaten.^26,^ ^35^ The program that focused on informing eligible participants that they could double their benefit at farmers markets found that 61 percent who had never used this benefit before used it at least once by the end of the season and 27 percent used it three or more times.^19^ Another study of a food prescription program found that 71 percent of participants redeemed their prescription at the food pantry at least once, and the average number of redemptions was 6.5 of the available 12 redemptions.^15^ Another study, which provided vouchers for up to $50 for an on-site farmers market, found that all participants attended the farmers market on at least 2 days (average of 4.5 days) and made an average of 10.7 sales transactions.^22^ Two studies found that 73 percent^26^ to 91 percent^35^ of participants were able to use most or all of the food provided.

## Contextual Question 6 What are the patient, provider, and health system facilitators and barriers to implementing assessment for food insecurity?

Assessment for food insecurity involves identifying individuals or households who lack consistent access to nutritious and culturally appropriate food. The facilitators and barriers to implementing effective assessment programs may vary depending on the specific context and healthcare setting.

### Facilitators to Implementing Effective Assessment Programs

Multiple factors at the patient, provider, and health system levels may impact the implementation of food insecurity assessment in healthcare settings (Table 23).^84^ Patient-level factors that may facilitate implementation include increased patient awareness, trusting relationships, and confidentiality.^124,^ ^125^ When patients are aware of the potential impacts of food insecurity on their health, they may be more receptive to assessment and support. Strong relationships between patients and healthcare providers can encourage patients to disclose their food insecurity status.^126,^ ^127^ Likewise, assurances of confidentiality can help patients feel more comfortable sharing sensitive information about their unmet social needs.^124^

Provider-level facilitators include adequate training and education, access to screening tools and protocols, and a supportive work environment.^128^ Healthcare providers who receive training on food insecurity screening and interventions, including trauma-informed care, can better address the issue sensitively and effectively.^124,^ ^125^ Having standardized screening tools and protocols in place can guide providers in identifying and addressing food insecurity.^126,^ ^127^ An organizational culture that values food insecurity assessment and offers resources and support for providers can also help facilitate implementation.^127^

Health system-level facilitators include policy support, resource allocation, and integration of services. Supportive policies at the health system level, such as guidelines or incentives for food insecurity screening, can encourage implementation. Sufficient resources, including appropriate staffing (e.g., community health workers, translation services), training, and funding can enable health systems to implement food insecurity assessment more effectively.^126,^ ^127,^ ^129^ Integrating food security assessment with existing organizational practices, such as use of electronic health records or social work referrals, can enhance implementation.^130–132^

### Barriers to Implementing Effective Assessment Programs

Patient-level barriers to implementing food insecurity assessment programs may include stigma or shame, limited health literacy, or fear of consequences.^124^ Patients may feel embarrassed or stigmatized about their food insecurity, causing hesitation to disclose this information.^84^ In one qualitative study of patients recruited at family medicine and pediatric clinics, a patient responded, “Feeling as though you can’t provide for yourself or you can’t take care of yourself…and people look down on you when you can’t take care of yourself or you don’t have those basic needs or, like, housing…there’s already kind of a stigma just in general with low income, low socioeconomic status, things of that nature.”^125^ Furthermore, patients with limited health literacy may struggle to understand the purpose and importance of food insecurity assessments, impeding their participation. While most patients express a preference for written versus verbal assessment of unmet social needs,^130^ patients with limited health literacy may need to be offered alternative forms of assessment. Finally, patients may fear that admitting food insecurity could lead to negative repercussions, such as involvement of Child Protective Services. In one recent study exploring parental perspectives of screening for adverse child experiences and unmet social needs, parents expressed concerns about potential consequences of assessment. For example, one participant stated, “We want to tell you about it. We need help more than anything in the world, but we’re afraid by asking for help our kids are in danger of being taken away from us.” Another parent noted, “I am in the process of legalizing my documents…my children are stressed because of that. They think that someone is going to take them, or that I won’t be here anymore.”^124^

Common provider-level barriers to assessment include time constraints, competing priorities, lack of knowledge or comfort level, and concerns about lack of referral resources.^128^ Providers often have limited time during patient visits, making it challenging to incorporate food insecurity assessment into their workflow.^130,^ ^133^ Likewise, providers may also feel overwhelmed by other clinical tasks, leading them to deprioritize food insecurity assessment.^133^ Providers who are unfamiliar with the prevalence and impact of food insecurity may not prioritize or understand the need for assessment, may feel uncomfortable asking patients about unmet social needs, or may have concerns that there are inadequate organizational or community resources for appropriate referral.^84,^ ^131^

Health system-level barriers commonly include limited organizational resources, fragmented care, resistance to change, and data management issues.^130^ Health systems with constrained budgets and resources may struggle to allocate the necessary support for food insecurity assessment.^129^ Lack of coordination and communication between different healthcare providers and community organizations can impede effective implementation, and resistance to adopting new practices or screening tools may arise from entrenched systems and routines within a given health system.^133^ Finally, health systems may have concerns about social risk data collection, management, and privacy by their own and partnering organizations.^84^

## Contextual Question 7 What are the patient, provider, health system, and community facilitators and barriers to implementing interventions to address food insecurity?

Implementing interventions to address food insecurity requires consideration of facilitators and barriers at various levels, including the patient, provider, health system, and community (Table 23). Here we discuss commonly recognized facilitators and barriers; note that these facilitators and barriers are general and may vary based on the specific context, healthcare setting, and community.

### Facilitators to Implementing Effective Intervention Programs

Multiple factors may influence the implementation of interventions for food insecurity, including patient-, provider-, health system-, and community-level factors.^84^ Patient-level facilitators may include awareness and perception, motivation and readiness, and social support. When patients understand the benefits of interventions for food insecurity and perceive them as valuable, they are more likely to engage and participate.^134^ Patients motivated to improve their food security and ready to make changes in their lives are more likely to actively engage in interventions.^124^ Finally, having a supportive network of family, friends, or community members can enhance patient engagement and adherence to interventions, particularly for food insecurity interventions with a focus on healthy eating.^135^

Common provider-level facilitators include training and education, screening and referral tools, and collaborative relationships.^127^ Providers who receive training on food insecurity, its impact on health, and available interventions can address the issue more effectively.^136,^ ^137^ One qualitative study reported that nurses responsible for implementing a clinic-integrated food prescription program desired additional training to better understand culturally specific beliefs, values, and customs as well as behavioral change theory.^135^ Having standardized screening tools and referral systems in place can help providers identify and connect patients with appropriate interventions. Building relationships and collaborating with community organizations, food banks, and social services can enhance providers’ ability to refer patients to relevant interventions.

Health system-level facilitators include policy support, integration of services, and data collection and evaluation. Supportive policies that recognize the importance of addressing food insecurity and allocate resources for interventions are important to facilitate implementation.^127,^ ^138^ Integrating food insecurity interventions into existing healthcare services, such as embedding nutrition counseling within primary care, can improve access and delivery.^139^ Establishing systems to collect data on food insecurity and evaluate the impact of interventions can drive continuous improvement and accountability.^138,^ ^140^

Finally, community-level facilitators may include collaborative partnerships, community engagement, and access to resources. Building collaborations between healthcare organizations, community-based organizations, and local government entities can enhance the reach and effectiveness of interventions.^138^ Engaging community members in the design and implementation of interventions fosters trust, buy-in, and sustainability.^141^ Availability of food pantries, community gardens, farmers markets, and other local food initiatives can improve access to affordable and nutritious food.^127^

As previously noted, strong collaborations between health systems and community partners are critical to successful implementation of interventions to address food insecurity. For example, a pilot study of a food prescription program implemented in two school-based clinics and one federally qualified health center in an area with a high rate of food insecurity conducted surveys and key informant interviews to assess perceptions of healthcare providers and implementation staff. Implementation partners included a food bank, two food pantries, and a healthcare implementation partner. Responses highlighted the importance of training, ongoing support for programming, and effective communication between implementation partners as important predictors of implementation success.^15^ One interviewee stated, “Overall, I think the trainings, particularly with the clinics, went extremely well because we had to rely on them a lot.” Another participant highlighted the importance of trust and communication between organizational partners, noting, “Once you build a relationship with them, it’s all about community trust, and if you do not close that loop of communication, you’re going to break that trust.”

### Barriers to Implementing Effective Intervention Programs

Patient-level barriers to implementing effective intervention programs include stigma or shame, lack of knowledge or skills, and limited resources. The perceived stigma associated with receiving assistance for food insecurity may deter patients from seeking or accepting interventions.^119,^ ^136^ Patients may lack knowledge about available resources and how to access them, or they may lack the necessary skills to prepare and access healthy food.^135^ Finally, financial constraints, work conflicts, physical limitations, transportation challenges, or lack of access to grocery stores and fresh produce can hinder patients’ ability to engage in interventions.^119,^ ^134,^ ^136,^ ^142^

Common provider-level barriers may include time constraints, limited awareness and resources, and inadequate reimbursement. Providers may have limited time during patient visits, making it challenging to discuss food insecurity comprehensively and provide detailed interventions.^143^ Providers may also have limited knowledge of available community resources or face challenges in accessing and coordinating appropriate interventions for their patients.^144^ Furthermore, the lack of financial incentives or reimbursement for addressing food insecurity can undermine providers’ (and health systems’) motivation to prioritize and invest time in interventions.^145^

Health system-level barriers can include limited resources, fragmented systems of care, and inadequate policies and procedures.^140^ Insufficient funding, staffing, and infrastructure can hinder the development and implementation of effective interventions at the health system level. Lack of coordination and communication between healthcare providers, community organizations, and social services can also create barriers to accessing and delivering interventions. Absence of policies or regulations that mandate or support interventions to address food insecurity can impede implementation efforts.

Common community-level barriers may include limited resources, cultural or language barriers, and geographic disparities between communities. Communities with limited infrastructure, funding, and resources may struggle to develop and sustain interventions to address food insecurity.^127^ Cultural and linguistic diversity within communities can present challenges in delivering culturally appropriate interventions and engaging diverse populations.^130^ Finally, rural communities may face unique challenges, such as limited access to transportation and a scarcity of food retail options, making it difficult to implement interventions effectively.