# Appendix E Background & Discussion Tables and Figures

Appendix E Table 1 Multi-Domain Social Risk Factor Assessment Tools That Include Screening for Food +/− Nutrition Insecurity

Name of Tool | Target population | Total # of questions (# of food insecurity questions)
AAFP Tool^44^ | Non-specified | 15 (2)
AccessHealth: Spartanburg^45^ | Non-specified | 26 (1)
Accountable Health Communities (AHC) Tool^46,^ ^47^ | Medicare and Medicaid beneficiaries | 26 (2)
Arlington Screening Tool^48^ | Non-specified | 11 (1)
BMC-Thrive^49^ | Non-specified | 11 (3)
HealthBegins^49,^ ^50^ | Non-specified | 28 (3)
Health Leads Social Needs Screening Toolkit^51,^ ^52^ | Non-specified | 43 (1)
HelpSteps^13,^ ^53^ | Pediatrics/young adults | 130 (2)
Medicare Total Health Assessment Questionnaire^54^ | Medicare beneficiaries | 39 (2)
NC Medicaid^55^ | Medicaid beneficiaries | 11 (2)
Income, Housing, Education, Legal status, Literacy, Personal Safety (IHELLP)^56^ | Pediatrics | 17 (3)
iScreen^57^ | Pediatrics | 23 (4)
Legal Checkup^58^ | Pediatrics | 18 (1)
LIFESCREEN-C^59^ | College students | 18 (1)
Medical-Legal Partnership (MLP)^60^ | Non-specified | 10 (3)
Protocol for Responding to and Assessing Patient Assets, Risks, and Experiences (PRAPARE)^61^ | Community Health Center patients | 36 (1)
Safe Environment for Every Kid (SEEK)^62^ | Pediatrics | 20 (2)
Screener for Intensifying Community Referrals for Health (SINCERE)^63^ | Adults with low literacy | 10 (1)
Social History Template^64,^ ^65^ | Pediatrics | 7 (1)
Structural Vulnerability Assessment Tool^66^ | Non-specified | 43 (1)
Survey of Well-Being of Young Children (SWYC)^67^ | Pediatrics | 10 (1)
Total Health Assessment Questionnaire for Medicare Members^68^ | Medicare beneficiaries | 36 (3)
WE CARE Survey^69^ | Pediatrics | 10 (2)
WellRx Questionnaire^70^ | Primary care patients | 11 (1)
Your Current Life Situation^49^ | Non-specified | 32 (2)

Appendix E Table 2 Recommendations of Others Related to Assessing for and Intervening on Food Insecurity

Organization | Year | Recommendation
AARP^71^ | 2016 | AARP stresses the importance of routine food insecurity screening and referral in primary care practice and developed a resource guide and toolkit to support implementation of screening.
Academy of Nutrition and Dietetics^72^ | 2017 | The Academy of Nutrition and Dietetics recommends conducting screening and measuring food security status in all settings, and endorses the use of screening tools such as the Hunger Vital Sign, and referral to appropriate healthcare and community-based resources.
American Academy of Family Physicians^73^ | 2019 | The American Academy of Family Physicians endorses screening patients for social needs, and its EveryONE Project™ initiative offers a social needs screening tool that includes housing, food, transportation, utilities, personal safety, employment, education, child care, and financial strain.
American Academy of Pediatrics^74^ | 2015 | The American Academy of Pediatrics recommends that pediatricians screen and identify children at risk for food insecurity (using 2-item Hunger Vital Sign screener); connect families to needed community resources; and advocate with other key partners and stakeholders for federal, state, and local policies that support access to adequate and healthy food.
American College of Cardiology/American Heart Association^75^ | 2019 | In their recommendations for patient-centered approaches to comprehensive cardiovascular disease prevention, the American College of Cardiology and American Heart Association state that risk factors tied to socioeconomic status, such as food insecurity, should inform treatment advice; therefore, cardiovascular disease prevention would benefit from social needs screening.
American College of Obstetricians and Gynecologists^76^ | 2018 | The American College of Obstetricians and Gynecologists recommends obstetrician–gynecologists and other healthcare providers:; - Inquire about and document social and structural determinants of health that may influence a patient’s health and use of healthcare, such as access to stable housing, access to food and safe drinking water, utility needs, safety in the home and community, immigration status, and employment conditions;; - Maximize referrals to social services to help improve patients’ abilities to fulfill these needs; and; - Advocate for policy changes that promote safe and healthy living environments.
American College of Physicians^77^ | 2022 | The American College of Physicians believes that physicians and other medical professionals should undertake activities to better understand and mitigate food insecurity experienced by their patients.; - Healthcare teams should screen for food insecurity as part of office and hospital visits, with financial, technical, and policy support from policymakers and payers.; - Screening tools and resources for addressing food insecurity should be developed and validated.; - Practices and hospitals should establish referral mechanisms to community and government resources, with financial, technical, and policy support from policymakers and payers.
American Diabetes Association^78^ | 2023 | The section on Tailoring Treatment for Social Context in the American Diabetes Association’s 2023 Standards of Medical Care in Diabetes recommends:; Assess food insecurity, housing insecurity/homelessness, financial barriers, and social capital/social community support and apply that information to treatment decisions, with referral to appropriate local community resources.; - Food insecurity can be assessed using the 2-item Hunger Vital Sign screener.; Provide patients with additional self-management support from lay health coaches, navigators, or community health workers when available.; - Interventions such as food prescription programs are considered promising practices to address food insecurity.; Consider the involvement of community health workers to support the management of diabetes and cardiovascular risk factors, especially in underserved communities and healthcare systems.; In those with diabetes and food insecurity, priority is to mitigate the increased risk of uncontrolled hyperglycemia (from steady consumption of inexpensive carbohydrate-rich processed foods, binge eating, financial constraints to filling diabetes medication prescriptions, and anxiety/depression leading to poor diabetes self-care behaviors) or severe hypoglycemia as a result of inadequate or erratic carbohydrate consumption following the administration of sulfonylureas or insulin.
Task Force on Hunger, Nutrition, and Health^79^ | 2022 | In its report, the Task Force makes the following recommendations about healthcare:; - Accelerate access to “Food Is Medicine” services to prevent and treat diet-related illness.; - Increase access to and insurance coverage for behavioral interventions and nutritional counseling to improve diet and health.; - Build a diverse healthcare workforce with appropriate training and expertise in diet and health.; - Facilitate health system screening for food and nutrition insecurity and followup referrals to appropriate interventions.; - Leverage the integral role hospitals play in regional food systems and local communities to improve food and nutrition security for community members.