# Appendix D Additional Evidence Tables

Appendix D Table 1 Results, Key Question 2

Appendix D Table 2 Detailed Descriptions of Interventions, Key Question 4

Appendix D Table 3 All Food Insecurity Outcome Results, Key Question 4

Appendix D Table 4 Behavioral Outcome Results (Food Security Only Interventions), Key Question 4