# Appendix C Excluded Studies List

Reason for Exclusion
E1. Setting
E1a: Study conducted outside the US
E1b: No link with healthcare system
E2. Population
E2a. % of population food insecure <50% or not reported
E3. Study design
E4. No relevant outcomes
E4a. Multidomain/multicomponent study without food insecurity outcome
E4b. <12 weeks followup
E5. Study aim
E6. Intervention
E7. Comparator
E7a: No control/comparator (KQ1 and KQ4)
E7b: No reference standard (KQ2 only)
E8. Language: not in English
E9. Poor study quality
E10. Unable to locate article
E11. Publication type: Conference abstract only

1 Abel, Dori, Drucker, Gabriela, . Assessment of a Fruit and Vegetable Prescription Program in the Northern Manhattan Community. American Journal of Health Promotion. 36(6): 1014–1018. 2022. 10.1177/08901171221076778 KQ4E4, KQ5E435325560
2 Ackermann, RT, Liss, DT, . A randomized comparative effectiveness trial of a primary care-community linkage for preventing type 2 diabetes. Journal of general internal medicine. 30: S88–S89. 2015. KQ4E6, KQ5E6
3 Adams, E, Hargunani, D, . Screening for Food Insecurity in Pediatric Primary Care: A Clinic’s Positive Implementation Experiences. J Health Care Poor Underserved. 28(1): 24–29. 2017. 10.1353/hpu.2017.0004 KQ2E4
4 Agarwal, Gina, Pirrie, Melissa, . Legal needs of patients attending an urban family practice in Hamilton, Ontario, Canada: an observational study of a legal health clinic. BMC Fam Pract. 21(1). 2020. KQ1E7, KQ3E7, KQ4E7, KQ5E7
5 Akiya, K, Fisher, E, . Aligning Health Care and Social Services to Reduce Hospitalizations and Emergency Department Visits: An Evaluation of the Community Care Connections Program. Med Care. 59(8): 671–678. 2021. PMID: 34054026. 10.1097/mlr.0000000000001578 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a34054026
6 Amezquita, Lillian, George, Paul. Food insecurity: how to recognize and address it. J Fam Pract. 69(2): 74;78;80;81. 2020. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3
7 Anderson, Della, Patch, Enedina, . Nursing student coaches for emergency department super utilizers. J Nurs Educ. 56(1): 27–30. 2017. KQ4E4a, KQ5E4a28118472
8 Arbour, Mary Catherine, Floyd, Baraka, . Cross-Sector Approach Expands Screening and Addresses Health-Related Social Needs in Primary Care. Pediatrics. 148(5). 2021. 10.1542/peds.2021-050152 KQ1E4, KQ3E4, KQ4E4, KQ5E4
9 Arbour, MaryCatherine, Fico, Placidina, . Benefits of a Universal Intervention in Pediatric Medical Homes to Identify and Address Health-Related Social Needs: An Observational Cohort Study. Acad Pediatr. 18: 18. 2022. 10.1016/j.acap.2022.06.013 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a
10 Arevian, Ac, Jones, F, . Depression Remission From Community Coalitions Versus Individual Program Support for Services: findings From Community Partners in Care, Los Angeles, California, 2010-2016. Am J Public Health. 109(S3): S205–s213. 2019. PMID: 31242001. 10.2105/AJPH.2019.305082 KQ4E4a, KQ5E4a31242001
11 Bailey-Davis, L, Moore, Am, . Comparing enhancements to well-child visits in the prevention of obesity: ENCIRCLE cluster-randomized controlled trial. BMC Public Health. 22(1): 2429. 2022. 10.1186/s12889-022-14827-w KQ4E6, KQ5E636572870
12 Bakre, S, Shea, B, . Changes in Food Insecurity Among Individuals Using a Telehealth and Nutrition Platform: Longitudinal Study. JMIR Formative Research. 6(10): e41418. 2022. PMID: 36282563. 10.2196/41418 KQ4E6, KQ5E436282563
13 Bakshi, S, Carlson, LC, . Improving care coordination and reducing ED utilization through patient navigation. Am J Manag Care. 28(5): 201–206. 2022. PMID: 35546582. 10.37765/ajmc.2022.89140 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a35546582
14 Barcelos Winchester, Suzy. Social Determinants of Health Assessment Tool: Implications for Healthcare Practice. Soc Work Public Health. 34(5): 395–408. 2019. 10.1080/19371918.2019.1614507 KQ2E431088227
15 Barnidge, E, LaBarge, G, . Screening for Food Insecurity in Pediatric Clinical Settings: Opportunities and Barriers. J Community Health. 42(1): 51–57. 2017. 10.1007/s10900-016-0229-z , KQ3E427492774
16 Bayoumi, Imaan, Birken, CatherineS, . Screening for marginal food security in young children in primary care. BMC Pediatr. 21(1): 196. 2021. 10.1186/s12887-021-02674-4 KQ1E1a, KQ2E1a, KQ3E1a, KQ4E1a, KQ5E1a33892660
17 Bazos, DA, Weeks, WB, . The development of a survey instrument for community health improvement. Health Serv Res. 36(4): 773–92. 2001. KQ1E4, KQ3E411508639
18 Beavis, Anna Louise, Sanneh, Awa, . Basic social resource needs screening in the gynecologic oncology clinic: a quality improvement initiative. Am J Obstet Gynecol. 223(5): 735.e1–735.e14. 2020. KQ1E4, KQ3E4, KQ4E4, KQ5E4
19 Bechtel, Nancie, Jones, Alexandria, . Evaluation of the core 5 social determinants of health screening tool. Public Health Nurs. 39(2): 438–445. 2022. 10.1111/phn.12983 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a34628675
20 Beck, AF, Henize, AW, . Forging a pediatric primary care-community partnership to support food-insecure families. Pediatrics. 134(2): e564–71. 2014. 10.1542/peds.2013-3845 KQ4E4a, KQ5E4a25049345
21 Beck, AF, Klein, MD, . Identifying and treating a substandard housing cluster using a medical-legal partnership. Pediatrics. 130(5): 831–8. 2012. 10.1542/peds.2012-0769 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a23090340
22 Beck, AF, Klein, MD, . Identifying social risk via a clinical social history embedded in the electronic health record. Clin Pediatr (Phila). 51(10): 972–7. 2012. 10.1177/0009922812441663 KQ1E4, KQ3E422511197
23 Berkowitz, SA, Basu, S, . Eliminating Food Insecurity in the USA: a Target Trial Emulation Using Observational Data to Estimate Effects on Health-Related Quality of Life. J Gen Intern Med. 38(10): 2308–2317. 2023. PMID: 36814050. 10.1007/s11606-023-08095-6 KQ1E3, KQ3E3, KQ4E3, KQ5E336814050
24 Berkowitz, SA, Hulberg, AC, . Addressing basic resource needs to improve primary care quality: a community collaboration programme. BMJ Qual Saf. 25(3): 164–72. 2016. 10.1136/bmjqs-2015-004521 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a
25 Berkowitz, SA, Hulberg, AC, . Addressing Unmet Basic Resource Needs as Part of Chronic Cardiometabolic Disease Management. JAMA Intern Med. 177(2): 244–252. 2017. 10.1001/jamainternmed.2016.7691 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a27942709
26 Berkowitz, SA, O’Neill, J, . Health Center-Based Community-Supported Agriculture: An RCT. Am J Prev Med. 57(6 Suppl 1): S55–S64. 2019. PMID: 31522922. 10.1016/j.amepre.2019.07.015 KQ4E2a, KQ5E2a31522922
27 Berkowitz, SA, Terranova, J, . Association Between Receipt of a Medically Tailored Meal Program and Health Care Use. JAMA Intern Med. 179(6):786–783. 2019. 10.1001/jamainternmed.2019.0198 KQ1E2, KQ3E2, KQ4E2, KQ5E231009050
28 Berkowitz, SA, Terranova, J, . Meal Delivery Programs Reduce The Use Of Costly Health Care In Dually Eligible Medicare And Medicaid Beneficiaries. Health Aff (Millwood). 37(4): 535–542. 2018. 10.1377/hlthaff.2017.0999 KQ4E3, KQ5E329608345
29 Bikson, K, McGuire, J, . Psychosocial problems in primary care: patient and provider perceptions. Soc Work Health Care. 48(8): 736–49. 2009. 10.1080/00981380902929057 KQ1E4, KQ3E4, KQ4E4, KQ5E420182986
30 Billioux, A, Verlander, K, . Standardized screening for health-related social needs in clinical settings: The accountable health communities screening tool. 2017. KQ1E4, KQ3E4
31 Birkhead, GS, LeBaron, CW, . The immunization of children enrolled in the Special Supplemental Food Program for Women, Infants, and Children (WIC). The impact of different strategies. Jama. 274(4): 312–6. 1995. PMID: 7609260. KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a7609260
32 Blancafort Alias, Sergi, Monteserin Nadal, Rosa, . Promoting social capital, self-management and health literacy in older adults through a group-based intervention delivered in low-income urban areas: results of the randomized trial AEQUALIS. BMC Public Health. 21(1): 84. 2021. 10.1186/s12889-020-10094-9 KQ1E1a, KQ2E1a, KQ3E1a, KQ4E1a, KQ5E1a33413233
33 Blitstein, JL, Lazar, D, . Foods for Health: An Integrated Social Medical Approach to Food Insecurity Among Patients With Diabetes. Am J Health Promot. 35(3): 369–376. 2021. PMID: 33043687. 10.1177/0890117120964144 KQ4E2a, KQ5E2a33043687
34 Borden, CG, Ashe, EM, . A novel pharmacy liaison program to address health-related social needs at an urban safety-net hospital. Am J Health Syst Pharm. 80(16): 1071–1081. 2023. PMID: 37210728. 10.1093/ajhp/zxad113 KQ4E4a, KQ5E4a37210728
35 Bottino, CJ, Rhodes, ET, . Food Insecurity Screening in Pediatric Primary Care: Can Offering Referrals Help Identify Families in Need?. Acad Pediatr. 17(5): 497–503. 2017. 10.1016/j.acap.2016.10.006 KQ1E4, KQ3E4, KQ4E4, KQ5E428302365
36 Bourgois, P, Holmes, SM, . Structural Vulnerability: Operationalizing the Concept to Address Health Disparities in Clinical Care. Acad Med. 92(3): 299–307. 2017. 10.1097/ACM.0000000000001294 KQ1E4, KQ3E427415443
37 Briefel, RonetteR, Chojnacki, GregoryJ, . A Cluster Randomized Controlled Trial of a Home-Delivered Food Box on Food Security in Chickasaw Nation. J Acad Nutr Diet. 121(1S): S46–S58. 2021. 10.1016/j.jand.2020.07.021 KQ4E1b, KQ5E1b33342524
38 Brown, AF, Behforouz, H, . The care connections program: a randomized trial of community health workers to improve care for medically and socially complex patients. J Gen Intern Med. 35(SUPPL 1): S288-. 2020. 10.1007/s11606-020-05890-3 KQ4E4, KQ5E4
39 Brown, E, Bloom, JR. The nurse practitioner and hypertension control: a pilot study. Eval Health Prof. 2(1): 87–99. 1979. KQ4E4a, KQ5E4a10241088
40 Brown, Onikia, Mukigi, Dorcas. O9 A Text-Delivered Intervention to Improve Dietary Habits, Stress Management Behaviors and Create Awareness of Food Assistance Resources Among College Students. Society for Nutrition Education and Behavior, 52nd Annual Conference, Nutrition Education: Rooted in Food, July 27-30, 2019, Orlando, Florida. J Nutr Educ Behav. 51: S4–S5. 2019. 10.1016/j.jneb.2019.05.315 KQ1E11, KQ3E11, KQ4E11, KQ5E11
41 Brown, Rachel, Reilly, Georgia, . Farm to Families: Clinic-based Produce Provision to Address Food Insecurity During the Pandemic. Pediatrics. 150(4): 01. 2022. 10.1542/peds.2022-057118 KQ4E4, KQ5E4
42 Bryce, R, Guajardo, C, . Participation in a farmers’ market fruit and vegetable prescription program at a federally qualified health center improves hemoglobin A1C in low income uncontrolled diabetics. Prev Med Rep. 7: 176–179. 2017. PMID: 28702315. 10.1016/j.pmedr.2017.06.006 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a28702315
43 Buchanan, D, Doblin, B, . The effects of respite care for homeless patients: a cohort study. Am J Public Health. 96(7): 1278–81. 2006. 10.2105/ajph.2005.067850 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a16735635
44 Buitron de la Vega, P, Losi, S, . Implementing an EHR-based Screening and Referral System to Address Social Determinants of Health in Primary Care. Med Care. 57 Suppl 6 Suppl 2: S133–s139. 2019. 10.1097/mlr.0000000000001029 KQ1E7, KQ3E7, KQ4E7, KQ5E731095052
45 Burkhardt, MC, Beck, AF, . Enhancing accurate identification of food insecurity using quality-improvement techniques. Pediatrics. 129(2): e504–10. 2012. 10.1542/peds.2011-1153 KQ1E4, KQ3E4, KQ4E4, KQ5E422250022
46 Burnam, MA, Morton, SC, . An experimental evaluation of residential and nonresidential treatment for dually diagnosed homeless adults. J Addict Dis. 14(4): 111–34. 1995. PMID: 8929936. 10.1300/j069v14n04_07 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a8929936
47 Burrington, ChristineM, Hohensee, ThomasE, . A pilot study of an online produce market combined with a fruit and vegetable prescription program for rural families. Preventive Medicine Reports. 17: 101035. 2020. 10.1016/j.pmedr.2019.101035 KQ4E5, KQ5E532021759
48 Byhoff, Elena, Guardado, Rubeen, . A Community Partnership to Reduce Food Insecurity and Improve Patient-Reported Depression. NEJM Catalyst Innovations in Care Delivery. 4(2): 1–11. 2023. 10.1056/CAT.22.0330 KQ4E2a, KQ5E2a
49 Caldwell, JuliaI, Kuo, Tony, . Health Behavior Changes Among Adults in the Supplemental Nutrition Assistance Program Education, Los Angeles County, California. Prev Chronic Dis. 18: E102. 2021. 10.5888/pcd18.210221 KQ4E1b, KQ5E1b34914578
50 Calloway, EE, Carpenter, LR, . Development of three new multidimensional measures to assess household food insecurity resilience in the United States. Frontiers in Public Health. 10: 1048501. 2022. PMID: 36589949. 10.3389/fpubh.2022.1048501 KQ2E436589949
51 Calloway, EE, Carpenter, LR, . New measures to assess the “Other” three pillars of food security-availability, utilization, and stability. International Journal of Behavioral Nutrition & Physical Activity. 20(1): 51. 2023. PMID: 37101157. 10.1186/s12966-023-01451-z KQ2E437101157
52 Calloway, EricE, Carpenter, LeahR, . Development of new measures to assess household nutrition security, and choice in dietary characteristics. Appetite. 179: 106288. 2022. 10.1016/j.appet.2022.106288 KQ2E436049571
53 Calvo-Friedman, Alessandra, Clapp, Jenifer, . Scaling Primary Care Social Needs Screening and Referrals in New York City’s Safety-Net Health System. NEJM Catalyst Innovations in Care Delivery. 4(3): CAT. 22.0371. 2023. KQ1E4, KQ3E4, KQ4E4, KQ5E4
54 Chagin, Kevin, Choate, Franklin, . A Framework for Evaluating Social Determinants of Health Screening and Referrals for Assistance. J Prim Care Community Health. : 1–8. 2021. 10.1177/21501327211052204 KQ1E4, KQ3E4, KQ4E4, KQ5E4
55 Chase, J, Bilinski, J, . Caring for Emergency Department Patients With Complex Medical, Behavioral Health, and Social Needs. JAMA. 324(24): 2550–2551. 2020. PMID: 33351045. 10.1001/jama.2020.17017 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a33351045
56 Chatterjee, Avik, Brown, Rory, . “Feastworthy is Something That Gives Us Our Dignity Back:” Feasibility of A Delivered Prepared Meal Program for Families in Motel-Shelters. J Health Care Poor Underserved. 29(4): 1333–1355. 2018. 10.1353/hpu.2018.0099 KQ4E1b, KQ5E1b30449750
57 Cho, Jinmyoung, Marishak-Simon, Sherry, . The impact of a nutrition counseling program on the use of hospital services for Meals on Wheels clients. J Prev Interv Community. 51(3): 225–237. 2023. 10.1080/10852352.2021.1930818 KQ1E7a, KQ3E7a, KQ4E4, KQ5E434096479
58 Ciaranello, AL, Molitor, F, . Providing health care services to the formerly homeless: a quasi-experimental evaluation. J Health Care Poor Underserved. 17(2): 441–61. 2006. PMID: 16702726. 10.1353/hpu.2006.0056 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a16702726
59 Clark, CR, Baril, N, . Addressing social determinants of health to improve access to early breast cancer detection: results of the Boston REACH 2010 Breast and Cervical Cancer Coalition Women’s Health Demonstration Project. Journal of Women’s Health. 18(5): 677–90. 2009. 10.1089/jwh.2008.0972 KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a
60 Clark, CR, Baril, N, . Case management intervention in cervical cancer prevention: the Boston REACH coalition women’s health demonstration project. Prog Community Health Partnersh. 5(3): 235–47. 2011. 10.1353/cpr.2011.0034 KQ1E4, KQ3E4, KQ4E4, KQ5E422080772
61 Clerkin, KirstenD, Pohl, CarlaJ, . Influencing nutritional habits of college students using a food pantry. Journal of American College Health. 69(8): 937–941. 2021. 10.1080/07448481.2020.1721506 KQ4E1b, KQ5E1b32045338
62 Cohen, DA, Estrada, EL, . Food prescription pilots: feasibility, acceptability and affordability of improving diet through menu planning and grocery delivery. J Hum Nutr Diet. 36(4): 1556–1563. 2023. PMID: 36653939. 10.1111/jhn.13142 KQ4E4, KQ5E436653939
63 Cohen-Silver, J, Adams, S, . Development of the Pediatric Social Risk Instrument Using a Structured Panel Approach. Clin Pediatr (Phila). 57(12): 1414–1422. 2018. PMID: 30003793. 10.1177/0009922818784959 KQ2E430003793
64 Colvin, JD, Bettenhausen, JL, . Caregiver Opinion of In-Hospital Screening for Unmet Social Needs by Pediatric Residents. Acad Pediatr. 16(2): 161–7. 2016. 10.1016/j.acap.2015.06.002 KQ1E4, KQ3E426946270
65 Colvin, JD, Bettenhausen, JL, . Multiple Behavior Change Intervention to Improve Detection of Unmet Social Needs and Resulting Resource Referrals. Acad Pediatr. 16(2): 168–74. 2016. 10.1016/j.acap.2015.06.001 KQ1E4, KQ3E426183003
66 Cook, CA, Freedman, JA, . Screening for social and environmental problems in a VA primary care setting. Health Soc Work. 21(1): 41–7. 1996. 10.1093/hsw/21.1.41 KQ1E4, KQ3E4, KQ4E4, KQ5E48626157
67 Cook, M, Taylor, K, . Participation in the Georgia Food for Health program and cardiovascular disease risk factors: A longitudinal observational study. Public Health Nutr. : 1–30. 2023. PMID: 37548244. 10.1017/S1368980023001611 KQ4E4, KQ5E436213951
68 Corey, JenelleR, Courts, KellyA, . Understanding Caregiver Perspective on Social Determinants of Health Interventions in Pediatric Primary Care. Popul Health Manag. 25(2): 172–177. 2022. 10.1089/pop.2021.0317 KQ4E4b, KQ5E4b35442798
69 Corney, RH. The effectiveness of attached social workers in the management of depressed female patients in general practice. Psychological Medicine - Monograph Supplement. 6: 1–47. 1984. KQ4E66387754
70 Costich, MA, Peretz, PJ, . Impact of a Community Health Worker Program to Support Caregivers of Children With Special Health Care Needs and Address Social Determinants of Health. Clin Pediatr (Phila): 9922819851263. 2019. 10.1177/0009922819851263 KQ1E2, KQ3E2, KQ4E2, KQ5E2
71 Crichton, EmmaS, Manhan, AndrewJ, . The Potential Impact of Food Insecurity in an Urban Trauma Population. Am Surg. 88(8): 2045–2049. 2022. 10.1177/00031348221094217 KQ2E7b35487593
72 Cueva, Katie, Lovato, Ventura, . Increasing Healthy Food Availability, Purchasing, and Consumption: Lessons Learned from Implementing a Mobile Grocery. Progress in Community Health Partnerships. 12(1): 65–72. 2018. 10.1353/cpr.2018.0007 KQ4E1b, KQ5E1b29606694
73 Cullen, Danielle, Abel, Dori, . Exploring the Gap: Food Insecurity and Resource Engagement. Acad Pediatr. 21(3): 440–445. 2021. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a32795688
74 Cullen, Danielle, Blauch, Abigail, . Complete Eats: Summer Meals Offered by the Emergency Department for Food Insecurity. Pediatrics. 144(4): e20190201. 2019. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a31484676
75 Czaja, SJ, Boot, WR, . Improving Social Support for Older Adults Through Technology: Findings From the PRISM Randomized Controlled Trial. Gerontologist. 58(3): 467–477. 2018. PMID: 28201730. 10.1093/geront/gnw249 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a28201730
76 Daundasekara, Sajeevika Saumali, Schuler, BrittanyR, . A latent class analysis to identify socio-economic and health risk profiles among mothers of young children predicting longitudinal risk of food insecurity. PLoS ONE [Electronic Resource]. 17(8): e0272614. 2022. 10.1371/journal.pone.0272614 KQ2E536001540
77 David, Pyone, Qureshi, NadiaK, . Social Determinants of Health Screening at Well Child Visits: A Pilot Program Implemented During the COVID-19 Pandemic. Lobal Pediatric Health. 8: 2333794X211060971. 2021. 10.1177/2333794X211060971 KQ4E4, KQ5E4
78 De Marchis, E, Pantell, M, . Prevalence of Patient-Reported Social Risk Factors and Receipt of Assistance in Federally Funded Health Centers. J Gen Intern Med. 35(1): 360–364. 2020. 10.1007/s11606-019-05393-w KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E331677105
79 deJong, NealA, Kimple, KellyS, . A Quality Improvement Intervention Bundle to Reduce 30-Day Pediatric Readmissions. Pediatric Quality & Safety. 5(2): e264. 2020. 10.1097/pq9.0000000000000264 KQ4E4a, KQ5E4a32426630
80 Dubowitz, H, Feigelman, S, . Screening for depression in an urban pediatric primary care clinic. Pediatrics. 119(3): 435–43. 2007. 10.1542/peds.2006-2010 , KQ4E5, KQ5E517332195
81 Dubowitz, H, Lane, WG, . The safe environment for every kid model: impact on pediatric primary care professionals. Pediatrics. 127(4): e962–70. 2011. 10.1542/peds.2010-1845 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a21444590
82 Dubowitz, H, Prescott, L, . Screening for intimate partner violence in a pediatric primary care clinic. Pediatrics. 121(1): e85–91. 2008. 10.1542/peds.2007-0904 KQ1E5, KQ3E518166548
83 Dubowitz, H. The Safe Environment for Every Kid model: promotion of children’s health, development, and safety, and prevention of child neglect. Pediatr Ann. 43(11): e271–7. 2014. 10.3928/00904481-20141022-11 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a25369580
84 Dubowitz, Howard, Lane, WendyG, . The SEEK Model of Pediatric Primary Care: Can Child Maltreatment Be Prevented in a Low-Risk Population?. Acad Pediatr. 12(4): 259–268. 2012. 10.1016/j.acap.2012.03.005 KQ1E4, KQ3E4, KQ4E4, KQ5E422658954
85 Duncan, PW, Bushnell, CD, . Randomized Pragmatic Trial of Stroke Transitional Care: The COMPASS Study. Circ Cardiovasc Qual Outcomes. 13(6): e006285. 2020. PMID: 32475159. 10.1161/CIRCOUTCOMES.119.006285 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a32475159
86 Duru, OK, Harwood, J, . Evaluation of a National Care Coordination Program to Reduce Utilization Among High-cost, High-need Medicaid Beneficiaries With Diabetes. Med Care. 58 Suppl 6 Suppl 1: S14–S21. 2020. PMID: 32412949. 10.1097/MLR.0000000000001315 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a32412949
87 Ebadi-Vanestanagh, M, Molani-Gol, R, . Effects of the nutrition education intervention on food security, anthropometry, and body composition in women: A randomized controlled trial. Nutr Health. : 2601060231155538. 2023. PMID: 36775939. 10.1177/02601060231155538 KQ1E1a, KQ2E1a, KQ3E1a, KQ4E1a, KQ5E1a36775939
88 Eicher-Miller, HeatherA, Rivera, RebeccaL, . Supplemental Nutrition Assistance Program-Education Improves Food Security Independent of Food Assistance and Program Characteristics. Nutrients. 12(9): 29. 2020. 10.3390/nu12092636 KQ4E1b, KQ5E1b
89 Eicher-Miller, HeatherA, Wright, BreanneN, . Evaluating a Food Pantry-Based Intervention to Improve Food Security, Dietary Intake, and Quality in Midwestern Food Pantries. J Acad Nutr Diet. 26: 26. 2022. 10.1016/j.jand.2022.02.016 KQ2E1b, KQ4E1b, KQ5E1b
90 Elliott, Jennifer Padden, Christian, StephanieN, . Pharmacist Involvement in Addressing Public Health Priorities and Community Needs: The Allegheny County Racial and Ethnic Approaches to Community Health (REACH) Project. Prev Chronic Dis. 18: E07. 2021. 10.5888/pcd18.200490 KQ1E4, KQ3E4, KQ4E4, KQ5E433507859
91 Emmert-Aronson, Benjamin, Grill, KatherineB, . Group Medical Visits 2.0: The Open Source Wellness Behavioral Pharmacy Model. Journal of Alternative & Complementary Medicine. 25(10): 1026–1034. 2019. 10.1089/acm.2019.0079 KQ4E4a, KQ5E4a31460769
92 Esquivel MK, Higa A, Hitchens M, Shelton C, . Keiki produce prescription (KPRx) program feasibility study to reduce food insecurity and obesity risk. Hawai’i J Heal Soc Welf. 79(5). 2020. KQ4E2a, KQ5E2a
93 Farthing, Heather, Simko, Sarah, . Development and evaluation of electronic social needs assessment and resource connection tool in facilitating utilization of community services that address upstream health. Journal of Student-Run Clinics. 7(1). 2021. KQ1E4b, KQ3E4b, KQ4E4b, KQ5E4b
94 Feehan, Katie, Kehinde, Folasade, . Development of a Multidisciplinary Medical Home Program for NICU Graduates. Matern Child Health J. 24(1): 11–21. 2020. 10.1007/s10995-019-02818-0 KQ4E4a, KQ5E4a31745836
95 Feigelman, S, Dubowitz, H, . Screening for harsh punishment in a pediatric primary care clinic. Child Abuse Negl. 33(5): 269–77. 2009. 10.1016/j.chiabu.2008.09.011 KQ1E4, KQ3E419477005
96 Feigelman, S, Dubowitz, H, . Training pediatric residents in a primary care clinic to help address psychosocial problems and prevent child maltreatment. Acad Pediatr. 11(6): 474–80. 2011. 10.1016/j.acap.2011.07.005 KQ2E421959095
97 Felder, KimberlyK, Jungbauer, RebeccaM, . Social Risk Screening Changes Medical Decision-Making in a Complex Outpatient Pediatric Antibiotic Therapy Program. J Pediatric Infect Dis Soc. 12(2): 117–119. 2023. 10.1093/jpids/piac128 KQ1E4, KQ3E4, KQ4E4, KQ5E436512521
98 Ferrer, B. Risk assessment tool to improve birth outcomes in Boston. The 128th Annual Meeting of the American Public Health Association. 2000. KQ1E4, KQ3E4, KQ4E4, KQ5E4
99 Ferrer, RL, Neira, LM, . Primary Care and Food Bank Collaboration to Address Food Insecurity: A Pilot Randomized Trial. Nutr Metab Insights. 12: 1178638819866434. 2019. PMID: 31384130. 10.1177/1178638819866434 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a31384130
100 Fields, Robert. Mission Health Partners: A Community-Based Social Determinants Driven Accountable Care Organization. N C Med J. 78(4): 245–247. 2017. 10.18043/ncm.78.4.245 KQ1E4, KQ3E4, KQ4E4, KQ5E428724674
101 Fiori, Kevin, Patel, Milani, . From Policy Statement to Practice: Integrating Social Needs Screening and Referral Assistance With Community Health Workers in an Urban Academic Health Center. J Prim Care Community Health. 10: 215013271989920. 2019. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a
102 Fitzhugh, CD, Pearsall, MS, . Social Determinants of Health in Maternity Care: A Quality Improvement Project for Food Insecurity Screening and Health Care Provider Referral. Health Equity. 5(1): 606–611. 2021. 10.1089/heq.2020.0120 KQ1E4, KQ3E4, KQ4E4, KQ5E434909527
103 Fleegler, EW, Lieu, TA, . Families’ health-related social problems and missed referral opportunities. Pediatrics. 119(6): e1332–41. 2007. 10.1542/peds.2006-1505 KQ1E4, KQ3E4, KQ4E4, KQ5E417545363
104 Flocke, SusanA, Ohri-Vachispati, Punam, . Developing multidimensional measures of healthy food access among low-income adults in Cleveland, Ohio, USA. Public Health Nutr. 20(16): 2859–2868. 2017. 10.1017/S1368980017002002 KQ2E428847323
105 Forbes, JM, Forbes, CR, . “Prevention Produce”: Integrating Medical Student Mentorship into a Fruit and Vegetable Prescription Program for At-Risk Patients. Perm J. 23. 2019. PMID: 30939289. 10.7812/tpp/18-238 KQ4E4b, KQ5E4b30939289
106 Freedman, D, VanderHorst, N. PS3-55: Utilization of high-technology to collect health risk assessment information from medicare members: A feasibility study of interactive voice response (IVR) and an online survey tool. Clin Med Res. 11(3): 175–176. 2013. KQ1E4, KQ3E4, KQ4E4, KQ5E4
107 Freeman, AL, Li, T, . Community Health Worker Intervention in Subsidized Housing: New York City, 2016-2017. Am J Public Health. 110(5): 689–692. 2020. 10.2105/AJPH.2019.305544 KQ1E1b, KQ3E1b, KQ4E1b, KQ5E1b32191526
108 Friedman, Nicole L, Banegas, Matthew P. Toward addressing social determinants of health: a health care system strategy. Perm J. 22. 2018. KQ1E4, KQ3E4, KQ4E4, KQ5E4
109 Fritz, CristinQ, Thomas, Jacob, . Referral and Resource Utilization Among Food Insecure Families Identified in a Pediatric Medical Setting. Acad Pediatr. 21(3): 446–454. 2021. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a33253935
110 Gadhoke, Preety, Pemberton, Salome, . Development and validation of the Social Determinants of Health Questionnaire and implications for “Promoting Food Security and Healthy Lifestyles” in a complex urban food ecosystem. Ecol Food Nutr. 57(4): 261–281. 2018. 10.1080/03670244.2018.1481835 KQ2E429923747
111 Gany, FrancescaM, Pan, Sabrina, . Development of a Medically Tailored Hospital-based Food Pantry System. J Health Care Poor Underserved. 31(2): 595–602. 2020. KQ1E2, KQ3E2, KQ4E2, KQ5E233410795
112 Garey, L, Reitzel, LR, . Health-Related Quality of Life Among Homeless Smokers: Risk and Protective Factors of Latent Class Membership. Behav Med. 45(1): 40–51. 2019. 10.1080/08964289.2018.1447905 KQ1E4, KQ3E429558273
113 Garg, A, Brochier, A, . A Social Care System Implemented in Pediatric Primary Care: A Cluster RCT. Pediatrics. 152(2): 01. 2023. PMID: 37492934. 10.1542/peds.2023-061513 KQ4E4a, KQ5E4a37492934
114 Garg, A, Butz, AM, . Improving the management of family psychosocial problems at low-income children’s well-child care visits: the WE CARE Project. Pediatrics. 120(3): 547–58. 2007. 10.1542/peds.2007-0398 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a17766528
115 Garg, A, Butz, AM, . Screening for basic social needs at a medical home for low-income children. Clin Pediatr (Phila). 48(1): 32–6. 2009. 10.1177/0009922808320602 KQ1E4, KQ3E4, KQ4E3, KQ5E318566347
116 Garg, A, Marino, M, . Addressing families’ unmet social needs within pediatric primary care: the health leads model. Clin Pediatr (Phila). 51(12): 1191–3. 2012. 10.1177/0009922812437930 KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a22387923
117 Garg, A, Sarkar, S, . Linking urban families to community resources in the context of pediatric primary care. Patient Educ Couns. 79(2): 251–4. 2010. 10.1016/j.pec.2009.10.011 KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a19962849
118 Garg, A, Toy, S, . Addressing social determinants of health at well child care visits: a cluster RCT. Pediatrics. 135(2): e296–304. 2015. 10.1542/peds.2014-2888 KQ1E4, KQ3E4, KQ4E4, KQ5E425560448
119 Germán, Miguelina, Alonzo, JayxaK, . Early Childhood Referrals by HealthySteps and Community Health Workers. Clin Pediatr (Phila). 62(4): 321–328. 2023. 10.1177/00099228221120706 KQ4E4, KQ5E436113109
120 Ghouse, Amrien, Gunther, William, . Evaluation of a COVID-influenced Curriculum to Address Food Insecurity in a Detroit Family Medicine Residency Clinic. Spartan Medical Research Journal. 5(2): 17649. 2020. KQ4E5, KQ5E533655191
121 Giuse, NB, Koonce, TY, . Institute of Medicine Measures of Social and Behavioral Determinants of Health: A Feasibility Study. Am J Prev Med. 52(2): 199–206. 2017. 10.1016/j.amepre.2016.07.033 KQ1E4, KQ3E427659121
122 Glendenning-Napoli, A, Dowling, B, . Community-based case management for uninsured patients with chronic diseases: effects on acute care utilization and costs. Prof Case Manag. 17(6): 267–75. 2012. PMID: 23034434. 10.1097/NCM.0b013e3182687f2b KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a23034434
123 Glenn, LE, Nichols, M, . Impact of a community-based approach to patient engagement in rural, low-income adults with type 2 diabetes. Public Health Nurs. 37(2): 178–187. 2020. 10.1111/phn.12693 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a31833102
124 Gold, R, Bunce, A, . Adoption of Social Determinants of Health EHR Tools by Community Health Centers. Ann Fam Med. 16(5): 399–407. 2018. 10.1370/afm.2275 KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a30201636
125 Gold, R, Kaufmann, J, . Implementation Support for a Social Risk Screening and Referral Process in Community Health Centers. NEJM Catalyst Innovations in Care Delivery. 4(4). 2023. PMID: 37153938. 10.1056/CAT.23.0034 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a37153938
126 Gordon, Ar, Briefel, Rr, . Delivering Summer Electronic Benefit Transfers for Children through the Supplemental Nutrition Assistance Program or the Special Supplemental Nutrition Program for Women, Infants, and Children: benefit Use and Impacts on Food Security and Foods Consumed. J Acad Nutr Diet. 117(3): 367–375. 2017. 10.1016/j.jand.2016.11.002 KQ4E1b, KQ5E1b28017594
127 Gordon, LesleneE, Nguyen, AllisonW, . Considerations for Social Needs Screening in a Local Public Health Agency. Journal of Public Health Management & Practice. 28(2): E441–E445. 2022. 10.1097/PHH.0000000000001423 KQ1E4, KQ3E4, KQ4E4, KQ5E434475367
128 Gottlieb, L, Hessler, D, . A randomized trial on screening for social determinants of health: the iScreen study. Pediatrics. 134(6): e1611–8. 2014. 10.1542/peds.2014-1439 KQ2E425367545
129 Gunderson, JM, Wieland, ML, . Community Health Workers as an Extension of Care Coordination in Primary Care: A Community-Based Cosupervisory Model. J Ambul Care Manage. 41(4): 333–340. 2018. 10.1097/jac.0000000000000255 KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a30015685
130 Gupta, D, Self, S, . Understanding the Role of a Technology and EMR-based Social Determinants of Health Screening Tool and Community-based Resource Connections in Health Care Resource Utilization. Med Care. 61(7): 423–430. 2023. PMID: 36729786. 10.1097/MLR.0000000000001800 KQ1E5, KQ3E5, KQ4E5, KQ5E536729786
131 Gurvey, J, Rand, K, . Examining health care costs among MANNA clients and a comparison group. J Prim Care Community Health. 4(4): 311–7. 2013. PMID: 23799677. 10.1177/2150131913490737 KQ4E2a, KQ5E2a23799677
132 Gusmano, MK, Rodwin, VG, . Medicare Beneficiaries Living In Housing With Supportive Services Experienced Lower Hospital Use Than Others. Health Aff (Millwood). 37(10): 1562–1569. 2018. PMID: 30273020. 10.1377/hlthaff.2018.0070 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a30273020
133 Hager, K, De Kesel Lofthus, A, . Electronic Medical Record-Based Referrals to Community Nutritional Assistance for Food-Insecure Patients. Ann Fam Med. 18(3): 278. 2020. 10.1370/afm.2530 KQ1E4, KQ3E4, KQ4E4, KQ5E432393567
134 Haney, KE, Measom, MT, . Mitigating Food Insecurity During the COVID-19 Pandemic: A Replicable Food Delivery Service Using Public-Private Partnerships. J Health Care Poor Underserved. 33(4S): 195–201. 2022. PMID: 36533468. 10.1353/hpu.2022.0168 KQ4E4, KQ5E436533468
135 Hanna, SL, Wu, CL, . Food Insecurity Screening of Hospitalized Patients: A Descriptive Analysis. Hospital Pediatrics. 12(6): e196–e200. 2022. PMID: 35546296. 10.1542/hpeds.2022-006549 KQ1E4, KQ3E4, KQ4E4, KQ5E435546296
136 Hanson, Kl, Kolodinsky, J, . Adults and Children in Low-Income Households That Participate in Cost-Offset Community Supported Agriculture Have High Fruit and Vegetable Consumption. Nutrients. 9(7): 726–735. 2017. 10.3390/nu9070726 KQ4E1b, KQ5E1b28698460
137 Hardy, R, Boch, S, . Social Determinants of Health Needs and Pediatric Health Care Use. J Pediatr. 238: 275–281.e1. 2021. PMID: 34329688. 10.1016/j.jpeds.2021.07.056 KQ1E5, KQ3E5, KQ4E5, KQ5E534329688
138 Harrison, PA, Sidebottom, AC. Systematic prenatal screening for psychosocial risks. J Health Care Poor Underserved. 19(1): 258–76. 2008. 10.1353/hpu.2008.0003 KQ1E4, KQ3E4, KQ4E4, KQ5E418264001
139 Hassaballa, I, Davis, L, . Examining implementation and effects of a comprehensive community intervention addressing type 2 diabetes among high-risk minority patients in Durham County, NC. J Prev Interv Community. 49(1): 20–42. 2021. PMID: 31364960. 10.1080/10852352.2019.1633069 KQ1E4a KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a31364960
140 Hassan, A, Scherer, EA, . Improving Social Determinants of Health: Effectiveness of a Web-Based Intervention. Am J Prev Med. 49(6): 822–31. 2015. 10.1016/j.amepre.2015.04.023 KQ4E4b, KQ5E4b26215831
141 Hensley, C, Joseph, A, . Addressing social determinants of health at a federally qualified health center. Int Public Health J. 9(2): 189–98. 2017. KQ1E4, KQ3E4, KQ4E4, KQ5E4
142 Hensley, CG, Lungelow, L, . A Community Resource Liaison Embedded in Pediatric Primary Care Mitigates Social Risks through Identification and Connection. J Health Care Poor Underserved. 32(4): 2211–2221. 2021. 10.1353/hpu.2021.0193 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a34803070
143 Herrick, AL, Stall, R, . It gets better: resolution of internalized homophobia over time and associations with positive health outcomes among MSM. AIDS Behav. 17(4): 1423–30. 2013. 10.1007/s10461-012-0392-x KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a23283578
144 Hess, Allison, Passaretti, Michelle, . Fresh Food Farmacy. American Journal of Health Promotion. 33(5): 830–832. 2019. KQ4E4, KQ5E431120339
145 Hessler, D, Fisher, L, . The impact of enhancing self-management support for diabetes in Community Health Centers through patient engagement and relationship building: a primary care pragmatic cluster-randomized trial. Transl Behav Med. 12(9): 909–918. 2022. PMID: 36205473. 10.1093/tbm/ibac046 KQ4E2a, KQ5E2a36205473
146 Hewner, Sharon, Casucci, Sabrina, . Integrating Social Determinants of Health into Primary Care Clinical and Informational Workflow during Care Transitions. EGEMS. 5(2): 2. 2017. 10.13063/2327-9214.1282 KQ4E4, KQ5E4
147 Hickey, E, Phan, M, . A Mixed-Methods Evaluation of a Novel Food Pantry in a Pediatric Primary Care Center. Clin Pediatr (Phila). 59(3): 278–284. 2020. 10.1177/0009922819900960 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a31970997
148 Higginbotham, K, Davis Crutcher, T, . Screening for Social Determinants of Health at Well-Child Appointments: A Quality Improvement Project. Nurs Clin North Am. 54(1): 141–148. 2019. 10.1016/j.cnur.2018.10.009 KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a30712540
149 Hill, S, Topel, K, . Engagement in a Social Needs Navigation Program and Healthcare Utilization in Pediatric Primary Care. Acad Pediatr. . 2022. PMID: 35597440. 10.1016/j.acap.2022.05.012 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a35597440
150 Hoisington, AT, Braverman, MT, . Health care providers’ attention to food insecurity in households with children. Prev Med. 55(3): 219–22. 2012. 10.1016/j.ypmed.2012.06.007 KQ2E422710141
151 Holcomb, Jennifer, Oliveira, LuisC, . Predicting health-related social needs in Medicaid and Medicare populations using machine learning. Sci Rep. 12(1): 4554. 2022. 10.1038/s41598-022-08344-4 KQ2E435296719
152 Hopkins, LauraC, Holloman, Christopher, . Caregiver Nutritional Health Outcomes of the Simple Suppers Study: Results from a 10 Week, Two-Group Quasi-Experimental Family Meals Intervention. Nutrients. 14(2): 07. 2022. 10.3390/nu14020250 KQ4E4a, KQ5E4
153 Horning, MelissaL, Hill, Terese, . The East Side Table Make-at-Home Meal-Kit Program is feasible and acceptable: A pilot study. Appetite. 160: 105087. 2021. 10.1016/j.appet.2020.105087 KQ4E1b, KQ5E1b33359465
154 Hsu, Clarissa, Hertel, Erin, . Evaluation of the Learning to Integrate Neighborhoods and Clinical Care Project: Findings from Implementing a New Lay Role into Primary Care Teams to Address Social Determinants of Health. Permanente Journal. 22. 2018. 10.7812/TPP/18-101 KQ4E4a, KQ5E4a
155 Isaacs, Karen. Implementing Social Determinant of Health Screening in a Family Medicine Clinic: A Pilot Study. Am J Med Qual. 37(3): 200–206. 2022. 10.1097/JMQ.0000000000000016 KQ1E4, KQ3E4, KQ4E4, KQ5E434419977
156 Iyer, SN, Dawson, MZ, . Added Value of Early Literacy Screening in Preschool Children. Clin Pediatr (Phila). 56(10): 959–963. 2017. 10.1177/0009922817702937 KQ1E5, KQ3E528420261
157 Izumi, BettyT, Higgins, CesarE, . Feasibility of Using a Community-Supported Agriculture Program to Increase Access to and Intake of Vegetables among Federally Qualified Health Center Patients. J Nutr Educ Behav. 50(3): 289–296.e1. 2018. 10.1016/j.jneb.2017.09.016 KQ4E2a, KQ5E2a29173943
158 Jacobs, EA, Schwei, R, . Evaluation of Peer-to-Peer Support and Health Care Utilization among Community-Dwelling Older Adults. JAMA network open. 2020. PMID: CN-02215141. 10.1001/jamanetworkopen.2020.30090 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a
159 Jaffee, KD, Liu, GC, . Race, urban community stressors, and behavioral and emotional problems of children with special health care needs. Psychiatr Serv. 56(1): 63–9. 2005. 10.1176/appi.ps.56.1.63 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a15637194
160 Janson, IsaacA, Foster, ToddL, . An Outpatient Critical Care Transition Clinic Model Reduces Admissions/Readmissions in Medically Complex Patients. American Journal of Managed Care. 27(9): e301–e307. 2021. 10.37765/ajmc.2021.88742 KQ4E4a, KQ5E4a34533912
161 Jimenez, Elizabeth Yakes, Piltch, Emily, . Development and Pilot Testing of the Prioritizing Food Security Solutions Toolkit. J Acad Nutr Diet. 119(10): 1738–1746. 2019. 10.1016/j.jand.2019.07.023 , KQ4E3, KQ5E331561812
162 Joachim-Celestin, Maud, Rockwood, NicholasJ, . Evaluating the Full Plate Living lifestyle intervention in low-income monolingual Latinas with and without food insecurity. Women’s health. 18: 17455057221091350. 2022. 10.1177/17455057221091350 KQ4E4a, KQ5E4
163 Johnson, CassandraM, Ammerman, AliceS, . The Four Domain Food Insecurity Scale (4D-FIS): development and evaluation of a complementary food insecurity measure. Transl Behav Med. 10(6): 1255–1265. 2020. 10.1093/tbm/ibaa125 KQ2E433421083
164 Joseph, CarlyA, Seguin, MichelleL. “Something Fun to Look Forward to”: Lessons From Implementing the Prescription for Health Farmers’ Market Initiative in Rural Upper Michigan. Health Promot Pract. : 15248399221093966. 2022. 10.1177/15248399221093966 KQ4E4b, KQ5E4b
165 Joshi, K, Smith, S, . Implementing a Produce Prescription Program for Hypertensive Patients in Safety Net Clinics. Health Promot Pract. 20(1): 94–104. 2019. PMID: 29380633. 10.1177/1524839917754090 KQ4E4, KQ5E429380633
166 Kangovi, S, Mitra, N, . Community Health Worker Support for Disadvantaged Patients With Multiple Chronic Diseases: A Randomized Clinical Trial. Am J Public Health. 107(10): 1660–1667. 2017. PMID: 28817334. 10.2105/ajph.2017.303985 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a28817334
167 Kangovi, S, Mitra, N, . Effect of Community Health Worker Support on Clinical Outcomes of Low-Income Patients Across Primary Care Facilities: A Randomized Clinical Trial. JAMA Intern Med. 178(12): 1635–1643. 2018. PMID: 30422224. 10.1001/jamainternmed.2018.4630 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a30422224
168 Kangovi, S, Mitra, N, . Patient-centered community health worker intervention to improve posthospital outcomes: a randomized clinical trial. JAMA Intern Med. 174(4): 535–43. 2014. 10.1001/jamainternmed.2013.14327 KQ1E6, KQ3E6, KQ4E6, KQ5E624515422
169 Kearney, Lauren, Wiener, Renda Soylemez, . A mixed methods study to inform and evaluate a longitudinal nurse practitioner/community health worker intervention to address social determinants of health and chronic obstructive pulmonary disease self-management. BMC Pulm Med. 22(1): 74. 2022. 10.1186/s12890-022-01863-w KQ4E4a, KQ5E435232414
170 Kelley, L, Capp, R, . Patient Navigation to Reduce Emergency Department (ED) Utilization Among Medicaid Insured, Frequent ED Users: A Randomized Controlled Trial. J Emerg Med. 14: 14. 2020. PMID: 32184056. 10.1016/j.jemermed.2019.12.001 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a32184056
171 Kells, S. Introducing screening for family risks in young children in primary care. 2018. KQ1E4, KQ3E4, KQ4E4, KQ5E4
172 Kelly, Cheryl, Maytag, Allison, . Results of an Initiative Supporting Community-Based Organizations and Health Care Clinics to Assist Individuals With Enrolling in SNAP. Journal of Public Health Management and Practice. Publish Ahead of Print. 2020. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a
173 Kenyon, C, Sandel, M, . Revisiting the social history for child health. Pediatrics. 120(3): e734–8. 2007. 10.1542/peds.2006-2495 KQ1E4, KQ3E417766513
174 Kerr, David, Barua, Souptik, . Farming for life: impact of medical prescriptions for fresh vegetables on cardiometabolic health for adults with or at risk of type 2 diabetes in a predominantly Mexican-American population. BMJ Nutrition Prevention & Health. 3(2): 239–246. 2020. 10.1136/bmjnph-2020-000133 KQ4E2a, KQ5E2a
175 Kerver, JeanM, Brophy-Herb, HollyE, . Supporting family meal frequency: Screening Phase results from the Simply Dinner Study. Appetite. 174: 106009. 2022. 10.1016/j.appet.2022.106009 KQ4E4b, KQ5E4b35337884
176 Khidir, Hazar, DeLuca, Michael, . The Health and Social Needs of Patients Discharged From the Emergency Department With Suspected COVID-19. Public Health Rep. 136(3): 309–314. 2021. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a33593138
177 Kim, J, Dubowitz, H, . Comparison of 3 data collection methods for gathering sensitive and less sensitive information. Ambul Pediatr. 8(4): 255–60. 2008. 10.1016/j.ambp.2008.03.033 KQ1E4, KQ3E4, KQ4E4, KQ5E418644548
178 Klein, MD, Alcamo, AM, . Can a video curriculum on the social determinants of health affect residents’ practice and families’ perceptions of care?. Acad Pediatr. 14(2): 159–66. 2014. 10.1016/j.acap.2013.11.002 KQ1E4, KQ3E4, KQ4E4, KQ5E424602579
179 Klein, MD, Beck, AF, . Doctors and lawyers collaborating to HeLP children--outcomes from a successful partnership between professions. J Health Care Poor Underserved. 24(3): 1063–73. 2013. 10.1353/hpu.2013.0147 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a23974381
180 Klein, MD, Kahn, RS, . Training in social determinants of health in primary care: does it change resident behavior?. Acad Pediatr. 11(5): 387–93. 2011. 10.1016/j.acap.2011.04.004 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a21640683
181 Knoblock-Hahn, Amy, Murphy, Anne, . Integrative Nutrition and Health Models Targeting Low-Income Populations: A Pilot Intervention in Three Food Banks. J Acad Nutr Diet. 117(1): 128–131. 2017. 10.1016/j.jand.2016.04.011 KQ4E4, KQ5E427245761
182 Knowles, M, Khan, S, . Successes, Challenges, and Considerations for Integrating Referral into Food Insecurity Screening in Pediatric Settings. J Health Care Poor Underserved. 29(1): 181–191. 2018. 10.1353/hpu.2018.0012 KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a29503293
183 Ko, NY, Battaglia, TA, . Burden of socio-legal concerns among vulnerable patients seeking cancer care services at an urban safety-net hospital: a cross-sectional survey. BMC Health Serv Res. 16: 196. 2016. 10.1186/s12913-016-1443-1 KQ1E4, KQ3E427296566
184 Kulie, Paige, Steinmetz, Erika, . A health-related social needs referral program for Medicaid beneficiaries treated in an emergency department. Am J Emerg Med. 47: 119–124. 2021. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a33799141
185 Kusnoor, SV, Koonce, TY, . Collection of social determinants of health in the community clinic setting: a cross-sectional study. BMC Public Health. 18(1): 550. 2018. 10.1186/s12889-018-5453-2 KQ1E4, KQ3E4, KQ4E4, KQ5E429699539
186 Kw, Linkins, Brya, JJ, . Frequent Users of Health Services Initiative: Final Evaluation Report. 2008. KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a
187 Kwan, BM, Rockwood, A, . Community Health Workers: Addressing Client Objectives Among Frequent Emergency Department Users. Journal of Public Health Management & Practice. 24(2): 146–154. 2018. 10.1097/PHH.0000000000000540 KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a28141671
188 Labrada, Mabel, Mintzer, MichaelJ, . Dramatic Reduction in 30-Day Readmissions Through High-Risk Screening and Two-Phase Interdisciplinary Care. South Med J. 110(12): 757–760. 2017. 10.14423/SMJ.0000000000000745 KQ4E4a, KQ5E4a29197308
189 LaForge, K, Gold, R, . How 6 Organizations Developed Tools and Processes for Social Determinants of Health Screening in Primary Care: An Overview. J Ambul Care Manage. 41(1): 2–14. 2018. 10.1097/JAC.0000000000000221 KQ1E4, KQ3E428990990
190 Lal, Maureen M. Innovative Nurse-Led Initiatives Improve Population Health. J Nurs Adm. 50(2): 59–60. 2020. 10.1097/NNA.0000000000000841 KQ4E4, KQ5E431977941
191 Larimer, ME, Malone, DK, . Health care and public service use and costs before and after provision of housing for chronically homeless persons with severe alcohol problems. Jama. 301(13): 1349–57. 2009. PMID: 19336710. 10.1001/jama.2009.414 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a19336710
192 Lax, Y, Keller, K, . The Use of Telemedicine for Screening and Addressing Social Needs in a Primary Care Pediatric Population in Brooklyn, New York. J Community Health. 05: 05. 2023. PMID: 37405613. 10.1007/s10900-023-01254-0 KQ1E7, KQ3E7, KQ4E5, KQ5E537405613
193 LeBaron, CW, Starnes, D, . The impact of interventions by a community-based organization on inner-city vaccination coverage: Fulton County, Georgia, 1992-1993. Arch Pediatr Adolesc Med. 152(4): 327–32. 1998. PMID: 9559706. 10.1001/archpedi.152.4.327 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a9559706
194 Lee, JY, Shen, S, . Development of Older Adult Food Insecurity Index to Assess Food Insecurity of Older Adults. Journal of Nutrition, Health & Aging. 26(7): 739–746. 2022. 10.1007/s12603-022-1816-6 KQ2E435842765
195 Lee, Keon-Hyung, Davenport, Laura. Can case management interventions reduce the number of emergency department visits by frequent users?. Health Care Manag (Frederick). 25(2): 155–159. 2006. KQ1E4, KQ4E4a, KQ5E416699330
196 Leibel, Sydney, Geng, Bob, . Screening Social Determinants of Health in a Multidisciplinary Severe Asthma Clinical Program. Pediatric Quality & Safety. 5(5): e360. 2020. 10.1097/pq9.0000000000000360 KQ4E4a, KQ5E4a33204931
197 Levine, DM, Kakani, P, . Randomized controlled study using text messages to help connect new medicaid beneficiaries to primary care. Npj digital medicine. 4(1). 2021. PMID: CN-02264884. 10.1038/s41746-021-00389-5 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a
198 Lewis, CaraC, Wellman, Robert, . Comparing the performance of two social risk screening tools in a vulnerable subpopulation. Journal of Family Medicine & Primary Care. 9(9): 5026–5034. 2020. 10.4103/jfmpc.jfmpc_650_20 KQ2E4
199 Liberman, DB, Pham, PK, . Social Emergency Medicine: Capitalizing on the Pediatric Emergency Department Visit to Screen and Connect Patients and Families to Community Resources. Acad Pediatr. 2022. 10.1016/j.acap.2021.12.028 KQ4E4b, KQ5E4b
200 Lin, MP, Blanchfield, BB, . ED-based care coordination reduces costs for frequent ED users. Am J Manag Care. 23(12): 762–766. 2017. PMID: 29261242. KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a29261242
201 Lindau, ST, Makelarski, J, . CommunityRx: A Population Health Improvement Innovation That Connects Clinics To Communities. Health Aff (Millwood). 35(11): 2020–2029. 2016. 10.1377/hlthaff.2016.0694 KQ4E4a, KQ5E4a27834242
202 Lindau, ST, Makelarski, JA, . CommunityRx: A Real-World Controlled Clinical Trial of a Scalable, Low-Intensity Community Resource Referral Intervention. Am J Public Health. 109(4): 600–606. 2019. 10.2105/AJPH.2018.304905 KQ1E4, KQ3E4, KQ4E4a, KQ5E4a30789775
203 Lipton, FR, Nutt, S, . Housing the homeless mentally ill: a longitudinal study of a treatment approach. Hosp Community Psychiatry. 39(1): 40–5. 1988. PMID: 3338726. 10.1176/ps.39.1.40 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a3338726
204 Liss, DT, Ackermann, RT, . Effects of a Transitional Care Practice for a Vulnerable Population: a Pragmatic, Randomized Comparative Effectiveness Trial. J Gen Intern Med. 34:1758–1765. 2019. 10.1007/s11606-019-05078-4 KQ1E4, KQ3E4, KQ4E4a, KQ5E4a31144279
205 Livet, M, Levitt, JM, . The pharmacist as a public health resource: Expanding telepharmacy services to address social determinants of health during the COVID-19 pandemic. Explor Res Clin Soc Pharm. 2: 100032. 2021. PMID: 35481124. 10.1016/j.rcsop.2021.100032 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a35481124
206 Lopez, MA, Yu, X, . Social Needs Screening in Hospitalized Pediatric Patients: A Randomized Controlled Trial. Hospital Pediatrics. 13(2): 95–114. 2023. PMID: 36594231. 10.1542/hpeds.2022-006815 KQ1E4, KQ3E4, KQ4E4, KQ5E436594231
207 Losonczy, LI, Hsieh, D, . The Highland Health Advocates: a preliminary evaluation of a novel programme addressing the social needs of emergency department patients. Emergency Medicine Journal. 34(9): 599–605. 2017. PMID: 28642372. 10.1136/emermed-2015-205662 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a28642372
208 Lumpkin, JohnR, Taylor, LoriH, . Impact of Food Delivery and Health Coaching on Outcomes and Costs of Care: A Payer’s Perspective. NEJM Catalyst Innovations in Care Delivery. 4(4): 1–20. 2023. PMID: 162855510. Language: English. Entry Date: 20230503. Revision Date: 20230503. Publication Type: Article. 10.1056/CAT.22.0351 KQ4E2a, KQ5E2a
209 Lussiez, A, Hallway, A, . Evaluation of an Intervention to Address Smoking and Food Insecurity at Preoperative Surgical Clinic Appointments. JAMA Network Open. 5(10): e2238677. 2022. PMID: 36301545. 10.1001/jamanetworkopen.2022.38677 KQ1E7a, KQ3E7a, KQ4E4b, KQ5E436301545
210 Lyonnais, Mary Jane, Kaur, ArchanaP, . A Mixed-Methods Examination of the Impact of the Partnerships to Improve Community Health Produce Prescription Initiative in Northeastern North Carolina. Journal of Public Health Management & Practice. 28(3): 233–242. 2022. 10.1097/PHH.0000000000001490 KQ4E1b, KQ5E1b35121710
211 Lyonnais, Mary Jane, Rafferty, AnnP, . A Produce Prescription Program in Eastern North Carolina Results in Increased Voucher Redemption Rates and Increased Fruit and Vegetable Intake among Participants. Nutrients. 14(12): 2431–N.PAG. 2022. 10.3390/nu14122431 KQ4E2a, KQ5E2a35745161
212 MacLeod, KaraE, Chapel, JohnM, . The implementation cost of a safety-net hospital program addressing social needs in Atlanta. Health Serv Res. 2021. KQ4E4, KQ5E4
213 Marcinkevage, Jessica, Auvinen, Alyssa, . Washington State’s Fruit and Vegetable Prescription Program: Improving Affordability of Healthy Foods for Low-Income Patients. Prev Chronic Dis. 16: N.PAG-N.PAG. 2019. 10.5888/pcd16.180617 KQ4E4, KQ5E4
214 Mares, AlvinS, Rosenheck, RobertA. A Comparison of Treatment Outcomes Among Chronically Homeless Adults Receiving Comprehensive Housing and Health Care Services Versus Usual Local Care. Administration and Policy in Mental Health AND Mental Health Services Research. 38(6): 459–475. 2011. PMID: 1018347566; 201202650. 10.1007/s10488-011-0333-4 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a21259068
215 Martel, ML, Klein, LR, . Emergency Department Experience with Novel Electronic Medical Record Order for Referral to Food Resources. West J Emerg Med. 19(2): 232–237. 2018. 10.5811/westjem.2017.12.35211 KQ1E7a, KQ3E4, KQ4E4, KQ5E429560048
216 Matiz, Luz Adriana, Leong, Stephen, . Integrating community health workers into a community hearing health collaborative to understand the social determinants of health in children with hearing loss. Disabil Health J. 15(1): 101181. 2022. 10.1016/j.dhjo.2021.101181 KQ4E4a, KQ5E4a34412985
217 Mayer, VL, Deshpande, R, . Feasibility of a subsidized farmshare programin primary care practices. J Gen Intern Med. 35(SUPPL 1): S131–S132. 2020. 10.1007/s11606-020-05890-3 KQ1E11, KQ3E11, KQ4E11, KQ5E11
218 Mayer, VL, Deshpande, R, . Impact of a subsidized farm share program on diet and food security: results of a pilot randomized controlled trial. J Gen Intern Med. 35(SUPPL 1): S158-. 2020. 10.1007/s11606-020-05890-3 KQ1E11, KQ3E11, KQ4E11, KQ5E11
219 McClintock, HF, Bogner, HR. Incorporating Patients’ Social Determinants of Health into Hypertension and Depression Care: A Pilot Randomized Controlled Trial. Community Ment Health J. 53(6): 703–710. 2017. KQ4E4, KQ5E428378301
220 McCurley, JL, Fung, V, . Assessment of the Massachusetts Flexible Services Program to Address Food and Housing Insecurity in a Medicaid Accountable Care Organization. JAMA Health Forum. 4(6): e231191. 2023. PMID: 37266960. 10.1001/jamahealthforum.2023.1191 KQ1E4, KQ3E4, KQ4E4, KQ5E437266960
221 McGuire, J, Bikson, K, . How many social workers are needed in primary care? A patient-based needs assessment example. Health Soc Work. 30(4): 305–13. 2005. 10.1093/hsw/30.4.305 KQ1E4, KQ3E4, KQ4E4, KQ5E416323722
222 Melvin, SandraC, Gipson, June. The Open Arms Healthcare Center’s Integrated HIV Care Services Model. Prev Chronic Dis. 16: E135. 2019. 10.5888/pcd16.180633 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a31580796
223 Menendez, Telma, Barragan, NoelC, . Using Health Navigators to Connect At-Risk Clients to Community Resources. J Public Health Manag Pract. 28(2): E397–E403. 2022. 10.1097/PHH.0000000000001396 KQ1E4, KQ3E4, KQ4E4, KQ5E434225304
224 Metcalfe, Jessica Jarick, McCaffrey, Jennifer, . Community-based nutrition education and hands-on cooking intervention increases farmers’ market use and vegetable servings. Public Health Nutr. 25(9): 2601–2613. 2022. 10.1017/S1368980022000660 KQ4E4b, KQ5E4b35311633
225 Meyer, Dodi, Lerner, Eva, . Universal Screening of Social Determinants of Health at a Large US Academic Medical Center, 2018. Am J Public Health. 110(S2): S219–S221. 2020. 10.2105/AJPH.2020.305747 KQ1E4, KQ3E4, KQ4E4, KQ5E432663083
226 Miller, DK, Lewis, LM, . Controlled trial of a geriatric case-finding and liaison service in an emergency department. J Am Geriatr Soc. 44(5): 513–20. 1996. PMID: 8617898. 10.1111/j.1532-5415.1996.tb01435.x KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a8617898
227 Molitor, Fred, Doerr, Celeste, . P185 - The Discrepancy in Reported Dietary Behaviors and Food Insecurity Between Latina and African American Lower-Income Mothers: Results From a Population-Based Survey. J Nutr Educ Behav. 50: S166–S167. 2018. 10.1016/j.jneb.2018.04.214 KQ4E4, KQ5E4
228 Montez, K, Brown, CL, . Trends in food insecurity rates at an academic primary care clinic: a retrospective cohort study. BMC Pediatr. 21(1): 364. 2021. 10.1186/s12887-021-02829-3 KQ4E3, KQ5E334452604
229 Moreno, G, Mangione, CM, . Connecting Provider to home: A home-based social intervention program for older adults. J Am Geriatr Soc. 69(6): 1627–1637. 2021. PMID: 33710616. 10.1111/jgs.17071 KQ4E4a, KQ5E4a33710616
230 Moreno, Gerardo, Mangione, CarolM, . Connecting Provider to home: A home-based social intervention program for older adults. J Am Geriatr Soc. . 2021. KQ4E4a, KQ5E4a
231 Morse, GA, Calsyn, RJ, . An experimental comparison of three types of case management for homeless mentally ill persons. Psychiatr Serv. 48(4): 497–503. 1997. PMID: 9090733. 10.1176/ps.48.4.497 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a9090733
232 Musicus, AvivaA, Vercammen, KelseyA, . Implementation of a Rooftop Farm Integrated With a Teaching Kitchen and Preventive Food Pantry in a Hospital Setting. Am J Public Health. 109(8): 1119–1121. 2019. 10.2105/AJPH.2019.305116 KQ4E4, KQ5E431219722
233 Myers, Ca, Martin, Ck, . Food Insecurity and Weight Loss in an Underserved Primary Care Population: a Post Hoc Analysis of a Cluster Randomized Trial. Ann Intern Med. 174(7): 1032–1034. 2021. PMID: 33683931. 10.7326/M20-6326 KQ4E6, KQ5E633683931
234 Ng, Tze-Pin, Hai, Shan, . The Elderly Nutritional Index for Geriatric Malnutrition Assessment (ENIGMA): concurrent, construct and predictive validity in an external evaluation cohort of community-dwelling older persons. Br J Nutr. : 1–12. 2021. 10.1017/S0007114521003433 KQ1E1a, KQ2E1a, KQ3E1a, KQ4E1a, KQ5E1a
235 Nguyen, AL, Angulo, M, . A clinic-based pilot intervention to enhance diabetes management for elderly Hispanic patients. J Health Environ Educ. 8: 1–6. 2016. PMID: 27110482. 10.18455/08001 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a27110482
236 Nguyen, KH, Trivedi, AN, . Receipt of Social Needs Assistance and Health Center Patient Experience of Care. Am J Prev Med. 60(3): e139–e147. 2021. 10.1016/j.amepre.2020.08.030 KQ4E4a, KQ5E4a33309453
237 Nikolaus, CassandraJ, Loehmer, Emily, . P36 - Impact of Food Assistance Program Participation on Food Security Patterns: A Longitudinal Study of Women in Illinois. J Nutr Educ Behav. 50: S24–S24. 2018. 10.1016/j.jneb.2018.04.065 KQ4E11, KQ5E11
238 Okin, RL, Boccellari, A, . The effects of clinical case management on hospital service use among ED frequent users. Am J Emerg Med. 18(5): 603–8. 2000. PMID: 10999578. 10.1053/ajem.2000.9292 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a10999578
239 Oldfield, BenjaminJ, Casey, Meghan, . Screening for Social Determinants of Health Among Children: Patients’ Preferences for Receiving Information to Meet Social Needs and a Comparison of Screening Instruments. Popul Health Manag. 24(1): 141–148. 2021. 10.1089/pop.2019.0211 KQ2E7b32096695
240 Olds, Dl. Prenatal and infancy home visiting by nurses: from randomized trials to community replication. Prevention science. 3(3): 153–172. 2002. PMID: 12387552. KQ1E4, KQ3E4, KQ4E4, KQ5E412387552
241 Olsho, Lew, Klerman, Ja, . Financial incentives increase fruit and vegetable intake among Supplemental Nutrition Assistance Program participants: a randomized controlled trial of the USDA Healthy Incentives Pilot. Am J Clin Nutr. 104(2): 423–435. 2016. 10.3945/ajcn.115.129320 KQ4E1b, KQ5E1b27334234
242 Onyekere, C, Ross, S, . Medical Student Volunteerism Addresses Patients’ Social Needs: A Novel Approach to Patient-Centered Care. Ochsner J. 16(1): 45–9. 2016. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a27046404
243 O’Toole, JK, Burkhardt, MC, . Resident confidence addressing social history: is it influenced by availability of social and legal resources?. Clin Pediatr (Phila). 51(7): 625–31. 2012. 10.1177/0009922812438081 KQ2E422399566
244 O’Toole, JK, Solan, LG, . Watch and learn: an innovative video trigger curriculum to increase resident screening for social determinants of health. Clin Pediatr (Phila). 52(4): 344–50. 2013. 10.1177/0009922813475702 KQ2E423393307
245 O’Toole, TP, Johnson, EE, . Tailoring Care to Vulnerable Populations by Incorporating Social Determinants of Health: the Veterans Health Administration’s “Homeless Patient Aligned Care Team” Program. Prev Chronic Dis. 13: E44. 2016. 10.5888/pcd13.150567 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a27032987
246 O’Toole, TP, Roberts, CB, . Screening for Food Insecurity in Six Veterans Administration Clinics for the Homeless, June-December 2015. Prev Chronic Dis. 14: E04. 2017. 10.5888/pcd14.160375 KQ1E4, KQ3E4, KQ4E4, KQ5E428084988
247 Page-Reeves, J, Kaufman, W, . Addressing Social Determinants of Health in a Clinic Setting: The WellRx Pilot in Albuquerque, New Mexico. J Am Board Fam Med. 29(3): 414–8. 2016. 10.3122/jabfm.2016.03.150272 KQ1E4, KQ3E4, KQ4E4, KQ5E427170801
248 Palakshappa, D, Doupnik, S, . Suburban Families’ Experience With Food Insecurity Screening in Primary Care Practices. Pediatrics. 140(1). 2017. 10.1542/peds.2017-0320 KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a
249 Palakshappa, D, Goodpasture, M, . Written Versus Verbal Food Insecurity Screening in One Primary Care Clinic. Acad Pediatr. 20(2): 203–207. 2020. PMID: 31629943. 10.1016/j.acap.2019.10.011 KQ1E4, KQ3E431629943
250 Palakshappa, D, Vasan, A, . Clinicians’ Perceptions of Screening for Food Insecurity in Suburban Pediatric Practice. Pediatrics. 140(1). 2017. 10.1542/peds.2017-0319 KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a
251 Palakshappa, Deepak, Benefield, AndrewJ, . Feasibility of Mobile Technology to Identify and Address Patients’ Unmet Social Needs in a Primary Care Clinic. Popul Health Manag. 24(3): 385–392. 2021. 10.1089/pop.2020.0059 KQ1E4, KQ3E4, KQ4E4, KQ5E432924796
252 Palar, K, Napoles, T, . Comprehensive and Medically Appropriate Food Support Is Associated with Improved HIV and Diabetes Health. J Urban Health. 94(1): 87–99. 2017. PMID: 28097614. 10.1007/s11524-016-0129-7 KQ4E7, KQ5E728097614
253 Pantell, MatthewS, Hessler, Danielle, . Association of 2 Social Needs Interventions With Child Emergency Department Use and Hospitalizations: A Secondary Analysis of a Randomized Clinical Trial. JAMA Pediatr. 176(7): 716–717. 2022. 10.1001/jamapediatrics.2022.0503 KQ4E4a, KQ5E4a35404396
254 Parker, D. Housing as an intervention on hospital use: access among chronically homeless persons with disabilities. J Urban Health. 87(6): 912–9. 2010. PMID: 21125341. 10.1007/s11524-010-9504-y KQ1E2, KQ3E2, KQ4E2, KQ5E221125341
255 Parsons, PL, Slattum, PW, . Evaluation of an interprofessional care coordination model: Benefits to health professions students and the community served. Nurs Outlook. 69(3): 322–332. 2021. PMID: 33220911. 10.1016/j.outlook.2020.09.007 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a33220911
256 Patel, M, Bathory, E, . Resident Documentation of Social Determinants of Health: Effects of a Teaching Tool in the Outpatient Setting. Clin Pediatr (Phila). 57(4): 451–456. 2018. 10.1177/0009922817728697 KQ1E4, KQ3E428877598
257 Patel, MR, Resnicow, K, . Solutions to Address Diabetes-Related Financial Burden and Cost-Related Nonadherence: Results From a Pilot Study. Health Educ Behav. 45(1): 101–111. 2018. PMID: 28443371. 10.1177/1090198117704683 KQ4E4, KQ5E428443371
258 Peahl, AF, Rubin-Miller, L, . Understanding social needs in pregnancy: Prospective validation of a digital short-form screening tool and patient survey. AJOG Global Reports. 3(1): 100158. 2023. PMID: 36922957. 10.1016/j.xagr.2022.100158 KQ2E436922957
259 Peek, ME, Wilkes, AE, . Early lessons from an initiative on Chicago’s South Side to reduce disparities in diabetes care and outcomes. Health Aff (Millwood). 31(1): 177–86. 2012. 10.1377/hlthaff.2011.1058 KQ1E4, KQ3E4, KQ4E4, KQ5E422232108
260 Perrin, EC, Sheldrick, C, . The Survey of Well-being of Young Children (SWYC) user’s manual. . 2018(May 12). 2016. KQ1E4, KQ3E4, KQ4E4, KQ5E4
261 Pettignano, R, Bliss, LR, . Can access to a medical-legal partnership benefit patients with asthma who live in an urban community?. J Health Care Poor Underserved. 24(2): 706–17. 2013. 10.1353/hpu.2013.0055 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a23728038
262 Pettignano, R, Caley, SB, . Medical-legal partnership: impact on patients with sickle cell disease. Pediatrics. 128(6): e1482–8. 2011. 10.1542/peds.2011-0082 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a22084325
263 Phan, TL, Curran, JL, . Disparities in parent confidence managing child weight-related behaviors. Patient Educ Couns. 98(1): 85–9. 2015. 10.1016/j.pec.2014.10.016 KQ1E4, KQ3E425468400
264 Picquart, M, Vautier, V, . The EPICES score: A tool for assessing parental socioeconomic vulnerability of children with type 1 diabetes. Archives de Pediatrie. 27(8): 511–512. 2020. 10.1016/j.arcped.2020.08.002 KQ1E1a, KQ2E1a, KQ3E1a, KQ4E1a, KQ5E1a33011027
265 Plasden, CM. Effects of an education intervention on implementing a social determinants of health screening tool in primary care. 2017. KQ1E4, KQ3E4
266 Poleshuck, E, Wittink, M, . A Comparative Effectiveness Trial of Two Patient-Centered Interventions for Women with Unmet Social Needs: Personalized Support for Progress and Enhanced Screening and Referral. Journal of Women’s Health. 29(2): 242–252. 2020. PMID: 31502906. 10.1089/jwh.2018.7640 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a31502906
267 Polk, Sarah, Leifheit, KathrynM, . Addressing the Social Needs of Spanish- and English-Speaking Families in Pediatric Primary Care. Acad Pediatr. 20(8): 1170–1176. 2020. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a32200111
268 Porter, ChristineM, Wechsler, AlyssaM, . Adult Health Status Among Native American Families Participating in the Growing Resilience Home Garden Study. Prev Chronic Dis. 16: E113. 2019. 10.5888/pcd16.190021 KQ4E1b, KQ5E1b31441769
269 Prather, AA, Gottlieb, LM, . National Academy of Medicine Social and Behavioral Measures: Associations With Self-Reported Health. Am J Prev Med. 53(4): 449–456. 2017. 10.1016/j.amepre.2017.02.010 KQ1E4, KQ3E4, KQ4E4, KQ5E428341220
270 Pruitt, Z, Emechebe, N, . Expenditure Reductions Associated with a Social Service Referral Program. Popul Health Manag. 21(6): 469–476. 2018. 10.1089/pop.2017.0199 KQ4E4a, KQ5E4a29664702
271 Rabaut, LeslieJ. Medically Tailored Meals as a Prescription for Treatment of Food-Insecure Type 2 Diabetics. Journal of Patient-centered Research & Reviews. 6(2): 179–183. 2019. 10.17294/2330-0698.1693 KQ1E4, KQ3E4, KQ4E4, KQ5E431414029
272 Rabovsky, AJ, Rothberg, MB, . Content and Outcomes of Social Work Consultation for Patients with Diabetes in Primary Care. Journal of the American Board of Family Medicine: JABFM. 30(1): 35–43. 2017. KQ1E4, KQ3E4, KQ4E4, KQ5E428062815
273 Radcliff, Elizabeth, Gustafson, Erin, . Uptake of Supplemental Nutrition Assistance Program Benefits by Participants in a Home Visiting Program. Soc Work. 63(3): 244–251. 2018. 10.1093/sw/swy022 KQ4E4, KQ5E429722863
274 Rascon, MayraS, Garcia, MelawhyL, . Comprando Rico y Sano: Increasing Latino Nutrition Knowledge, Healthful Diets, and Food Access Through a National Community-Based Intervention. American Journal of Health Promotion. 36(5): 876–880. 2022. 10.1177/08901171211073956 KQ4E6, KQ5E635081775
275 Raven, MC, Doran, KM, . An intervention to improve care and reduce costs for high-risk patients with frequent hospital admissions: a pilot study. BMC Health Serv Res. 11: 270. 2011. PMID: 21995329. 10.1186/1472-6963-11-270 10.1186/1472-6963-11-270. KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a21995329
276 Real, FJ, Beck, AF, . Impact of a Neighborhood-Based Curriculum on the Helpfulness of Pediatric Residents’ Anticipatory Guidance to Impoverished Families. Matern Child Health J. 20(11): 2261–2267. 2016. KQ1E4, KQ3E4, KQ4E4, KQ5E427480423
277 Reves, SarahR, O’Neal, JonathanP, . A 60-Second Survey to Identify Patients’ Unmet Social Needs. Ann Fam Med. 17(3): 274–274. 2019. 10.1370/afm.2391 KQ1E4, KQ3E4, KQ4E4, KQ5E431085533
278 Rich, AlexanderR, Clark, Colleen. Gender differences in response to homelessness services. Eval Program Plann. 28(1): 69–81. 2005. 10.1016/j.evalprogplan.2004.05.003 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a
279 Ridberg RA, Bell JF, . A pediatric fruit and vegetable prescription program increases food security in low-income households. J Nutr Educ Behav. 51(1): 224–230. 2019. 10.1016/j.jneb.2018.08.003 KQ4E2a, KQ5E2a30224295
280 Ridberg RA, Bell JF, , . Effect of a fruit and vegetable prescription program on children’s fruit and vegetable consumption. Prev Chronic Dis. 16(E73). 2019. KQ4E2a, KQ5E2a
281 Rinehart, Rebecca, Zajac, Lauren, . Integrating a Social Determinants of Health Screener at an Outpatient Pediatric Clinic in East Harlem, New York City. J Health Care Poor Underserved. 32(4): 2267–2277. 2021. 10.1353/hpu.2021.0199 KQ1E4, KQ3E4, KQ4E4, KQ5E434803076
282 Rivera, Rl, Maulding, Mk, . SNAP-Ed (Supplemental Nutrition Assistance Program-Education) Increases Long-Term Food Security among Indiana Households with Children in a Randomized Controlled Study. J Nutr. 146(11): 2375–2382. 2016. PMID: 27683869. 10.3945/jn.116.231373 KQ4E2a, KQ5E2a27683869
283 Rogers, ChristopherK, Parulekar, Manisha, . Local Perspective into Electronic Health Record Design, Integration, and Implementation of Screening and Referral for Social Determinants of Health. Perspectives in Health Information Management. 19(2): 53–71. 2022. KQ1E4, KQ3E4, KQ4E4
284 Rosen Valverde, JenniferN, Backstrand, Jeffrey, . Medical-Legal Partnership Impact on Parents’ Perceived Stress: A Pilot Study. Behav Med. 45(1): 70–77. 2018. KQ1E4, KQ3E4, KQ4E4, KQ5E429944063
285 Rosenblum, A, Nuttbrock, L, . Medical outreach to homeless substance users in New York City: preliminary results. Subst Use Misuse. 37(8–10): 1269–73. 2002. PMID: 12180566. 10.1081/ja-120004184 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a12180566
286 Rotenstein, Lisa, Melia, Caroline, . Development of a Primary Care Transitions Clinic in an Academic Medical Center. J Gen Intern Med. 37(3): 582–589. 2022. 10.1007/s11606-021-07019-6 KQ4E4a, KQ5E4a34327654
287 Roth, SE, Gronowski, B, . Evaluation of an Integrated Intervention to Address Clinical Care and Social Needs Among Patients with Type 2 Diabetes. J Gen Intern Med. 38(Suppl 1): 38–44. 2023. PMID: 36864267. 10.1007/s11606-022-07920-8 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a36864267
288 Rouillard, ChristopherJ, Nasser, MahmoudA, . Evaluation of a Natural Language Processing Approach to Identify Social Determinants of Health in Electronic Health Records in a Diverse Community Cohort. Med Care. 60(3): 248–255. 2022. 10.1097/MLR.0000000000001683 KQ2E434984989
289 Sakr-Ashour, FayrouzA, Wambogo, Edwina, . Social Relationships, Food Security, Protein Intake, and Hospitalization in Homebound Older Adults: A PATH Analysis. J Nutr Gerontol Geriatr. 41(3): 201–216. 2022. 10.1080/21551197.2022.2084203 KQ4E3, KQ5E435703450
290 Sandhu, Sahil, Xu, Jacqueline, . A Community Resource Navigator Model: Utilizing Student Volunteers to Integrate Health and Social Care in a Community Health Center Setting. Int J Integr Care. 21(1). 2021. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a
291 Sassine, AJ, Rabbitt, MP, . Development and Validation of a Physical Food Security Tool for Older Adults. J Nutr. 153(4): 1273–1282. 2023. PMID: 36868513. 10.1016/j.tjnut.2023.02.034 KQ2E436868513
292 Sastre, Lauren, Wynn, Desiree, . Link between redemption of a medical food pantry voucher and reduced hospital readmissions. Preventive Medicine Reports. 23: 101400. 2021. 10.1016/j.pmedr.2021.101400 KQ4E3, KQ5E334136336
293 Sato Imuro, SE, Sabharwal, A, . Temporal changes in bio-behavioral and glycemic outcomes following a produce prescription program among predominantly Hispanic/Latino adults with or at risk of type 2 diabetes. Heliyon. 9(8): e18440. 2023. PMID: 37533982. 10.1016/j.heliyon.2023.e18440 KQ4E2a, KQ5E2a37533982
294 Saxe-Custack, Amy, LaChance, Jenny, . Influence of a Pediatric Fruit and Vegetable Prescription Program on Child Dietary Patterns and Food Security. Nutrients. 13(8): 29. 2021. 10.3390/nu13082619 KQ4E2a, KQ5E2a
295 Schechter, SarahB, Lakhaney, Divya, . Community Health Worker Intervention to Address Social Determinants of Health for Children Hospitalized With Asthma. Hospital Pediatrics. 11(12): 1370–1376. 2021. 10.1542/hpeds.2021-005903 KQ4E4a, KQ5E434849926
296 Schickedanz, A, Sharp, A, . Impact of Social Needs Navigation on Utilization Among High Utilizers in a Large Integrated Health System: a Quasi-experimental Study. J Gen Intern Med. 34(11): 2382–2389. 2019. 10.1007/s11606-019-05123-2 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a31228054
297 Schlosser, AllisonV, Joshi, Kakul, . “The coupons and stuff just made it possible”: economic constraints and patient experiences of a produce prescription program. Transl Behav Med. 9(5): 875–883. 2019. KQ4E4, KQ5E431570919
298 Schoenberg, NE, Ciciurkaite, G, . Community to clinic navigation to improve diabetes outcomes. Preventive medicine reports. 5: 75–81. 2017. KQ4E4a, KQ5E4a27957410
299 Sege, R, Preer, G, . Medical-Legal Strategies to Improve Infant Health Care: A Randomized Trial. Pediatrics. 136(1): 97–106. 2015. 10.1542/peds.2014-2955 KQ1E6, KQ3E6, KQ4E6, KQ5E626034248
300 Seligman, HilaryK, Smith, Morgan, . Comprehensive Diabetes Self-Management Support From Food Banks: A Randomized Controlled Trial. Am J Public Health. 108(9): 1227–1234. 2018. 10.2105/AJPH.2018.304528 KQ4E1b, KQ5E1b30024798
301 Seligman, HK, Levi, R, . Impact of Enhanced Food Pantry Services on Food Security among Adults with Diabetes Using a Crossover Study Design. Curr Dev Nutr. 6(4): nzac021. 2022. 10.1093/cdn/nzac021 KQ1E1b, KQ2E1b, KQ3E1b, KQ4E1b, KQ5E1b35415385
302 Selvaraj, K, Ruiz, MJ, . Screening for Toxic Stress Risk Factors at Well-Child Visits: The Addressing Social Key Questions for Health Study. J Pediatr. 05: 05. 2018. 10.1016/j.jpeds.2018.09.004 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a
303 Serres, SK, Chen, C. Utilizing trauma admissions as an opportunity to identify developmental and behavioral concerns. Am J Surg. 214(4): 661–665. 2017. 10.1016/j.amjsurg.2017.07.001 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a28728674
304 Shaheen, Amy, Squire, Michelle Anderson, . System Approaches to Social Determinants of Health Screening and Intervention. NEJM Catalyst Innovations in Care Delivery. 4(4): 1–20. 2023. 10.1056/CAT.22.0361 KQ1E4, KQ3E4, KQ4E4, KQ5E4
305 Shannon, GR, Wilber, KH, . Reductions in costly healthcare service utilization: findings from the Care Advocate Program. J Am Geriatr Soc. 54(7): 1102–7. 2006. PMID: 16866682. KQ4E4a, KQ5E4a16866682
306 Sharma, SV, McWhorter, JW, . Impact of a Virtual Culinary Medicine Curriculum on Biometric Outcomes, Dietary Habits, and Related Psychosocial Factors among Patients with Diabetes Participating in a Food Prescription Program. Nutrients. 13(12). 2021. 10.3390/nu13124492 KQ1E3, KQ3E3, KQ4E3, KQ5E3
307 Shearer, AJ, Hilmes, CL, . Community Linkage Through Navigation to Reduce Hospital Utilization Among Super Utilizer Patients: A Case Study. Hawaii J Med Public Health. 78(6 Suppl 1): 98–101. 2019. PMID: 31285978. KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a31285978
308 Shern, DL, Tsemberis, S, . Serving street-dwelling individuals with psychiatric disabilities: outcomes of a psychiatric rehabilitation clinical trial. Am J Public Health. 90(12): 1873–8. 2000. PMID: 11111259. 10.2105/ajph.90.12.1873 KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E211111259
309 Shrodes, JenniferC, Williams, Amaris, . Feasibility of Cooking Matters for Diabetes: A 6-week Randomized, Controlled Cooking and Diabetes Self-Management Education Intervention. J Acad Nutr Diet. 06: 06. 2022. 10.1016/j.jand.2022.07.020 KQ4E4a, KQ5E4a
310 Silverman, J, Krieger, J, . The Value of Community Health Workers in Diabetes Management in Low-Income Populations: A Qualitative Study. J Community Health. 43(5): 842–847. 2018. KQ4E4, KQ5E429497934
311 Silverstein, M, Conroy, K, . Screening for social determinants of health in pediatric primary care. Pediatr Ann. 37(11): 740–6. 2008. PMID: 19024841. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E319024841
312 Sjoberg, Heidi, Liu, Wenhui, . Optimizing care coordination to address social determinants of health needs for dual-use veterans. BMC Health Serv Res. 22(1): 59. 2022. 10.1186/s12913-021-07408-x KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a35022053
313 Slagel, Nicholas, Newman, Taylor, . A Pilot Fruit and Vegetable Prescription (FVRx) Program Improves Local Fruit and Vegetable Consumption, Nutrition Knowledge, and Food Purchasing Practices. Health Promot Pract. : 15248399211018169. 2021. 10.1177/15248399211018169 KQ4E5, KQ5E5
314 Smith, AM, Zallman, L, . Implementing an electronic system to screen and actively refer to community based agencies for food insecurity in primary care. Healthc (Amst). 8(1): 100385. 2020. 10.1016/j.hjdsi.2019.100385 KQ1E7a, KQ3E4, KQ4E7a, KQ5E431611165
315 Smith, Amy, Wish, Jack, . Feed to Heal: Leveraging Technology for Food Insecurity Referrals in Health Care. NEJM Catalyst Innovations in Care Delivery. 4(4): CAT. 22.0373. 2023. KQ1E4, KQ3E4, KQ4E4, KQ5E4
316 Smith, S, Malinak, D, . Addressing Food Insecurity in Family Medicine and Medical Education. Fam Med. 49(10): 765–771. 2017. KQ1E4, KQ3E4, KQ4E4, KQ5E429190401
317 Smith, S, Malinak, D, . Implementation of a food insecurity screening and referral program in student-run free clinics in San Diego, California. Preventive Medicine Reports. 5: 134–139. 2017. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a27990340
318 Srebnik, D, Connor, T, . A pilot study of the impact of housing first-supported housing for intensive users of medical hospitalization and sobering services. Am J Public Health. 103(2): 316–21. 2013. 10.2105/AJPH.2012.300867 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a23237150
319 Stanley, MA, Wilson, N, . Calmer Life: A Culturally Tailored Intervention for Anxiety in Underserved Older Adults. American Journal of Geriatric Psychiatry. 24(8): 648–658. 2016. KQ4E4, KQ5E4
320 Steiner, JF, Stenmark, SH, . Food Insecurity in Older Adults in an Integrated Health Care System. J Am Geriatr Soc. 66(5): 1017–1024. 2018. 10.1111/jgs.15285 KQ1E4, KQ3E429492953
321 Stenmark, SH, Steiner, JF, . Lessons Learned from Implementation of the Food Insecurity Screening and Referral Program at Kaiser Permanente Colorado. Perm J. 22: 18–093. 2018. 10.7812/tpp/18-093 KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a
322 Stotz, SarahA, Thompson, Jennifer Jo, . A Supplemental Produce and eLearning Nutrition Education Program for Georgians Who Use Safety-Net Clinics for Their Health Care. J Nutr Educ Behav. 51(9): 1099–1106. 2019. 10.1016/j.jneb.2019.06.018 KQ4E4a, KQ5E4a31345674
323 Swavely, Deborah, Whyte, Veronica, . Complexities of Addressing Food Insecurity in an Urban Population. Popul Health Manag. 22(4): 300–307. 2019. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a30418091
324 Swindle, TarenM, Phelps, Josh, . Identifying a Fine Line between Food Insecurity and Food Acquisition Stress: A Mixed Methods Exploration. J Hunger Environ Nutr. 16(1): 45–63. 2021. 10.1080/19320248.2019.1697407 KQ2E433868533
325 Talavera, GA, Castaneda, SF, . Latinos understanding the need for adherence in diabetes (LUNA-D): a randomized controlled trial of an integrated team-based care intervention among Latinos with diabetes. Transl Behav Med. . 2021. PMID: CN-02285103. 10.1093/tbm/ibab052 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a
326 Taveras, ElsieM, Perkins, MeghanE, . Twelve-Month Outcomes of the First 1000 Days Program on Infant Weight Status. Pediatrics. 148(2). 2021. 10.1542/peds.2020-046706 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a
327 Taylor, DR, Bernstein, BA, . Keeping the Heat on for Children’s Health: A Successful Medical-Legal Partnership Initiative to Prevent Utility Shutoffs in Vulnerable Children. J Health Care Poor Underserved. 26(3): 676–85. 2015. 10.1353/hpu.2015.0074 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a26320904
328 Theilla, Miriam, Singer, Pierre, . Community optimized management for better eating after hospital sTay among geriatric patients of poor socio-economic status - The COMEAT study. Clinical Nutrition. 41(8): 1746–1751. 2022. 10.1016/j.clnu.2022.06.023 KQ4E1a, KQ5E1a35780702
329 Thomas, KS, Akobundu, U, . More Than A Meal? A Randomized Control Trial Comparing the Effects of Home-Delivered Meals Programs on Participants’ Feelings of Loneliness. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 71(6): 1049–1058. 2016. PMID: 26613620. KQ4E2a, KQ5E2a26613620
330 Thomas, KS, Dosa, D. More than a Meal Pilot Research Study: RESULTS FROM A PILOT RANDOMIZED CONTROL TRIAL OF HOME-DELIVERED MEAL PROGRAMS… 2015. KQ1E1b, KQ3E1b, KQ4E1b, KQ5E1b
331 Tong, ST, Liaw, WR, . Clinician Experiences with Screening for Social Needs in Primary Care. J Am Board Fam Med. 31(3): 351–363. 2018. 10.3122/jabfm.2018.03.170419 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a29743219
332 Toro, PA, Passero Rabideau, JM, . Evaluating an intervention for homeless persons: results of a field experiment. J Consult Clin Psychol. 65(3): 476–84. 1997. PMID: 9170771. 10.1037//0022-006x.65.3.476 KQ4E4a, KQ5E4a9170771
333 Trapl ES, Joshi K, Taggart M, Patrick A, . Mixed methods evaluation of a produce prescription program for pregnant women. J Hunger Environ Nutr. 12(4): 529–43. 2017. 10.1080/19320248.2016.1227749 KQ1E4, KQ3E4, KQ4E4, KQ5E4
334 Trapl, ErikaS, Smith, Samantha, . Dietary Impact of Produce Prescriptions for Patients With Hypertension. Prev Chronic Dis. 15: E138. 2018. 10.5888/pcd15.180301 KQ4E4a, KQ5E4a30447106
335 Trinacty, ConnieM, LaWall, Emiline, . Adding Social Determinants in the Electronic Health Record in Clinical Care in Hawai’i: Supporting Community-Clinical Linkages in Patient Care. Hawaii J Med Public Health. 78(6 Suppl 1): 46–51. 2019. , KQ4E4, KQ5E431285969
336 Tsemberis, S, Kent, D, . Housing stability and recovery among chronically homeless persons with co-occuring disorders in Washington, DC. Am J Public Health. 102(1): 13–6. 2012. PMID: 22390393. 10.2105/ajph.2011.300320 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a22390393
337 Turner, WesliH, Kay, Emma Sophia, . Implementation of a Novel Clinic/Community Partnership Addressing Food Insecurity Among Adults With HIV in the Southern United States: A Program Brief. JANAC: Journal of the Association of Nurses in AIDS Care. 34(3): 307–315. 2023. 10.1097/JNC.0000000000000399 KQ4E4, KQ5E4
338 Valluri, Sruthi, Mason, SusanM, . The impact of financial incentives and restrictions on cyclical food expenditures among low-income households receiving nutrition assistance: a randomized controlled trial. International Journal of Behavioral Nutrition & Physical Activity. 18(1): 157. 2021. 10.1186/s12966-021-01223-7 KQ4E1b, KQ5E1b34863192
339 Vaudin, Anna, Simon, JudyR, . Developing the Expanded Food Security Screener and Pilot Testing It for Prioritization of Applicants to the Home-Delivered Meal Program. Top Clin Nutr. 35(1): 19–27. 2020. 10.1097/TIN.0000000000000199 KQ2E7b
340 Velasquez, David, Kondo, Jordan, . Maximizing food security for unauthorized immigrants during COVID-19. Health Affairs Forefront. 2020. KQ4E3, KQ5E3
341 Veldheer, Susan, Scartozzi, Christina, . Impact of a Prescription Produce Program on Diabetes and Cardiovascular Risk Outcomes. J Nutr Educ Behav. 53(12): 1008–1017. 2021. 10.1016/j.jneb.2021.07.005 KQ4E4a, KQ5E4a34426064
342 Vest, JR, Menachemi, N, . Impact of Risk Stratification on Referrals and Uptake of Wraparound Services That Address Social Determinants: A Stepped Wedged Trial. Am J Prev Med. 56(4): e125–e133. 2019. 10.1016/j.amepre.2018.11.009 KQ1E4, KQ3E4, KQ4E4, KQ5E430772150
343 Wagner, Victoria, Sy, Jennifer, . Effectiveness of intensive case management for homeless adolescents: Results of a 3-month follow-up. J Emot Behav Disord. 2(4): 219–227. 1994. 10.1177/106342669400200404 KQ1E4a KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a
344 Waitzkin, H, Getrich, C, . Promotoras as mental health practitioners in primary care: a multi-method study of an intervention to address contextual sources of depression. J Community Health. 36(2): 316–31. 2011. PMID: 20882400. 10.1007/s10900-010-9313-y KQ4E4, KQ5E420882400
345 Walker, DanielM, DePuccio, MatthewJ, . Utilization Patterns of a Food Referral Program: Findings from the Mid-Ohio Farmacy. Journal of the American Board of Family Medicine: JABFM. 34(6): 1174–1182. 2021. 10.3122/jabfm.2021.06.210036 KQ4E4, KQ5E434772772
346 Walker, JenniferJ, Sayama, Mike, . As a Community, We CAN: How Collaboration in East Hawai’i Led to Community-Wide Initiatives Focused on Reducing Avoidable Emergency Department Visits and Inpatient Admissions. Hawaii J Med Public Health. 78(6 Suppl 1): 41–45. 2019. KQ1E4, KQ3E4, KQ4E4, KQ5E431285968
347 Wallace, AndreaS, Luther, Brenda, . Implementing a Social Determinants Screening and Referral Infrastructure During Routine Emergency Department Visits, Utah, 2017-2018. Prev Chronic Dis. 17: E45. 2020. 10.5888/pcd17.190339 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a32553071
348 Wang, Guangyi, Seligman, Hilary, . Impact of fruit and vegetable benefits on pregnancy outcomes among WIC participants: a natural experiment. Transl Behav Med. 08: 08. 2022. 10.1093/tbm/ibac063 KQ4E1b, KQ5E1b
349 Wang, GX, Gauthier, R, . Improving Diabetes Care Through Population Health Innovations and Payments: Lessons from Western Maryland. J Gen Intern Med. 38(Suppl 1): 48–55. 2023. PMID: 36864271. 10.1007/s11606-022-07918-2 KQ1E4, KQ3E4, KQ4E4, KQ5E436864271
350 Watt TT, Appel L, Lopez V, Flores B, . A primary care-based early childhood nutrition intervention: evaluation of a pilot program serving low-income Hispanic women. J Racial Ethn Health Disparities. 2(4): 537–47. 2015. 10.1007/s40615-015-0102-2 KQ4E2a, KQ5E2a26863560
351 Watt, TT, Appel, L, . A Primary Care-Based Early Childhood Nutrition Intervention: Evaluation of a Pilot Program Serving Low-Income Hispanic Women. Journal of Racial & Ethnic Health Disparities. 2(4): 537–47. 2015. PMID: 26863560. 10.1007/s40615-015-0102-2 KQ4E5, KQ5E526863560
352 Weinreb, L, Upshur, CC, . Managing Depression Among Homeless Mothers: Pilot Testing an Adapted Collaborative Care Intervention. Prim Care Companion CNS Disord. 18(2). 2016. PMID: 27486545. 10.4088/PCC.15m01907 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a27486545
353 Weinstein, EM, Galindo, RJ, . Impact of a nutrition educational intervention coupled with improved access to fresh produce on fruit and vegetable purchase and consumption in patients with type 2 diabetes. Diabetes. 62: A190–A191. 2013. KQ4E5, KQ5E5
354 Weinstein, O, Donovan, K, . Nourishing Underserved Populations Despite Scarcer Resources: Adaptations of an Urban Safety Net Hospital During the COVID-19 Pandemic. Am J Public Health. 111(4): 663–666. 2021. 10.2105/AJPH.2020.306132 KQ4E4, KQ5E433600252
355 Weintraub, D, Rodgers, MA, . Pilot study of medical-legal partnership to address social and legal needs of patients. J Health Care Poor Underserved. 21(2 Suppl): 157–68. 2010. 10.1353/hpu.0.0311 KQ1E6, KQ3E6, KQ4E6, KQ5E620453383
356 Wesson, D, Kitzman, H, . Innovative Population Health Model Associated With Reduced Emergency Department Use And Inpatient Hospitalizations. Health Aff (Millwood). 37(4): 543–550. 2018. PMID: 29608367. 10.1377/hlthaff.2017.1099 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a29608367
357 Wilder, V, Gagnon, M, . Community Health Needs Assessment as a Teaching Tool in a Family Medicine Residency. Fam Med. 48(8): 635–7. 2016. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a27655197
358 Wilkin, Margaret, Sun, Betty. Improved Health Outcomes in Low-Resource Diabetes Patients After Participation in a Home-Delivered Healthy Meal Program. J Nutr Educ Behav. 55(7): 37–37. 2023. 10.1016/j.jneb.2023.05.080 KQ4E11, KQ5E11
359 Williams, Amaris, Shrodes, JenniferC, . Outcomes of Cooking Matters for Diabetes: A 6-week Randomized, Controlled Cooking and Diabetes Self-Management Education Intervention. J Acad Nutr Diet. 10: 10. 2022. 10.1016/j.jand.2022.07.021 KQ4E2a, KQ5E2a
360 Witbeck, Gregory, Hornfeld, Susan, . Emergency room outreach to chronically addicted individuals: A pilot study. J Subst Abuse Treat. 19(1): 39–43. 2000. 10.1016/s0740-5472(99)00090-2 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a10867299
361 Woo Baidal, JA, Meyer, D, . Feasibility of Food FARMacia: Mobile Food Pantry to Reduce Household Food Insecurity in Pediatric Primary Care. Nutrients. 14(5). 2022. 10.3390/nu14051059 KQ4E4, KQ5E4
362 Wright, AN, Timmons, JZ, . Pediatrician-Prescribed Grocery Delivery for Families Facing Food Insecurity. J Health Care Poor Underserved. 33(1): 451–456. 2022. 10.1353/hpu.2022.0034 KQ4E4, KQ5E435153233
363 Xu, Stanley, Goodrich, GlennK, . Identifying Relative Changes in Social Risk Factors: An Analytic Approach. Med Care. 59(2): e9–e15. 2021. 10.1097/MLR.0000000000001441 KQ1E6, KQ3E6, KQ4E6, KQ5E633165148
364 Yaggy, SD, Michener, JL, . Just for Us: an academic medical center-community partnership to maintain the health of a frail low-income senior population. Gerontologist. 46(2): 271–6. 2006. KQ1E7a, KQ3E7a, KQ4E7a, KQ5E7a16581892
365 York, Benjamin, Kujan, Mary, . Farming for Life: Pilot assessment of the impact of medical prescriptions for vegetables on health and food security among Latino adults with type 2 diabetes. Nutr Health. 26(1): 9–12. 2020. 10.1177/0260106019898995 KQ4E2a, KQ5E2a31916481
366 Young, Scott M, Clark, Colleen, . Comparing two service delivery models for homeless individuals with complex behavioral health needs: Preliminary data from two SAMHSA treatment for homeless studies. J Dual Diagn. 5(3–4): 287–304. 2009. 10.1080/15504260903359015 KQ1E4a, KQ3E4a, KQ4E4a, KQ5E4a
367 Yun, S, Ehrhardt, E, . Missouri Community, Public Health, and Primary Care Linkage: 2011-2012 Pilot Project Results & Evaluation. Mo Med. 112(4): 323–8. 2015. KQ1E4, KQ3E4, KQ4E4, KQ5E426455066
368 Zielinski, S, Paradis, HA, . The Identification of Psychosocial Risk Factors Associated With Child Neglect Using the WE-CARE Screening Tool in a High-Risk Population. J Pediatr Health Care. 31(4): 470–475. 2017. 10.1016/j.pedhc.2016.12.005 KQ1E4, KQ3E4, KQ4E4, KQ5E428189398