# Appendix B Included Studies List

1. Aiyer JN, Raber M, Bello RS, . A pilot food prescription program promotes produce intake and decreases food insecurity. Translational Behavioral Medicine. 2019;9(5):922–30. PMID: 31570927. 10.1093/tbm/ibz112 31570927
  a. Hassan A, Blood EA, Pikcilingis A, . Youths’ health-related social problems: concerns often overlooked during the medical visit. Journal of Adolescent Health. 2013;53(2):265–71. 10.1016/j.jadohealth.2013.02.024
  b. Wylie SA, Hassan A, Krull EG, . Assessing and referring adolescents’ health-related social problems: qualitative evaluation of a novel web-based approach. J Telemed Telecare. 2012;18(7):392–8. 10.1258/jtt.2012.120214 23045724
2. Baer TE, Scherer EA, Fleegler EW, . Food Insecurity and the Burden of Health-Related Social Problems in an Urban Youth Population. J Adolesc Health. 2015;57(6):601–7. PMID: 26592328. 10.1016/j.jadohealth.2015.08.013 26592328
3. Berkowitz SA, Delahanty LM, Terranova J, . Medically Tailored Meal Delivery for Diabetes Patients with Food Insecurity: a Randomized Cross-over Trial. J Gen Intern Med. 2019;34(3):396–404. PMID: 30421335. 10.1007/s11606-018-4716-z 30421335
4. Berkowitz SA, Hulberg AC, Placzek H, . Mechanisms Associated with Clinical Improvement in Interventions That Address Health-Related Social Needs: A Mixed-Methods Analysis. Popul Health Manag. 2018. PMID: 30562141. 10.1089/pop.2018.0162 30562141
5. Blumberg SJ, Bialostosky K, Hamilton WL, . The effectiveness of a short form of the Household Food Security Scale. Am J Public Health. 1999;89(8):1231–4. PMID: 10432912. 10.2105/ajph.89.8.1231 10432912
6. Byker Shanks C, Vanderwood K, Grocke M, . The UnProcessed Pantry Project (UP3): A Community-Based Intervention Aimed to Reduce Ultra-Processed Food Intake Among Food Pantry Clients. Fam Community Health. 2022;45(1):23–33. PMID: 34783688. 10.1097/FCH.0000000000000310 34783688
7. Cohen AJ, Richardson CR, Heisler M, . Increasing Use of a Healthy Food Incentive: A Waiting Room Intervention Among Low-Income Patients. American journal of preventive medicine. 2017;52(2):154–62. PMID: 28109458. 10.1016/j.amepre.2016.11.008 28109458
8. Cook M, Ward R, Newman T, . Food Security and Clinical Outcomes of the 2017 Georgia Fruit and Vegetable Prescription Program. Journal of Nutrition Education and Behavior. 2021;53(9):770–8. PMID: 34509277. 10.1016/j.jneb.2021.06.010 34509277
9. Fischer L, Bodrick N, Mackey ER, . Feasibility of a Home-Delivery Produce Prescription Program to Address Food Insecurity and Diet Quality in Adults and Children. Nutrients. 2022;14(10):10. PMID: 35631144. 10.3390/nu14102006 35631144
10. Freedman DA, Choi SK, Hurley T, . A farmers’ market at a federally qualified health center improves fruit and vegetable intake among low-income diabetics. Prev Med. 2013;56(5):288–92. PMID: 23384473. 10.1016/j.ypmed.2013.01.018 23384473
11. Gattu RK, Paik G, Wang Y, . The Hunger Vital Sign Identifies Household Food Insecurity among Children in Emergency Departments and Primary Care. Children (Basel). 2019;6(10). PMID: 31581751. 10.3390/children6100107 31581751
12. Gottlieb L, Hessler D, Long D, . Are acute care settings amenable to addressing patient social needs: A sub-group analysis. The American journal of emergency medicine. 2018;36(11):2108–9. PMID: 29576258. 10.1016/j.ajem.2018.03.034 29576258
  a. Gottlieb LM, Hessler D, Long D, . Effects of Social Needs Screening and In-Person Service Navigation on Child Health: A Randomized Clinical Trial. Jama, Pediatr. 2016;170(11):e162521. PMID: 27599265. 10.1001/jamapediatrics.2016.2521 27599265
13. Gottlieb LM, Adler NE, Wing H, . Effects of In-Person Assistance vs Personalized Written Resources About Social Services on Household Social Risks and Child and Caregiver Health. JAMA netw. 2020;3(3):e200701. PMID: 32154888. 10.1001/jamanetworkopen.2020.0701 32154888
14. Gundersen C, Engelhard EE, Crumbaugh AS, . Brief assessment of food insecurity accurately identifies high-risk US adults. Public Health Nutr. 2017;20(8):1367–71. PMID: 28215190. 10.1017/S1368980017000180 28215190
15. Hager ER, Quigg AM, Black MM, . Development and validity of a 2-item screen to identify families at risk for food insecurity. Pediatrics. 2010;126(1):e26–32. PMID: 20595453. 10.1542/peds.2009-3146 20595453
16. Hager K, Du M, Li Z, . Impact of Produce Prescriptions on Diet, Food Security, and Cardiometabolic Health Outcomes: A Multisite Evaluation of 9 Produce Prescription Programs in the United States. Circ Cardiovasc Qual Outcomes. 2023;16(9):e009520. PMID: 37641928. 10.1161/circoutcomes.122.009520 37641928
17. Harle CA, Wu W, Vest JR. Accuracy of Electronic Health Record Food Insecurity, Housing Instability, and Financial Strain Screening in Adult Primary Care. JAMA. 2023;329(5):423–4. PMID: 36749341. 10.1001/jama.2022.23631 36749341
18. Harrison C, Goldstein JN, Gbadebo A, . Validation of a 2-Item Food Insecurity Screen Among Adult General Medicine Outpatients. Population Health Management. 2021;24(4):509–14. PMID: 33021444. 10.1089/pop.2020.0183 33021444
19. Izumi BT, Martin A, Garvin T, . CSA Partnerships for Health: outcome evaluation results from a subsidized community-supported agriculture program to connect safety-net clinic patients with farms to improve dietary behaviors, food security, and overall health. Translational Behavioral Medicine. 2020;10(6):1277–85. PMID: 33421087. 10.1093/tbm/ibaa041 33421087
20. Jones LJ, VanWassenhove-Paetzold J, Thomas K, . Impact of a Fruit and Vegetable Prescription Program on Health Outcomes and Behaviors in Young Navajo Children. Current Developments in Nutrition. 2020;4(8). PMID: 32734135. 10.1093/cdn/nzaa109 32734135
21. Kempainen S, Cutts DB, Robinson-O’Brien R, . A Collaborative Pilot to Support Patients With Diabetes Through Tailored Food Box Home Delivery. Health Promot Pract. 2023:15248399221100792. PMID: 36627767. 10.1177/15248399221100792 36627767
22. Lane WG, Dubowitz H, Feigelman S, . The Effectiveness of Food Insecurity Screening in Pediatric Primary Care. Int J Child Health Nutr. 2014;3(3):130–8. PMID: 28649292. 10.6000/1929-4247.2014.03.03.3 28649292
  a. Dubowitz H, Feigelman S, Lane W, . Pediatric primary care to help prevent child maltreatment: the Safe Environment for Every Kid (SEEK) Model. Pediatrics. 2009;123(3):858–64. PMID: 19255014. 10.1542/peds.2008-1376 19255014
23. Makelarski JA, Abramsohn E, Benjamin JH, . Diagnostic Accuracy of Two Food Insecurity Screeners Recommended for Use in Health Care Settings. Am J Public Health. 2017;107(11):1812–7. PMID: 28933929. 10.2105/ajph.2017.304033 28933929
24. Morales ME, Epstein MH, Marable DE, . Food Insecurity and Cardiovascular Health in Pregnant Women: Results From the Food for Families Program, Chelsea, Massachusetts, 2013-2015. Prev Chronic Dis. 2016;13:E152. PMID: 27809418. 10.5888/pcd13.160212 27809418
25. Orsega-Smith E S N, Cotugna N. Local pediatricians partner with food bank to provide produce prescription program. J Hunger Environ Nutr. 2020;15(3):353–9. 10.1080/19320248.2019.1592051
26. Radandt NE, Corbridge T, Johnson DB, . Validation of a Two-Item Food Security Screening Tool in a Dental Setting. J Dent Child30869587 (Chic). 2018;85(3):114–9. PMID: 30869587.30869587
27. Ranjit N, Aiyer JN, Toups JD, . Clinical outcomes of a large-scale, partnership-based regional food prescription program: results of a quasi-experimental study. BMC Res Notes. 2023;16(1):13. PMID: 36765390. 10.1186/s13104-023-06280-8 36765390
28. Renaud J, McClellan SR, DePriest K, . Addressing Health-Related Social Needs Via Community Resources: Lessons From Accountable Health Communities. Health Aff (Millwood). 2023 05 17 ed2023. p. 832–40. PMID. 10.1377/hlthaff.2022.01507 37196207
29. Rivera RL, Adams M, Dawkins E, . Delivering Food Resources and Kitchen Skills (FoRKS) to Adults with Food Insecurity and Hypertension: A Pilot Study. Nutrients. 2023;15(6):17. PMID: 36986184. 10.3390/nu15061452 36986184
30. Saxe-Custack A, LaChance J, Hanna-Attisha M. Child Consumption of Whole Fruit and Fruit Juice Following Six Months of Exposure to a Pediatric Fruit and Vegetable Prescription Program. Nutrients. 2019;12(1):20. PMID: 31877635. 10.3390/nu12010025 31861789
31. Scher K, Sohaki A, Tang A, . A community partnership to evaluate the feasibility of addressing food insecurity among adult patients in an urban healthcare system. Pilot Feasibility Stud. 2022;8(1):59. PMID: 35264239. 10.1186/s40814-022-01013-3 35264239
32. Seligman HK, Lyles C, Marshall MB, . A pilot food bank intervention featuring diabetes-appropriate food improved glycemic control among clients in three states. Health affairs (Project Hope). 2015;34(11):1956–63. PMID: 26526255. 10.1377/hlthaff.2015.0641 26526255
33. Shankar KN, Dugas JN, Flacks J, . High touch, high trust: Using community health advocates and lawyers to address ED high utilizers. American Journal of Emergency Medicine. 2022;60:171–6. PMID: 36037733. 10.1016/j.ajem.2022.07.049 36037733
34. Singer C, Porta C. Improving patient well-being in the United States through care coordination interventions informed by social determinants of health. Health Soc Care Community. 2022;17:17. PMID: 35301764. 10.1111/hsc.13776 35301764
35. Slagel N, Newman T, Sanville L, . Effects of a Fruit and Vegetable Prescription Program With Expanded Education for Low-Income Adults. Health Education & Behavior 2022. p. 849–60. PMID: 35535592. 10.1177/10901981221091926 35535592
36. Wetherill MS, Chancellor McIntosh H, Beachy C, . Design and Implementation of a Clinic-Based Food Pharmacy for Food Insecure, Uninsured Patients to Support Chronic Disease Self-Management. J Nutr Educ Behav. 2018;50(9):947–9. PMID: 30064811. 10.1016/j.jneb.2018.05.014 30064811
37. Woo Baidal JA, Duong N, Goldsmith J, . Association of a primary care-based mobile food pantry with child body mass index: A propensity score matched cohort study. Pediatric Obesity. 2023;18(6):e13023. PMID: 36939408. 10.1111/ijpo.13023 36939408
38. Wu AW, Weston CM, Ibe CA, . The Baltimore Community-Based Organizations Neighborhood Network: Enhancing Capacity Together (CONNECT) Cluster RCT. American journal of preventive medicine. 2019;57(2):e31–e41. PMID: 31248746. 10.1016/j.amepre.2019.03.013 31248746
39. Xie J, Price A, Curran N, . The impact of a produce prescription programme on healthy food purchasing and diabetes-related health outcomes. Public Health Nutr. 2021/04/28 ed2021. p. 3945–55. PMID: 33902771. 10.1017/s1368980021001828 33902771