# Appendix A Detailed Methods

## Literature Search Strategies

Original search – Date delivered 8/21/23

Sources Searched: database and platform | Number of items 2017/2018 -present
MEDLINE via Ovid | 4173
CINAHL via Ebsco | 3318
Cochrane Central Register of Controlled Clinical Trials via Wiley | 1279

Search filters used:

- Ayiku L, Levay P, Hudson T. The NICE OECD countries’ geographic search filters: Part 1-methodology for developing the draft MEDLINE and Embase (Ovid) filters. J Med Libr Assoc. 2021 Apr 1;109(2):258–266. 10.5195/jmla.2021.978. PMID: 34285668; PMCID: PMC8270368.34285668
- Chris Cooper, Jo Varley-Campbell and Patrice Carter, Established search filters may miss studies when identifying randomized controlled trials. Journal of Clinical Epidemiology J Clin Epidemiol. 2019 Aug;112:12–19. 10.1016/j.jclinepi.2019.04.002. PMID: 30986533.30986533

Study design filters:

- Glanville JM, Lefebvre C, Miles JN, Camosso-Stefinovic J. How to identify randomized controlled trials in MEDLINE: ten years on. Journal of the Medical Library Association 2006; 94: 130–136. https://www.ncbi.nlm.nih.gov/pmc/articles/PMC1435857/. PMCID: PMC1435857, PMID: 1663670416636704
- Box 3.d Cochrane Highly Sensitive Search Strategy for identifying randomized trials in MEDLINE: sensitivity- and precision-maximizing version (2008 revision); Ovid format from: Lefebvre C, Glanville J, Briscoe S, Littlewood A, Marshall C, Metzendorf M-I, Noel-Storr A, Rader T, Shokraneh F, Thomas J, Wieland LS. Chapter 4: Searching for and selecting studies. In: Higgins JPT, Thomas J, Chandler J, Cumpston M, Li T, Page MJ, Welch VA (editors). Cochrane Handbook for Systematic Reviews of Interventions version 6.2 (updated February 2021). Cochrane, 2021. Available from www.training.cochrane.org/handbook
- Tudor Car L, Li L, Smith H, Atun R. Cochrane review: Search strategies to identify observational studies in MEDLINE and EMBASE. J Evid Based Med. 2019;12(3):225–226. 10.1111/jebm.12358 31441237

## Literature Search for Primary Literature

### MEDLINE via Ovid

Ovid MEDLINE(R) ALL <1946 to August 21, 2023>

ID | Search | Hits
1 | Food insecurity/ | 1107
2 | Hunger/ or Food deserts/ or Food Supply/ or Food security/ | 20812
3 | ((food or nutrition$ or malnutrition$ or hunger$) adj2 (insecur$ or unstable or stable or stabilit$ or instabilit$ or uncertain$ or vulnerab$ or hardship$ or insufficien$ or stress$ or access or (secur$ not (global or production or environment$ or parasite$ or microb$ or bacteria$ or climate)))).ti,ab,kf. | 20461
4 | (food desert$ or food availability).ti,ab,kf. | 4851
5 | Food Assistance/ or Access to Healthy Foods/ | 1703
6 | (food adj (aid or aide or assist$ or bag$ or bank$ or box$ or pantr$ or shelf or shelves or benefit$ or donation or donated)).ti,ab,kf. | 1766
7 | food.ti,ab,kf. and “Health Services Needs and Demand”/ | 510
8 | (((food or nutrition$ or malnutrition$ or hunger$) adj (risk or risks)) and (geriatric or elderly or pediatric or paediatric or children)).ti,ab,kf. | 1696
9 | limit 8 to (“in data review” or in process or publisher or “pubmed not medline”) | 213
10 | or/1-7,9 | 41963
11 | mass screening/ or (screen$ or detect$ or identif$).ti,kf. | 1058121
12 | Needs Assessment/ or (need$ adj1 assess$).ti,ab,kf. | 39440
13 | (instrument$ or tool$ or measur$ or assessment or survey or score or checklist or question$).ti. | 1084961
14 | or/11-13 | 2123741
15 | 10 and 14 | 2911
16 | (screen$ and ((food or nutrition$ or malnutrition$ or hunger$) adj2 (insecur$ or unstable or stable or stabilit$ or instabilit$ or uncertain$ or vulnerab$ or hardship$ or insufficien$ or stress$ or access or (secur$ not (global or production or environment$ or parasite$ or microb$ or bacteria$ or climate))))).ti,ab,kf. | 1022
17 | (hunger vital sign or hunger screen).ti,ab,kf. | 28
18 | (Household Food Security or adult Food Security or cps Food Security).ti,ab,kf. | 947
19 | (Household Food Insecurity Access Scale or HFIAS).ti,ab,kf. | 196
20 | USDA food security.ti,ab,kf. | 29
21 | Geriatric Malnutrition Assessment.ti,ab,kf. | 4
22 | (“Risk of Impaired Nutritional Status and Growth” or STRONGkids).ti,ab,kf. | 67
23 | or/16-22 | 2154
24 | 15 or 23 | 4626
25 | (clinical trial or adaptive clinical trial or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or randomized controlled trial or equivalence trial or pragmatic clinical trial or Meta-Analysis).pt. | 1095328
26 | clinical trials as topic/ or adaptive clinical trials as topic/ or clinical trials, phase iii as topic/ or clinical trials, phase iv as topic/ or controlled clinical trials as topic/ or non-randomized controlled trials as topic/ or randomized controlled trials as topic/ or equivalence trials as topic/ or intention to treat analysis/ or pragmatic clinical trials as topic/ or meta-analysis as topic/ | 384182
27 | control groups/ or double-blind method/ or single-blind method/ or random allocation/ or placebos/ | 323375
28 | (random$ or placebo or phase iii or phase 3).ti,ab. | 1468330
29 | (RCT or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$).ti,ab. | 429787
30 | ((control$ or clinical) adj3 (study or studies or trial$ or group$)).ti,ab. | 1779891
31 | (Nonrandom$ or non random$ or non-random$ or quasi-random$ or quasirandom$).ti,ab. | 51166
32 | ((open label or open-label) adj5 (study or studies or trial$)).ti,ab. | 42341
33 | ((equivalence or superiority or non-inferiority or noninferiority) adj3 (study or studies or trial$)).ti,ab. | 10538
34 | (pragmatic study or pragmatic studies).ti,ab. | 539
35 | ((pragmatic or practical) adj3 trial$).ti,ab. | 5327
36 | ((quasiexperimental or quasi-experimental) adj3 (study or studies or trial$)).ti,ab. | 10959
37 | (metaanaly$ or meta analy$).ti,ab. | 247908
38 | cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/ or case-control studies/ | 2646629
39 | longitudinal.ti,ab. | 302501
40 | (follow up or followup).ti,ab. | 1159606
41 | (prospective$ or retrospective$).ti,ab. | 1699294
42 | (comparison group$ or (matched adj2 compar$)).ti,ab. | 33500
43 | observational.ti,ab. | 240901
44 | population$.ti,ab. | 2035744
45 | Registries/ | 106041
46 | (registr$ or register$).ti,ab. | 509851
47 | cohort.ti,ab. | 718291
48 | (pool$ or logistic regression or pre-post or “pre and post$” or matching or sub-group analys$ or “we observed”).ti,ab. | 1068328
49 | or/25-48 | 8359962
50 | (201806* or 201807* or 201808* or 201809* or 201810* or 201811* or 201812* or 2019* or 2020* or 2021* or 2022*).dt,da,ez. | 7052516
51 | 24 and 49 and 50 [food insecurity screening] | 1401
52 | “Sensitivity and Specificity”/ | 366216
53 | “Predictive Value of Tests”/ | 221536
54 | ROC Curve/ | 69654
55 | Receiver operat$.ti,ab. | 115984
56 | ROC curve$.ti,ab. | 49449
57 | sensitivit$.ti,ab. | 950799
58 | specificit$.ti,ab. | 557873
59 | predictive value.ti,ab. | 108973
60 | accuracy.ti,ab. | 506434
61 | False Negative Reactions/ | 18295
62 | False Positive Reactions/ | 28578
63 | Diagnostic Errors/ | 39472
64 | “Reproducibility of Results”/ | 450748
65 | Reference Values/ | 163592
66 | Reference Standards/ | 45484
67 | Observer Variation/ | 44762
68 | Psychometrics/ | 86111
69 | Psychometric$.ti,ab. | 56745
70 | false positive$.ti,ab. | 66059
71 | false negative$.ti,ab. | 37324
72 | miss rate$.ti,ab. | 630
73 | error rate$.ti,ab. | 17085
74 | evaluation study/ | 261730
75 | or/52-74 | 2786421
76 | (2017* or 2018* or 2019* or 2020* or 2021* or 2022*).dt,da,ez. | 8789453
77 | 24 and 75 and 76 [food insecurity screen accuracy] | 288
78 | (exp *Fruit/ or *Vegetables/ or Food/ or Cooking/ or exp Meals/) and (Prescriptions/ or (prevention or address$ or prescription$ or prescribe$ or provision or provisions assistance).ti,kf.) | 1090
79 | ((food adj1 medicine) or (food adj1 (aid or aide or assist$ or bag$ or bank$ or box$ or pantr$ or shelf or shelves or benefit$ or donation or donated))).ti,ab,kf. | 2634
80 | ((food or fruit or vegetable or meals or foods or fruits or vegetables or meals) adj4 (prevention or address$ or prescription$ or prescribe$ or provision or provisions assistance or afford$)).ti,ab,kf. | 6669
81 | ((Diet$ or nutrition$) adj (outcome$ or counsel$)).ti,ab,kf. | 5864
82 | supermarkets/ or (food store or food stores or grocery store or grocery stores or (meal deliver$ adj program$) or medically tailored or untailored food).ti,ab,kf. | 2674
83 | (EBT or WIC or “ Women, Infants, and Children” or “ Women, Infants, Children” or SNAP or food stamp$).ti,ab,kf. | 16096
84 | Patient Education as Topic/ or “Referral and Consultation”/ or Patient Navigation/ or Health Promotion/ or (referral$ or mitigat$ or communityrx or (community adj2 information)).ti,ab,kf. | 475825
85 | or/78-84 | 507173
86 | 10 and 85 | 6774
87 | (5 or 6 or 7) and (1 or 2 or 3 or 4 or 8) | 1665
88 | 86 or 87 | 7034
89 | 49 and 50 and 88 [food insecurity interventions] | 1832
90 | “Social Determinants of Health”/ | 5839
91 | *Social Conditions/ | 4036
92 | *Poverty/ or *poverty areas/ | 20624
93 | Socioeconomic Factors/ and Food/ | 670
94 | *Employment/ | 26818
95 | *Unemployment/ | 3837
96 | ((social$ or socio$) adj1 (environment$ or determin$) adj5 (screen$ or detect$ or identif$ or question$ or intervention$ or refer$ or assessment or services)).ti,ab,kf. | 2012
97 | ((((determinant$ or determinate$) adj2 health) or ((social$ or socio$) adj1 (condition$ or factor$ or gradient$ or need$ or require$ or equit$ or inequit$ or disparit$ or equal$ or inequal$ or hardship$ or depriv$ or challeng$ or difficult$ or barrier$ or vulnerab$ or disadvantag$ or risk$ or status$ or circumstance$ or position$ or class$)) or ((economic$ or income$ or financ$) adj2 (achieve$ or status or attain$ or equit$ or inequit$ or disparit$ or equal$ or inequalit$ or level$ or background$ or opportunit$ or disadvantage$ or advantage$ or marginal$ or disenfranchis$ or vulnerab$ or strain$ or strugg$ or stable or unstable or stabilit$ or instabilit$ or difficult$ or problem$ or (low not (countries or country or lmic)))) or unemployment or unemployed or underemploy$ or (occupation$ adj2 (status or level or class)) or jobless$ or workless$ or (employment adj2 (status or securit$ or insecurit$ or marginal$ or precarious$ or terminat$))) adj5 (screen$ or detect$ or identif$ or question$ or intervention$ or refer$ or assessment or services)).ti,kf. | 2067
98 | or/90-95 | 60514
99 | 10 or 14 or 85 | 2610519
100 | 98 and 99 | 8573
101 | 49 and 50 and (96 or 97 or 100) [targeted social needs screening] | 2462
102 | 51 or 77 or 89 or 101 | 5157
103 | limit 102 to english language | 5088
104 | 103 not ((exp animal/ or nonhuman/) not exp human/) | 5023
105 | afghanistan/ or africa/ or africa, northern/ or africa, central/ or africa, eastern/ or “africa south of the sahara”/ or africa, southern/ or africa, western/ or albania/ or algeria/ or andorra/ or angola/ or “antigua and barbuda”/ or argentina/ or armenia/ or azerbaijan/ or bahamas/ or bahrain/ or bangladesh/ or barbados/ or belize/ or benin/ or bhutan/ or bolivia/ or borneo/ or “bosnia and herzegovina”/ or botswana/ or brazil/ or brunei/ or bulgaria/ or burkina faso/ or burundi/ or cabo verde/ or cambodia/ or cameroon/ or central african republic/ or chad/ or exp china/ or comoros/ or congo/ or cote d’ivoire/ or croatia/ or cuba/ or “democratic republic of the congo”/ or cyprus/ or djibouti/ or dominica/ or dominican republic/ or ecuador/ or egypt/ or el salvador/ or equatorial guinea/ or eritrea/ or eswatini/ or ethiopia/ or fiji/ or gabon/ or gambia/ or “georgia (republic)”/ or ghana/ or grenada/ or guatemala/ or guinea/ or guinea-bissau/ or guyana/ or haiti/ or honduras/ or independent state of samoa/ or exp india/ or indian ocean islands/ or indochina/ or indonesia/ or iran/ or iraq/ or jamaica/ or jordan/ or kazakhstan/ or kenya/ or kosovo/ or kuwait/ or kyrgyzstan/ or laos/ or lebanon/ or liechtenstein/ or lesotho/ or liberia/ or libya/ or madagascar/ or malaysia/ or malawi/ or mali/ or malta/ or mauritania/ or mauritius/ or mekong valley/ or melanesia/ or micronesia/ or monaco/ or mongolia/ or montenegro/ or morocco/ or mozambique/ or myanmar/ or namibia/ or nepal/ or nicaragua/ or niger/ or nigeria/ or oman/ or pakistan/ or palau/ or exp panama/ or papua new guinea/ or paraguay/ or peru/ or philippines/ or qatar/ or “republic of belarus”/ or “republic of north macedonia”/ or romania/ or exp russia/ or rwanda/ or “saint kitts and nevis”/ or saint lucia/ or “saint vincent and the grenadines”/ or “sao tome and principe”/ or saudi arabia/ or serbia/ or sierra leone/ or senegal/ or seychelles/ or singapore/ or somalia/ or south africa/ or south sudan/ or sri lanka/ or sudan/ or suriname/ or syria/ or taiwan/ or tajikistan/ or tanzania/ or thailand/ or timor-leste/ or togo/ or tonga/ or “trinidad and tobago”/ or tunisia/ or turkmenistan/ or uganda/ or ukraine/ or united arab emirates/ or uruguay/ or uzbekistan/ or vanuatu/ or venezuela/ or vietnam/ or west indies/ or yemen/ or zambia/ or zimbabwe/ | 1249029
106 | “Organisation for Economic Co-Operation and Development”/ | 479
107 | australasia/ or exp australia/ or austria/ or baltic states/ or belgium/ or exp canada/ or chile/ or colombia/ or costa rica/ or czech republic/ or exp denmark/ or estonia/ or europe/ or finland/ or exp france/ or exp germany/ or greece/ or hungary/ or iceland/ or ireland/ or israel/ or exp italy/ or exp japan/ or korea/ or latvia/ or lithuania/ or luxembourg/ or mexico/ or netherlands/ or new zealand/ or north america/ or exp norway/ or poland/ or portugal/ or exp “republic of korea”/ or “scandinavian and nordic countries”/ or slovakia/ or slovenia/ or spain/ or sweden/ or switzerland/ or turkey/ or exp united kingdom/ or exp united states/ | 3441235
108 | European Union/ | 17388
109 | Developed Countries/ | 21229
110 | or/106-109 | 3456831
111 | 105 not 110 | 1160791
112 | 104 not 111 | 4194
113 | remove duplicates from 112 | 4173

### Cochrane Central Register of Controlled Clinical Trials via Wiley

Date Run: 8/21/2317:43:43

ID | Search | Hits
#1 | ((food or nutrition* or malnutrition* or hunger*) NEAR/2 (insecur* or unstable or stable or stabilit* or instabilit* or uncertain* or vulnerab* or hardship* or insufficien* or stress* or access or (secur* not (global or production or environment* or parasite* or microb* or bacteria* or climate)))):ti,ab,kw | 2211
#2 | (“food desert*” or “food availability”):ti,ab,kw | 122
#3 | (food NEAR (aid or aide or assist* or bag* or bank* or box* or pantr* or shelf or shelves or benefit* or donation or donated)):ti,ab,kw | 746
#4 | (((food or nutrition* or malnutrition*) NEAR (risk or risks)) and (geriatric or elderly or pediatric or paediatric or children)):ti,ab,kw | 946
#5 | #1 OR #2 OR #3 OR #4 with Cochrane Library publication date from Jan 2017 to present, in Trials | 2657
#6 | (screen* or detect* or identif*):ti,kw | 37638
#7 | (need* NEAR/1 assess*):ti,ab,kw | 1309
#8 | (instrument* or tool* or measur* or assessment or survey or score or checklist or question*):ti | 51935
#9 | (screen* and ((food or nutrition* or malnutrition* or hunger*) NEAR/2 (insecur* or unstable or stable or stabilit* or instabilit* or uncertain* or vulnerab* or hardship* or insufficien* or stress* or access or (secur* NOT (global or production or environment* or parasite* or microb* or bacteria* or climate))))):ti,ab,kw | 201
#10 | (“hunger vital sign” or “hunger screen”):ti,ab,kw | 3
#11 | (“Household Food Security” or “adult Food Security” or “cps Food Security”):ti,ab,kw | 107
#12 | (“Household Food Insecurity Access Scale” or HFIAS):ti,ab,kw | 25
#13 | “USDA food security”:ti,ab,kw | 8
#14 | Geriatric Malnutrition Assessment:ti,ab,kw | 185
#15 | (“Risk of Impaired Nutritional Status and Growth” or STRONGkids):ti,ab,kw | 8
#16 | ((food NEAR/1 medicine) or (food NEAR/1 (aid or aide or assist* or bag* or bank* or box* or pantr* or shelf or shelves or benefit* or donation or donated))):ti,ab,kw | 391
#17 | ((food or fruit or vegetable or meals or foods or fruits or vegetables or meals) NEAR/4 (prevention or address* or prescription* or prescribe* or provision or provisions assistance or afford*)):ti,ab,kw | 1131
#18 | ((Diet* or nutrition*) NEAR (outcome* or counsel*)):ti,ab,kw | 12892
#19 | ((meal deliver* NEAR program*) or medically tailored or untailored food or “food store” or “food stores” or “grocery store” or “grocery store”):ti,ab,kw | 417
#20 | (EBT or WIC or “ Women, Infants, and Children” or “ Women, Infants, Children” or SNAP or food stamp*):ti,ab,kw | 1104
#21 | (referral* or mitigat* or communityrx or (community NEAR/2 information)):ti,ab,kw | 21977
#22 | {OR #6-#21} | 122323
#23 | #5 AND #22 | 1192
#24 | (((social* or socio*) NEAR/1 (environment* or determin*))):ti,ab,kw | 2298
#25 | ((((determinant* or determinate*) NEAR/2 health) or ((social* or socio*) NEAR/1 (condition* or factor* or gradient* or need* or require* or equit* or inequit* or disparit* or equal* or inequal* or hardship* or depriv* or challeng* or difficult* or barrier* or vulnerab* or disadvantag* or risk* or status* or circumstance* or position* or class*)) or ((economic* or income* or financ*) NEAR/2 (achieve* or status or attain* or equit* or inequit* or disparit* or equal* or inequalit* or level* or background* or opportunit* or disadvantage* or advantage* or marginal* or disenfranchis* or vulnerab* or strain* or strugg* or stable or unstable or stabilit* or instabilit* or difficult* or problem* or (low not (countries or country or lmic)))) or unemployment or unemployed or underemploy* or (occupation* NEAR/2 (status or level or class)) or jobless* or workless* or (employment NEAR/2 (status or securit* or insecurit* or marginal* or precarious* or terminat*)))):ti,kw | 11419
#26 | #24 OR #25 with Cochrane Library publication date from Jan 2017 to present | 7331
#27 | #23 AND #26 | 146
#28 | #5 OR #27 | 2657
#29 | #28 NOT (clinicaltrials or trialsearch):so | 1647
#30 | #29 NOT conference:pt | 1279

### CINAHL via Ebsco

ID | Search | Limits | Hits
S1 | (MH “Food Security+”) OR (MM “Hunger”) OR (MM “Food Deserts”) OR (MM “Food Supply”) OR (MH “Food Assistance”) | Expanders - Apply equivalent subjects | 9,133
S2 | TI ( ((food OR nutrition* OR malnutrition* OR hunger) N2 (insecur* OR unstable OR stable OR stabilit* OR instabilit* OR uncertain* OR vulnerab* OR hardship* OR insufficien* OR stress* OR access OR (secur* not (global OR production OR environment* OR parasite* OR microb* OR bacteria* OR climate)))) ) OR AB ( ((food OR nutrition* OR malnutrition* OR hunger) N2 (insecur* OR unstable OR stable OR stabilit* OR instabilit* OR uncertain* OR vulnerab* OR hardship* OR insufficien* OR stress* OR access OR (secur* not (global OR production OR environment* OR parasite* OR microb* OR bacteria* OR climate)))) ) | Expanders - Apply equivalent subjects | 9,104
S3 | TI “food desert*” OR TI “food availability” OR AB “food desert*” OR AB “food availability” | Expanders - Apply equivalent subjects | 874
S4 | TI ( (food N1 (aid OR aide OR assist* OR bag* OR bank* OR box* OR pantr* OR shelf OR shelves OR benefit* OR stamp* OR donation OR donated)) ) OR AB ( (food N1 (aid OR aide OR assist* OR bag* OR bank* OR box* OR pantr* OR shelf OR shelves OR benefit* OR stamp* OR donation OR donated)) ) | Expanders - Apply equivalent subjects | 1,732
S5 | TI ( (((food OR nutrition* OR malnutrition* OR hunger) N1 (risk OR risks)) and (geriatric OR elderly OR pediatric OR paediatric OR children)) ) OR AB ( (((food OR nutrition* OR malnutrition*) N1 (risk OR risks)) and (geriatric OR elderly OR pediatric OR paediatric OR children)) ) | Expanders - Apply equivalent subjects | 1,579
S6 | (TI food OR AB food) AND (MH “Health Services Needs and Demand+”) | Expanders - Apply equivalent subjects | 312
S7 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 | Expanders - Apply equivalent subjects | 17,218
S8 | (MH “Health Screening”) OR TI ( screen* OR detect* OR identif* ) | Expanders - Apply equivalent subjects | 196,442
S9 | (MH “Needs Assessment”) OR TI need* N1 assess* OR AB need* N1 assess* | Expanders - Apply equivalent subjects | 32,845
S10 | TI (instrument* OR tool* OR measur* OR assessment OR survey OR score OR checklist OR question*) | Expanders - Apply equivalent subjects | 392,505
S11 | S8 OR S9 OR S10 | Expanders - Apply equivalent subjects | 596,417
S12 | S7 AND S11 | Expanders - Apply equivalent subjects | 1,899
S13 | TI ( (screen* AND ((food OR nutrition* OR malnutrition* OR hunger) N2 (insecur* OR unstable OR stable OR stabilit* OR instabilit* OR uncertain* OR vulnerab* OR hardship* OR insufficien* OR stress* OR access OR (secur* NOT (global OR production OR environment* OR parasite* OR microb* OR bacteria* OR climate))))) ) OR AB ( (screen* AND ((food OR nutrition* OR malnutrition* OR hunger) N2 (insecur* OR unstable OR stable OR stabilit* OR instabilit* OR uncertain* OR vulnerab* OR hardship* OR insufficien* OR stress* OR access OR (secur* NOT (global OR production OR environment* OR parasite* OR microb* OR bacteria* OR climate))))) ) | Expanders - Apply equivalent subjects | 601
S14 | TI ( “hunger vital sign” OR “hunger screen” ) OR AB ( “hunger vital sign” OR “hunger screen” ) | Expanders - Apply equivalent subjects | 17
S15 | TI ( “Household Food Security” OR “adult Food Security” OR “cps Food Security” ) OR AB ( “Household Food Security” OR “adult Food Security” OR “cps Food Security” ) | Expanders - Apply equivalent subjects | 546
S16 | TI ( “Household Food Insecurity Access Scale” OR HFIAS ) OR AB ( “Household Food Insecurity Access Scale” OR HFIAS ) | Expanders - Apply equivalent subjects | 116
S17 | TI “USDA food security” OR AB “USDA food security” | Expanders - Apply equivalent subjects | 13
S18 | TI “Geriatric Malnutrition Assessment” OR AB “Geriatric Malnutrition Assessment” | Expanders - Apply equivalent subjects | 3
S19 | TI ( “Risk of Impaired Nutritional Status and Growth” OR STRONGkids ) OR AB ( “Risk of Impaired Nutritional Status and Growth” OR STRONGkids ) | Expanders - Apply equivalent subjects | 45
S20 | S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 | Expanders - Apply equivalent subjects | 1,252
S21 | S12 OR S20 | Expanders - Apply equivalent subjects | 2,838
S22 | (MH “Clinical Trials+”) OR (MH “Meta Analysis”) OR (MH “Placebos”) OR (MH “Random Sample+”) OR (MH “Control Group”) OR (MH “Pretest-Posttest Design+”) OR (MH “Cluster Sample+”) OR (MH “Sample Size”) OR (MH “Comparative Studies+”) OR (MH “Crossover Design”) OR PT (Clinical Trial OR Meta Analysis OR Meta Synthesis OR Randomized Controlled Trial OR Systematic Review) OR (TI (random* OR placebo OR randomly OR “phase iii” OR “phase 3” OR RCT OR sham OR dummy OR double blind* OR allocated OR allocation OR triple blind* OR treble blind* OR Nonrandom* OR quasirandom* OR pragmatic study OR pragmatic studies OR metaanaly* OR meta analy*)) OR (AB (random* OR placebo OR randomly OR “phase iii” OR “phase 3” OR RCT OR sham OR dummy OR double blind* OR allocated OR allocation OR triple blind* OR treble blind* OR Nonrandom* OR quasirandom* OR pragmatic study OR pragmatic studies OR metaanaly* OR meta analy*)) OR (TI ((control* OR clinical) N3 (study OR studies OR trial* OR group*))) OR (TI ((open label OR open-label) N5 (study OR studies OR trial*))) OR (TI ((equivalence OR superiority OR non-inferiority OR noninferiority) N3 (study OR studies OR trial*))) OR (TI ((pragmatic OR practical) N3 trial*)) OR (TI ((quasiexperimental OR quasi-experimental) N3 (study OR studies OR trial*))) OR (AB ((control* OR clinical) N3 (study OR studies OR trial* OR group*))) OR (AB ((open label OR open-label) N5 (study OR studies OR trial*))) OR (AB ((equivalence OR superiority OR non-inferiority OR noninferiority) N3 (study OR studies OR trial*))) OR (AB ((pragmatic OR practical) N3 trial*)) OR (AB ((quasiexperimental OR quasi-experimental) N3 (study OR studies OR trial*))) OR (MH (sample size) AND AB (assigned OR allocated OR control)) | Expanders - Apply equivalent subjects | 1,359,639
S23 | (MH “Case Control Studies+”) OR (MH “Prospective Studies+”) OR (MH “Evaluation Research+”) OR (MH “Retrospective Design”) OR (MH “Cross Sectional Studies”) OR (MH “Multivariate Analysis”) OR (MH “Chi Square Test+”) OR (MH “Multiple Logistic Regression”) OR (MH “Observational Methods+”) OR (TI (case control* OR cohort OR longitudinal OR follow-up OR followup OR prospective* OR comparison group* OR control group* OR observational OR retrospective* OR database* OR nonrandomi* OR non-randomi* OR population* OR registr* OR register* OR cross-sectional OR multivariate OR pool* OR logistic regression OR pre-post OR “pre and post*” OR matching OR sub-group analys$ or “we observed” OR (matched N2 compar$))) OR (AB (case control* OR cohort OR longitudinal OR follow-up OR followup OR prospective* OR comparison group* OR control group* OR observational OR retrospective* OR database* OR nonrandomi* OR non-randomi* OR population* OR registr* OR register* OR cross-sectional OR multivariate OR pool* OR logistic regression OR pre-post OR “pre and post*” OR matching OR sub-group analys$ or “we observed” OR (matched N2 compar$))) | Expanders - Apply equivalent subjects | 2,311,205
S24 | S22 OR S23 | Expanders - Apply equivalent subjects Limiters - Published Date: 20180601-; English Language; Publication Type: Journal Article, Research | 697,191
S25 | S21 AND S24 | Expanders - Apply equivalent subjects | 962
S26 | (MH “Sensitivity and Specificity”) OR (MH “Predictive Value of Tests”) OR (MH “ROC Curve”) OR (MH “Diagnostic Errors+”) OR (MH “Reproducibility of Results”) OR (MM “Reference Values”) OR (MH “Evaluation Research+”) OR (TI (“receiver operat*” OR “ROC curve*” OR “sensitivit*” OR “specificit*” OR “predictive value” OR “accuracy” OR “Psychometric*” OR “false positive*” OR “false negative*” OR “miss rate*” OR “error rate*” OR “likelihood ratio*” OR ((pre-test OR pretest OR post-test) N1 probability))) OR (AB (“receiver operat*” OR “ROC curve*” OR “sensitivit*” OR “specificit*” OR “predictive value” OR “accuracy” OR “Psychometric*” OR “false positive*” OR “false negative*” OR “miss rate*” OR “error rate*” OR “likelihood ratio*” OR ((pre-test OR pretest OR post-test) N1 probability))) | Expanders - Apply equivalent subjects Limiters - Published Date: 20170101-; English Language; Publication Type: Journal Article, Research | 314,432
S27 | S21 AND S26 | Expanders - Apply equivalent subjects | 251
S28 | S25 OR S27 | Expanders - Apply equivalent subjects | 1,027
S29 | ((MH “Food”) OR (MM “Fruit+”) OR (MM “Vegetables+”)) AND ((MH “Prescriptions, Non-Drug”) OR (MH “Diet Therapy+”) OR (MH “Therapeutics”) OR (MH “Early Intervention+”) OR (MH “Feeding Methods+”) OR (MH “Nutritional Support+”) OR (MH “Eating Behavior+”) OR (TI (prevention OR address* OR prescription* OR prescribe* OR provision OR provisions assistance)) ) | Expanders - Apply equivalent subjects | 7,179
S30 | TI ( ((food N1 medicine) OR (food N1 (aid OR aide OR assist* OR bag* OR bank* OR box* OR pantr* OR shelf OR shelves OR benefit* OR donation OR donated))) ) OR AB ( ((food N1 medicine) OR (food N1 (aid OR aide OR assist* OR bag* OR bank* OR box* OR pantr* OR shelf OR shelves OR benefit* OR donation OR donated))) ) | Expanders - Apply equivalent subjects | 2,085
S31 | TI ( ((food OR fruit OR vegetable OR meals OR foods OR fruits OR vegetables OR meals) N4 (prevention OR address* OR prescription* OR prescribe* OR provision OR provisions assistance OR afford*)) ) OR AB ( ((food OR fruit OR vegetable OR meals OR foods OR fruits OR vegetables OR meals) N4 (prevention OR address* OR prescription* OR prescribe* OR provision OR provisions assistance OR afford*)) ) | Expanders - Apply equivalent subjects | 3,547
S32 | TI ( ((Diet* OR nutrition*) N1 (outcome* OR counsel*)) ) OR AB ( ((Diet* OR nutrition*) N1 (outcome* OR counsel*)) ) | Expanders - Apply equivalent subjects | 4,235
S33 | ((MH “Grocery Stores”) OR (MH “Convenience Stores”)) OR (TI ( ((meal deliver* N1 program*) OR medically tailored OR untailored food OR “food store” or “food stores” or “grocery store” or “grocery store”) ) OR AB ( ((meal deliver* N1 program*) OR medically tailored OR untailored food OR “food store” or “food stores” or “grocery store” or “grocery store”) )) | Expanders - Apply equivalent subjects | 1,256
S34 | ((MH “Meal Preparation+”) OR (MH “Menu Planning”) OR (MH “Meals+”)) AND ((MH “Prescriptions, Non-Drug”) OR (MH “Diet Therapy+”) OR (MH “Therapeutics”) OR (MH “Early Intervention+”) OR (MH “Feeding Methods+”) OR (MH “Nutritional Support+”)) | Expanders - Apply equivalent subjects | 5,559
S35 | TI ( EBT OR WIC OR “ Women, Infants, and Children” OR “ Women, Infants, Children” OR SNAP OR food stamp* ) OR AB ( EBT OR WIC OR “ Women, Infants, and Children” OR “ Women, Infants, Children” OR SNAP OR food stamp* ) | Expanders - Apply equivalent subjects | 4,067
S36 | (MH “Patient Navigation”) OR (MH “Referral and Consultation”) OR (MH “Patient Education”) OR (MH “Health Promotion Methods”) OR (TI ( referral* OR mitigat* OR communityrx OR (community N2 information) ) OR AB ( referral* OR mitigat* OR communityrx OR (community N2 information) )) | Expanders - Apply equivalent subjects | 196,218
S37 | S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 | Expanders - Apply equivalent subjects | 221,035
S38 | S7 AND S24 AND S37 | Expanders - Apply equivalent subjects | 1,300
S39 | S11 OR S37 | Expanders - Apply equivalent subjects | 793,181
S40 | ((MH “Social Determinants of Health”) OR (MM “Poverty+”) OR (MH “Socioeconomic Factors+”) OR (MM “Employment”) OR (MM “Unemployment”)) AND ((MH “Meal Preparation+”) OR (MH “Menu Planning”) OR (MH “Meals+”) OR (MH “Fruit+”) OR (MH “Vegetables+”) OR (MH “Food”) OR TI (food OR fruit OR vegetable OR meals OR foods OR fruits OR vegetables OR meals) OR AB (food OR fruit OR vegetable OR meals OR foods OR fruits OR vegetables OR meals)) | Expanders - Apply equivalent subjects | 14,072
S41 | S39 AND S40 | Expanders - Apply equivalent subjects | 4,304
S42 | TI ( (((social* or socio*) N1 (environment* or determin*)) N5 (screen* or detect* or identif* or question* or intervention* or refer* or assessment or services)) ) OR AB ( (((social* or socio*) N1 (environment* or determin*)) N5 (screen* or detect* or identif* or question* or intervention* or refer* or assessment or services)) ) | Expanders - Apply equivalent subjects | 2,070
S43 | TI ((((determinant* or determinate*) N2 health) or ((social* or socio*) N1 (condition* or factor* or gradient* or need* or require* or equit* or inequit* or disparit* or equal* or inequal* or hardship* or depriv* or challeng* or difficult* or barrier* or vulnerab* or disadvantag* or risk* or status* or circumstance* or position* or class*)) or ((economic* or income* or financ*) N2 (achieve* or status or attain* or equit* or inequit* or disparit* or equal* or inequalit* or level* or background* or opportunit* or disadvantage* or advantage* or marginal* or disenfranchis* or vulnerab* or strain* or strugg* or stable or unstable or stabilit* or instabilit* or difficult* or problem* or (low not (countries or country or lmic)))) or unemployment or unemployed or underemploy* or (occupation* N2 (status or level or class)) or jobless* or workless* or (employment N2 (status or securit* or insecurit* or marginal* or precarious* or terminat*))) N5 (screen* or detect* or identif* or question* or intervention* or refer* or assessment or services)) | Expanders - Apply equivalent subjects | 1,769
S44 | S41 OR S42 OR S43 | Expanders - Apply equivalent subjects | 7,821
S45 | S24 AND S44 | Expanders - Apply equivalent subjects | 1,893
S46 | S28 OR S38 OR S45 | Expanders - Apply equivalent subjects | 3,330
S47 | (MH animals NOT MH humans) | Expanders - Apply equivalent subjects | 96,769
S48 | S46 NOT S47 | Expanders - Apply equivalent subjects | 3,318

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Include | Exclude
Condition | KQs 1–5: Food insecurity | KQs 1–5:; - Water insecurity; - Other social risk factors (e.g., unemployment, financial strain, housing instability) in the absence of food insecurity
Populations^*^ | KQs 1–5: All ages; - Children and their caregivers; - Adolescents; - Adults; - Perinatal, pregnant, and postpartum populations; - Older adults and their caregivers; - Persons with stable common chronic conditions (e.g., diabetes, hypertension) | KQs 1–5:; - Persons with acute medical or psychiatric conditions; - Persons undergoing treatment for cancer; - Persons with severe malnutrition or nutritional deficiencies
Assessment | KQs 1–3: Risk assessment or screening for food insecurity using tool that addresses food insecurity with other social risk factors or food insecurity alone | KQs 1–3:; - Nutrition assessment (anthropometric, biochemical, clinical, or dietary assessment); - Risk assessment or screening tools for social risk factors that do not explicitly address food insecurity
Interventions | KQs 4, 5:; - Healthcare-related interventions^†^ targeting food insecurity Individual or household-level (e.g., referral to social services, provision of information about resources); - Healthcare system–level (e.g., policies, programs, staff training, primary care collaboration with community services) | KQs 4, 5:; - Interventions focused on adherence to dietary recommendations for management of chronic conditions; - Public health/community-level policies
Comparators | KQs 1, 4: Control group (can include historical control, active control/comparator)^§^; KQ 2: Any reference standard; KQs 3, 5: No comparator required if explicitly addresses harms | KQs 1, 4: No control/comparator; KQ 2: No reference standard
Outcomes | KQs 1, 4:; - Food and nutrition security outcomes; - Access to food; - Behavioral outcomes (e.g., dietary intake, substance use); - Physiologic outcomes (e.g., blood pressure, hemoglobin A1c, healthy weight gain in pregnancy); - Healthcare-related decision-making outcomes; - Healthcare-related patient participation outcomes (e.g., medication compliance, attendance at medical appointments); - Healthcare utilization (e.g., emergency department visits, hospitalization); - Health or surrogate health outcomes (e.g., low birth weight, developmental outcomes in children, incident diabetes, mental health, cardiovascular events, quality of life); KQ 2: Test accuracy, predictive validity, and discrimination; KQs 3, 5: Any harms or unintended consequences | KQs 1, 4:; - Knowledge, skills, and self-efficacy outcomes; - Provider-level outcomes (e.g., confidence in screening, awareness of resources); - Community-level outcomes (e.g., number of food pantries); - Cost outcomes; KQ 2: Test positivity or test yield only
Settings | KQs 1–5:; - Any setting linked with healthcare system (e.g., primary care, behavioral health care, specialty care, emergency department); - Conducted in the United States; KQs 1–3: Screening conducted in clinical setting or identified through healthcare delivery or payment system (e.g., health plan data); KQs 4, 5: Interventions or programs integrated into, associated with, or referred from healthcare | KQs 1–5:; - No link with healthcare system; - Conducted outside the United States
Study designs | KQs 1, 4:; - Randomized or clinically controlled trials, nonrandomized studies with a contemporaneous control or comparison, quasi-experimental studies (e.g., pre-post studies); - Minimum 12-week followup; KQ 2: Diagnostic test accuracy or risk assessment studies; KQs 3, 5: Randomized or clinically controlled trials, nonrandomized studies, and quasi-experimental studies | KQs 1, 4: Randomized or clinically controlled trials, nonrandomized studies with less than 12- week followup; KQ 2: Test performance studies without reference standard; KQs 3, 5: Case series, case reports, or editorials
Study quality | Fair to good | Poor

* For all KQs, populations of interest include persons at higher risk for food insecurity (e.g., by age, race and ethnicity, health status, or other social risk factors).

† Healthcare-related interventions are those in which the patient’s food insecurity was identified through healthcare and/or the intervention itself is provided directly via a healthcare system, based within a healthcare system, or delivered in partnership with a healthcare system.

§ Does not apply to pre-post study design.

Appendix A Table 2 Quality Rating Criteria

Study Design | Adapted Quality Criteria
Adapted Risk Of Bias In Non-randomised Studies of Interventions (ROBINS-I)^1^ | Bias due to confounding; - No baseline confounding; - No time-varying confounding; Bias in selecting participants into the study; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias in classifying interventions; - Intervention groups are clearly defined; - Information used to define intervention groups was recorded at the start of the intervention; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias due to deviations from intended interventions; - No deviations from intended intervention; - Important co-interventions are balanced across intervention groups; - Analysis adjusts for deviations from intended intervention that could have affected outcomes; Bias from missing data; - Outcome data are available for all, or nearly all, participants; - Proportion of participants and reasons for missing data are similar across groups; - Appropriate statistical methods used to account for missing data or there was evidence that results were robust to the presence data; Bias in measurement of outcomes; - Blinding of participants; - Blinding of outcome assessors; - Methods of outcome assessment are comparable across intervention groups; - No systematic errors in measurement of the outcome related to intervention received; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported
Diagnostic accuracy studies, adapted from the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) II instrument^2^ | Patient Selection; - Was a consecutive or random sample of patients enrolled?; - Did the study avoid inappropriate exclusions?; Index Test; - Were the index test results interpreted without knowledge of the reference standard results?; - If a threshold was used, was it prespecified or was a range of values presented?; Reference Standard; - Is the reference standard likely to correctly classify the target condition?; - Were the reference standard results interpreted without knowledge of the index test?; - Were staff trained in the use of the reference standard?; - Was fidelity of the reference standard monitored or reported?; Flow and Timing; - Was there an appropriate interval between the index test and reference standard?; - Did all patients receive a reference standard?; - Did all patients receive the same reference standard?; ○ Were all patients included in the analysis?
Randomized clinical trials, adapted from U.S. Preventive Services Task Force Manual^3^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported
Pre-Post, adapted from National Heart, Lung, and Blood Institute Study Quality Assessment Tool for Before-After (Pre-Post) Studies With No Control Group^4^ | Critical signaling question (if answered no, then no other questions addressed):; Interrupted Time-Series Design; Were outcome measures of interest taken multiple times before the intervention and multiple times after the intervention (i.e., did they use an interrupted time-series design)?; Further questions:; Was the study question or objective clearly stated?; Were eligibility/selection criteria for the study population prespecified and clearly described?; Were the participants in the study representative of those who would be eligible for the test/service/intervention in the general or clinical population of interest?; Were all eligible participants that met the prespecified entry criteria enrolled?; Was the sample size sufficiently large to provide confidence in the findings?; Was the test/service/intervention clearly described and delivered consistently across the study population?; Were the outcome measures prespecified, clearly defined, valid, reliable, and assessed consistently across all study participants?; Were the people assessing the outcomes blinded to the participants’ exposures/interventions?; Was the loss to followup after baseline 20% or less? Were those lost to followup accounted for in the analysis?; Did the statistical methods examine changes in outcome measures from before to after the intervention? Were statistical tests done that provided p values for the pre-to-post changes?; If the intervention was conducted at a group level (e.g., a whole hospital, a community, etc.) did the statistical analysis take into account the use of individual-level data to determine effects at the group level?

Appendix A Figure 1 Literature Flow Diagram

This figure is the literature flow diagram demonstrating the number of citations reviewed and included for each Key Question. This figure is noted in the Methods section of the report.

Appendix A Figure 2 Quality Assessment Ratings, by Domain, Key Questions 1 and 4

Note: Interrupted time-series design indicates multiple observations before and after the intervention; all included studies included only one observation prior to the intervention and one observation after the intervention, which we considered high risk of bias, and were not further evaluated.

Abbreviations: RCT=randomized controlled trial; NRSI=nonrandomized studies of interventions

This figure illustrates the quality assessment of each included study for Key Questions 1 and 4 by domain. This figure is noted in the Results section of the report.

Appendix A Figure 3 Quality Assessment Ratings, by Domain, Key Question 2

This figure illustrates the quality assessment of each included study for Key Question 2 by domain.