# References

1 Kuo G, Choo QL, Alter HJ, et al. An assay for circulating antibodies to a major etiologic virus of human non-A, non-B hepatitis. Science. 1989;244(4902):362-4. [pmid: 2496467].
2 Alter HJ, Purcell RH, Shih JW, et al. Detection of antibody to hepatitis C virus in prospectively followed transfusion recipients with acute and chronic non-A, non-B hepatitis. N Engl J Med. 1989;321(22):1494-500. [pmid: 2509915].
3 Esteban JI, Lopez-Talavera JC, Genesca J, et al. High rate of infectivity and liver disease in blood donors with antibodies to hepatitis C virus. Ann Intern Med. 1991;115:443-449. [pmid: 1651674].
4 Esteban JI, Gonzalez A, Hernandez JM, et al. Evaluation of antibodies to hepatitis C virus in a study of transfusion-associated hepatitis. N Engl J Med. 1990;323(16):1107-12. [pmid: 2170839].
5 Sanchez-Tapias JM, Barrera JM, Costa J, et al. Hepatitis C virus infection in patients with nonalcoholic chronic liver disease. Ann Intern Med. 1990;112:921-924. [pmid: 2111108].
6 Alter MJ, Margolis HS, Krawczynski K, et al. The natural history of community-acquired hepatitis C in the United States. The Sentinel Counties Chronic non-A, non-B Hepatitis Study Team. N Engl J Med. 1992;327(27):1899-905. [pmid: 1280771].
7 Alter HJ. To C or not to C: these are the questions. Blood. 1995;85(7):1681-95. [pmid: 7535582].
8 Recommendations for prevention and control of hepatitis C virus (HCV) infection and HCV-related chronic disease. Centers for Disease Control and Prevention. MMWR 1998;47:(RR-19):1–39.
9 Alter MJ, Kruszon-Moran D, Nainan OV, et al. The prevalence of hepatitis C virus infection in the United States, 1988 through 1994. N Engl J Med. 1999;341(8):556-62. [pmid: 10451460].
10 Alter MJ. Epidemiology of hepatitis C. Hepatology. 1997;26(3 Suppl 1):62S-65S. [pmid: 9305666].
11 Patrick DM, Tyndall MW, Cornelisse PG, et al. Incidence of hepatitis C virus infection among injection drug users during an outbreak of HIV infection. Can Med Assoc J. 2001;165(7):889-95. [pmid: 11599327]. [pmcid: 81496].
12 Villano SA, Vlahov D, Nelson KE, et al. Incidence and risk factors for hepatitis C among injection drug users in Baltimore, Maryland. J Clin Microbiol. 1997;35(12):3274-7. [pmid: 9399533]. [pmcid: 230161].
13 Bell J, Batey RG, Farrell GC, et al. Hepatitis C virus in intravenous drug users. Med J Aust. 1990;153(5):274-6. [pmid: 2118227].
14 Disease burden from viral hepatitis A, B, and C in the United States. In: Centers for Disease Control and Prevention; 2002.
15 Culver DH, Alter MJ, Mullan RJ, et al. Evaluation of the effectiveness of targeted lookback for HCV infection in the United States-interim results. Transfusion. 2000;40(10):1176-81. [pmid: 11061852].
16 Singer ME, Younossi ZM. Cost effectiveness of screening for hepatitis C virus in asymptomatic, average-risk adults. Am J Med. 2001;111(8):614-21. [pmid: 11755504].
17 Gordon FD. Cost-effectiveness of screening patients for hepatitis C. Am J Med. 1999;107(6B):36S-40S. [pmid: 10653454].
18 Dubois F, Desenclos JC, Mariotte N, et al. Hepatitis C in a French population-based survey, 1994: seroprevalence, frequency of viremia, genotype distribution, and risk factors. The Collaborative Study Group. Hepatology. 1997;25(6):1490-6. [pmid: 9185773].
19 Busch MP. Insights into the epidemiology, natural history and pathogenesis of hepatitis C virus infection from studies of infected donors and blood product recipients. Transfus Clin Biol. 2001;8(3):200-6. [pmid: 11499958].
20 Kim WR. The burden of hepatitis C in the United States. Hepatology. 2002;36:S30-S34. [pmid: 12407574].
21 Kim WR, Gross JB Jr., Poterucha JJ, et al. Outcome of hospital care of liver disease associated with hepatitis C in the United States. Hepatology. 2001;33:201-206. [pmid: 11124837].
22 Armstrong GL, Alter MJ, McQuillan GM, et al. The past incidence of hepatitis C virus infection: implications for the future burden of chronic liver disease in the United States. Hepatology. 2000;31:777-782. [pmid: 10706572].
23 Deuffic S, Buffat L, Poynard T, et al. Modeling the hepatitis C virus epidemic in France. Hepatology. 1999;29(5):1596-601. [pmid: 10216148].
24 Wong JB, McQuillan GM, McHutchison JG, et al. Estimating future hepatitis C morbidity, mortality, and costs in the United States. Am J Public Health. 2000;90(10):1562-1569. [pmid: 11029989]. [pmcid: 1446368].
25 Seeff LB, Buskell-Bales Z, Wright EC, et al. Long-term mortality after transfusion-associated non-A, non-B hepatitis. N Engl J Med. 1992;327:1906-1911. [pmid: 1454085].
26 Seeff LB. Mortality and morbidity of transfusion-associated type C hepatitis: an NHLBI multi-center study [abstract]. Hepatology. 1994;20(4):204A.
27 Seeff LB, Hollinger B, Alter HJ, et al. Long-term mortality and morbidity of transfusion-associated non-A, non-B, and Type C hepatitis: a National Heart, Lung, and Blood Institute Collaborative Study. Hepatology. 2001;33:455-463. [pmid: 11172349].
28 Harris HE, Ramsay ME, Andrews N, et al. Clinical course of hepatitis C virus during the first decade of infection: cohort study. BMJ. 2002;324(7335):450-3. [pmid: 11859045]. [pmcid: 65664].
29 Seeff LB, Miller RN, Rabkin CS, et al. 45-year follow-up of hepatitis C virus infection in healthy young adults. Ann Intern Med. 2000;132(2):105-11. [pmid: 10644270].
30 Locasciulli A, Testa M, Pontisso P, et al. Prevalence and natural history of hepatitis C infection in patients cured of childhood leukemia. Blood. 1997;90(11):4628-33. [pmid: 9373275].
31 Vogt M, Lang T, Frosner G, et al. Prevalence and clinical outcome of hepatitis C infection in children who underwent cardiac surgery before the implementation of blood-donor screening. N Engl J Med. 1999;341(12):866-70. [pmid: 10498458].
32 Kenny-Walsh E. Clinical outcomes after hepatitis C infection from contaminated anti-D immune globulin. Irish Hepatology Research Group. N Engl J Med. 1999;340(16):1228-33. [pmid: 10210705].
33 Barrett S, Goh J, Coughlan B, et al. The natural course of hepatitis C virus infection after 22 years in a unique homogenous cohort: spontaneous viral clearance and chronic HCV infection. Gut. 2001;49(3):423-30. [pmid: 11511566]. [pmcid: 1728443].
34 Koff RS. Impaired health-related quality of life in chronic hepatitis C: the how, but not the why. Hepatology. 1999;29(1):277-279. [pmid: 9862878].
35 Foster GR, Goldin RD, Thomas HC. Chronic hepatitis C virus infection causes a significant reduction in quality of life in the absence of cirrhosis. Hepatology. 1998;27:209-212. [pmid: 9425939].
36 Coughlan B, Sheehan J, Hickey A, et al. Psychological well being and quality of life in women with an iatrogenic hepatitis C virus infection. Br J Health Psychol. 2002;7:105-116. [pmid: 14596721].
37 Rodger AJ, Jolley D, Thompson SC, et al. The impact of diagnosis of hepatitis C virus on quality of life. Hepatology. 1999;30(5):1299-301. [pmid: 10534353].
38 Guidelines for laboratory testing and result reporting of antibody to hepatitis C virus. MMWR Morb Mortal Wkly Rep 2003;52:(RR-3):1–16.
39 Schiff ER, de Medina M, Kahn RS. New perspectives in the diagnosis of hepatitis C. Semin Liver Dis. 1999;19(Suppl 1):3-15. [pmid: 10349688].
40 Saito M, Hasegawa A, Kashiwakuma T, et al. Performance of an enzyme-linked immunosorbent assay system for antibodies to hepatitis C virus with two new antigens (c11/c7). Clin Chem. 1992;38(12):2434-9. [pmid: 1281050].
41 Brown D, Powell L, Morris A, et al. Improved diagnosis of chronic hepatitis C virus infection by detection of antibody to multiple epitopes: confirmation by antibody to synthetic oligopeptides. J Med Virol. 1992;38(3):167-71. [pmid: 1283751].
42 Carithers RL Jr., Marquardt A, Gretch DR. Diagnostic testing for hepatitis C. Semin Liver Dis. 2000;20(2):159-71. [pmid: 10946421].
43 Damen M, Zaaijer H, Cuypers HT, et al. Reliability of the third-generation recombinant immunoblot assay for hepatitis C virus. Transfusion. 1995;35(9):745-749. [pmid: 7570934].
44 Dow BC, Buchanan I, Munro H, et al. Relevance of RIBA-3 supplementary test to HCV PCR positivity and genotypes for HCV confirmation of blood donors. J Med Virol. 1996;49(2):132-6. [pmid: 8991936].
45 Pawlotsky JM, Bastie A, Pellet C, et al. Significance of indeterminate third-generation hepatitis C virus recombinant immunoblot assay. J Clin Microbiol. 1996;34(1):80-3. [pmid: 8748278]. [pmcid: 228735].
46 Pawlotsky JM. Use and interpretation of virological tests for hepatitis C. Hepatology. 2002;36:S65-S73. [pmid: 12407578].
47 Dore GJ, Kaldor J, McCaughan GW. Systematic review of role of polymerase chain reaction in defining infectiousness among people infected with hepatitis C virus. BMJ. 1997;315:333-341. [pmid: 9270453]. [pmcid: 2127245].
48 Alberti, A, Chemello, L, Diodati, G, et al. Treatment of chronic hepatitis C with different regimens of interferon alpha-2a (IFN-2a) [AASLD abstract]. Hepatology 1992;16:(2 Pt 2).
49 Prieto M, Olaso V, Verdu C, et al. Does the healthy hepatitis C virus carrier state really exist? An analysis using polymerase chain reaction. Hepatology. 1995;22(2):413-7. [pmid: 7635408].
50 Montalto G, Zignego AL, Ruggeri MI, et al. Serum HCV-RNA and liver histologic findings in patients with long-term normal transaminases. Dig Dis Sci. 1997;42(8):1703-7. [pmid: 9286237].
51 Poynard T, Ratziu V, Charlotte F, et al. Rates and risk factors of liver fibrosis progression in patients with chronic hepatitis C. J Hepatol. 2001;34(5):730-9. [pmid: 11434620].
52 Puoti C, Stati T, Magrini A. Serum HCV RNA titer does not predict the severity of liver damage in HCV carriers with normal aminotransferase levels. Liver. 1999;19(2):104-9. [pmid: 10220739].
53 Shakil AO, Conry-Cantilena C, Alter HJ, et al. Volunteer blood donors with antibody to hepatitis C virus: clinical, biochemical, virologic, and histologic features. Ann Intern Med. 1995;123:330-337. [pmid: 7542854].
54 McCormick SE, Goodman ZD, Maydonovitch CL, et al. Evaluation of liver histology, ALT elevation, and HCV RNA titer in patients with chronic hepatitis C. Am J Gastroenterol. 1996;91(8):1516-22. [pmid: 8759653].
55 Reichard O, Norkrans G, Fryden A, et al. Comparison of 3 quantitative HCV RNA assays—accuracy of baseline viral load to predict treatment outcome in chronic hepatitis C. Scand J Infect Dis. 1998;30(5):441-6. [pmid: 10066040].
56 Yokosuka O, Kojima H, Imazeki F, Tagawa M, Saisho H, Tamatsukuri S, Omata M. Spontaneous negativation of serum hepatitis C virus RNA is a rare event in type C chronic liver diseases: analysis of HCV RNA in 320 patients who were followed for more than 3 years. J Hepatol. 1999;31(3):394-9. [pmid: 10488695].
57 Zaaijer HL, Cuypers HT, Reesink HW, et al. Reliability of polymerase chain reaction for detection of hepatitis C virus. Lancet. 1993;341(8847):722-4. [pmid: 8095626].
58 Pawlotsky JM. Measuring hepatitis C viremia in clinical samples: can we trust the assays?. Hepatology. 1997;26(1):1-4. [pmid: 9214444].
59 Long GS, Bacon BR, Bisceglie AM. Interpreting serologic tests for hepatitis C virus infection: balancing cost and clarity. Cleve Clin J Med. 1996;63(5):264-8. [pmid: 8870336].
60 Gretch DR. Diagnostic tests for hepatitis C. Hepatology. 1997;26(3 Suppl 1):43S-47S. [pmid: 9305663].
61 Sakugawa H, Nakasone H, Nakayoshi T, et al. High proportion of false positive reactions among donors with anti-HCV antibodies in a low prevalence area. J Med Virol. 1995;46(4):334-8. [pmid: 7595410].
62 Ishak K, Baptista A, Bianchi L, et al. Histological grading and staging of chronic hepatitis. J Hepatol. 1995;22:696-699. [pmid: 7560864].
63 Bedossa P, Poynard T. An algorithm for the grading of activity in chronic hepatitis C. The METAVIR Cooperative Study Group. Hepatology. 1996;24(2):289-93. [pmid: 8690394].
64 Knodell RG, Ishak KG, Black WC, et al. Formulation and application of a numerical scoring system for assessing histological activity in asymptomati chronic active hepatitis. Hepatology. 1981;1:431-435. [pmid: 7308988].
65 Hoofnagle J. Course and outcome of hepatitis C. Hepatology. 2002;36:S21-S29. [pmid: 12407573].
66 Wiese M, Berr F, Lafrenz M, et al. Low frequency of cirrhosis in a hepatitis C (genotype 1b) single-source outbreak in germany: a 20-year multicenter study. Hepatology. 2000;32(1):91-6. [pmid: 10869294].
67 Puoti C, Castellacci R, Montagnese F, Hepatitis C. virus carriers with persistently normal aminotransferase levels: healthy people or true patients?. Dig Liver Dis. 2000;32(7):634-43. [pmid: 11142566].
68 Galmiche JP. French consensus conference on hepatitis C: screening and treatment. Gut. 1998;42(6):892-8. [pmid: 9691933]. [pmcid: 1727138].
69 National Institutes of Health Consensus Development Conference Panel statement: management of hepatitis C. Hepatology 1997;26:(3 Suppl 1):2S–10S.
70 Freeman AJ, Dore GJ, Law MG, et al. Estimating progression to cirrhosis in chronic hepatitis C virus infection. Hepatology. 2001;34:809-816. [pmid: 11584380].
71 Harris DR, Gonin R, Alter HJ, et al. The relationship of acute transfusion-associated hepatitis to the development of cirrhosis in the presence of alcohol abuse. Ann Intern Med. 2001;134(2):120-124. [pmid: 11177315].
72 Peters MG, Terrault NA. Alcohol use and hepatitis C. Hepatology. 2002;36:S220-S225. [pmid: 12407597].
73 Wiley TE, McCarthy M, Breidi L, et al. Impact of alcohol on the histological and clinical progression of hepatitis C infection. Hepatology. 1998;28(3):805-809. [pmid: 9731576].
74 Pessione F, Degos F, Marcellin P, et al. Effect of alcohol consumption on serum hepatitis C virus RNA and histological lesions in chronic hepatitis C. Hepatology. 1998;27(6):1717-1722. [pmid: 9620348].
75 Caldwell SH, Jeffer LJ, Ditomaso A, et al. Antibody to hepatitis C is common among patients with alcohol liver disease with and without risk factors. Am J Gastroenterol. 1991;86(9):1219-1223. [pmid: 1652885].
76 Degos F. Hepatitis C and alcohol. J Hepatol. 1999;31(Suppl 1):113-8. [pmid: 10622572].
77 Lesens O, Deschenes M, Steben M, et al. Hepatitis C virus is related to progressive liver disease in human immunodeficiency virus-positive hemophiliacs and should be treated as an opportunistic infection. J Infect Dis. 1999;179(5):1254-8. [pmid: 10191232].
78 Soto B, Sanchez-Quijano A, Rodrigo L, et al. Human immunodeficiency virus infection modifies the natural history of chronic parenterally-acquired hepatitis C with an unusually rapid progression to cirrhosis. J Hepatol. 1997;26(1):1-5. [pmid: 9147999].
79 Koff RS. Risks associated with hepatitis A and hepatitis B in patients with hepatitis C. J Clin Gastroenterol. 2001;33(1):20-6. [pmid: 11418785].
80 Zarski JP, Bohn B, Bastie A, et al. Characteristics of patients with dual infection by hepatitis B and C viruses. J Hepatol. 1998;28(1):27-33. [pmid: 9537860].
81 Roudot-Thoraval F, Bastie A, Pawlotsky JM, et al. Epidemiological factors affecting the severity of hepatitis C virus-related liver disease: a French survey of 6,664 patients. Hepatology. 1997;26:485-490. [pmid: 9252163].
82 Gordon SC, Bayati N, Silverman AL. Clinical outcome of hepatitis C as a function of mode of transmission. Hepatology. 1998;28(2):562-7. [pmid: 9696025].
83 Gordon SC, Elloway RS, Long JC, et al. The pathology of hepatitis C as a function of mode of transmission: blood transfusion vs. intravenous drug use. Hepatology. 1993;18(6):1338-43. [pmid: 8244258].
84 Thomas DL, Shih JW, Alter HJ, et al. Effect of human immunodeficiency virus on hepatitis C virus infection among injecting drug users. J Infect Dis. 1996;174(4):690-5. [pmid: 8843204].
85 Prati D, Capelli C, Zanella A, et al. Influence of different hepatitis C virus genotypes on the course of asymptomatic hepatitis C virus infection. Gastroenterology. 1996;110:178-183. [pmid: 8536854].
86 Wiley TE, Brown J, Chan J. Hepatitis C in African Americans: its natural history and histological progression. Am J Gastroenterol. 2002;97(3):700-706. [pmid: 11922566].
87 Seeff LB. Natural history of chronic hepatitis C. Hepatology. 2002;36:S35-S46. [pmid: 12407575].
88 Thomas DL, Astemborski J, Rai RM, et al. The natural history of hepatitis C virus infection: host, viral, and environmental factors. JAMA. 2000;284(4):450-6. [pmid: 10904508].
89 Rodger AJ, Roberts S, Lanigan A, et al. Assessment of long-term outcomes of community-acquired heptitis C infection in a cohort with sera stored from 1971 to 1975. Hepatology. 2000;32(3):582-587. [pmid: 10960453].
90 Fanning L, Kenny E, Sheehan M, et al. Viral load and clinicopathological features of chronic hepatitis C (1b) in a homogeneous patient population. Hepatology. 1999;29(3):904-7. [pmid: 10051496].
91 Albloushi SS, Murray FE, Callagy G, et al. Changes in liver histopathology in women infected with hepatitis C through contaminated anti-D immunoglobulin injections in Ireland. Eur J Gastroenterol Hepatol. 1997;10(1):69-73. [pmid: 9512956].
92 Alberti A, Noventa F, Benvegnu L, et al. Prevalence of liver disease in a population of asymptomatic persons with hepatitis C virus infection. Ann Intern Med. 2002;137:961-974. [pmid: 12484711].
93 Irving WL. Hepatitis C virus infection and liver disease in blood donors. Br J Hosp Med. 1994;51(11):567-569. [pmid: 7952744].
94 Alberti A, Morsica G, Chemello L, et al. Hepatitis C viraemia and liver disease in symptom-free individuals with anti-HCV. Lancet. 1992;340(8821):697-8. [pmid: 1355801].
95 Alberti A, Chemello L, Cavalletto D, et al. Antibody to hepatitis C virus and liver disease in volunteer blood donors. Ann Intern Med. 1991;114(12):1010-2. [pmid: 1851402].
96 McLindon JP, Paver WK, Babbs C, et al. Hepatitis C-related chronic liver disease among asymptomatic blood donors in the North West of England. J Infect. 1994;30:253-259. [pmid: 7545715].
97 McMahon RF, Yates AJ, McLindon J, et al. The histopathological features of asymptomatic hepatitis C virus-antibody positive blood donors. Histopathology. 1994;24(6):517-24. [pmid: 7520412].
98 Jonas MM. Challenges in the treatment of hepatitis C in children. Clin Liver Dis. 2001;5(4):1063-71. [pmid: 11685795].
99 Zanetti AR, Tanzi E, Paccagnini S, et al. Mother-to-infant transmission of hepatitis C virus. Lombardy Study Group on Vertical HCV Transmission. Lancet. 1995;345(8945):289-91. [pmid: 7530793].
100 Tajiri H, Miyoshi Y, Funada S, et al. Prospective study of mother-to-infant transmission of hepatitis C virus. Pediatr Infect Dis J. 2001;20(1):10-4. [pmid: 11176560].
101 Conte D, Fraquelli M, Prati D, et al. Prevalence and clinical course of chronic hepatitis C virus (HCV) infection and rate of HCV vertical transmission in a cohort of 15,250 pregnant women. Hepatology. 2000;31(3):751-5. [pmid: 10706568].
102 Gibb DM, Goodall RL, Dunn DT, et al. Mother-to-child transmission of hepatitis C virus: evidence for preventable peripartum transmission. Lancet. 2000;356(9233):904-7. [pmid: 11036896].
103 Sanchez-Quijano A, Andreu J, Gavilan F, et al. Influence of human immunodeficiency virus type 1 infection on the natural course of chronic parenterally acquired hepatitis C. Eur J Clin Microbiol Infect Dis. 1995;14(11):949-53. [pmid: 8654444].
104 Furusyo N, Hayashi J, Kanamoto-Tanaka Y, et al. Liver damage in hemodialysis patients with hepatitis C virus viremia: a prospective 10-year study. Dig Dis Sci. 2000;45(11):2221-8. [pmid: 11215743].
105 Rostaing L, Rumeau JL, Cisterne JM, et al. Liver histology in renal transplant patients after more than 10 years of hepatitis C virus infection. Transplant Proc. 1996;28(5):2836-7. [pmid: 8908089].
106 Kliem V, van den Hoff U, Brunkhorst R, et al. The long-term course of hepatitis C after kidney transplantation. Transplantation. 1996;62(10):1417-21. [pmid: 8958266].
107 Gebo, K, Jenckes, M, Chander, G, et al. Management of Chronic Hepatitis C. Evidence Report/Technology Assessment No. 60. AHRQ Publication No. 02-E030. Rockville, MD: Agency for Healthcare Research and Quality; 2002.
108 Harris RP, Helfand M, Woolf SH, et al. Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
109 Wejstal R. Sexual transmission of hepatitis C virus. J Hepatol. 1999;31(Suppl 1):92-95. [pmid: 10622568].
110 Alter MJ. Hepatitis C virus infection in the United States. J Hepatol. 1999;31(Suppl 1):88-91. [pmid: 10622567].
111 Kaur S, Rybicki L, Bacon BR, et al. Performance characteristics and results of a large-scale screening program for viral hepatitis and risk factors associated with exposure to viral hepatitis B and C: results of the National Hepatitis Screening Survey. National Hepatitis Surveillance Group. Hepatology. 1996;24(5):979-86. [pmid: 8903363].
112 Bellentani S, Pozzato G, Saccoccio G, et al. Clinical course and risk factors of hepatitis C virus related liver disease in the general population: report from the Dionysos study. Gut. 1999;44(6):874-80. [pmid: 10323892]. [pmcid: 1727553].
113 Cheung RC. Epidemiology of hepatitis C virus infection in American veterans. Am J Gastroenterol. 2000;95(3):740-747. [pmid: 10710068].
114 Austin GE, Jensen B, Leete J, et al. Prevalence of hepatitis C virus seropositivity among hospitalized US veterans. Am J Med Sci. 2000;319(6):353-359. [pmid: 10875289].
115 Gore SM, Bird AG, Cameron SO, et al. Prevalence of hepatitis C in prisons: WASH-C surveillance linked to self-reported risk behaviours. Q J Med. 1999;92:25-32.
116 Prefontaine RG, Chaudhary RK, Mathias RG. Analysis of risk factors associated with hepatitis B and C infections in correctional institutions in British Columbia. Can J Infect Dis. 1994;5:153-156.
117 Roy E, Haley N, Leclerc P, et al. Risk factors for hepatitis C virus infection among street youths. Can Med Assoc J. 2001;165(5):557-60. [pmid: 11563207]. [pmcid: 81413].
118 Osmond DH, Padian NS, Sheppard HW, et al. Risk factors for hepatitis C virus seropositivity in heterosexual couples. JAMA. 1993;269:361-365. [pmid: 8418342].
119 Zylberberg H, Thiers V, Lagorce D, et al. Epidemiological and virological analysis of couples infected with hepatitis C virus. Gut. 1999;45(1):112-6. [pmid: 10369713]. [pmcid: 1727577].
120 Magriples U, Bernstein P, Snyder E, et al. Can risk factor screening predict hepatitis C antibody reactivity?. Am J Perinatol. 1998;15(6):395-8. [pmid: 9722062].
121 Neal KR, Jones DA, Killey D, et al. Risk factors for hepatitis C virus infection. A case-control study of blood donors in the Trent Region (UK). Epidemiol Infect. 1994;112(3):595-601. [pmid: 8005225].
122 Kaldor JM, Archer GT, Buring ML, et al. Risk factors for hepatitis C virus infection in blood donors: a case-control study. Med J Aust. 1992;157(4):227-30. [pmid: 1279364].
123 Gunn RA, Murray PJ, Ackers ML, et al. Screening for chronic hepatitis B and C virus infections in an urban sexually transmitted disease clinic: rationale for integrating services. Sex Transm Dis. 2001;28(3):166-70. [pmid: 11289199].
124 Stary A, Kopp W, Hofmann H, et al. Seroepidemiologic study of hepatitis C virus in sexually transmitted disease risk groups. Sex Transm Dis. 1992;19(5):252-8. [pmid: 1384151].
125 Weinstock HS, Bolan G, Reingold AL, et al. Hepatitis C virus infection among patients attending a clinic for sexually transmitted diseases. JAMA. 1993;269:392-394. [pmid: 8418348].
126 Alter MJ, Hadler SC, Judson FN, et al. Risk factors for acute non-A, non-B hepatitis in the United States and association with hepatitis C virus infection. JAMA. 1990;264(17):2231-2235. [pmid: 2170702].
127 Garfein RS, Vlahov D, Galai N, et al. Viral infection in short-term injection drug users: the prevalence of the hepatitis C, hepatitis B, human immunodeficiency, and human t-lymphotropic viruses. Am J Public Health. 1996;86:655-661. [pmid: 8629715]. [pmcid: 1380472].
128 Akahane Y, Kojima M, Sugai Y, et al. Hepatitis C virus infection in spouses of patients with type C chronic liver disease. Ann Intern Med. 1994;120(9):748-752. [pmid: 8147548].
129 Kao JH, Chen PJ, Yang PM, et al. Intrafamilial transmission of hepatitis C virus: the important role of infections between spouses. J Infect Dis. 1992;166:900-903. [pmid: 1382107].
130 Kumar RM. Interspousal and intrafamilial transmission of hepatitis C virus: a myth or a concern?. Obstet Gynecol. 1998;91(3):426-31. [pmid: 9491872].
131 Seeff LB, Alter HJ. Spousal transmission of the hepatitis C virus?. Ann Intern Med. 1994;120(9):807-809. [pmid: 8147555].
132 Shev S, Widell A, Bergstrom T, et al. Herpes simplex virus-2 may increase susceptibility of the sexual transmission of hepatitis C. Sex Transm Dis. 1995;22(4):210-6. [pmid: 7482102].
133 Hallam NF, Fletcher ML, Read SJ, et al. Low risk of sexual transmission of hepatitis C virus. J Med Virol. 1993;40:251-253. [pmid: 7689092].
134 Diago M, Zapater R, Tuset C, et al. Intrafamily transmission of hepatitis C virus: sexual and non-sexual contacts. J Hepatol. 1996;25(2):125-8. [pmid: 8878771].
135 Neumayr G, Propst A, Schwaighofer H, et al. Lack of evidence for the heterosexual transmission of hepatitis C. Q J Med. 1999;92:505-508.
136 Conry-Cantilena C, Vanraden M, Gibble J, et al. Routes of infection, viremia, and liver disease in blood donors found to have hepatitis C virus infection. N Engl J Med. 1996;334:1691-1696. [pmid: 8637513].
137 Brackmann SA, Gerritzen A, Oldenburg J, et al. Search for intrafamial transmission of hepatitis C virus in hemophilia patients. Blood. 1993;81(4):1077-1082. [pmid: 8381312].
138 Gordon SC, Patel AH, Kulesza GW, et al. Lack of evidence for the heterosexual transmission of hepatitis C. Am J Gastroenterol. 1992;87(12):1849-1851. [pmid: 1333172].
139 Bresters D, Mauser-Bunschoten EP, Reesink HW, et al. Sexual transmission of hepatitis C virus. Lancet. 1993;342:210-211. [pmid: 8100931].
140 Everhart JE, Di Bisceglie A, Murray LM, et al. Risk for non-A, non-B (type C) hepatitis through sexual or household contact with chronic carriers. Ann Intern Med. 1990;112(7):544-545. [pmid: 1690526].
141 Meisel H, Reip A, Faltus B, et al. Transmission of hepatitis C virus to children and husbands by women infected with contaminated anti-D immunoglobulin. Lancet. 1995;345:1209-1211. [pmid: 7537841].
142 Power J, Davidson F, O'Riordan J, et al. Hepatitis C infection from anti-D immunoglobulin. Lancet. 1995;346:372-373. [pmid: 7677904].
143 Terrault NA. Sexual activity as a risk factor for hepatitis C. Hepatology. 2002;36:S99-S105. [pmid: 12407582].
144 Alter MJ, Coleman PJ, Alexander WJ, et al. Importance of heterosexual activitiy in the transmission of hepatitis B and non-A, non-B hepatitis. JAMA. 1989;262(9):1201-1205. [pmid: 2503630].
145 Salleras L, Bruguera M, Vidal J, et al. Importance of sexual transmission of hepatitis C virus in seropositive pregnant women: a case-control study. J Med Virol. 1997;52:164-167. [pmid: 9179763].
146 Feldman JG, Minkoff H, Landesman S, et al. Heterosexual transmission of hepatitis C, hepatitis B, and HIV-1 in a sample of inner city women. Sex Transm Dis. 2000;27(6):338-42. [pmid: 10907909].
147 Thomas DL, Zenilman JM, Alter HJ, et al. Sexual transmission of hepatitis C virus among patients attending sexually transmitted diseases clinics in Baltimore—an analysis of 309 sex partnerships. J Infect Dis. 1995;171(4):768-75. [pmid: 7535827].
148 Rosman AS, Waraich A, Galvin K, et al. Alcoholism is associated with hepatitis C but not hepatitis B in an urban population. Am J Gastroenterol. 1996;91(3):498-505. [pmid: 8633498].
149 Kelen GD, Green GB, Purcell RH, et al. Hepatitis B and hepatitis C in emergency department patients. N Engl J Med. 1992;326(21):1399-404. [pmid: 1373867].
150 Booth JCL, O'Grady J, Neuberger J. Clinical guidelines on the management of hepatitis C. Gut. 2001;49(Suppl 1):i1-i21. [pmid: 11413125].
151 Schreiber GB, Busch MP, Kleinman SH, et al. The risk of transfusion-transmitted viral infections. The Retrovirus Epidemiology Donor Study. N Engl J Med. 1996;334(26):1685-90. [pmid: 8637512].
152 Alter MJ. Prevention of spread of hepatitis C. Hepatology. 2002;36:S93-S98. [pmid: 12407581].
153 Haley RW, Fischer RP. Commercial tattooing as a potentially important source of hepatitis C infection. Medicine. 2001;80:134-151. [pmid: 11307589].
154 Balasekaran R, Bulterys M, Jamal MM, et al. A case-control study of risk factors for sporadic hepatitis C infection in the southwestern United States. Am J Gastroenterol. 1999;96(5):1341-1346. [pmid: 10235216].
155 Silverman AL, Sekhon JS, Saginaw SJ, et al. Tattoo application is not associated with an increased risk for chronic viral hepatitis. Am J Gastroenterol. 2000;95(5):1312-1315. [pmid: 10811345].
156 Murphy EL, Bryzman S, Williams AE, et al. Demographic determinants of hepatitis C virus seroprevalence among blood donors. JAMA. 1996;275(13):995-1000. [pmid: 8596257].
157 CDC's position on tattooing and HCV infection. In: Centers for Disease Control and Prevention; 2003.
158 Nubling CM, von Wangenheim G, Staszewski S, et al. Hepatitis C virus antibody prevalence among human immunodeficiency virus-1-infected individuals: analysis with different test systems. J Med Virol. 1994;44(1):49-53. [pmid: 7798885].
159 Thio CL, Nolt KR, Astemborski J, et al. Screening for hepatitis C virus in human immunodeficiency virus-infected individuals. J Clin Microbiol. 2000;38(2):575-7. [pmid: 10655348]. [pmcid: 86151].
160 Quan CM, Krajden M, Grigoriew GA, et al. Hepatitis C virus infection in patients infected with the human immunodeficiency virus. Clin Infect Dis. 1993;17(1):117-9. [pmid: 7688986].
161 Stuyver L, Claeys H, Wyseur A, et al. Hepatitis C virus in a hemodialysis unit: molecular evidence for nosocomial transmission. Kidney Int. 1996;49(3):889-95. [pmid: 8648934].
162 Courouce AM, Le Marrec N, Girault A, et al. Anti-hepatitis C virus (anti-HCV) seroconversion in patients undergoing hemodialysis: comparison of second- and third-generation anti-HCV assays. Transfusion. 1994;34(9):790-5. [pmid: 8091469].
163 Staples CT, Rimland D, Dudas D. Hepatitis C in the HIV (human immunodeficiency virus) Atlanta V.A. (Veterans Affairs Medical Center) Cohort Study (HAVACS): the effect of coinfection on survival. Clin Infect Dis. 1999;29:150-154. [pmid: 10433578].
164 Flamm SL, Parker RA, Chopra S. Risk factors associated with chronic hepatitis C virus infection: limited frequency of an unidentified source of transmission. Am J Gastroenterol. 1998;93(4):597-600. [pmid: 9576454].
165 Lapane KL, Jakiche AF, Sugano D, et al. Hepatitis C infection risk analysis: who should be screened? Comparison of multiple screening strategies based on the National Hepatitis Surveillance Program. Am J Gastroenterol. 1998;93(4):591-6. [pmid: 9576453].
166 Yawn B, Wollan P, Gazzuola L, et al. Diagnosis and 10-year follow-up of a community-based hepatitis C cohort. J Fam Pract. 2002;51(2):135-140. [pmid: 11978211].
167 Colin C, Lanoir D, Touzet S, et al. Sensitivity and specificity of third-generation hepatitis C virus antibody detection assays: an analysis of the literature. J Viral Hepat. 2001;8(2):87-95. [pmid: 11264728].
168 Uyttendaele S, Claeys H, Mertens W, et al. Evaluation of third-generation screening and confirmatory assays for HCV antibodies. Vox Sang. 1994;66(2):122-9. [pmid: 7514324].
169 Wolff C, Kleesiek K, Petersen N, et al. Hepatitis C viremia in German blood donors: serum alanine aminotransferase is not a valid marker for screening. Transfusion. 1994;34(4):361-2. [pmid: 7513910].
170 Lavanchy D, Steinmann J, Moritz A, et al. Evaluation of a new automated third-generation anti-HCV enzyme immunoassay. J Clin Lab Anal. 1996;10(5):269-76. [pmid: 8887006].
171 Courouce, AM, Janot, C. Development of screening and confirmation tests for antibodies to hepatitis C virus. Curr Stud Hematol Blood Transfus 1994(61):36–48.
172 Courouce AM, Barin F, Botte C, et al. A comparative evaluation of the sensitivity of seven anti-hepatitis C virus screening tests. Vox Sang. 1995;69(3):213-6. [pmid: 8578733].
173 Huber KR, Sebesta C, Bauer K. Detection of common hepatitis C virus subtypes with a third-generation enzyme immunoassay. Hepatology. 1996;24(3):471-3. [pmid: 8781309].
174 Busch MP, Watanabe KK, Smith JW, et al. False-negative testing errors in routine viral marker screening of blood donors. For the Retrovirus Epidemiology Donor Study. Transfusion. 2000;40(5):585-9. [pmid: 10827264].
175 Prince AM, Scheffel JW, Moore B. A search for hepatitis C virus polymerase chain reaction-positive but seronegative subjects among blood donors with elevated alanine aminotransferase. Transfusion. 1997;37(2):211-4. [pmid: 9051098].
176 Coughlan BM, Sheehan JD, Carr A, et al. Evaluation of a brief group-based psychological/educational (psych/ED) treatment programme for women with an iatrogenic hepatitis C virus (HCV) infection. Gastroenterology. 2001;129(Suppl 1):A568.
177 Zarski JP, Leroy V. Counselling patients with hepatitis C. J Hepatol. 1999;31(Suppl 1):136-40. [pmid: 10622576].
178 Anonymous. National Institutes of Health consensus development conference statemtn: management of hepatitis C: 2002—June 10–12, 2002. Hepatology 2002;36:S3–S20.
179 Dienstag JL. The role of liver biopsy in chronic hepatitis C. Hepatology. 2002;36:S152-S160. [pmid: 12407589].
180 Perrillo RP. The role of liver biopsy in hepatitis C. Hepatology. 1997;26(Suppl 1):57S-61S. [pmid: 9305665].
181 Gebo KA, Herlong HF, Torbenson MS, et al. Role of liver biopsy in management of chronic hepatitis C: a systematic review. Hepatology. 2002;36:S161-S172. [pmid: 12407590].
182 Management of Hepatitis C. In: National Institutes of Health; 2002.
183 Lauer GM, Walker B. Medical Progress: Hepatitis C Virsus Infection. N Engl J Med. 2001;345(1):41-52. [pmid: 11439948].
184 EASL International Consensus Conference on Hepatitis C. Paris, 26–28, February 1999, Consensus Statement. European Association for the Study of the Liver. J Hepatol. 1999;30(5):956-61. [pmid: 10365827].
185 Booth JC, Brown JL, Thomas HC. The management of chronic hepatitis C virus infection. Gut. 1995;37(4):449-54. [pmid: 7489926]. [pmcid: 1382891].
186 Muir AJ, Provenzale D. A descriptive evaluation of eligibility for therapy among veterans with chronic hepatitis C virus infection. J Clin Gastroenterol. 2002;34(3):268-71. [pmid: 11873110].
187 Cawthorne CH, Rudat KR, Burton MS, et al. Limited success of HCV antiviral therapy in United States veterans. Am J Gastroenterol. 2002;97(1):149-55. [pmid: 11808940].
188 Falck-Ytter Y, Kale H, Mullen KD, et al. Surprisingly small effect of antiviral treatment in patients with hepatitis C. Ann Intern Med. 2002;136(4):288-92. [pmid: 11848726].
189 Foster GR, Goldin RD, Main J, et al. Management of chronic hepatitis C: clinical audit of biopsy based management algorithm. BMJ. 1997;315(7106):453-8. [pmid: 9284661]. [pmcid: 2127336].
190 Bacon BR. Treatment of patients with hepatitis C and normal serum aminotransferase levels. Hepatology. 2002;36:S179-S184. [pmid: 12407592].
191 Garcia-Tsao G. Outpatient liver biopsy: how safe is it?. Ann Intern Med. 1993;118(2):150-152. [pmid: 8416312].
192 Bravo AA, Sheth SG, Chopra S. Liver biopsy. N Engl J Med. 2001;344(7):495-500. [pmid: 11172192].
193 Froehlich F, Lamy L, Fried M, et al. Practice and complications of liver biopsy. Dig Dis Sci. 1993;38(8):1480-1484. [pmid: 8344104].
194 Janes CH, Lindor KD. Outcomes of patients hospitalized for complications after outpatient liver biopsy. Ann Intern Med. 1993;118:96-98. [pmid: 8416324].
195 Gilmore IT, Burroughs A, Murray-Lyon IM, et al. Indications, methods, and outcomes of percutaneous liver biopsy in England and Wales. Gut. 1995;36:437-441. [pmid: 7698705]. [pmcid: 1382461].
196 Cadranel JF, Rufat P, Degos F. Practices of liver biopsy in France: results of a prospective nationwide survey. Hepatology. 2000;32:477-481. [pmid: 10960438].
197 McGill DB, Rakela J, Zinsmeister AR, et al. A 21-year experience with major hemorrhage after percutaneous liver biopsy. Gastroenterology. 1990;99:1396-1400. [pmid: 2101588].
198 Saadeh S, Cammell G, Carey WD, et al. The role of liver biopsy in chronic hepatitis C. Hepatology. 2001;33:196-200. [pmid: 11124836].
199 Farrell RJ, Smiddy PF, Pilkington RM, et al. Guided versus blind liver biopsy for chronic hepatitis C: clinical benefits and costs. J Hepatol. 1999;30:580-587. [pmid: 10207798].
200 Vautier G, Scott B, Jenkins D. Liver biopsy: blind or guided?. BMJ. 1994;309:1455-1456. [pmid: 7804036]. [pmcid: 2541611].
201 Pasha T, Gabriel S, Therneau T, et al. Cost-effectiveness of ultrasound-guided liver biopsy. Hepatology. 1998;27(5):1220-1226. [pmid: 9581674].
202 Caturelli E, Giacobbe A, Facciorusso D, et al. Percutaneous biopsy in diffuse liver disease: increasing diagnostic yield and decreasing complication rate by routine ultrasound assessment of puncture site. Am J Gastroenterol. 1996;91(7):1318-1321. [pmid: 8677986].
203 Lindor KD, Bru C, Jorgensen RA, et al. The role of ultrasonography and automatic-needle biopsy in outpatient percutaneous liver biopsy. Hepatology. 1996;23:1079-1083. [pmid: 8621137].
204 Hoofnagle JH, di Bisceglie AM. The treatment of chronic viral hepatitis. N Engl J Med. 1997;336(5):347-56. [pmid: 9011789].
205 Poynard T, Leroy V, Cohard M, et al. Meta-analysis of interferon randomized trials in the treatment of viral hepatitis C: effects of dose and duration. Hepatology. 1996;24(4):778-89. [pmid: 8855176].
206 Kjaergard LL, Krogsgaard K, Gluud C. Interferon alfa with or without ribavirin for chronic hepatitis C: systematic review of randomised trials. BMJ. 2001;323(7322):1151-5. [pmid: 11711405]. [pmcid: 59848].
207 Chander G, Sulkowski MS, Jenckes MW, et al. Treatment of chronic hepatitis C: a systematic review. Hepatology. 2002;36:S135-S144. [pmid: 12407587].
208 Shepherd J, Waugh N, Hewitson P. Combination therapy (interferon alfa and ribavirin) in the treatment of chronic hepatitis C: a rapid and systematic review. Health Technol Assess. 2000;4(33):1-67. [pmid: 11134916].
209 Hoofnagle JH. Management of hepatitis C: current and future perspectives. J Hepatol. 1999;31(Suppl 1):264-8. [pmid: 10622600].
210 Fried MW, Shiffman ML, Reddy KR, et al. Peginterferon Alfa-2a plus ribavirin for chronic hepatitis C virus infections. N Engl J Med. 2002;347(13):975-82. [pmid: 12324553].
211 Manns MP, McHutchison JG, Gordon SC, et al. Peginterferon alfa-2b plus ribavirin compared with interferon alfa-2b plus ribavirin for initial treatment of chronic hepatitis C: a randomised trial. Lancet. 2001;358(9286):958-65. [pmid: 11583749].
212 Glue P, Rouzier-Panis R, Raffanel C, et al. A dose-ranging study of pegylated interferon alfa-2b and ribavirin in chronic hepatitis C. The Hepatitis C Intervention Therapy Group. Hepatology. 2000;32(3):647-53. [pmid: 10960463].
213 Heathcote EJ, Shiffman ML, Cooksley WG, et al. Peginterferon alfa-2a in patients with chronic hepatitis C and cirrhosis. N Engl J Med. 2000;343(23):1673-80. [pmid: 11106716].
214 Lindsay KL, Trepo C, Heintges T, et al. A randomized, double-blind trial comparing pegylated interferon alfa-2b to interferon alfa-2b as initial treatment for chronic hepatitis C. Hepatology. 2001;34(2):395-403. [pmid: 11481625].
215 Reddy KR, Wright TL, Pockros PJ, et al. Efficacy and safety of pegylated (40-kd) interferon alpha-2a compared with interferon alpha-2a in noncirrhotic patients with chronic hepatitis C. Hepatology. 2001;33(2):433-8. [pmid: 11172346].
216 Zeuzem S, Feinman SV, Rasenack J, et al. Peginterferon alfa-2a in patients with chronic hepatitis C. N Engl J Med. 2000;343(23):1666-72. [pmid: 11106715].
217 Nishiguchi S, Shiomi S, Nakatani S, et al. Prevention of hepatocellular carcinoma in patients with chronic active hepatitis C and cirrhosis. Lancet. 2001;357(9251):196-7. [pmid: 11213099].
218 Chemello L, Cavalletto L, Bernardinello E, et al. Comparison of thrice weekly vs daily human leucocyte interferon-alpha therapy for chronic hepatitis C. TVVH Study Group. J Viral Hepat. 1999;6(4):321-7. [pmid: 10607247].
219 Bernardinello E, Cavalletto L, Chemello L, et al. Long-term clinical outcome after beta-interferon therapy in cirrhotic patients with chronic hepatitis C. TVVH Study Group. Hepato Gastroenterology. 1999;46(30):3216-22. [pmid: 10626189].
220 Perez R, Pravia R, Linares A, et al. Clinical efficacy of intramuscular human interferon-beta vs interferon-alpha 2b for the treatment of chronic hepatitis C. J Viral Hepat. 1995;2(2):103-6. [pmid: 7493297].
221 Villa E, Trande P, Grottola A, et al. Alpha but not beta interferon is useful in chronic active hepatitis due to hepatitis C virus. A prospective, double-blind, randomized study. Dig Dis Sci. 1996;41(6):1241-7. [pmid: 8654159].
222 Davis Gl, Balart LA, Schiff ER, et al. Assessing health-related quality of life in chronic hepatitis C using the Sickness Impact Profile. Clin Ther. 1994;16(2):334-43. [pmid: 8062327].
223 Seeff LB. Natural history of hepatitis C. Am J Med. 1999;107(6B):10S-15S. [pmid: 10653449].
224 Keeffe EB, Iwarson S, McMahon BJ, et al. Safety and immunogenicity of hepatitis A vaccine in patients with chronic liver disease. Hepatology. 1998;27(3):881-6. [pmid: 9500723].
225 Vento S, Garofano T, Renzini C, et al. Fulminant hepatitis associated with hepatitis A virus superinfection in patients with chronic hepatitis C. N Engl J Med. 1998;338(5):286-90. [pmid: 9445408].
226 Hasle G, Hoel T, Jensenius M. Mortality of hepatitis A in adults with hepatitis C antibodies. Lancet. 1998;351:1888. [pmid: 9652695].
227 Mele A, Tosti ME, Stroffolini T. Hepatitis associated with hepatitis A superinfection in patients with chronic hepatitis C. N Engl J Med. 1998;338(24):1771-1772. [pmid: 9625635].
228 Myers RP, Gregor JC, Marotta PJ. The cost-effectiveness of hepatitis A vaccination in patients with chronic hepatitis C. Hepatology. 2000;31(4):834-839. [pmid: 10733536].
229 Jacobs RJ, Koff RS, Meyerhoff AS. The cost-effectiveness of vaccinating chronic hepatitis C patients against hepatitis A. Am J Gastroenterol. 2002;97(2):427-34. [pmid: 11866283].
230 Arguedas MR, Heudebert GR, Fallon MB, et al. The cost-effectiveness of hepatitis A vaccination in patients with chronic hepatitis C viral infection in the United States. Am J Gastroenterol. 2002;97(3):721-8. [pmid: 11922569].
231 Nalpas B, Martin S, Fontaine H, et al. Impact of medical recommendations on alcohol consumption in HCV positive patients. J Hepatol. 2001;35(2):312-313. [pmid: 11580161].
232 Ompad DC, Fuller CM, Vlahov D, et al. Lack of behavior change after disclosure of hepatitis C virus infection among young injection drug uses in Baltimore, Maryland. Clin Infect Dis. 2002;35(7):783-788. [pmid: 12228813].
233 Ikeda K, Saitoh S, Arase Y, et al. Effect of interferon therapy on hepatocellular carcinogenesis in patients with chronic hepatitis type C: A long-term observation study of 1,643 patients using statistical bias correction with proportional hazard analysis. Hepatology. 1999;29(4):1124-30. [pmid: 10094956].
234 Bernstein D, Kleinman L, Barker CM, et al. Relationship of health-related quality of life to treatment adherence and sustained response in chronic hepatitis C patients. Hepatology. 2002;35(3):704-8. [pmid: 11870387].
235 Bonkovsky HL, Woolley JM, et al. Reduction of health-related quality of life in chronic hepatitis C and improvement with interferon therapy.The Consensus Interferon Study Group. Hepatology. 1999;29(1):264-70. [pmid: 9862876].
236 McHutchison JG, Ware JE Jr., Bayliss MS, et al. The effects of interferon alpha-2b in combination with ribavirin on health related quality of life and work productivity. J Hepatol. 2001;34(1):140-7. [pmid: 11211891].
237 Ware, J, Snow, K, Kosinski, M, et al. SF-36 Health Survey: Manual and Interpretation Guide. Boston: The Health Institute, New England Medical Center; 1993.
238 Samsa G, Edelman D, Rothman M, et al. Determining clinical important differences in health status measures. Pharmacoeconomics. 1999;15:141-155. [pmid: 10351188].
239 Strader DB. Understudied populations with hepatitis C. Hepatology. 2002;36:S226-S236. [pmid: 12407598].