# Evidence Tables

Evidence Table 1a. Intermediate outcomes

Author Year | Type of study, Setting | Aims | Study Duration | Eligibility Criteria | Exclusion Criteria | Screened/Eligible/ Enrolled Population | Withdrawals or lost to follow-up (%) Analyzed | Baseline liver disease | Method of Outcome Assessment and Timing of Assessment | Intervention + Control | Biochemical Response | | Virologic Response | | Histologic Response | | Variables associated with response | Adverse Events | Funding Source and Role | Internal Validity Rating | Relevance to screening | Comments
Pegylated Interferon plus Ribavarin | | | | | | | | | | | ETR | SR | TR | SR | Inflam | fibro | Pegylated Interferon plus Ribavarin
Fried 2002^210^ | RCT | To assess the efficacy of peginterferon alfa-2a plus ribavirin as compared to interferon alfa-2b plus ribavirin or to peginterfeon alfa-2a alone | 48 wks treatment | Adults with ≥ 2000 copies of HCV RNA by PCR, elevated ALT levels within 6 mo., liver biopsy consistent with chronic HCV, no previous interferon treatment | Neutropenia, thrombocytopenia, anemia, HIC, decomensatied liver disease, serum creatinine > 1.5 × normal, poorly controlled psychiatric disease, alcohol or drug dependence within one year, substantial coexisting medical condition | 1459/NR/1149 | 28 randomized but did not receive any study medication for multiple reasons including ineligibility and refusal of treatment. All persons receiving one dose of medicine included in final analysis. If <20 weeks follow up, counted as having no response to treatment | Genotype 1: 62% | HCV RNA: weeks 12, 72 | a INF alfa-2b 3 MU 3×/wk + RIB 1000–1200 mg/d; b PEG INF alfa-2a 180 ug/kg q wk; c PEG INF alfa-2a 180 ug/kg q wk + RIB 1000–1200 mg/d | N/A | N/A | 52% | 44% | N/A | N/A | Best treatment results if genotype other than 1, age of 40 or less, body weight 75 kg or less | Dose Reduction: 83+181/68+48/159+203(???) | Hoffman-LaRoche, Univ. of N. Carolina Gen. Clin. Rsrch. Cntrs., and NIH. Sponsors involved in analysis of data. Authors had full access to the data and the decision to publish was not limited by the sponsor. | Good | Good | Sponsor, investigators, and patients blind to whether patients receiving PEG INF received RIB or placebo.
| Multicenter (81) in USA, Europe, Austraila, Brazil | | 24 wks follow-up | | | Male: 71% | 1121 analyzed | ALT: 90 U/L | Safety assessment at weeks 1, 2, 4, 6, 8, 12, 16, 20, 24, 28, 32, 36, 40, 44, 48, 52, 60, 72 | | | | 59% | 29% | | | | Dose Discontinuation: 140 (22%)/72(32%)/100(32%) | | | | Randomization stratified by country and by genotype (1 vs. other).
| | | | | | Mean age: 42.5 years | | HCV RNA: 6.0 × 10*6 | | | | | 69% | 56% | | | | Fatigue: 55/44/54% | | | | Genotype 1 SVR 36% vs 21% vs 46% (a/b/c)
| | | | | | Range: NR | | Cirrhosis or bridging fibrosis: 13% | | | | | (a vs c p<0.001) | (a vs c, b vs c p<0.001) | | | | Headache: 52/51/47%
| | | | | | Race: 84% White | | Source: | | | | | (b vs c p=0.001) | | | | | Fever: 56/38/43%
| | | | | | | | Transfusion: 20% | | | | | | | | | | Myalgia: 50/42/42%
| | | | | | | | IVDU: 40% | | | | | | | | | | Nausea: 33/26/29%
| | | | | | | | | | | | | | | | | | Depression: 30/20/22%
| | | | | | | | | | | | | | | | | | Dermatitis: 22/11/21%
| | | | | | | | | | | | | | | | | | Deaths: 3, none thought to be related to treatment
Glue 2000^212^ | RCT | To assess the safety, tolerability, pharmacokinetics and pharmacodynamics of combined pegylated interferon and ribavirin | 24 wks treatment | Adults with compensated chronic HCV, postive HCV RNA by PCR, recent liver biopsy consistent with chronic hepatitis | HIV, Hep B, significant other medical or psychiatric illness, substance abuse, uncompensated liver disease, other causes of liver disease, previous treatment for HCV | NR/NR/72 | 5 withdrawals: | Genotype 1: 44% | HCV-RNA: weeks 0, 1, 4, 12, 24, 28, 36, 48 | a PEG INF 2b 0.35 ug/gk q wk; b PEG INF 2b 0.70 ug/kg q wk; c PEG INF 2b 1.40 ug/kg q wk; d PEG INF 2b 0.35 ug/kg q wk + RIB 600–800 mg/d; e PEG INF 2b 0.70 ug/kg q wk + RIB 600–1200 mg/d; f PEG INF 2b 1.40 ug/kg q wk + RIB 600–1200 mg/d | N/A | N/A | 50% | 0% | N/A | N/A | N/A | Dose Reduction: NR | Schering Plough Research Institute, employer of lead author | Fair | Unclear | Drug dosing study
| France | | 24 wks follow-up | | | Male: 49% | 1 neutropenia | | | | | | 63% | 44% | | | | Dose Discontinued: 1 (tx group not specified)
| | | | | | Mean age: 39.8 years | 2 alcohol abuse | | | | | | 50% | 42% | | | | Flu symptoms: 17–44%
| | | | | | Range: 20–68 | 2 personal reasons | | | | | | 58% | 17% | | | | Headache: 50–56%
| | | | | | Race: NR | 72 analyzed | | | | | | 69% | 53% | | | | Asthenia: 0–22%
| | | | | | | | | | | | | 81% | 60% | | | | Mean Hgb reduction: 1.5/2/2.5 g/dL
Manns 2001^211^ | RCT | To assess the safety and efficacy of two regiments of PEG INF and ribavirin, and to identify predictors of response | 48 wks treatment | Adults, previously untreated, positive HCV RNA by PCR, recent liver biopsy consistent with chronic hepatitis, elevated ALT | Decompensated cirrhosis, other causes of liver disease, HIV, organ transplantation, significant other medical or psychiatric conditions, unable to take contraception | 2316/NR/1530 | 1530 analyzed | Genotype 1: 68% | HCV RNA: weeks 0, 4, 12, 24, 36, 48, 12, 24 | a INF 2b 1.5 ug/kg 3×/wk + RIB 1000–1200 mg/d; b PEG INF 2b 1.5 ug/kg q wk × 4 wks then 0.5 ug/kg × 44 wks + RIB 1000–1200 mg/day × 48 wks; c PEG INF 2b 1.5 ug/kg q wk+ RIB 800 mg/d × 48 wks | 69% | 47% | 54% | 47% | 69% | 20% | Best treatment result with genotype other than 1, lower viral, lighter weight, female gender, younger age, absence of cirrhosis | Dose Reduction: 34/36/42% | Schering Plough sponsor; role not specified | Good | Fair
| Multicenter (62) in Europe, Canada, Argentina, USA | | 24 wks follow-up | | | Male: 66% | | ALT: 2.3 × nl | Liver biopsy: Knodell index, at the end of the follow-up period | | 63% | 48% | 56% | 47% | 70% | 19% | | Dose Discontinued: 13/13/14%
| | | | | | Mean age: 43 years | | HCV RNA: 2.7 × 10*6 | | | 65% | 54% | 65% | 54% | 68% | 21% | | Fatigue: 60/62/64%
| | | | | | Range: 21–68 | | Histology: 7.9 (Knodell) | | | | | (a vs c p<0.001) | (a vs c p=0.01) | | | | Headache: 58/58/62%
| | | | | | Race: NR | | Cirrhosis: 29% | | | | | | | | | | Myalgia: 50/48/56%
| | | | | | | | Source: | | | | | | | | | | Fever: 33/44/46%
| | | | | | | | Transfusion: 22% | | | | | | | | | | Diarrhea: 17/16/22%
| | | | | | | | IVDU: 65% | | | | | | | | | | Depression: 34/29/31%
| | | | | | | | | | | | | | | | | | Injection site reaction: 36/59/58%
| | | | | | | | | | | | | | | | | | Deaths: 0
Pegylated Interferon | | | | | | | | | | | | | | | | | Pegylated Interferon
Heathcote 2000^213^ | RCT | To compare the efficacy and safety of two doses of PEG INF alfa-2a with standard INF theray in HCV patients with cirrhosis or bridging fibrosis | 48 wks treatment | Adults, chronic HCV, biopsy-proven cirrhosis or bridging fibrosis, not perviously treated, ALT abnormal 2× in past 6 mo, biopsy done within past year | Presence of other liver diseases, decompensated cirrhosis, HIV, medical or psychiatric conditions | 397/271/271 | 50 withdrew (18.5%) | Genotype 1: 56% | HCV RNA: weeks 1, 2, 4, 6, 8, and q 4 wks till end | a INF alfa-2a 3 MU 3×/wk; b PEG INF 90 ug q wk; c PEG INF 180 ug q wk | 22% | 15% | 14% | 8% | 31% | N/A | Best result with genotype other than 1 | Dose Reduction: 14/2/14% | Hoffmann-LaRoche designed trial, monitored adherence to guidelines, and monitored analysis | Fair | Unclear | Emphasis on cirrhotic patients may not apply to asymptomatic general population
| Multicenter (30) in USA, Canada, Austraila, UK | | 24 wks follow-up | | | Male: 72% | 271 analyzed | ALT: 110 U/L | ALT levels | | 35% | 20% | 42% | 15% | 44% | | | Dose Discontinued: 8/7/13%
| | | | | | Mean age: 47 yrs | | HCV RNA: 6.1×10*6 | viral genotyping | | 39% | 34% | 44% | 30% | 54% | | | Fatigue: 52/51/53%
| | | | | | Range: NR | | Histology: 13 (HAI) | Histologic eval: biopsy at 72 wks, Histological Activity Index | | (a vs c p = 0.02) | (a vs c p=0.004) | (a vs c p=0.001) | (a vs c p=0.001) | (a vs c p=0.02) | | | Headache: 46/52/43%
| | | | | | Race: 88% White | | Cirrhosis: 78% | Safety assessment | | | | | | | | | Myalgia: 33/35/44%
| | | | | | Weight: 79 kg | | Source: | | | | | | | | | | Fever: 31/28/33%
| | | | | | | | Transfusion: 25% | | | | | | | | | | Diarrhea: 16/20/21%
| | | | | | | | IVDU: 48% | | | | | | | | | | Depression: 18/20/21%
| | | | | | | | | | | | | | | | | | Injection site reaction: 12/14/27%
| | | | | | | | | | | | | | | | | | Death: 0/1/3(#)
Lindsay 2001^214^ | RCT | To evaluate the safety and efficacy of PEG INF as compared to INF in adult patients with chronic HCV not previously treated | 48 wks treatment | Adults, chronic HCV, compensated liver disease, positive HCV RNA, liver biopsy within past year, abnormal ALT 1× in past 6 mo | Any other cause for liver disease, HIV, substance abuse, preexisting medical condition that might interfere with tx, hemophilia, hemoglbnpths, breastfeeding, nonpregnant, using contraception | NR/NR/1224 | 1219 analyzed | Genotype 1: 70% | HCV RNA: weeks 4, 12, 24, 36, 48, 52, 60, 72 | a INF alfa-2b 3MU 3×/wk; b PEG INF alfa-2b 0.5 ug/kg q wk; c PEG INF alfa-2b 1.0 ug/kg q wk; d PEG INF alfa-2b 1.5 ug/kg q wk | 20% * | 12% * | 24% | 12% | 47% | | Best result with genotype other than 1, baseline HCV RNA < 2 million copies | Dose Reduction: 6/9/14/19% | Schering Plough, U of Southern California | Good | Unclear
| Multicenter (53) USA, Europe, Australia | | 24 wks follow-up | | | Male: 63% | 5 withdrew before receiving treatment for reasons unrelated to study | ALT: 2.3 × nl | ALT levels | | 25% | 17% | 33% | 18% | 49% | | | Dose Discontinued: 6/9/11/9%
| | | | | | Mean age: 43 yrs | 23% withdrew | HCV RNA: 3.4×10*6 | Histologic eval: biopsy at 72 wks, Histological Activity Index | | 31% | 24% | 41% | 25% | 50% | | | Fatigue: 50/43/51/45%
| | | | | | Range: 18–73 | | Histology: 6.9 (HAI) | Safety assessment | | 33% | 23% | 49% | 23% | 48% | | | Headache: 58/61/64/64%
| | | | | | Race: 91% White | | Cirrhosis: 3.5% | | | (a vs d, p<0.001, a vs c, p=0.002, a vs b, p=0.14) | (a vs d, a vs c, p<0.001, a vs b, p=0.13) | (a vs d, a vs c p<0.001, a vs b p=0.01) | (a vs d, a vs c p<0.001, a vs b p=0.04) | (NS) | | | Myalgia: 53/48/54/61%
| | | | | | Weight: 80 kg | | Source: | | | | | | | (61% of all subjects) | | | Fever: 30/31/45/44%
| | | | | | | | Transfusion: 21% | | | | | | | | | | Nausea: 20/21/26/25%
| | | | | | | | IVDU: 48% | | | | | | | | | | Irritability: 24/19/18/17%
| | | | | | | | Years since exposed: 19 | | | | | | | | | | Injection site reaction: 16/44/42/40%
| | | | | | | | | | | | | | | | | | Deaths: 0
Reddy 2001^215^ | RCT | To evaluate the safety and efficacy of 4 doses of PEG INF alfa-2a as compared to INF alfa-2a. Primary intent is to establish the most appropriate dose of PEG INF for future trials | 48 wks treatment | Adults, chronic HCV, not previously treated, without cirroshis or bridging fibrosis on biopsy, ALT abnormal 2× at least 2 wks apart, biopsy within past year, positive HCV Ab test | Liver disease from other causes, neutropenia, thrombocytopenia, renal damage, hx of preexisting medical or psychiatric illness, current pregnancy or breastfeeding, alcohol or drug dependence within previous 12 months, administration of antineoplastic, immunomodulatory, antiviral, investigational compounds | NR/NR/159 | 159 analyzed | Genotype 1: 73% | HCV RNA: wks 1, 2, 4, 6, 8 and every 4 wks until end | a INF alfa-2a 3 MU 3×/wk; b PEG INF alfa-2a 45 ug q wk; c PEG INF alfa-2a 90 ug q wk; d PEG INF alfa-2a 180 ug q wk; e PEG INF alfa-2a 270 ug q wk | 15% | 9% | 12% | 3% | 57% | | NR | Dose Reduction: “similar” except for treatment d (12%) | Hoffmann-La Roche, role not specified | Fair | Unclear | Dosing study; design permitted differences in treatment group characteristics, limiting the validity of the results
| Multicenter, USA | | 24 wks follow-up | | | Male: 76% | | ALT: 96 | ALT levels | | 20% | 10% | 30% | 10% | 47% | | | Dose D/C: 10/0/22/20%
| | | | | | Mean age: 42 | | HCV RNA: 2.2×10*6 | Viral Genotype | | 20% | 25% | 45% | 30% | 59% | | | Fatigue: 21/14/12/30/28%
| | | | | | Range: NR | | Cirrhosis: 10% | Histologic eval: biopsy at 72 wks, HAI score | | 38% | 38% | 60% | 36% | 63% | | | Headache: 18/8/7/26/19%
| | | | | | Race: 88% white | | Source: NR | Safety assessment | | 27% | 27% | 56% | 29% | 66% | | | Myalgia: 19/8/13/14/19%
| | | | | | Weight: 86 kg | | | | | (a vs d, p=0.04) | (a vs d p=0.004) | (a vs c, p=0.01, a vs d, a vs e, p<0.0001) | (a vs c, p=0.009, a vs d, p=0.0006, a vs e p=0.004) | | | | Fever: 9/3/2/11/11%
| | | | | | | | | | | | | | | | | | Diarrhea: 6/5/5/14/13%
| | | | | | | | | | | | | | | | | | Depression: 3/6/7/12/15%
| | | | | | | | | | | | | | | | | | Injection site reaction: 6/7/6/11/10%
| | | | | | | | | | | | | | | | | | Deaths: 0
Zeuzem 2000^216^ | RCT | To compare the efficacy and safety of PEG INF and INF, and establish equivalent doses | 48 wks treatment | Adults, not previously treated with interferon, positive HCV Ab, HCV RNA > 2000 copies, ALT abnl 2× in past 6 mo, liver biopsy consistent with chronic hepatitis, biopsy performed within past year | Neutropenia, thrombocytopenia, abnormal kidney function, evidence of other liver disease, HIV, decompensated liver disease, organ transplant, cancer, severe cardiac or pulmonary disease, or other significant medical problem, not on contraception | 613/531/531 | 61 (23%) withdrew from PEG INF | Genotype 1: 30% | HCV RNA, 0, 2, 4, 6, 8, then q 4 wks until 72 wks | a INF alfa-2a 6 MU 3×/wk × 12 wks, then 3 MU 3×/wk × 36 wks; b PEG INF alfa-2a 180 ug q wk × 48 wks | 39% | 24% | 28% | 19% | 55% | | Yonger age, smaller body surface area, lower HCV RNA, higher ALT, not cirrhotic, HCV genotype other than 1 | Dose Reduction: 51/47% | Hoffmann-LaRoche designed study, analyzed data in conjunction with the authors | Fair | Unclear | Large, differential withdrawal, substantial number of INF withdrawals for “insufficient therapeutic response”
| Multicenter (36) Australia, Canada, Germany, Mexico, New Zealand, Spain, Switzerland, Taiwan, and the UK | | 24 wks follow-up | | | Male: 67% | 110 (42%) withdrew from INF | ALT: 139 | ALT | | 46% | 45% | 69% | 39% | 63% | | | Dose Discontinued: 10/7%
| | | | | | Age: 41 yrs | 531 analyzed | HCV RNA: 7.8×10*6 | Genotype | | (NS) | (p=0.001) | (p=0.001) | (p=0.001) | | | | Fatigue: 60/65%
| | | | | | Range: NR | | Histology: 8.8 HAI score | Histology from biosy at 72 wks, HAI score used | | | | | | | | | Headache: 60/66%
| | | | | | Race: 85.5% White | | Cirrhosis: 13.5 (includes bridging fibrosis) | Adverse events | | | | | | | | | Myalgia: 42/43%
| | | | | | Weight: 75 kg | | Source: | | | | | | | | | | Fever: 37/52%
| | | | | | | | Transfusion: 23% | | | | | | | | | | Diarrhea: 19/20%
| | | | | | | | IVDU: 37% | | | | | | | | | | Depression: 16/23%
| | | | | | | | | | | | | | | | | | Injection site reaction: 5/11%
| | | | | | | | | | | | | | | | | | Deaths: 1 (unrelated to tx)

* Combined biochemical and virological response

ETR=end of treatment response; SR=sustained response; Inflam=inflammation; Fibro=fibrosis; NR=not reported; RCT=randomized controlled trial; HCV=hepatitis C virus;

HCV RNA=hepatitis C ribonucleic acid; PCR=polymerase chain reaction; ALT=alanine aminotransferase; RIB=ribavirin; PEG INF=pegylated interferon; INF=interferon; HIV=human immunodeficiency virus

Evidence Table 1b. Quality of RCTs for treatment—intermediate outcomes

Author Year | Random assignment? | Allocation concealed? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors blinded? | Patient unaware of treatment? | Intention to treat analysis? | Maintenance of comparable groups? | Reporting of attrition, crossovers, adherence, and contamination? | Differential loss to follow up or high loss? | Statistical analysis appropriate? | Internal Validity Rating
Pegylated Interferon plus Ribavarin
Fried 2002^210^ | Yes, in blocks of 5 | Not reported | Yes | Yes | For PEG INF (RIB vs. Placebo) but not for PEG INF vs. INF | For PEG INF (RIB vs. Placebo) but not for PEG INF vs. INF | Yes | Yes | Yes | High overall loss (22% PEG+RIB, 32% INF+RIB, 32% PEG alone) | Yes | Good
Glue 2000^212^ | Yes, by individual | No | Not stated, were not similar % genotype 1 or viral load | Yes | No | No | Not done, but calculable | Groups maintained, however not certain if similar at baseline | Yes | No | No | Fair
Manns 2001^211^ | Yes, in blocks of 3 | Yes, centralized | Yes | Yes | Pathologist blinded for post treatment biopsy evaluation | No | Yes | Yes | Yes | No | Yes | Good
Pegylated Interferon
Heathcote 2000^213^ | Yes, in blocks of 6 | Yes, centralized | Yes | Yes | Pathologist blinded for post treatment biopsy evaluation | No | Yes, except for histology | Yes | Yes | No | Yes | Fair
Lindsay 2001^214^ | Yes, method not clarified | Not clarified | More genotype 1 in PEG INF 1.5 group, (p=0.09), otherwise similar | Yes | Yes | Yes | Yes, except for histology | Yes | Partially | Non differential, high loss (23%) | Yes | Good
Reddy 2001^215^ | Yes, by individual | Not clarified | Gender, race, % genotype 1, ALT levels, HCV RNA levels, cirrhosis % differences | Yes | Pathologist blinded for post treatment biopsy evaluation | No | Yes, except for histology | Not similar at baseline | No | Non differential, high loss (23%) | OK | Fair
Zeuzem 2000^216^ | Yes, by individual | Not clarified | Difference in HCV RNA levels, otherwise similar | Yes | No | No | Yes, except for histology | Uncertain | Partially | Large, differential loss (23% PEG, 42% INF) | Yes | Fair

HCV=hepatitis C virus; HCV RNA=hepatitis C ribonucleic acid; ALT=alanine aminotransferase; PEG INF=pegylated interferon; INF=interferon

Evidence Table 2. Interferon plus ribavirin intermediate outcomes

Author Year | Aims | Time period covered and sources used in literature search | Eligibility Criteria | Exclusion Criteria | Funding Source and Role | Method of appraisal | Characteristics of identified articles | Population Characteristics | Results (95% CI) | Variables associated with response | Adverse Events | Internal Validity Rating | Relevance to screening
Interferon plus Ribavarin
Reviews
Gebo 2002^107^ | To determine the most effective therapy for HCV | Used data from Kjaergard, added additional articles found from September 2000 - March 2002 | RCTs with planned follow up at least 24 weeks after the end of treatment, written in English, human, original data | Meeting abstracts and other incomplete reports | US government | Used standardized template. All article titles read and assessed by two reviewers. All articles read and assessed by two reviewers. | Kjaergard, 2000, used to summarize material prior to September 2000. 4 additional articles identified after that date. | 4 additional articles heterogenous with respect to treatment regemen, dose, and duration. | In general, there is good data to support an increased benefit from combination therapy over interferon alone. There were some inconsistencies in the additional four studies reviewed independently of the Kjaergard review, however, these studies were heterogenous with respect to patient population and study design. The magnitude of the relative treatment effect may depend on the dose and duration of treatment. | | See Kjaergard | Good | Good
| | MEDLINE, Biological Abstracts, Science Citation Index, Manual Alternative and Natural Therapy, Allied and Complementatry Medicine Database, CAB Health, PsychINFO, Sociological Abstracts, manual searches
Kjaergard 2001^206^ | To assess the efficacy and safety of interferon with and without ribavirin for naïve patients, relapsers, and non-repsonders with chronic HCV. | 1966-August 2000 | Trials in which patients with chronic HCV were randomized to INF-alfa plus RIB versus INF-alfa alone; patients were naïve, non-responders, or relapsers. | Hep B, HIV, hepatic decompensation | Danish governmental grants | Used standard template. All articles read and assessed by two reviewers. | 15 RCTs of naïve patients. | Articles heterogenous in terms of treatment regemens, dose, and duration of treatment. | RR no ETBR: 0.63 (0.58–0.70) | Not cirrhotic, longer treatment duration more likely to improve. | Dose Reduction: 2.44 1.58–3.75 | Good | Good
| | Cochrane Hepato-Biliary Group, Cochrane Library, EMBASE, MEDLINE, hand search of specialist journals and bibliographies, authors of included trials, pharmaceutical companies | | | | | | | RR no SBR: 0.78 (0.64–0.94) | | Dose Discontinued: 1.28 (1.07–1.52)
| | | | | | | | | RR no SVR: 0.75 (0.65–0.79) | | Anemia: 16.67 (5.68–48.89
| | | | | | | | | RR no HAI improvment: 0.83 (0.74–0.93) | | Cough: 1.66 (1.19–2.37)
| | | | | | | | | | | Dyspepsia: 1.72 (1.17–2.54)
| | | | | | | | | | | Leukopenia: 4.52 (1.55–13.23)
| | | | | | | | | | | Cirrhosis: 6 combo and 12 INF
| | | | | | | | | | | HCC: 0 combo, 1 INF
| | | | | | | | | | | Transplants: none
| | | | | | | | | | | Deaths: 2 INF pts died (1 suicide, 1 accidental), 1 combo died (accidental)
Shepherd 2000^208^ | To review the clinical and cost-effectiveness of combination therapy in patients with HCV | 1993-1999 | RCTs or systematic reviews of RCTs evaluating interferon alfa and ribavirin compared with interferon alfa alone or with placebo | Non-randomized studies, abstracts only | Governmental grant | Used standized template. Quality assessment assigned by one reviewer. Another reviewer checked these results and disagreements were resolved through discussion. | 19 RCTs identified, 2 meta-analyses. | Quality of studies variable, though larger studies were of high quality. | SVR, 24 wks tx combo vs INF: 33% vs. 6% (p<0.05) | | Dose Reduction: 9–26% (NS) | Good | Fair
| | Cochrane Controlled Trials Register, Database of Abstracts of Reviews of Effectiveness, Cochrane Database of Systematic Reviews, MEDLINE, PreMEDLINE, EMBASE, reference lists | | | | | | | SVR, 48 wks tx combo vs INF: 41% vs 16% (p<0.05) | | Dose Discontinued: 8–21% (NS)
| | | | | | | | | RR SVR: 4.90 (2.63–9.13) | | Flu symptoms: 63–67% (NS)
| | | | | | | | | | | GI symptoms: 19–25% (NS)
| | | | | | | | | | | Psychiatric symptoms: 32–37% (NS)
| | | | | | | | | | | Respiratory symptoms: 9–15% (NS)
| | | | | | | | | | | Dermatalogic symptoms: 28–32% (NS)

CI=confidence interval; HCV=hepatitis C virus;; INF=interferon; RIB=ribavirin; HIV=human immunodeficiency virus; RCT=randomized controlled trial; RR=relative risk; ETBR=end of treatment biochemical response; SBR=sustained biochemical response; SVR=sustained virological response; HAI=histologic activity index; HCC=hepatocellular carcinoma; tx=treatment

Evidence Table 3a. Long term outcomes

Author Year | Type of study, Setting | Aims | Duration of follow up after study | Eligibility Criteria | Exclusion Criteria | Screened/Eligible/Enrolled Population | Withdrawals or lost to follow-up (%) Analyzed | Baseline liver disease | Method of Outcome Assessment and Timing of Assessment | Intervention + Control | Biochemical Response | | Virological response | | Long term outcomes | Adverse Effects | Funding Source and Role | Internal Validity Rating | Relevance to screening | Comments
Interferon only
RCTs | | | | | | | | | | | ETR | SR | ETR | SR | RCTs
Bernardinello 1999^219^ | RCT | To describe the long-term results of an RCT done to evaluate INF-beta. | Up to 5 years | Chronic HCV, anit-HCV positive, HCV-RNA positive, 2× normal ALT, liver biopsy consistent with activer cirrhosis, 18–65 years old, informed consent | Portal HTN with varices at risk of bleeding, Child C cirrhosis, previous episode of hepatic decompensation, ascites, thrombocytopenia, WBC<2000, alcohol abuse, cardiac/renal dysfunction, autoimmune/thyroid disease | NR/NR/61 | Analyzed: 61 | Genotype 1: 73% | Assessed hematological, biochemical and virological parameters q month × 3 months then q 6 months. Also had an US of liver q 6 months, and had an EGD q 6 months during tx and q 12 months until end of study. | a) INF-beta IM 6 MU/tiw × 6 m then 3 MU/tiw × 6 mo; b) no treatment | 13% | 11% | 11% | 3% | Probability of developing clinically significant liver related events: NS | Drop out: none due to sx | Grant from Regione Veneto, Ricerca Sanitaria Finalizzata | Fair | Unclear | Author notes that INF-beta has been found to be less efficacious when given i.m. as it was in this study.
| Italy | | | | | Male: 54% | | ALT: 161 Ul/L | | | 9% | 9% | 0% | 0% | Cumulative probability of decompensation: 24% vs. 35% (tx vs. no tx.) | Dose redx: none
| | | | | | Mean Age: 57 yrs | | HCV RNA: NR | | | | | | | Risk of death: 9% vs. 4.4% (tx vs. no tx) | Fatigue: 24%
| | | | | | Range: NR | | Histology: 84% Child A | | | | | | | HCC: 5.3 % (2 cases) tx vs. 4.3% (1 case) no tx | Depression: 21%
| | | | | | Race: NR | | Cirrhosis: 100% | | | | | | | SR: at 60 months 5% tx vs 4% no tx had SVR, and 16% tx vs. 17% no tx had SBR. | Myalgias: 21%
| | | | | | | | Source: NR | | | | | | | | Headache: 21%
| | | | | | | | Duration of cirrhosis (presumed): 41 months | | | | | | | | Flu sx: 16%
Chemello 1999^218^ | RCT | To describe the long-term results of an RCT done to evaluate INF-alfa tiw vs. daily | Up to 6 years | 18–60 years old, ALT > 2× normal on 3 occasions 6 months prior to randomization, chronic HCV, HCV RNA positive, histologic features consistent with chronic HCV, with or without cirrhosis (Child A), a liver biopsy during 12 months prior to enrollment, no previous INF tx | other causes of liver disease, active alcohol or IVDU, autoimmune or thyroid disease, pregancy, cytopenia, cirrhosis Child B or C, history of liver decompensation or presence of portal HTN, ascites, varicies, variceal bleeding, hepatic encephalopathy, or other serious medical condition | NR/NR/149 | Analyzed: 149 | Genotype 1: 56% | Evaluated 1, 3, 6, 9 , 12 months during treatment, then anually therafter. | a) INF-alfa 3 MU/tiw × 6 m IM; b) INF-afla 3 MU qd × 3 m then tiw × 3 mo IM | 47% | 13% | 36% | 31% | Histologic improvement: NS between groups | Drop out: 9 vs 3 | Grant from the Regione Veneto, Ricerca Sanitaria Finalizzata, Italy | Fair | Unclear
| Itally | | | | | Male: 66% | 60 (49%) had follow up liver biopsy | ALT: 223 IU/L | | | 37% | 20% | 9% | 9% | 73% SR, 35% TR and 15% NR had improvement | Dose redx: NR
| | | | | | Mean Age: 48 yrs | | HCV RNA: NR | | | | | | | 0% SR, 29% TR and 43% NR had worsening | Flu sx: 29%
| | | | | | Range: NR | | Cirrhosis: 16% | | | | | | | SR: at 72 mo 9% group a and 14% group b had continued biochemical response and 9% of group a and 12% of group b had continued virological response | Myalgias: 39%
| | | | | | Race: NR | | Duration of disease: 119 mo | | | | | | | | Fatigue: 55%
| | | | | | | | | | | | | | | | Irritability: 26%
| | | | | | | | | | | | | | | | Depression: 5%
| | | | | | | | | | | | | | | | Headache: 17%
Nishiguchi 2001^217^ | RCT | To describe the long-term results of an RCT done to evaluate INF-alfa | 8.7 years | Chronic active hepatitis, with compensated Child A cirrhosis, abnormal ALT > 1 year, detectable HCV in serum | Liver disease of another etiology, thrombocytopenia, HIV, immunosuppression, autoimmune hepatitis, HCC, Hep B, alcohol use. | 136/108/90 | Analyzed: 90 | Genotype 1: 2% | Evaluated q 3 months | a) INF-alfa 6 MU/tiw × 24 wks; b) symptomatic tx. | | | 35% | 16%* | HCC: 27% (a) vs. 73% (b) (p<0.001) | Fever, flu sx, thrombocytopenia, all resolved once end of treatment reached | Ministry of Welfare, Japan | Good | Unclear
| Japan | | | | | Male: 57% | | ALT: 108 IU/L | | | | | | | Death: 11% (a) vs. 58% (b) (p<0.001)
| | | | | | Mean Age: 56 yrs | | HCV RNA: NR | | | | | | | Univariate:
| | | | | | Range: NR | | Cirrhosis: 100% | | | | | | | RR of progression to Child B: 0.302 (0.156–0.583)
| | | | | | Race: NR | | | | | | | | | RR of development of HCC: 0.244 (0.126–0.475)
| | | | | | | | | | | | | | | RR of death: 0.169 (0.065–0.440)
| | | | | | | | | | | | | | | Multivariate:
| | | | | | | | | | | | | | | RR progression to Child B: 0.250 (0.124–0.505)
| | | | | | | | | | | | | | | RR development of HCC: 0.256 (0.125–0.522)
| | | | | | | | | | | | | | | RR death: 0.135 (0.049–0.372)

* p<0.05

ETR=end of treatment response; SR=sustained response; tx=treatment; HCC=hepatocellular carcinoma; sx=symptoms; rdx=reduction; Child C=measure of abnormalities of liver histology; HCV=hepatitis C virus; HCV RNA=hepatitis C ribonucleic acid; WBC=white blood cell; NR=not reported; ALT=alanine aminotransferase

Evidence Table 3b. Quality of RCTs for long term outcomes

Author Year | Random assignment? | Allocation concealed? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors blinded? | Patient unaware of treatment? | Intention to treat analysis? | Maintenance of comparable groups? | Reporting of attrition, crossovers, adherence, and contamination? | Differential loss to follow up or high loss? | Statistical analysis appropriate? | Internal Validity Rating
Interferon
Bernardinello 1999^219^ | Yes, by computer | Not clarified | Yes | Yes | Not clarified | Not clarified, but unlikely as no placebo | Yes | Not clarified | No | Not reported | Yes | Fair
Chemello 1999^218^ | Yes, by computer | Not clarified | Yes | Yes | Pathologist blinded for post treatment biopsy evaluation | Not clarified | Yes | Not clarified | No | Not reported | Yes | Fair
Nishiguchi 1995^217^ | Yes, by computer | No | Yes | Yes | No | No | Yes | Not clarified | Yes | No | Yes | Good

RCT=randomized controlled trial

Evidence Table 4. Quality of Life

Author Year | Study Type | Sample Size | Quality of Life Measure | Treatment | Results | | | | | Blinded to treatment response | Internal Validity Rating
Pegylated Interferon versus Interferon
Bernstein 2002^234^ | Pooled analysis from 3 RCTs | 1441 | SF-36 | a) Peg INF 180 ug × 48 wks; b) INF 3 MU tiw × 48 wks or 6MU tiw × 12 wks then 3MU tiw × 36 wks | FSS | SVR | NR | Diff | p | Blinded to 24 week treatment response until after completed questionaire, but could have known prior response status | Fair (open label, loss to follow up appears high but difficult to tell; no references for trials pooled; not clear if all 1441 patients included in analysis)
| Open label study | | FFS | | TS | -0.4 | 0.1 | -0.5 | <0.001
| | | | | VAS | -9.1 | 2.4 | -11.5 | <0.001
| | | | | SF-36
| | | | | PF | 2.4 | -2.2 | 4.6 | <0.001
| | | | | PR | 8.2 | -1.6 | 9.8 | <0.001
| | | | | BP | 2.8 | -0.1 | 2.9 | <0.01
| | | | | GH | 8.5 | -3.6 | 9.1 | <0.001
| | | | | VT | 9.2 | -0.4 | 9.6 | <0.001
| | | | | SF | 4.6 | -1.6 | 6.2 | <0.001
| | | | | RE | 4.5 | -3.9 | 8.4 | <0.01
| | | | | MH | 2.5 | -2.1 | 4.6 | <0.001
| | | | | PCS | 2.2 | -0.6 | 2.8 | <0.001
| | | | | MCS | 2.0 | -1.0 | 3.0 | <0.001
Interferon + Ribavirin versus Interferon alone
McHutchinson 2001^236^ | Double blind placebo controlled RCT | 828 | HQLQ | a) INF 3 MU tiw + Placebo for 24 or 48 wks; b) INF 3 MU tiw + Ribavirin 100–1200 mg/day for 24 or 48 wks | | SVR | | | | Could have been aware of results of biochemical or virologic testing | Fair (not blinded to treatment results)
| | | SF-36 | | PF | 2.5
| | | | | RP | 5.0
| | | | | BP | 1.5 | (Values shown are the standard deviation of change from NRs.)
| | | | | GH | 5.0
| | | | | VT | 4.5
| | | | | SF | 3.0
| | | | | RE | 3.0
| | | | | MH | 2.5
| | | | | SLP | 3.5
| | | | | DIS | 5.0
| | | | | HHD | 5.5
Interferon alone
Bonkovsky 1999^235^ | Multicenter double blind RCT | 642 | HRQOL | a) INF Consensus 3–9 ug tiw × 24 wks; b) INF alfa-2b 15 ug tiw × 24 wks | | SVR | NR | Diff | p | Blinded to viral load testing but could have been aware of transaminase test results | Fair (22% loss to follow up; not blinded to treatment results)
| | | SF-36 | | PF | +8 | +2 | +6 | <0.05
| | | MOS | | RP | +26 | +4 | +22 | <0.01
| | | | | BP | +3 | +4 | -1 | NS
| | | | | GH | +7 | 0 | +7 | <0.01
| | | | | VT | +12 | +4 | +8 | <0.05
| | | | | SF | +12 | +3 | +9 | <0.05
| | | | | RE | +15 | +4 | +11 | NS
| | | | | MH | +6 | +2 | +4 | NS
| | | | | APT | +8 | +2 | +6 | <0.01
| | | | | COG | +3 | +1 | +2 | NS
| | | | | CUR | +16 | +2 | +14 | <0.01
| | | | | DIS | +8 | +3 | +5 | NS
| | | | | SEX | +8 | +4 | +4 | <0.05
| | | | | SLP | +4 | +3 | +1 | NS

ug = micrograms

MU = million units

tiw = three times per week

wks = weeks

pts = patients

RCT = Randomized controlled trial

PF = Physical function

RP = Ability to perform physical roles

BP = Degree of bodily pain

GH = Sense of general health

COG = Cognitive function

DIS = Feeling of health distress

SLP = Sleep quality

PCS = Physical component summary

HHD = Hepatitis specific health distress

SF = Short form

FFS = Fatigue Severity Scale

HQLQ = Hepatitis Quality of Life Questionaire

HRQOL = Health Related Quality of Life

MOS = Medical Outcomes Study

VT = Overal sense of vitality

SF (results) = Social function

RE = Ability to perform emotional roles

MH = Overal sense of mental health

APT = Appetite

CUR = Perception of current health

SEX = Sexual functioning

Diff = Difference

MCS = Mental component summary