# Future Research Priorities

In assessing the balance of benefits and harms from screening for HCV infection in the general population from indirect evidence, we highlight several areas of key uncertainties and areas for future research:

[underlined: Natural history:] Important gaps remain in our understanding of the natural history of untreated patients with HCV infection who are likely to be identified by screening. Recent studies in cohorts that identified patients by screening populations with known exposures appear to show that in most patients with long-standing chronic HCV infection, there is an indolent course. If this is true, screening will identify many patients with chronic HCV infection who would not benefit from treatments aimed at preventing progression to cirrhosis. If untreated chronic HCV infection leads to important morbidity in the absence of cirrhosis, there may be other important goals from treatment. Additional studies are needed to define the progression from asymptomatic to symptomatic HCV infection and how long symptomatic patients remain unidentified without screening.

[underlined: Population screened:] Reasonable screening strategies might be to screen all patients with acknowledged established risk factors, patients more likely to rapidly progress to serious disease (e.g., patients with alcohol abuse, older patients), all patients in specific settings with a high prevalence of HCV infection (e.g., incarcerated persons, urban populations, VA patients, homeless persons), or all patients in the general population. Studies that adequately assess the usefulness of risk factor assessment to guide selective screening strategies, or the harms and benefits of selective versus universal screening are needed. Little is known regarding patient preferences for screening.

[underlined: Work-up:] Although liver biopsy is the only accurate method to assess the histologic stage of HCV infection, there is some controversy regarding the necessity of pretreatment liver biopsy in all patients. Because liver biopsy is a potentially harmful invasive procedure, studies that evaluate the outcomes of patients who receive treatment without liver biopsies would be helpful in determining whether all or selected patients should undergo pretreatment biopsy.

[underlined: Interventions:] Trials evaluating intermediate and long-term outcomes of treatment for HCV infection have been in referral populations and may not be completely applicable to patients found on screening. Many studies showing improvement in long-term clinical outcomes have been conducted in Japan, where chronic HCV infection appears to follow a substantially more aggressive course. The case for screening would be greatly strengthened by data showing that treatment in earlier, asymptomatic stages of disease in Western countries is associated with improved outcomes compared to treatment that is reserved for patients who have become symptomatic and could be identified without screening. Little is known about the benefits and risks of treatment in patients typically excluded from or under-represented in randomized trials (ongoing substance abuse, co-morbid conditions, the elderly, non-white race).^239^

[underlined: Harms:] Many patients with anti-HCV antibodies will either have no evidence of chronic infection or chronic HCV infection with disease that is too mild to qualify for treatment. No studies have adequately assessed the harmful impacts due to anxiety, labeling, or relationships with family and sexual partners that result from screening for HCV infection in these patients, and whether these harmful impacts can be minimized by appropriate counseling. The short-term adverse effects of interferon-based therapies must be balanced against potential long-term benefits in patients who are likely to be asymptomatic and may have low potential to progress to cirrhosis.

[underlined: Outcomes:] Although treatments are increasingly effective in improving intermediate outcomes of HCV infection, there is still only limited evidence that this leads to better clinical outcomes. Few studies have adequately assessed the impact of treatment on quality of life or symptoms, which may be a more relevant outcome for the majority of patients who are unlikely to develop cirrhosis. Studies assessing quality of life outcomes in an intention-to-treat format (rather than according to response to treatment) are also lacking.

Screening for chronic HCV infection may have importance not only in terms of individual clinical outcomes, but also as a public health measure. Screening might help identify patients who would benefit from counseling about alcohol use, hepatitis A and B vaccinations, or on ways to avoid spreading disease. Studies demonstrating important individual or public health benefits from counseling, immunizations, and behavioral changes following a diagnosis of HCV in asymptomatic patients would greatly strengthen the case for screening.