# Conclusions

There is no direct evidence on benefits of screening for HCV infection in the general adult population. Other evidence obtained for the systematic review is summarized in Table 7. It indicates the type of study design and the quality of evidence for each key question. Table 8 estimates the yield from screening in a hypothetical cohort of 1000 adults in the general population and in a high-risk (intravenous drug use) population, using the highest-quality and most applicable available evidence. We did not include areas in this table in which reliable data to estimate the magnitude of benefit or harm were not available (harm from false-positive screening tests, harm from labeling, benefit from counseling or immunizations, benefit from improvement in long-term clinical outcomes).

Table 7 Summary of findings of systematic review

Arrow | Question | Level and type of evidence | Overall evidence for the link | Findings
1 | Does screening for hepatitis C reduce the risk or rate of harm and premature death and disability? | None. | N/A | No controlled studies or observational studies links screening directly to health outcomes.
2 | Can clinical or demographic characteristics identify a subgroup of asymptomatic patients at higher risk for infection? | II-3. Cross-sectional studies | Good for intravenous drug use, high-risk sexual behaviors, and transfusions prior to 1990 | Intravenous drug use, the most important risk factor for HCV infection, is associated with a prevalence of 50–90%, and is present in at least 50% of infected individuals. High-risk sexual behaviors are another important risk factor. Although transfusions prior to 1990 remain a risk factor, more recent transfusions do not pose a significant risk. Other risk factors have inconsistent associations with HCV infection. No prospective study has applied a screening strategy in the general population and measured what proportion of infected patients was identified correctly.
| | | Fair other risk factors.
3 | What are the test characteristics of HCV antibody testing? | Studies of diagnostic test characteristics | Fair for sensitivity | Using viremia as the reference standard, sensitivity of 3rd-generation ELISA testing appears to be 94% or higher.
| | | Fair for specificity | Limited data found a specificity of 97% or greater using viremia as the reference standard.
4 | What is the predictive value of a positive screening test and what are the harms associated with screening for hepatitis C virus? | II-3. Large population-based cross-sectional studies. One small, poor-quality cross-sectional study on harms of screening. | Good for positive predictive values. | False-positive HCV screening tests may not result in potentially harmful diagnostic tests and treatments because PCR is performed to confirm active infection, but other harms (labelling, anxiety, quality of life) that are more difficult to measure are likely to occur. In two large population-based studies the positive predictive value for viremia of positive ELISA with confirmatory positive RIBA was 84–86%. Small observational studies have found worse quality of life in patients aware of their HCV infection (true-positives); no studies are available on harms of screening in false-positives.
| | | Poor for harms.
5a | What are the test characteristics of the work-up for treatable disease? | One good systematic review evaluated blood tests' ability to predict liver findings on biopsy. | Fair | Blood tests only have modest value in predicting fibrosis on liver biopsy. No study has evaluated outcomes between patients who had and did not have pretreatment liver biopsy.
5b | In patients found to be positive for hepatitis C antibody, what proportion of patients would qualify for antiviral treatment? | II-3. Cohort studies and cross-sectional studies | Fair | In three fair quality cohort studies, only 30% of patients referred for treatment received treatment. Co-morbid conditions and contraindications disqualified many patients. Approximately 10% of patients refused treatment despite eligibility.
6 | What are the harms associated with the work-up for active HCV disease? | II-3. Cross-sectional studies | Fair | The risk of major complications (bleeding, death, perforation) from percutaneous liver biopsy was around 1–2%, with mortality less than 0.3%, in the highest-quality large trial of patients with a variety of indications for biopsy. The risks may be lower in patients undergoing liver biopsy specifically for evaluation of HCV infection.
7a | How well does antiviral treatment reduce the rate of viremia, improve transaminase levels, and improve histology? | I. Well-designed randomized clinical trials | Good | Treatment improves intermediate outcomes. Newer treatments have achieved higher rates of success (54–69% with pegylated interferon + ribavirin) than older treatments. Trials were performed in patients referred for treatment of HCV infection who probably had more severe illness than would be seen in patients identified by screening.
7b | How well does antiviral treatment improve health outcomes in asymptomatic patients with hepatitis C? | I, II-2. Cohort studies and clinical trials | Fair | One good quality RCT from Japan found a reduction in HCC and mortality after INF treatment. Cohort studies found similar results, but baseline characteristics between patients receiving and not receiving treatment may have differed. Many of these studies were performed in Japan, where chronic HCV infection appears associated with more frequent severe complications.
| | | | Data on long-term quality of life outcomes according to treatment received is sparse.
7c | How well do counseling and immunizations in asymptomatic patients with hepatitis C improve outcomes or prevent spread of disease? | II-3. Case-control and cross-sectional studies | Poor | There are no studies evaluating whether counseling HCV patients or administering appropriate immunizations improves clinical outcomes or prevents spread of disease. One small retrospective study from France found that patients drinking excess alcohol cut down their intake after brief counseling. One small cross-sectional study found that intravenous drug users did not alter high-risk behaviors after becoming aware of having HCV. In one study, hepatitis A and B immunization series resulted in seroconversion in over 90% of patients with HCV and was tolerated well.
8 | What are the harms (including intolerance to treatment) associated with antiviral intervention? | I. Well-designed randomized clinical trials | Good | Antiviral treatment frequently causes a wide array of adverse symptoms, however, these are usually mild and self-limiting. The most common adverse events are flu-like symptoms. In addition, depression, gastrointestinal, and dermatological effects are common. The overall rate of serious or life-threatening adverse events has been 1–2%.
| | | | In trials specifically of pegylated interferon plus ribavirin, myalgias occurred in 42–56%, fatigue 54–64%, headache 47–62%, and depression 22–31%. No serious complications or deaths occurred. Withdrawals due to adverse events occurred in 14–22%.
9 | Have improvement in intermediate outcomes been shown to reduce the risk or rate of harm from hepatitis C? | II-2. Fair-quality cohort studies and clinical trials | Fair | A limited number of cohort studies have shown that patients who achieve intermediate outcomes after treatment are less likely to develop HCC than those who do not achieve intermediate outcomes and than those who do not receive treatment. Three fair-quality clinical trials found that patients who are sustained responders to treatment have signficant improvements in health-related quality of life.

HCV=hepatitis C virus; ELISA: enzyme-linked immunoassay; RIBA=recombinant immunoblot assay

Table 8 Estimated yield of screening for hepatitis C virus

Base case assumptions | | Source | Number out of 1000 average-risk adults screened | Number out of 1000 adults screened who report IVDU
Prevalence of anti-HCV antibodies in population | 2% in general U.S. population | NHANES III (1.8% in general population, 2.3% in adults >20 years old) | 20 | 500–900
| 50 to >90% in U.S. patients with past or current IVDU | Numerous cross-sectional studies
Proportion of anti-HCV antibody positive patients with viremia | 72–84% | NHANES III, Dionysos study (Italy), French population-based study (Dubois) | 14 | 360–765
Proportion of patients with viremia that will develop cirrhosis after 10–20 years | 0–10% | 6 community-based cohorts of patients exposed to HCV infection | 0–1.4 | 0–76
Proportion of patients with viremia that has abnormal transaminases | 60–66% | Dionysos study (Italy), French population-based study | 8–9 | 216–505
Proportion of patients undergoing liver biopsy who have major complications | 1–2% for major complications (bleeding, death, perforation) | 1 large fair-quality observational study with independent ascertainment of complications in patients referred for biopsy for a variety of indications; numerous other poor- and fair-quality observational studies (small randomized trials of patients with HCV infection suggest a lower rate of complications) | 0.14 major complications and <0.04 deaths if all patients with viremia undergo biopsy | 4–15 major complications and 0–2 deaths
| <0.3% mortality | | 0.08–0.18 major complications and <0.03 deaths if only patients with abnormal transaminases undergo biopsy | 2–10 major complications and 0–1.5 deaths
Proportion of patients referred for evaluation of HCV infection that received therapy | 30% | 3 fair-quality observational studies of patients referred for evaluation of HCV infection | 4, if all patients with viremia referred | 108–230
| | | 2–3, if only patients with abnormal transaminases referred | 65–152
Proportion of patients who received interferon-based therapy that completed treatment course | 80–90% | Numerous good-quality randomized trials and systematic reviews | 3.2–3.6, if all patients with viremia referred | 86–207
| | | 1.6–2.7, if only patients with abnormal transaminases referred | 52–137
Proportion of patients who received interferon-based therapy that had a serious or life-threatening adverse event | 1–2% | Numerous good-quality randomized trials and systematic reviews | 0.04–0.08, in all patients with viremia referred | 1–5
| | | 0.02–0.06, if only patients with abnormal transaminases referred | 0.6–3
Proportion of patients who receive treatment that have a sustained virologic response to best available therapy (pegylated interferon and ribavirin) | 54–60% for pegylated interferon and ribavirin combination therapy | 3 randomized clinical trials (2 good-quality, 1 fair-quality) for pegylated interferon and ribavirin | 2, if all patients with viremia referred | 46–124
| | | 0.9–1.6, if only patients with abnormal transaminases referred | 28–82