# Methods

## Search Strategy

We searched the topic of HCV in the MEDLINE and Cochrane Library databases from 1989 (the year HCV was characterized) through July 2002, and searched updates of these databases through February 2003. We originally performed three MEDLINE searches, one for screening for HCV infection, one for work-up of HCV infection, and one for treatment of HCV infection. For screening, the medical subject headings (MeSH) hepatitis C and hepacivirus were combined with the terms mass screening, hepatitis C antibodies, predictive value of tests, and sensitivity and specificity, and the text words antibody testing. For work-up, the MeSH headings hepatitis C and hepacivirus were combined with the terms ultrasonography, liver function tests, liver biopsy, and viral load. For treatment, the MeSH headings antiviral agents, interferons, and ribavarin were combined with the terms hepatitis C and hepacivirus. We conducted a search for controlled studies of treatment of hepatitis C infection in the Cochrane Library databases, using the phrase hepatitis C in title, abstract, or keywords combined with terms for clinical trials. We retrieved the complete reference list from a recent Agency for Healthcare Research and Quality (AHRQ) evidence report commissioned by the National Institutes of Health (NIH) to update their consensus statement on management of HCV infection.^107^ Periodic hand searching of hepatology, gastroenterology, and major medical journals and review of the reference lists of retrieved articles supplemented the electronic searches.

We performed an additional MEDLINE search in February 2003 for other interventions (counseling on alcohol use, immunizations, and preventing spread of disease) in patients with HCV. For this search, we combined the MeSH headings hepatitis C, hepacivirus, or hepatitis C, chronic with the MeSH headings patient education, counseling, alcohol drinking, viral hepatitis vaccines, hepatitis A, or vaccination.

A single reader reviewed all English abstracts. Papers were selected for full review if they were about HCV infection, were relevant to key questions in the analytic framework, and met other key-question specific inclusion criteria (see below). Reviews, policy statements, and other papers with contextual value were also obtained from the searches. Studies published as abstracts were not included in the search; although pertinent abstracts may be referred to in the text they are not included in evidence tables.

## Inclusion Criteria

For all key questions, articles were limited to those that evaluated the general adult population with chronic HCV infection. We excluded studies that only focused on patients with end-stage liver disease, cirrhosis, or hepatocellular cancer. Although the population of interest was asymptomatic adults with chronic HCV infection who would be identified by screening, we included studies of patients with a broad spectrum of chronic HCV disease in order to get a picture of the benefits and adverse effects of screening and treatment in patients with different degrees of liver disease. Studies on HCV populations who had undergone transplantation were excluded, as were studies of pregnant patients, children, or those with end-stage renal disease or HIV. Studies of non-human subjects were also excluded, and studies had to include original data. Foreign language papers were considered if they were clinical trials and an abstract was available in English. We searched for relevant systematic reviews for all key questions.

For individual key questions, additional inclusion criteria were as follows:

- For key question 1, articles were included if they were clinical trials or observational studies that evaluated clinical outcomes in patients screened and not screened for HCV infection.
- For key question 2, we included large observational studies that used appropriate statistical methods to assess associations between various risk factors and the presence of HCV infection. Representative smaller observational studies were also reviewed.
- For key questions 3a, 3b, and 4, we included observational studies and systematic reviews that evaluated third-generation ELISAs (the most recent generation) and used a credible, current reference standard (third-generation RIBA or PCR). We did not include studies that evaluated third-generation ELISA only in relationship to an earlier generation ELISA test or only performed the reference standard in “discordant” samples from two screening tests. We included large population-based observational studies that reported the positive predictive value of confirmatory third-generation RIBA for viremia following third-generation ELISA.
- For key question 5a, we included studies that evaluated the ability of blood tests to predict liver biopsy results, and performed liver biopsy as the reference standard.
- For key question 5b, we included clinical trials and observational studies that reported the number of patients referred or considered for HCV treatment after a positive HCV antibody test, and that also provided detailed information about the reasons patients were considered ineligible for treatment.
- For key question 6, we included observational studies that reported complications from percutaneous liver biopsy specifically in patients with chronic HCV infection. We also included representative large higher-quality observational studies of complications from percutaneous liver biopsy performed for a variety of indications.
- For key questions 7a and 7b, we included controlled trials of antiviral treatment that evaluated relevant intermediate or clinical outcomes in treatment naïve populations. We included studies that evaluated pegylated interferon with or without ribavirin versus another treatment or placebo, and studies that evaluated non-pegylated interferon plus ribavirin compared to interferon alone or placebo. For question 7b, controlled trials of non-pegylated interferon without ribavarin were also included if they had greater than 5 years of post-treatment follow-up and evaluated clinical or histologic outcomes. We reviewed clinical trials that were previously included in good-quality systematic reviews to insure accuracy and reproducibility of the findings of the systematic reviews.
- For key question 7c, we included controlled trials and observational studies that evaluated the effectiveness of counseling and immunizations in patients with HCV for improving clinical outcomes related to hepatitis A or B infection, alcohol use, or preventing spread of disease.
- For key question 8, we included controlled antiviral trials and observational studies that reported adverse events in treatment naïve populations. We included studies of pegylated interferon with or without ribavirin versus another treatment or placebo, and studies of non-pegylated interferon plus ribavirin versus another treatment or placebo.
- For key question 9 we included controlled antiviral trials and observational studies in which long-term outcomes were stratified by intermediate responses to treatment.

## Data Extraction

We used predefined criteria from the USPSTF to assess the internal validity of included systematic reviews, trials and observational studies, which we rated as “good,” “fair,” or “poor.” We also rated the applicability of each study to the population that would be identified by screening. The rating system was developed by the USPTF and is described in detail elsewhere.^108^ For included trials and systematic reviews, we also abstracted information about setting, patients, interventions, and outcomes. For clinical trials, when possible we recorded the difference between the probability of a response in the treatment and control groups for each outcome studied. We evaluated the applicability of reviewed studies to the population likely to be identified by screening. We developed evidence tables for those key questions related to antiviral treatment of HCV infection (key questions 7a and 7b). We rated the overall body of evidence for each key question using the system developed by the USPTF.^108^