# References

1 U.S. Preventive Services Task Force. Screening for Iron Deficiency Anemia and Iron Supplementation in Pregnant Women to Improve Maternal Health and Birth Outcomes: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2015 Oct 6;163(7):529–36. doi: 10.7326/M15-1707. PMID: 26344176.26344176
2 Kemper AR, Fan T, Grossman DC, . Gaps in evidence regarding iron deficiency anemia in pregnant women and young children: summary of U.S. Preventive Services Task Force recommendations. Am J Clin Nutr. 2017 Dec;106(Suppl 6):1555S–8S. doi: 10.3945/ajcn.117.155788. PMID: 29070541.29070541
3 Cantor AG, Bougatsos C, Dana T, . Routine iron supplementation and screening for iron deficiency anemia in pregnancy: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2015 Apr 21;162(8):566–76. doi: 10.7326/M14-2932. PMID: 25820661.25820661
4 McDonagh M, Cantor A, Bougatsos C, . Routine iron supplementation and screening for iron deficiency anemia in pregnant women: a systematic review to update the U.S. Preventive Services Task Force recommendation. Agency for Healthcare Research and Quality. Rockville, MD: Mar 2015. PMID: 2592713625927136.
5 Griffin IJ, Abrams SA. Iron and breastfeeding. Pediatr. Clin. North Am. 2001;48(2):401–13. doi: 10.1016/s0031-3955(08)70033-6. PMID: 11339160.11339160
6 Centers for Disease Control and Prevention. Recommendations to prevent and control iron deficiency in the United States. MMWR Recomm. Rep. 1998 Apr 3;47(RR-3):1–29. PMID: 9563847.9563847
7 World Health Organization. Haemoglobin concentrations for the diagnosis of anaemia and assessment of severity World Health Organization. Geneva: 2011. https://apps.who.int/iris/handle/10665/85839. Accessed June 8 2024.
8 Pavord S, Daru J, Prasannan N, . UK guidelines on the management of iron deficiency in pregnancy. Br J Haematol. 2020 Mar;188(6):819–30. doi: 10.1111/bjh.16221. PMID: 31578718.31578718
9 van den Broek NR, Letsky EA, White SA, . Iron status in pregnant women: which measurements are valid? Br J Haematol. 1998 Dec;103(3):817–24. doi: 10.1046/j.1365-2141.1998.01035.x. PMID: 9858238.9858238
10 Tarancon-Diez L, Genebat M, Roman-Enry M, . Threshold ferritin concentrations reflecting early iron deficiency based on hepcidin and soluble transferrin receptor serum levels in patients with absolute iron deficiency. Nutrients. 2022 Nov 10;14(22)doi: 10.3390/nu14224739. PMID: 36432426.36432426
11 Galetti V, Stoffel NU, Sieber C, . Threshold ferritin and hepcidin concentrations indicating early iron deficiency in young women based on upregulation of iron absorption. EClinicalMedicine. 2021 Jul 31;39:101052. doi: 10.1016/j.eclinm.2021.101052. PMID: 34401687.34401687
12 Vyas DA, Eisenstein LG, Jones DS. Hidden in plain sight - reconsidering the use of race correction in clinical algorithms. N Engl J Med. 2020 Aug 27;383(9):874–82. doi: 10.1056/NEJMms2004740. PMID: 32853499.32853499
13 Institute of Medicine (US), Committee on the Prevention Detection and Management of Iron Deficiency Anemia Among U.S. Children and Women of Childbearing Age. Iron deficiency anemia: recommended guidelines for the prevention, detection, and management among U.S. children and women of childbearing age. Washington, DC: The National Academies Press; 1993. http://www.nap.edu/openbook.php?record_id=2251. Accessed June 8 2024.
14 American College of Obstetricians and Gynecologists’ Committee on Practice. Anemia in pregnancy: ACOG Practice Bulletin, Number 233. Obstet. Gynecol. 2021 Aug 1;138(2):e55–e64. doi: 10.1097/AOG.0000000000004477. PMID: 34293770.34293770
15 Weyand AC, McGann PT. Eliminating race-based reference ranges in haematology: a call to action. Lancet Haematol. 2021 Jun;8(6):e462–e6. doi: 10.1016/s2352-3026(21)00106-x. PMID: 34048684.34048684
16 Hamm RF, Wang EY, Levine LD, . Association Between Race and Hemoglobin at Delivery or Need for Transfusion When Using Race-Based Definitions for Treatment of Antepartum Anemia. Obstet. Gynecol. 2021 Jul 1;138(1):108–10. doi: 10.1097/aog.0000000000004439. PMID: 34259472.34259472
17 Krishnamurti L. Part 9: Iron-deficiency anemia. In: Thomas K. McInerny MF, ed American Academy of Pediatrics Textbook of Pediatric Care. Elk Grove Village, IL: American Academy of Pediatrics; 2009.
18 Scholl TO. Iron status during pregnancy: setting the stage for mother and infant. Am J Clin Nutr. 2005 May;81(5):1218S–22S. doi: 10.1093/ajcn/81.5.1218. PMID: 15883455.15883455
19 Mei Z, Cogswell ME, Looker AC, . Assessment of iron status in US pregnant women from the National Health and Nutrition Examination Survey (NHANES), 1999-2006. Am J Clin Nutr. 2011 Jun;93(6):1312–20. doi: 10.3945/ajcn.110.007195. PMID: 21430118.21430118
20 Corwin EJ, Murray-Kolb LE, Beard JL. Low hemoglobin level is a risk factor for postpartum depression. J Nutr. 2003 Dec;133(12):4139–42. doi: 10.1093/jn/133.12.4139. PMID: 14652362.14652362
21 Lee KA, Zaffke ME. Longitudinal changes in fatigue and energy during pregnancy and the postpartum period. J Obstet Gynecol Neonatal Nurs. 1999 Mar–Apr;28(2):183–91. doi: 10.1111/j.1552-6909.1999.tb01983.x. PMID: 10102546.10102546
22 Nair M, Choudhury MK, Choudhury SS, . Association between maternal anaemia and pregnancy outcomes: a cohort study in Assam, India. BMJ Glob Health. 2016 Apr 7;1(1):e000026. doi: 10.1136/bmjgh-2015-000026. PMID: 28588921.28588921
23 Hoffman R, Benz, J.E.J., Silberstein, L.E. Hematology: Basic Principles and Practice, 6th ed. Philadelphia, PA: Elsevier Saunders; 2013.
24 Mansukhani R, Shakur-Still H, Chaudhri R, . Maternal anaemia and the risk of postpartum haemorrhage: a cohort analysis of data from the WOMAN-2 trial. Lancet Glob Health. 2023 Aug;11(8):e1249–e59. doi: 10.1016/S2214-109X(23)00245-0. PMID: 37390833.37390833
25 Omotayo MO, Abioye AI, Kuyebi M, . Prenatal anemia and postpartum hemorrhage risk: a systematic review and meta-analysis. J Obstet Gynaecol Res. 2021 Aug;47(8):2565–76. doi: 10.1111/jog.14834. PMID: 34002432.34002432
26 Scholl TO, Hediger ML, Fischer RL, . Anemia vs iron deficiency: increased risk of preterm delivery in a prospective study. Am J Clin Nutr. 1992 May;55(5):985–8. doi: 10.1093/ajcn/55.5.985. PMID: 1570808.1570808
27 Murphy JF, O’Riordan J, Newcombe RG, . Relation of haemoglobin levels in first and second trimesters to outcome of pregnancy. Lancet. 1986 May 3;1(8488):992–5. doi: 10.1016/s0140-6736(86)91269-9. PMID: 2871331.2871331
28 Zhou LM, Yang WW, Hua JZ, . Relation of hemoglobin measured at different times in pregnancy to preterm birth and low birth weight in Shanghai, China. Am J Epidemiol. 1998 Nov 15;148(10):998–1006. doi: 10.1093/oxfordjournals.aje.a009577. PMID: 9829872.9829872
29 Klebanoff MA, Shiono PH, Selby JV, . Anemia and spontaneous preterm birth. Am J Obstet Gynecol. 1991 Jan;164(1):59–63. doi: 10.1016/0002-9378(91)90626-3. PMID: 1986627.1986627
30 Lu ZM, Goldenberg RL, Cliver SP, . The relationship between maternal hematocrit and pregnancy outcome. Obstet Gynecol. 1991 Feb;77(2):190–4. doi: 10.1097/00006250-199102000-00005.1988879
31 Singh K, Fong YF, Arulkumaran S. Anaemia in pregnancy--a cross-sectional study in Singapore. Eur J Clin Nutr. 1998 Jan;52(1):65–70. doi: 10.1038/sj.ejcn.1600517. PMID: 9481535.9481535
32 Bodnar LM, Cogswell ME, Scanlon KS. Low income postpartum women are at risk of iron deficiency. J Nutr. 2002 Aug;132(8):2298–302. doi: 10.1093/jn/132.8.2298. PMID: 12163678.12163678
33 Park CY, Eicher-Miller HA. Iron deficiency is associated with food insecurity in pregnant females in the United States: National Health and Nutrition Examination Survey 1999-2010. J Acad Nutr Diet. 2014 Dec;114(12):1967–73. doi: 10.1016/j.jand.2014.04.025. PMID: 24953790.24953790
34 Bodnar LM, Cogswell ME, McDonald T. Have we forgotten the significance of postpartum iron deficiency? Am J Obstet Gynecol. 2005 Jul;193(1):36–44. doi: 10.1016/j.ajog.2004.12.009. PMID: 16021056.16021056
35 Bodnar LM, Siega-Riz AM, Cogswell ME. High prepregnancy BMI increases the risk of postpartum anemia. Obes Res. 2004 Jun;12(6):941–8. doi: 10.1038/oby.2004.115. PMID: 15229333.15229333
36 Neymotin F, Sen U. Iron and obesity in females in the United States. Obesity (Silver Spring). 2011 Jan;19(1):191–9. doi: 10.1038/oby.2010.112. PMID: 20467417.20467417
37 American College of Obstetricians and Gynecologists. ACOG Practice Bulletin No. 95: anemia in pregnancy. Obstet. Gynecol. 2008 Jul;112(1):201–7. doi: 10.1097/AOG.0b013e3181809c0d. PMID: 18591330.18591330
38 Walsh T, O’Broin SD, Cooley S, . Laboratory assessment of iron status in pregnancy. Clin Chem Lab Med. 2011 Jul;49(7):1225–30. doi: 10.1515/CCLM.2011.187. PMID: 21627494.21627494
39 Byg KE, Milman N, Hansen S, . Serum ferritin is a reliable, non-invasive test for iron status in pregnancy: comparison of ferritin with other iron status markers in a longitudinal study on healthy pregnant women. Hematology. 2000;5(4):319–25. doi: 10.1080/10245332.2000.11746526. PMID: 11399631.11399631
40 Daru J, Allotey J, Pena-Rosas JP, . Serum ferritin thresholds for the diagnosis of iron deficiency in pregnancy: a systematic review. Transfus Med. 2017 Jun;27(3):167–74. doi: 10.1111/tme.12408. PMID: 28425182.28425182
41 Guyatt GH, Oxman AD, Ali M, . Laboratory diagnosis of iron-deficiency anemia: an overview. J Gen Intern Med. 1992 Mar–Apr;7(2):145–53. doi: 10.1007/bf02598003. PMID: 1487761.1487761
42 Viteri FE, Casanueva E, Tolentino MC, . Antenatal iron supplements consumed daily produce oxidative stress in contrast to weekly supplementation in Mexican non-anemic women. Reprod Toxicol. 2012 Aug;34(1):125–32. doi: 10.1016/j.reprotox.2012.03.010. PMID: 22507748.22507748
43 World Health Organization. Weekly iron–folic acid supplementation (WIFS) in women of reproductive age: its role in promoting optimal maternal and child health. Position statement. Geneva, Switzerland; 2009. https://iris.who.int/bitstream/handle/10665/89743/WHO_NMH_NHD_MNM_09.2_eng.pdf. Accessed June 8 2024.
44 Short MW, Domagalski JE. Iron deficiency anemia: evaluation and management. Am Fam.Physician. 2013 Jan 15;87(2):98–104. PMID: 23317073.23317073
45 Goddard AF, James MW, McIntyre AS, . Guidelines for the management of iron deficiency anaemia. Gut. 2011 Oct;60(10):1309–16. doi: 10.1136/gut.2010.228874. PMID: 21561874.21561874
46 Stoffel NU, von Siebenthal HK, Moretti D, . Oral iron supplementation in iron-deficient women: how much and how often? Mol Aspects Med. 2020 Oct;75:100865. doi: 10.1016/j.mam.2020.100865. PMID: 32650997.32650997
47 Tolkien Z, Stecher L, Mander AP, . Ferrous sulfate supplementation causes significant gastrointestinal side-effects in adults: a systematic review and meta-analysis. PLoS One. 2015 Feb 20;10(2):e0117383. doi: 10.1371/journal.pone.0117383. PMID: 25700159.25700159
48 Zijp IM, Korver O, Tijburg LB. Effect of tea and other dietary factors on iron absorption. Crit Rev Food Sci Nutr. 2000 Sep;40(5):371–98. doi: 10.1080/10408690091189194. PMID: 11029010.11029010
49 Stoffel NU, Cercamondi CI, Brittenham G, . Iron absorption from oral iron supplements given on consecutive versus alternate days and as single morning doses versus twice-daily split dosing in iron-depleted women: two open-label, randomised controlled trials. Lancet Haematol. 2017 Nov;4(11):e524–e33. doi: 10.1016/s2352-3026(17)30182-5. PMID: 29032957.29032957
50 Brittenham GM. Disorders of iron homeostasis: iron deficiency and overload. In: Hoffman R, Benz EJ, Silberstein L, Heslop H, Weitz J, Salama M, ., eds. Hematology: Basic Principles and Practive. 7th ed. Philadelphia, PA: Elsevier; 2018:478–90.
51 Govindappagari S, Burwick RM. Treatment of iron deficiency anemia in pregnancy with intravenous versus oral iron: systematic review and meta-analysis. Am J Perinatol. 2019 Mar;36(4):366–76. doi: 10.1055/s-0038-1668555. PMID: 30121943.30121943
52 Lewkowitz AK, Gupta A, Simon L, . Intravenous compared with oral iron for the treatment of iron-deficiency anemia in pregnancy: a systematic review and meta-analysis. J Perinatol. 2019 Apr;39(4):519–32. doi: 10.1038/s41372-019-0320-2. PMID: 30692612.30692612
53 Qassim A, Grivell RM, Henry A, . Intravenous or oral iron for treating iron deficiency anaemia during pregnancy: systematic review and meta-analysis. Med J.Aust. 2019 Oct;211(8):367–73. doi: 10.5694/mja2.50308. PMID: 31441077.31441077
54 Al RA, Unlubilgin E, Kandemir O, . Intravenous versus oral iron for treatment of anemia in pregnancy: a randomized trial. Obstet Gynecol. 2005 Dec;106(6):1335–40. doi: 10.1097/01.AOG.0000185260.82466.b4. PMID: 16319260.16319260
55 Achebe MM, Gafter-Gvili A. How I treat anemia in pregnancy: iron, cobalamin, and folate. Blood. 2017 Feb 23;129(8):940–9. doi: 10.1182/blood-2016-08-672246. PMID: 28034892.28034892
56 Branum AM, Bailey R, Singer BJ. Dietary supplement use and folate status during pregnancy in the United States. J Nutr. 2013 Apr;143(4):486–92. doi: 10.3945/jn.112.169987. PMID: 23365107.23365107
57 Department of Veteran Affairs, Department of Defense. VA/DoD clinical practice guideline for management of pregnancy. Rockville MD: Agency for Healthcare Research and Quality (AHRQ); 2018. https://www.healthquality.va.gov/guidelines/WH/up/VADoDPregnancyCPG4102018.pdf. Accessed June 8 2024.
58 World Health Organization. WHO recommendations on antenatal care for a positive pregnancy experience. Geneva, Switzerland: 2016. https://www.who.int/publications/i/item/9789241549912 PMID: 2807999828079998. Accessed June 8 2024.
59 U.S. Preventive Services Task Force. Procedure Manual. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual. Accessed June 8 2024.
60 Human Development Report 2020 United Nations Development Programme. New York, NY: 2020. https://hdr.undp.org/system/files/documents/hdr2020pdf.pdf.
61 United Nations. National Human Development Report 2019: China. UNDP (United Nations Development Programme). 2019. https://hdr.undp.org/system/files/documents/nhdrcnpdf.pdf. Accessed June 8 2024.
62 United Nations. Human Development Index (HDI). http://hdr.undp.org/en/statistics/. Accessed June 8 2024.
63 Barton DP, Joy MT, Lappin TR, . Maternal erythropoietin in singleton pregnancies: a randomized trial on the effect of oral hematinic supplementation. Am J Obstet Gynecol. 1994 Mar;170(3):896–901. doi: 10.1016/s0002-9378(94)70305-1. PMID: 8141223.8141223
64 Chan KKL, Chan BCP, Lam KF, . Iron supplement in pregnancy and development of gestational diabetes--a randomised placebo-controlled trial. BJOG. 2009 May;116(6):789–97; discussion 97-8. doi: 10.1111/j.1471-0528.2008.02014.x. PMID: 19432567.19432567
65 Chen S, Li N, Mei Z, . Micronutrient supplementation during pregnancy and the risk of pregnancy-induced hypertension: a randomized clinical trial. Clin Nutr. 2019 Feb;38(1):146–51. doi: 10.1016/j.clnu.2018.01.029. PMID: 29428785.29428785
66 Cogswell ME, Parvanta I, Ickes L, . Iron supplementation during pregnancy, anemia, and birth weight: a randomized controlled trial. Am J Clin Nutr. 2003 Oct;78(4):773–81. doi: 10.1093/ajcn/78.4.773. PMID: 14522736.14522736
67 Detlefs SE, Jochum MD, Salmanian B, . The impact of response to iron therapy on maternal and neonatal outcomes among pregnant women with anemia. Am J Obstet Gynecol MFM. 2022 Mar 4(2):100569. doi: 10.1016/j.ajogmf.2022.100569. PMID: 35033748.35033748
68 Eskeland B, Malterud K, Ulvik RJ, . Iron supplementation in pregnancy: is less enough? A randomized, placebo controlled trial of low dose iron supplementation with and without heme iron. Acta Obstet Gynecol Scand. 1997 Oct;76(9):822–8. doi: 10.3109/00016349709024359. PMID: 9351406.9351406
69 Falahi E, Akbari S, Ebrahimzade F, . Impact of prophylactic iron supplementation in healthy pregnant women on maternal iron status and birth outcome. Food Nutr Bull. 2011 Sep;32(3):213–7. doi: 10.1177/156482651103200305. PMID: 22073795.22073795
70 Jafarbegloo E, Tehran HA, Tehrani TD. Gastrointestinal complications of ferrous sulfate in pregnant women: a randomized double-blind placebo-controlled trial. Iranian Red Crescent Med J. 2015 Aug 29;17(8):e15001. doi: 10.5812/ircmj.15001. PMID: 26430520.26430520
71 Li Z, Mei Z, Zhang L, . Effects of prenatal micronutrient supplementation on spontaneous preterm birth: a double-blind randomized controlled trial in China. Am J Epidemiol. 2017 Aug 1;186(3):318–25. doi: 10.1093/aje/kwx094. PMID: 28472219.28472219
72 Liu J-m, Mei Z, Ye R, . Micronutrient supplementation and pregnancy outcomes: double-blind randomized controlled trial in China. JAMA Intern Med. 2013 Feb 25;173(4):276–82. doi: 10.1001/jamainternmed.2013.1632. PMID: 23303315.23303315
73 Liu Y, Li N, Mei Z, . Effects of prenatal micronutrients supplementation timing on pregnancy-induced hypertension: secondary analysis of a double-blind randomized controlled trial. Matern Child Nutr. 2021 Jul;17(3):e13157. doi: 10.1111/mcn.13157. PMID: 33594802.33594802
74 Makrides M, Crowther CA, Gibson RA, . Efficacy and tolerability of low-dose iron supplements during pregnancy: a randomized controlled trial. Am J Clin Nutr. 2003 Jul;78(1):145–53. doi: 10.1093/ajcn/78.1.145. PMID: 12816784.12816784
75 Mei Z, Serdula MK, Liu J-M, . Iron-containing micronutrient supplementation of Chinese women with no or mild anemia during pregnancy improved iron status but did not affect perinatal anemia. J Nutr. 2014 Apr 17;144(6):943–8. doi: 10.3945/jn.113.189894. PMID: 24744317.24744317
76 Meier PR, Nickerson HJ, Olson KA, . Prevention of iron deficiency anemia in adolescent and adult pregnancies. Clin Med Res. 2003 Jan;1(1):29–36. doi: 10.3121/cmr.1.1.29. PMID: 15931282.15931282
77 Milman N, Agger AO, Nielsen OJ. Iron supplementation during pregnancy. Effect on iron status markers, serum erythropoietin and human placental lactogen. A placebo controlled study in 207 Danish women. Dan Med Bull. 1991 Dec;38(6):471–6. PMID: 1802636.1802636
78 Milman N, Agger AO, Nielsen OJ. Iron status markers and serum erythropoietin in 120 mothers and newborn infants. Effect of iron supplementation in normal pregnancy. Acta Obstet Gynecol Scand. 1994 Mar;73(3):200–4. doi: 10.3109/00016349409023439. PMID: 8122498.8122498
79 Milman N, Byg KE, Agger AO. Hemoglobin and erythrocyte indices during normal pregnancy and postpartum in 206 women with and without iron supplementation. Acta Obstet Gynecol Scand. 2000 Feb;79(2):89–98. doi: 10.1034/j.1600-0412.2000.079002089.x. PMID: 10696955.10696955
80 Ouladsahebmadarek E, Sayyah-Melli M, Taghavi S A, S. Seyedhejazie, M. The effect of supplemental iron elimination on pregnancy outcome. Pak J Biol. Sci. 2011;27(3):641–5.
81 Romslo I, Haram K, Sagen N, . Iron requirement in normal pregnancy as assessed by serum ferritin, serum transferrin saturation and erythrocyte protoporphyrin determinations. Br J Obstet Gynaecol. 1983 Feb;90(2):101–7. doi: 10.1111/j.1471-0528.1983.tb08891.x. PMID: 6824608.6824608
82 Serdula MK, Zhou Y, Li H, . Prenatal iron containing supplements provided to Chinese women with no or mild anemia had no effect on hemoglobin concentration in post-partum women or their infants at 6 and 12 months of age. Eur J Clin Nutr. 2019 Nov 73(11):1473–9. doi: 10.1038/s41430-018-0365-x. PMID: 30446762.30446762
83 Siega-Riz AM, Hartzema AG, Turnbull C, . The effects of prophylactic iron given in prenatal supplements on iron status and birth outcomes: a randomized controlled trial. Am J Obstet Gynecol. 2006 Feb;194(2):512–9. doi: 10.1016/j.ajog.2005.08.011. PMID: 16458655.16458655
84 Wang L, Mei Z, Li H, . Modifying effects of maternal Hb concentration on infant birth weight in women receiving prenatal iron-containing supplements: a randomised controlled trial. Br J Nutr. 2016 Feb 28;115(4):644–9. doi: 10.1017/S0007114515004870. PMID: 26824731.26824731
85 Zeng L, Dibley MJ, Cheng Y, . Impact of micronutrient supplementation during pregnancy on birth weight, duration of gestation, and perinatal mortality in rural western China: double blind cluster randomised controlled trial. BMJ. 2008 Nov 7;337:a2001. doi: 10.1136/bmj.a2001. PMID: 18996930.18996930
86 Zhao G, Xu G, Zhou M, . Prenatal iron supplementation reduces maternal anemia, iron deficiency, and iron deficiency anemia in a randomized clinical trial in rural China, but iron deficiency remains widespread in mothers and neonates. J Nutr. 2015 Aug;145(8):1916–23. doi: 10.3945/jn.114.208678. PMID: 26063068.26063068
87 Zhou SJ, Gibson RA, Makrides M. Routine iron supplementation in pregnancy has no effect on iron status of children at six months and four years of age. J Pediatr. 2007 Oct;151(4):438–40. doi: 10.1016/j.jpeds.2007.06.001. PMID: 17889086.17889086
88 Ziaei S, Mehrnia M, Faghihzadeh S. Iron status markers in nonanemic pregnant women with and without iron supplementation. Int J Gynaecol Obstet. 2008 Feb;100(2):130–2. doi: 10.1016/j.ijgo.2007.07.027. PMID: 17977537.17977537
89 Ziaei S, Norrozi M, Faghihzadeh S, . A randomised placebo-controlled trial to determine the effect of iron supplementation on pregnancy outcome in pregnant women with haemoglobin > or = 13.2 g/dl. BJOG. 2007 Jun;114(6):684–8. doi: 10.1111/j.1471-0528.2007.01325.x. PMID: 17516958.17516958
90 Zhou SJ, Gibson RA, Crowther CA, . Effect of iron supplementation during pregnancy on the intelligence quotient and behavior of children at 4 y of age: long-term follow-up of a randomized controlled trial. Am J Clin Nutr. 2006 May;83(5):1112–7. doi: 10.1093/ajcn/83.5.1112. PMID: 16685054.16685054
91 Kanu FA, Hamner HC, Scanlon KS, . Anemia among pregnant women participating in the special supplemental nutrition program for women, infants, and children - United States, 2008-2018. MMWR. 2022 Jun 24;71(25):813–9. doi: 10.15585/mmwr.mm7125a1. PMID: 35737575.35737575
92 Santana G, Reise R, Koenig M, . Evaluating test utilization for anemia during pregnancy. Int. J. Lab. Hematol. 2022 Jun;44(3):673–8. doi: 10.1111/ijlh.13797. PMID: 35029326.35029326
93 Gavin NI, Adams EK, Hartmann KE, . Racial and ethnic disparities in the use of pregnancy-related health care among Medicaid pregnant women. Matern Child Health J. 2004 Sep;8(3):113–26. doi: 10.1023/b:maci.0000037645.63379.62. PMID: 15499869.15499869
94 Sharma AJ, Ford ND, Bulkley JE, . Use of the electronic health record to assess prevalence of anemia and iron deficiency in pregnancy. J Nutr. 2021 Nov 2;151(11):3588–95. doi: 10.1093/jn/nxab254. PMID: 34386820.34386820
95 Le CH. The Prevalence of Anemia and Moderate-Severe Anemia in the U.S. Population (NHANES 2003-2012). PLoS One. 2016;11(11):e0166635. doi: 10.1371/journal.pone.0166635. PMID: 27846276.27846276
96 Harley K, Eskenazi B, Block G. The association of time in the US and diet during pregnancy in low-income women of Mexican descent. Paediatr Perinat Epidemiol. 2005;19(2):125–34. doi: 10.1111/j.1365-3016.2005.00640.x. PMID: 15787887.15787887
97 Casanova BF, Sammel MD, Macones GA. Development of a clinical prediction rule for iron deficiency anemia in pregnancy. Am J Obstet Gynecol. 2005;193(2):460–6. doi: 10.1016/j.ajog.2004.12.008. PMID: 16098871.16098871
98 Kirschner W, Dudenhausen JW, Henrich W. Are there anamnestic risk factors for iron deficiency in pregnancy? Results from a feasibility study. J Perinat Med. 2016 Apr;44(3):309–14. doi: 10.1515/jpm-2014-0308. PMID: 25803071.25803071
99 Yefet E, Yossef A, Nachum Z. Prediction of anemia at delivery. Sci. Rep. 2021 Mar 18;11(1):6309. doi: 10.1038/s41598-021-85622-7. PMID: 33737646.33737646
100 Petry CJ, Ong KK, Hughes IA, . Associations between maternal iron supplementation in pregnancy and changes in offspring size at birth reflect those of multiple micronutrient supplementation. Nutrients. 2021 Jul 20;13(7):2480. doi: 10.3390/nu13072480. PMID: 34371987.34371987
101 Zhang Y, Xu S, Zhong C, . Periconceptional iron supplementation and risk of gestational diabetes mellitus: a prospective cohort study. Diabetes Res Clin Pract. 2021 Jun;176:108853. doi: 10.1016/j.diabres.2021.108853. PMID: 33961900.33961900
102 Martinez-Galiano JM, Amezcua-Prieto C, Cano-Ibanez N, . Maternal iron intake during pregnancy and the risk of small for gestational age. Matern Child Nutr. 2019 Jul;15(3):e12814. doi: 10.1111/mcn.12814. PMID: 30903732.30903732
103 Scholl TO, Hediger ML. Anemia and iron-deficiency anemia: compilation of data on pregnancy outcome. The American journal of clinical nutrition. 1994;59(2 Suppl):492S–501S. doi: 10.1093/ajcn/59.2.492S. PMID: 8304287.8304287
104 Pena-Rosas JP, De-Regil LM, Dowswell T, . Intermittent oral iron supplementation during pregnancy. Cochrane Database Syst Rev. 2012 Jul 11;7(7):CD009997. doi: 10.1002/14651858.CD009997. PMID: 22786531.22786531
105 Pena-Rosas JP, Viteri FE. Effects and safety of preventive oral iron or iron+folic acid supplementation for women during pregnancy. Cochrane Database Syst Rev. 2009 Oct 7(4):CD004736. doi: 10.1002/14651858.CD004736.pub3. PMID: 19821332.19821332
106 Reveiz L, Gyte GM, Cuervo LG, . Treatments for iron-deficiency anaemia in pregnancy. Cochrane Database Syst Rev. 2011 Oct 5(10):CD003094. doi: 10.1002/14651858.CD003094.pub3. PMID: 21975735.21975735
107 Cuervo LG, Mahomed K. Treatments for iron deficiency anaemia in pregnancy. Cochrane Database Syst Rev. 2001(2):CD003094. doi: 10.1002/14651858.CD003094. PMID: 11406073.11406073
108 Sterne JA, Sutton AJ, Ioannidis JP, . Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011 Jul 22;343:d4002. doi: 10.1136/bmj.d4002. PMID: 21784880.21784880
109 Cornell JE, Mulrow CD, Localio R, . Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014 Feb 18;160(4):267–70. doi: 10.7326/m13-2886. PMID: 24727843.24727843
110 Lagrew D, McNulty J, Sakowski C, . Improving Health Care Response to Obstetric Hemorrhage, a California Maternal Quality Care Collaborative Toolkit, 2022.Alliance for Innovation on Maternal Health. Obstetric Hemorrhage. American College of Obstetricians and Gynecologists. 2022. https://saferbirth.org/psbs/obstetric-hemorrhage Accessed June 8 2024.
111 Mahomed K. Iron and folate supplementation in pregnancy. Cochrane Database Syst Rev. 2000(2):CD001135. doi: 10.1002/14651858.CD001135. PMID: 10796246.10796246
112 Muñoz M, Peña-Rosas JP, Robinson S, . Patient blood management in obstetrics: management of anaemia and haematinic deficiencies in pregnancy and in the post-partum period: NATA consensus statement. Transfus Med. 2018 Feb;28(1):22–39. doi: 10.1111/tme.12443. PMID: 28722245.28722245