# Acknowledgements

The authors thank AHRQ Medical Officer Sheena Harris, MD, MPH, and the U.S. Preventive Services Task Force.