# Chapter 4 Discussion

## Summary of Review Findings

This report synthesizes evidence on the effects of iron supplementation and screening for ID and IDA during pregnancy. The evidence reviewed in this update is summarized for routine supplementation in Table 9 and for screening in Table 10.

Table 9 Summary of Evidence for Routine Iron Supplementation During Pregnancy

Key question; Outcome | No. of studies (k); No. of participants (N); Study design | Summary of findings by outcome | Consistency/precision; Reporting bias | Body of evidence limitations | Overall quality | Strength of evidence | Applicability
KQ 1. Benefits, maternal; Quality of life | k=1 RCT; n=430 | No statistically significant differences in quality of life for iron supplementation vs. placebo in one trial at 36 weeks of gestation, 6 weeks, 6 months, or 4 years postpartum. | Unable to assess consistency (1 trial); Imprecise; No reporting bias detected | Single trial; Outcome based on SF-36; reported as secondary outcome | Fair | Insufficient | 1 trial conducted in Australia; Applicability limited due to insufficient evidence
KQ 1. Benefits, maternal; Hypertensive disorders of pregnancy | k=5 RCTs; N=14,468 | No statistically significant difference for iron supplementation vs. placebo or no iron (5 trials; RR, 1.24 [95% CI, 0.75 to 2.06]; I^2^=48%).; No statistically significant interaction in stratified analyses by HDI country or supplement dose. | Inconsistent; Imprecise; Some reporting bias detected | Poorly defined outcome definition: 3 studies reported pregnancy-induced hypertension, 1 study reported preeclampsia and PIH, 2 studies reported the category of hypertensive diseases of pregnancy | Fair | Low for no effect of iron supplementation on hypertensive disorders of pregnancy | Studies conducted in Ireland, Iran (3), and rural China; Stratified analysis by HDI country or supplement dose did not affect results
KQ 1. Benefits, maternal; Gestational diabetes | k=2; N=2,214 | Two studies reported no statistically significant differences in rates of gestational diabetes for iron supplementation vs. placebo. | Consistent; Imprecise; No reporting bias detected | Diagnostic criteria defined in one of two studies | Fair | Insufficient | Studies conducted in Hong Kong and Iran; unclear diagnostic criteria
KQ 1. Benefits, maternal; Cesarean delivery | k=8 RCTs; N=6,160 | No statistically significant difference for iron supplementation vs. placebo or no iron (8 trials; RR, 1.01 [95% CI, 0.90 to 1.14]; I^2^=42.7%).; In 1 trial (n=1,164): Reduced risk of cesarean delivery for 60 mg elemental iron daily vs. placebo (25.2% vs. 33.1%; OR, 0.58 [95% CI, 0.37 to 0.89]).; No statistically significant interaction in stratified analyses by HDI country or supplement dose. | Inconsistent; Some imprecision; No reporting bias detected | Cesarean delivery may occur for a variety of indications, including elective reasons | Fair | Low for no effect on cesarean delivery | Studies conducted in Ireland, Hong Kong, Australia, U.S., Iran (3), rural China. Cesarean delivery rates were unusually high in two studies; Stratified analysis by HDI country or supplement dose did not affect results
KQ 1. Benefits, maternal; Hemorrhage | k=2 RCTs; N=341 | Two studies report no statistically significant difference in rates of maternal hemorrhage. | Consistent; Imprecise; No reporting bias detected | Low event rates in both studies | Fair | Insufficient for maternal hemorrhage | Studies conducted in Ireland and Iran
KQ1. Benefits, maternal; Iron deficiency anemia | k=7 RCTs; N=4,045 | Iron supplementation associated with statistically significant reduced risk of IDA vs. placebo or no iron:; 3rd trimester: 3 trials; RR, 0.63 (95% CI, 0.41 to 0.97); I^2^=0%; ARD, −4% (95% CI, −8% to 0%); Term: 4 trials; RR, 0.40 (95% CI, 0.26 to 0.61); I^2^=20.5%; ARD, −10% (95% CI, −16% to −3%); Statistically significant difference in stratified analyses, at term:; By HDI country: very high HDI: RR, 0.29 (95% CI, 0.15 to 0.55); I^2^=0.0%; ARD, −12% (95% CI, −19% to −6%) vs. medium to high HDI: RR, 0.49 (95% CI, 0.38 to 0.62); I^2^=NA; ARD, −5% (95% CI, −16% to 5%); By supplement dose: low dose: RR, 0.28 (95% CI, 0.12 to 0.68); I^2^=NA; ARD, −8% (95% CI, −13% to −3%) vs. high dose: RR, 0.42 (95% CI, 0.24 to 0.71); I^2^=21.0%; ARD, −11% (95% CI, −19% to −2%) | Consistent; Some imprecision; No reporting bias detected | Variable doses of iron supplements | Fair | Moderate for reduced risk of IDA during third trimester and at term | Studies conducted in the U.S. (3) Iran, Australia, Denmark, and rural China; similar results in subgroup analysis by country; The clinical significance of differences is uncertain
KQ1. Benefits, maternal; Iron deficiency | k=9 RCTs; N=16,556 | Iron supplementation associated with statistically significant reduced risk of ID vs. placebo or no iron:; 3rd trimester: 4 trials; RR, 0.70 (95% CI, 0.53 to 0.92); I^2^=77.4%; ARD, −17% (95% CI, −24% to −10%); Term: 6 trials; RR, 0.47 (95% CI, 0.33 to 0.67); I^2^=81.9%; ARD, −34% (95% CI, −46% to −22%); Mostly statistically significant differences in stratified analyses, at term:; By HDI country: very high HDI: RR, 0.35 (95% CI, 0.18 to 0.65); I^2^=79.3%; ARD, −44% (95% CI, −63% to −25%) though medium to high HDI analysis showed no difference; By supplement dose: low dose: RR, 0.57 (95% CI, 0.46 to 0.69); I^2^=0.0%; ARD, −32% (95% CI, −52% to −11%) vs. high dose: RR, 0.26 (95% CI, 0.09 to 0.77); I^2^=86.0%; ARD, −36% (95% CI, −54% to −18%) | Consistent; Some imprecision; No reporting bias detected | Study heterogeneity (I^2^) was high; Variable doses of iron supplements | Fair | Moderate for reduced risk of iron deficiency during third trimester and at term | Studies conducted in the U.S. (2), Norway (2), Iran, Australia, rural China (2), Denmark; Largest studies in rural China; analysis stratified by country showed similar results for very high HDI countries, but the medium to high countries analysis was no longer statistically significant; The clinical significance of differences is uncertain
KQ1. Benefits, maternal; Anemia | k=9 RCTs; N=20,330 | Iron supplementation associated with statistically significant decreased risk of anemia vs. placebo or no iron:; 3rd trimester: 7 trials; RR, 0.71 (95% CI, 0.51 to 0.97); I^2^=64.2%; 3 studies were statistically significant; ARD, −7.97% (95% CI, −15.28% to −0.66%); Term: 4 trials; RR, 0.43 (95% CI, 0.26 to 0.72); I^2^=43.7%; ARD, −11.73% (95% CI, −14.87 to −8.60%); Mostly statistically significant differences in stratified analyses, at term:; By HDI country: very high HDI: RR, 0.22 (95% CI, 0.06 to 0.84); I^2^=49.3%; ARD, −12.42% (95% CI, −18.76% to −6.08%) vs. medium to high HDI: RR, 0.53 (95% CI, 0.43 to 0.66); I^2^=NA; ARD, −11.67% (95% CI, −15.48% to −7.87%); By supplement dose: low dose: RR, 0.45 (95% CI, 0.25 to 0.82); I^2^=NA; ARD, −8.54% (95% CI, −14.76% to −2.33%) vs. high dose: RR, 0.22 (95% CI, 0.05 to 1.02); I^2^=61.1%; Anemia rates ranged from 0% to 45% in the supplementation and 4.5% to 61% in the placebo group. | Inconsistent; Imprecise; Some reporting bias detected | Type of anemia not defined in most studies | Fair | Low | Studies conducted in the U.S. (2), Norway, Australia, rural China (3), Denmark; Largest studies conducted in rural China
KQ1. Benefits, maternal; Hemoglobin | k=15 RCTs; N=20,069 | Findings were inconsistent during the 3rd trimester and postpartum, and mostly significant at term with higher hemoglobin values with supplementation vs. placebo.; Hemoglobin levels ranged from 11.0 to 13.9 g/dL in the supplementation and 10.5 to 13.4 g/dL in the placebo group. | Inconsistent; Imprecise; No reporting bias detected | Hemoglobin values decrease during pregnancy due to physiologic blood volume expansion and, in isolation, have unclear clinical significance | Fair | Low for increased hemoglobin | Studies conducted in the U.S. (3), Iran (5), Hong Kong, Australia, Ireland, Norway, Denmark, and rural China (2)
KQ1. Benefits, maternal; Serum ferritin | k=13 RCTs; N=19,075 | Reported ferritin levels were inconsistent during the 3rd trimester and postpartum, and mostly significant at term with higher serum ferritin values with supplementation vs. placebo in most studies.; Serum ferritin ranged from 7.4 to 34 µg/L in the supplementation group and 6.0 to 26 µg/L in the placebo group. | Inconsistent; Imprecise; Reporting bias not detected | Ferritin levels are associated with inflammation and in isolation, have unclear clinical significance | Fair | Low for increased serum ferritin | Studies conducted in the U.S. (3), Hong Kong, Iran (3), Australia, Ireland, Norway, Denmark, rural China (2); The clinical significance of these findings remains unclear
KQ 1. Benefits, infant; Mortality | k=6 trials; N=17,863 | Five trials reported no statistically significant differences between maternal iron supplementation and infant mortality, while 1 study reported a statistically significant difference in rates of neonatal deaths (1.1% vs. 2.0%, RR, 0.53 [95% CI, 0.29 to 0.97]). | Some inconsistency; Imprecise; No reporting bias detected | Not a prespecified outcome in any study; event rates were generally low | Fair | Insufficient | Studies conducted in Ireland, rural China (2), Australia, U.S., and Iran
KQ 1. Benefits, infant; Preterm birth | k=5 RCTs; N=18,714 | No statistically significant difference for iron supplementation vs. placebo (5 trials; RR, 0.92 [95% CI, 0.81 to 1.04]; I^2^=0%).; No statistically significant difference in stratified analyses by HDI country or supplement dose. | Consistent; Precise; No reporting bias detected | Reported as a secondary outcome | Fair | Moderate for no effect of iron supplementation on preterm birth | Studies conducted in Hong Kong, Iran (3), rural China (2); Stratified analysis by HDI country or supplement dose did not affect results
KQ 1. Benefits, infant; Small for gestational age | k=4 RCTs; N=6,803 | No statistically significant difference for iron supplementation vs. placebo (4 trials; RR, 0.94 [95% CI, 0.67 to 1.31]; I^2^=75.5%).; No statistically significant difference in stratified analyses by HDI country or supplement dose, with one exception: the 1 very high HDI trial (RR, 0.48 [95% CI, 0.26 to 0.87]). | Inconsistent; Imprecise; No reporting bias detected | Reported as a secondary outcome | Fair | Insufficient | Studies conducted in Hong Kong, rural China, and Iran
KQ1. Benefits, infant; Low birth weight | k=6 RCTs; N=17,261 | No statistically significant difference for iron supplementation vs. placebo (6 trials; RR, 0.95; [95% CI, 0.79 to 1.14]; I^2^=0.0%).; No statistically significant difference in stratified analyses by HDI country or supplement dose. | Some inconsistency; Some imprecision; No reporting bias detected | Reported as a secondary outcome | Fair | Moderate for no effect of iron supplementation on low birth weight | Studies conducted in Ireland, Iran, rural China (2), Australia, U.S.; Stratified analysis by HDI country or supplement dose did not affect results
KQ1. Benefits, infant; Hematologic outcomes | k=2 RCTs; N=12,943 | Infant hemoglobin and anemia reported at 6 months and 1 year in 1 trial, and infant hemoglobin, ferritin, ID, and IDA reported in another trial at 6 months.; No statistically significant differences reported between groups for any hematologic indices or time points. | Consistent; Imprecise; No reporting bias detected | Changes in infant intermediate outcomes up to 1 year could be multifactorial; only the smaller trial (n=430) reported ID and IDA outcomes and event rates were low | Fair | Insufficient | Studies conducted in rural China and Australia
KQ 2. Harms | k=12 RCTs; N=22,716 | 12 trials (11 included in KQ1) assessed harms of routine iron supplementation in pregnant women.; Most reported harms included transient treatment effects such as nausea, constipation, and diarrhea, and all but one found no difference in harms; 1 large trial conducted in rural China found a higher rate of gastrointestinal discomfort for those receiving supplementation (3.6% vs. 2.3%; RR, 1.59 [95% CI, 1.28 to 1.97]).; 9 trials found no statistically significant differences in nonadherence to supplementation vs. placebo between groups; however, 1 trial had lower nonadherence in the supplementation than the placebo group. | Mostly consistent; Some imprecision; Some reporting bias detected | Outcomes mostly reported as ad hoc events | Fair | Moderate for no major harms and some transient side effects of prenatal iron supplementation | Studies conducted in Hong Kong, the U.S. (3), Norway, rural China (3), Australia, Iran (2), Norway
KQ 3. Association | k=1 observational study; N=20,690 | Response to iron therapy was associated with a reduction in the odds of preeclampsia and preterm delivery compared with those with untreated anemia or those who did not respond to treatment. | Unable to assess consistency; Imprecise; Reporting bias detected | Inconsistent methods for defining anemia; included participants already using iron supplementation; lack of reporting on methods for outcome assessment; unclear documentation of ID or use of supplementation; unclear classification and reporting of symptoms. | Fair | Insufficient | Conducted in U.S.; some participants already using iron supplementation; lack of information on dosing, timing, or duration of treatment

Abbreviations: ARD, adjusted risk difference; CI, confidence interval; ID, iron deficiency; IDA, iron deficiency anemia; HDI, Human Development Index; KQ, Key Question; NA, not applicable; OR, odds ratio; PIH, pregnancy-induced hypertension; RCT, randomized controlled trial; RR, relative risk; U.S., United States.

Table 10 Summary of Evidence for Screening for Iron Deficiency and Iron Deficiency Anemia During Pregnancy

Key question | Number of studies (k); Number of participants (n); Study design | Summary of findings by outcome | Consistency/precision; Reporting bias | Body of evidence limitations | Overall quality | Strength of evidence | Applicability
KQ 1. Screening benefits | No studies | NA | NA | NA | NA | Insufficient | NA
KQ 2. Screening harms | No studies | NA | NA | NA | NA | Insufficient | NA
KQ 3. Treatment benefits | No studies | NA | NA | NA | NA | Insufficient | NA
KQ 4. Treatment harms | No studies | NA | NA | NA | NA | Insufficient | NA
KQ 5. Association; (Same KQ as KQ 3 in the supplementation framework) | k=1 observational study; N=20,690 | Response to iron therapy was associated with a reduction in the odds of preeclampsia and preterm delivery compared with those with untreated anemia or those who did not respond to treatment. | Unable to assess consistency; Imprecise; Some reporting bias detected | Inconsistent methods for defining anemia; included participants already using iron supplementation; lack of reporting on methods for outcome assessment; unclear documentation of ID or use of supplementation; unclear classification and reporting of symptoms. | Fair | Insufficient | Conducted in U.S.; some participants already using iron supplementation; lack of information on dosing, timing, or duration of treatment

Abbreviations: ID, iron deficiency; KQ, Key Question; NA, not applicable; U.S., United States.

Despite the inclusion of data from five additional RCTs of supplementation,^70,72,80,85,86^ conclusions were consistent with findings from the previous USPSTF review.^4^ Specifically, iron supplementation decreases the risk of ID or IDA during pregnancy and at delivery, without evidence of improvement in maternal or infant clinical outcomes. As in the prior USPSTF review, no studies evaluated benefits or harms of screening. Expanding the scope to assess the impact of iron supplementation or screening on ID alone or inclusion of trials from high HDI index countries (including rural China) did not impact results. The three newly included studies conducted in rural China had the largest sample sizes (n=12,513,^72^ 3,929,^85^ and 2,371^86^) and represented populations from countries with lower HDI (high vs. very high). With the addition of these trials, results remained consistent with findings from the prior review.

Sixteen trials of iron supplementation versus placebo or no supplementation evaluated clinical outcomes for pregnant individuals and their infants. Limited evidence from one study indicated no differences in maternal quality of life up to 4 years postpartum for iron supplementation during pregnancy compared with placebo. There were also no clear effects of prenatal iron supplementation on maternal clinical outcomes, including hypertensive disorders of pregnancy, gestational diabetes, or cesarean delivery, but estimates were imprecise. Results were somewhat inconsistent for cesarean delivery, with one fair-quality, large trial finding supplementation was associated with reduced risk of cesarean delivery but eight trials finding no difference. Effects on cesarean delivery are difficult to interpret due to lack of information on indications (e.g., elective or urgent) and the unclear causal association with ID or IDA. Some observational studies^100–102^ not included for this review have examined supplement use versus no use and effects on gestational diabetes and suggest iron supplementation may increase the risk of gestational diabetes, but results are susceptible to residual confounding.

Iron supplementation was not associated with rates of preterm delivery, low birth weight infants, or infants small for gestational age. There was insufficient evidence to assess the effect of prenatal iron supplementation on infant mortality due to inconsistent and imprecise estimates and low event rates in most trials. One trial reporting a decreased risk of infant mortality was conducted in China and favored supplementation. Infant mortality incidence in the U.S trial were too low to determine the direction of effect. Findings regarding infant outcomes were limited by relatively small numbers of trials (e.g., six trials reporting preterm delivery, three trials reporting small for gestational age, and six trials for low birth weight) and insufficient power in some trials to evaluate these outcomes.

Sixteen good- or fair-quality trials^63,64,66–69,72,76,78,81,83,85,86,88,89^ were consistent with the prior USPSTF review in finding an association between maternal iron supplements and improvement in hematologic parameters or incidence of IDA compared with placebo or no iron supplements, but the clinical significance of the findings remains unclear. Assessment and reporting of harms were limited, but no serious adverse effects were reported, including iron overload. Although one trial reported an increased risk of gastrointestinal side effects, other trials did not find increased risk with iron supplementation compared with placebo, and the direction of these effects was inconsistent.

As in the prior USPSTF review, no trial evaluated outcomes of screening versus no screening for IDA in pregnant persons; there were also no trials of screening for ID. One study added to this review provided insufficient evidence to evaluate the association between a change in maternal iron status and clinical outcomes and had serious methodological limitations.

In other reviews, data are mixed on the association between routine maternal iron supplementation and infant outcomes. An older literature review found that maternal anemia diagnosed at entry to prenatal care was associated with an increased risk for preterm delivery, but anemia diagnosed during the third trimester was not associated with these negative outcomes.^103^ Studies have evaluated the effect of treatment for IDA, including Cochrane reviews of up to 49 trials conducted in mostly developing countries, that compared daily oral iron versus intermittent oral iron supplementation or assessed iron treatment during pregnancy and found overall methodologically poor evidence showing no effect of supplementation or treatment on infant outcomes, including low birth weight, delayed development, preterm birth, infection, and postpartum hemorrhage.^104–107^ In the 2015 USPSTF review,^4^ trial and controlled observational study evidence from countries similar to the United States demonstrated inconsistent effects of routine supplementation, screening, and screening-related treatment on maternal and infant outcomes. Most studies included in this review focused on pregnant persons at average risk for anemia and excluded pregnant persons with very low hematologic indices at baseline or preexisting anemia or related chronic conditions. Therefore, results of this review may not apply to settings where pregnant individuals have lower baseline hematologic indices, preexisting anemia, or higher incidence of severe anemia.

## Limitations

This review had several limitations. First, we excluded non-English–language articles, which could result in language bias, though we did not identify any non-English–language studies that would have met inclusion criteria. Second, publication bias was not formally assessed with graphical or statistical methods^108^ because of small numbers of studies and differences in study design, populations, and outcomes assessed. Third, some trials eligible for inclusion because of country categorization as high on the HDI (e.g., Hong Kong, rural China, Iran) may have reduced applicability to the United States due to differences in nutritional status, diet, resources, infrastructure, or other factors.^60^ However, stratified analyses did not indicate subgroup differences based on HDI category. Fourth, due to anticipated statistical heterogeneity with regard to populations, setting, rates of ID or IDA, supplementation dose and timing, and other factors, the DerSimonian and Laird random-effects model was used to pool studies, which may result in overly narrow confidence intervals when heterogeneity is present, particularly when the number of studies was small.^109^ To evaluate statistical heterogeneity, subgroup analysis was performed to assess the sensitivity of results to variations across study characteristics, including country HDI rating and low and high supplementation dosing based on elemental iron doses. Results did not indicate statistically significant subgroup effects based on these characteristics (Table 2). However, the utility of stratified analyses was limited by relatively small numbers of trials.

## Emerging Issues/Next Steps

Screening and routine preventive supplementation of asymptomatic pregnant persons is common, though data on the reported incidence of IDA are limited. Observational studies report some differences in rates of screening and supplementation in key groups such as WIC recipients and by race or ethnicity. However, the influence of conflicting guidelines, variable clinical practices, changing cutoffs for diagnosis, and access to healthcare services may affect the accuracy of reported rates. Studies that evaluate the impact of social determinants of health, race or ethnicity, diagnostic criteria, age, cultural factors, or health literacy would help inform strategies to reduce disparities in diagnosis of ID or IDA and provision of iron (as treatment for ID or IDA, or as a supplement). New research in prenatal screening and iron supplementation appears to be very limited, likely due to current clinical recommendations, common U.S. practices of already routinely supplementing or screening for IDA during prenatal care, or that this area may not be perceived as high priority. Nonetheless, studies addressing effects of treating ID or IDA or routine iron supplementation on maternal or neonatal outcomes could better inform the utility of routine screening or supplementation.

## Relevance for Priority Populations

No study evaluated how outcomes of supplementation varied by population, including those defined by race or ethnicity. Observational studies suggest potential disparities in the incidence of ID and IDA by socioeconomic status and race or ethnicity, but data are difficult to interpret due to variation in practice guidelines and variability in diagnostic cutoffs by race or ethnicity and may be impacted by access to healthcare services. For example, two of the included iron supplementation trials conducted in the United States primarily included those eligible for WIC^66,83^ or were composed of a largely (>50%) Black population.^83^ Both of these trials ended the placebo phase of the trial at 28 weeks’ gestation, after which all participants in the study received routine iron supplementation, therefore limiting applicability to supplementation that persists through term. These studies were carried forward from the prior review and had findings consistent with other studies identified for this review.

## Future Research

Research is needed to clarify long-term effects of iron supplementation during pregnancy on maternal and infant health outcomes. Trials should use standardized definitions for hypertensive disorders of pregnancy and anemia and report outcomes for emergency cesarean delivery separately, including those with complications, and report indications for procedures. Few studies addressed postpartum outcomes, which varied widely and were less frequently reported. In the absence of more definitive data on the effects of supplementation or treatment for ID or IDA on health outcomes, research on the association between improvements in maternal hematologic outcomes following prenatal iron supplementation and health outcomes would be useful to understand the clinical implications of the positive effects of supplementation on hematological outcomes and how these changes impact clinical outcomes. Increased focus on efforts to reduce U.S. maternal morbidity and mortality rates, coupled with ongoing quality initiatives^110^ to recognize and prevent postpartum hemorrhage highlight the need for additional research that evaluates the association between less severe IDA or ID without anemia in asymptomatic pregnant populations and both the effects on the outcome of postpartum hemorrhage and the associated risk of postpartum hemorrhage. Additional trials with sufficient sample sizes and duration of followup would strengthen the evidence base informing infant and maternal benefits and harms of iron supplementation during pregnancy.

## Conclusions

Routine prenatal iron supplementation reduces the incidence of ID and IDA during pregnancy, but evidence on maternal and infant health outcomes is limited or indicates no benefit. Routine iron supplementation is not associated with significant maternal harms. No studies addressed the benefits or harms of screening for ID or IDA during pregnancy. Research is needed to understand the association between changes in maternal iron status measures and health outcomes.