# Chapter 3 Results

A total of 5,788 new references from electronic database searches, manual searches of recently published studies, and prior report references were reviewed, and 376 full-text papers were evaluated for inclusion. We included 18 studies (reported in 28 publications^63–90^), including 17 RCTs and one observational study of association^67^ for the supplementation framework. The same association study applied to Key Question 5 in the screening framework, but otherwise no studies evaluated the effectiveness of screening for ID or IDA. Twelve RCTs^63,64,66,68,69,74,76,77,81,83,88,89^ were carried forward from the prior USPSTF report^4^ addressing the supplementation framework; no association studies were included in the prior report. Five RCTs^70,72,80,85,86^ and the association study^67^ were newly added for this update. One of the supplementation trials only reported harms^70^ and therefore was not included in Key Question 1. Included studies and quality ratings are described in Appendix B.

## Routine Iron Supplementation During Pregnancy

### Key Question 1 What Are the Benefits of Routine Iron Supplementation During Pregnancy on Maternal and Infant Health Outcomes?

#### Summary

##### Maternal Outcomes

- Routine iron supplementation during pregnancy was associated with a statistically significant decreased risk of maternal IDA during the third trimester (3 trials; 9.1% vs. 13.8%; RR, 0.63 [95% CI, 0.41 to 0.97]; I^2^ =0%; ARD, −3.9% [95% CI, −7.7% to 0.02%]) and at term (4 trials; 8.6% vs. 19.8%; RR, 0.40 [95% CI, 0.26 to 0.61]; I^2^=20.5%; ARD, −9.59% [95% CI, −16.2% to −2.98%]), maternal ID during the third trimester (4 trials; 40.3% vs. 57.1%; RR, 0.70 [95% CI, 0.53 to 0.92]; I^2^=77.4%; ARD, −16.95% [95% CI, −24.13% to −9.8%]) and at term (6 trials; 46% vs. 70%; RR, 0.47 [95% CI, 0.33 to 0.67]; I^2^=81.9%; ARD, −34.25% [95% CI, −46.49% to −22.01%]), and anemia during the third trimester (7 trials; 18.1% vs. 26.0%; RR, 0.71 [95% CI, 0.51 to 0.97]; I^2^=64.2%; ARD, −7.97% [95% CI, −15.28% to −0.66%]) and at term (4 trials; 10.9% vs. 22.5%; RR, 0.43 [95% CI, 0.26 to 0.72]; I^2^=43.7%; ARD, −11.73% [95% CI, −14.87% to −8.60%]) compared with placebo or no iron supplementation. For ID and IDA, stratified analysis by HDI country and dose resulted in similar findings.
- Routine iron supplementation was not associated with reduced risk of hypertensive disorders of pregnancy compared with placebo, although the estimate was imprecise (5 trials; 4.7% vs. 3.1% [pooled, weighted rates]; RR, 1.24 [95% CI, 0.75 to 2.06]; I^2^=48.0%)
- Routine iron supplementation and placebo were associated with similar risk of cesarean delivery (8 trials; 42.8% vs. 41.5%; RR, 1.01 [95% CI, 0.90 to 1.14]; I^2^=42.7%); clinical indications for cesarean delivery were not reported in any study and estimates were imprecise.
- There were no statistically significant differences between routine iron supplementation during pregnancy versus placebo or no supplementation and quality of life (one trial), risk of gestational diabetes mellitus (two trials), or risk of maternal hemorrhage (two trials).

##### Infant Outcomes

- There were no statistically significant differences between iron supplementation during pregnancy versus placebo in risk of preterm birth (5 trials; 5.5% vs. 6.0%; RR, 0.92 [95% CI, 0.81 to 1.04]; I^2^=0.0%), infants with low birth weight (6 trials; 2.7% vs. 2.9%; RR, 0.95 [95% CI, 0.79 to 1.14]; I^2^=0.0%), or infants small for gestational age (4 trials; 15.3% vs. 15.2%; RR, 0.94 [95% CI, 0.67 to 1.31]; I^2^=75.5%), although some imprecision in estimates was present.
- There were no statistically significant differences between iron supplementation during pregnancy versus placebo in infant hematologic indices at 6-months or 1-year followup in two trials.

#### Evidence

Sixteen trials (in 26 publications) compared the effects of routine preventive iron supplementation versus no supplementation during pregnancy. Twelve trials (in 14 publications)^63,64,66,68,69,74,76–78,81,83,87–89^ were carried forward from the prior review^4^ (Appendix B Table 1). Four additional trials^65,71–73,75,80,82,84–86^ and two new secondary publications^79,90^ of older trials^74,77^ were identified for this update. Some of the added studies for this update were published prior to the 2015 USPSTF review but were identified during the expanded search because inclusion criteria were less restrictive regarding setting. Three studies were conducted in the United States,^66,76,83^ three studies in China (rural),^72,85,86^ four studies in Iran,^69,80,88,89^ and the others were conducted in Hong Kong,^64^ Australia,^74^ or Europe.^63,68,77,81^ Sample sizes of randomized study participants ranged from 52 to 12,513 participants, although only four studies had more than 1,000 participants. The three newly included studies conducted in rural China had the largest samples sizes (n=12,513,^72^ 3,929,^85^ and 2,371^86^). Most studies included pregnant persons at average risk for anemia and excluded pregnant persons with very low hematologic indices at baseline (<8 to 11 g/dL), preexisting anemia, or related chronic conditions.^63,64,66,68,72,74,76,80,83,86,88,89^ Baseline hemoglobin levels ranged from 11.9 to 14.3 g/dL. Several studies reported providing treatment beyond supplementation if hematologic indices dropped too low during the course of the study.^64,68,74,76,80,88,89^ The majority of studies enrolled pregnant persons in their 20s, although two studies also included adolescents.^76,83^ One Australian study^74^ reported 95 percent participants identified as White race and ethnicity; one U.S. study from Ohio reported 56 to 57 percent White, 24 to 25 percent Black, and 16 to 17 percent Hispanic race and ethnicity,^66^ and another U.S. study from North Carolina reported 31 to 37 percent White and 58 to 65 percent Black race and ethnicity.^83^ These two studies were limited to those eligible for or participating in the Special Supplemental Nutrition Program for Women, Infants, and Children (WIC) services. Race and ethnicity and socioeconomic status were not reported in the third U.S.-based study that was set in a private group practice in Wisconsin.^76^ In other studies, participants largely represented the country of origin or race and ethnicity was not reported. No studies stratified results according to population characteristics.

The timing of supplementation varied from the first prenatal visit up to 20 weeks’ gestation and continued until delivery; mean gestational age at enrollment ranged from 11 to 16 weeks but was not always reported. In two of the U.S. studies, all participants in the placebo group were reassigned to supplementation at 26 to 29 weeks’ gestation. As such, we only analyzed results relevant to that time period.^66,83^ Outcomes were measured during the third trimester, at delivery, or included followup into the postpartum period (1 day to 6 months postpartum); one study included health-related quality of life followup up to 4 years.^90^ Supplement dosing ranged from 20 to 200 mg of elemental iron daily. Intervention groups in the majority of studies received 30 to 60 mg of elemental iron daily, and two smaller studies used higher doses of either 120 mg^63^ or 200 mg.^81^ Nonadherence, usually based on pill counts or a similar measure, ranged from 4.5 to 68 percent and were mostly similar between groups in the 10 studies reporting adherence;^64,66,68,72,74,76,81,83,85,86^ however, adherence data were not available for all included participants.

Twelve studies were rated fair quality^63,64,66,68,69,76,77,80,81,83,85,86^ and four studies were rated good quality^72,74,88,89^ (Appendix B Table 2). Methodologic limitations of fair-quality studies included unclear randomization and allocation concealment methods; unclear masking of outcome assessors; high or unclear loss to followup or differential loss to followup; and inadequate randomization methods. As described in the methods, poor-quality studies were excluded from the review.

#### Maternal Clinical Outcomes

##### Quality of Life

One good-quality trial conducted in Australia (n=430) included in the prior report reported no statistically significant differences in a standardized clinical quality of life measurement, the Short-Form 36 (SF-36).^74,90^ Scores were measured at 36 weeks of gestation, 6 weeks postpartum, and 6 months and 4 years postpartum, and compared those taking 20 mg iron supplementation starting at 20 weeks of gestation versus placebo on the form’s eight health concepts of physical functioning, role-physical, bodily pain, general health, vitality, social functioning, role-emotional, and general mental health (Table 3).

Table 3 Effect of Maternal Iron Supplementation vs. Placebo on Maternal Health and Clinical Outcomes

Study, year; Quality | Country; N randomized | Iron supplement dose and formulation, initiation | Quality of life | Cesarean delivery | Gestational diabetes | Hypertensive disorders of pregnancy | Hemorrhage
Barton 1994^63^; Fair | Ireland; N=97 | 120 mg elemental iron daily starting at end of first trimester | - | 7.5% (4/53) vs. 9.1% (4/44), RR 0.83 (95% CI, 0.22 to 3.13) | - | Hypertensive disorder: 7.5% (4/53) vs. 9.0% (4/44), RR 0.83 (95% CI, 0.22 to 3.13) | Antepartum hemorrhage: 5.7% (3/53) vs. 4.5% (2/44), RR 1.25 (95% CI, 0.22 to 7.12)
Chan 2009^64^; Fair | Hong Kong; N=1,164 | 60 mg elemental iron daily starting at <16 weeks’ gestation | - | 25.2% (115/457) vs. 33.1% (155/468), RR 0.76 (95% CI, 0.62 to 0.93) | At 28 weeks: 9.9% (56/565) vs. 10% (60/599), OR 1.04, (95% CI, 0.7 to 1.53), RR 0.99 (95% CI, 0.70 to 1.40); Cumulative at 36 weeks: 13% (72/565) vs. 13% (77/599), RR 0.99 (95% CI, 0.73 to 1.34) | - | -
Falahi 2011^69^; Fair | Iran; N=148 | 60 mg elemental iron daily starting at <20 weeks’ gestation | - | - | - | Pregnancy-induced hypertension: 1.4% (1/70) vs. 0% (0/78), RR 3.34 (95% CI, 0.14 to 80.64) | -
Liu 2013^72^; Good | China (rural); N=12,513 | 30 mg elemental iron daily starting at <20 weeks’ gestation | - | - | - | Pregnancy-induced hypertension: 6.3% (374/5,933) vs. 7.1% (423/5,923), OR 0.88 (95% CI, 0.76 to 1.01), RR 0.88 (95% CI, 0.77 to 1.01) | -
Makrides 2003^74,90^; Good | Australia; N=430 | 20 mg elemental iron daily starting at 20 weeks’ gestation | SF-36: no significant differences in any of the 8 health concepts at 36 weeks of gestation, 6 weeks, 6 months, or 4 years postpartum | 23.6% (51/216) vs. 22.0% (47/214), RR 1.08 (95% CI, 0.76 to 1.52) | - | -
Meier 2003^76^; Fair | U.S.; N=144 | 60 mg elemental iron daily starting at 1st prenatal visit | - | Adolescents: 20% (4/20) vs. 6.2% (1/16), RR 3.20 (95% CI, 0.40 to 25.88); Adults: 14.3% (5/38) vs. 25% (9/36), RR 0.53 (95% CI, 0.20 to 1.42); Combined: 16% vs. 19%, p=NS | - | - | -
Ouladsahebmadarek, 2011^80^; Fair | Iran; N=960 | 30 mg elemental iron daily starting at 13 weeks’ gestation | - | 51.2% (210/410) vs. 45.7% (170/372), RR 1.12 (95% CI, 0.97 to 1.30) | 0.5% (2/410) vs. 0.8% (3/372), RR 0.61 (95% CI, 0.10 to 3.60) | Pregnancy-induced hypertension: 6.7% (25/410) vs. 3.4% (14/372), RR 1.62 (95% CI, 0.86 to 3.07); Preeclampsia: 3.9% (16/410) vs. 2.7% (10/372), RR 1.45 (95% CI, 0.67 to 3.16) | -
Zhao 2015^86^; Fair | China (rural); N=2,371 | 60 mg elemental iron daily starting at enrollment | - | 70.1% (571/815) vs. 66.0% (527/799), RR 1.06 (95% CI, 0.9933 to 1.14) | - | - | -
Ziaei 2007^89^; Good | Iran; N=750 | 50 mg elemental iron daily starting at 20 weeks’ gestation | - | 25.9% (96/370) vs. 23% (82/357), RR 1.13 (95% CI, 0.87 to 1.46) | - | Hypertensive disorder: 2.7% (10/370) vs. 0.8% (3/357), RR 3.22 (95% CI, 0.89 to 11.59) | -
Ziaei 2008^88^; Good | Iran; N=244 | 50 mg elemental iron daily starting at 20 weeks’ gestation | - | 10.5% (12/114) vs. 10.8% (13/120), RR 0.97 (95% CI, 0.46 to 2.04) | - | - | Postpartum hemorrhage: 1.8% (2/114) vs. 1.7% (2/120), RR 1.05 (95% CI, 0.15 to 7.35)

Abbreviations: CI, confidence interval; NS, not significant; OR, odds ratio; RR, relative risk; US, United States.

Bolded values show a statistically significant difference.

##### Hypertensive Disorders of Pregnancy

Five (three fair- and two good-quality) trials (N=14,468) reported an inconsistent effect of iron supplementation on risk of hypertensive disorders of pregnancy (Table 3).^63,69,72,80,89^ Three were included in the prior report. Studies were conducted in high and very high HDI countries with supplemental dosing from 30 to 120 mg elemental iron initiated at 13 to 20 weeks’ gestation. Hypertensive disorders were described as pregnancy-induced hypertension in three studies^69,72,80^ and were poorly defined in two studies.^63,89^ Routine iron supplementation was not associated with a reduced risk of hypertensive disorders of pregnancy compared with placebo (5 studies; N=13,610; 4.7% vs. 3.1% [pooled, weighted rates]; RR, 1.24 [95% CI, 0.75 to 2.06]; I^2^=48%; Figure 3),^63,69,72,80,89^ although the estimate was imprecise. While some statistical heterogeneity was present, no individual study reported a statistically significant effect. Stratified analysis by HDI country and dose resulted in similar findings (Appendix C Figures 1 and 2; Table 2). In the trial that reported preeclampsia, there was also no difference between supplementation versus placebo on this outcome (3.9% vs. 2.7%; RR, 1.45 [95% CI, 0.67 to 3.16]).

Figure 3 Meta-Analysis: Hypertensive Disorders of Pregnancy

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Figure 3 is a forest plot of hypertensive disorders of pregnancy. The overall risk ratio for five studies is 1.24 (95% confidence interval 0.75 to 2.06) with an I-squared of 48.0%.

##### Gestational Diabetes

Two fair-quality trials (N=2,124) reported no statistically significant differences between iron supplementation versus placebo in risk of gestational diabetes (Table 3).^64,80^ One trial from Hong Kong, also included in the prior report (n=1,164), found no difference in risk of gestational diabetes between 60 mg iron supplementation beginning at less than 16 weeks’ gestation versus placebo (based on oral glucose tolerance tests at 28 and 36 weeks) (9.9% vs. 10%; odds ratio [OR], 1.04 [95% CI, 0.7 to 1.53]).^64^ A second trial^80^ conducted in Iran (n=960) was newly added and also reported no differences in risk of gestational diabetes for 30 mg iron supplementation beginning in the first trimester versus placebo (criteria not reported; 0.5% vs. 0.8%; RR, 0.61 [95% CI, 0.10 to 3.60]).

##### Cesarean Delivery

Cesarean delivery was reported in eight trials (five fair- and three good-quality; N=6,160; Table 3)^63,64,74,76,80,86,88,89^ comparing groups of pregnant persons receiving 20 to 120 mg iron supplementation beginning in the first or second trimester versus no supplementation. Routine iron supplementation and placebo were associated with similar risk of cesarean delivery (8 studies; N=4,919; 42.8% vs. 41.5%; RR, 1.01 [95% CI, 0.90 to 1.14]; I^2^=42.7%; Figure 4). Findings were similar when analyses were stratified by country HDI category and dose (Appendix C Figures 3 and 4; Table 2). Clinical indications for cesarean delivery were not reported in any study. Five studies were included in the prior review. One large (n=1,164) fair-quality trial conducted in Hong Kong found a statistically significant reduction in the rate of cesarean delivery for pregnant persons receiving 60 mg elemental iron daily versus placebo (25.2% vs. 33.1%; OR, 0.58 [95% CI, 0.37 to 0.89]).^64^ However, seven trials conducted in Australia (n=430), the United States (n=144), Ireland (n=97), Iran (n=727; n=782; n=244), and rural China (n=2,371) demonstrated no effect on cesarean delivery rates for pregnant persons receiving 20 to 60 mg elemental iron supplementation versus placebo.^63,74,76,80,86,88,89^ Two studies from Iran and rural China had unusually high rates of cesarean delivery in the supplementation versus placebo groups, respectively (51.2% vs. 45.8%^80^ and 70.1% vs. 66.0%^86^), but the differences between groups were not statistically significant.

Figure 4 Meta-Analysis: Cesarean Delivery

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Figure 4 is a forest plot of cesarean delivery. The overall risk ratio for nine populations in eight studies is 1.01 (95% confidence interval 0.90 to 1.14) with an I-squared of 42.7%.

##### Hemorrhage

Two studies (N=341), both in the prior report, reported no statistically significant differences in risk of maternal hemorrhage, though rates of this outcome were low (Table 3).^63,88^ A fair-quality study from Ireland (n=97) comparing 120 mg supplemental iron with placebo starting at the end of the first trimester reported no differences in antepartum hemorrhage (5.7% vs. 4.5%; RR, 1.25 [95% CI, 0.22 to 7.12]).^63^ A good-quality study from Iran (n=244) comparing 50 mg elemental iron with placebo starting at 20 weeks’ gestation also reported no differences in risk of postpartum hemorrhage (1.8% vs. 1.7%; RR, 1.05 [95% CI, 0.15 to 7.35]).^88^

#### Maternal Hematologic Outcomes

Sixteen good- or fair-quality trials (N=23,844) reported maternal intermediate outcomes, including hematologic parameters or incidence of ID or IDA (Tables 4–6).^63–66,68,69,71–89^

Table 4 Effect of Maternal Iron Supplementation vs. Placebo on Maternal Hematologic Outcomes: Third Trimester

Study, year; Quality | Timing of measurement | Country; N randomized | Iron supplement dose, formulation, initiation | Hemoglobin, mean | Serum ferritin, mean | Iron deficiency^a^ % | Anemia^b^ % | Iron deficiency anemia^c^ %
Barton 1994^63^; Fair | 3rd trimester, 36 weeks | Ireland; N=97 | 120 mg elemental iron daily starting at end of first trimester | 13.5 vs. 12.6 g/dL, p=0.043 (adjusted for smoking p=0.25) | 32.6 vs. 12.8 µg/L, p=0.04 | - | “No patients were withdrawn from the study due to anemia” | -
Cogswell 2003^66^; Fair | 3rd trimester, 28 weeks | U.S.; N=275 | 30 mg elemental iron daily starting at <20 weeks’ gestation | 11.7 vs. 11.6 g/dL, p=0.499 | 7.4 vs. 7.4 µg/L, p=0.985 | 56.4% (62/110) vs. 65.1% (56/86), RR 0.87 (95% CI, 0.69 to 1.08) | 19.8% vs 26.7%, p=0.251 | 12.7% (14/110) vs. 20.9% (18/86), RR 0.61 (95% CI, 0.32 to 1.15)
Falahi 2011^69^; Fair | 3rd trimester, 28 weeks | Iran; N=148 | 60 mg elemental iron daily starting at <20 weeks’ gestation | - | - | 5.7% (4/70) vs. 24.4% (19/78), RR 0.23 (95% CI, 0.08 to 0.66) | - | 1.4% (1/70) vs. 3.8% (3/78), RR 0.37 (95% CI, 0.04 to 3.49)
Liu 2013^72^; Good | 3rd trimester, 24 to 28 weeks | China (rural); N=12,513 | 30 mg elemental iron daily starting at <20 weeks’ gestation | 12.2 vs. 12.2 g/dL, MD 0.04 (95% CI, 0.01 to 0.07) | - | - | 5.5% (327/5,913) vs. 7.7% (452/5,896), RR 0.72 (95% CI, 0.63 to 0.83) | -
Liu 2013^72^; Good | 3rd trimester, 28 to 32 weeks | China (rural); N=12,513 | 30 mg elemental iron daily starting at <20 weeks’ gestation | 12.4 vs. 12.5 g/dL, p>0.05 | 16.7 vs. 11.3 µg/L, p<0.05 | 35.3% (98/278) vs. 59.6% (168/282), RR 0.59 (95% CI, 0.49 to 0.71) | 7.2% vs. 5.3%, p>0.05 | -
Makrides 2003^74^; Good | 3rd trimester, 28 weeks | Australia; N=430 | 20 mg elemental iron daily starting at 20 weeks’ gestation | 12.0 vs. 11.6 g/dL, MD 0.34 (95% CI, 0.17 to 0.53) | - | - | 9.7% (20/206) vs. 24.9% (51/205), RR 0.39 (95% CI, 0.24 to 0.63) | -
Milman, 1991^77^; Fair | 3rd trimester, 27 to 30 weeks | Denmark; N=207 | 66 mg elemental iron daily starting at 14 to 16 weeks’ gestation | - | - | - | 9.0% vs. 22.4%, RR 0.40 (95% CI, 0.20 to 0.82) | -
Romslo, 1983^81^; Fair | 3rd trimester, 28 to 32 weeks | Norway; N=45 | 200 mg elemental iron starting at ≤10 weeks’ gestation | - | - | - | 9.1% vs. 21.7%, RR 0.42 (95% CI, 0.09 to 1.94) | -
Siega-Riz 2006^83^; Fair | 3rd trimester, 26 to 29 weeks | U.S.; N=429 | 30 mg elemental iron daily starting at <20 weeks’ gestation | 11.4 vs. 11.4 g/dL, p=0.81 | 22.0 vs. 20.3 µg/L, p=0.48 | 53% (85/160) vs. 65% (101/156), RR 0.82 (95% CI, 0.68 to 0.99)^a^ | 21% (34/160) vs. 19% (30/156), RR 1.11 (95% CI, 0.71 to 1.71) | 10% (16/160) vs. 15% (23/156), RR 0.68 (95% CI, 0.37 to 1.23)^b^
Zeng 2008^85^; Fair | 3rd trimester, 28 to 32 weeks | China (rural); N=3,929 (n=411 for this outcome) | 60 mg elemental iron daily starting at 14 weeks’ gestation | 11.0 vs. 10.5 g/dL, MD 0.50 (95% CI, 0.20 to 0.80) | - | - | 45.1% (87/193) vs. 61.0% (133/218), RR 0.74 (95% CI, 0.61 to 0.91) | -
Ziaei 2007^89^; Good | 3rd trimester, timing NR | Iran; N=750 | 50 mg elemental iron daily starting at 20 weeks’ gestation | 13.8 vs 12.6 g/dL, p<0.001 | - | - | - | -

Abbreviations: CI, confidence interval; MD, mean difference; RR, relative risk; US, United States.

a Iron deficiency defined as serum ferritin <12 µg/L.

b Anemia defined as hemoglobin <11.0 g/dL.

c Iron deficiency anemia defined as hemoglobin <11.0 g/dL and serum ferritin <12 µg/L).

Note that definitions used in some studies varied slightly from the above definitions.

Bolded values show a statistically significant difference.

Table 5 Effect of Maternal Iron Supplementation vs. Placebo on Maternal Hematologic Outcomes: Term

Study, year; Quality | Country; N randomized | Iron supplement dose, formulation, initiation | Hemoglobin, mean | Serum ferritin, mean | Iron deficiency^a^ % | Anemia^b^ % | Iron deficiency anemia^c^ %
Barton 1994^63^; Fair | Ireland; N=97 | 120 mg elemental iron daily starting at end of first trimester | 13.7 vs. 12.0 g/dL, p<0.001 | - | - | “No patients were withdrawn from the study due to anemia” | -
Chan 2009^64^; Fair | Hong Kong; N=1,164 | 60 mg elemental iron daily starting at <16 weeks’ gestation | 12.2 vs. 11.8 g/dL, p<0.001 | 30.0 vs. 24.9 µg/L, p<0.003 | - | - | -
Eskeland 1997^68^; Fair | Norway; N=90 | 27 mg elemental iron daily starting at 20 weeks’ gestation | - | - | 41% (20/49) (both iron arms) vs. 85% (17/20), RR 0.48 (95% CI, 0.33 to 0.71) | - | 0% (both iron arms) vs. 14% (4 cases)
Falahi 2011^69^; Fair | Iran; N=148 | 60 mg elemental iron daily starting at <20 weeks’ gestation | 12.3 vs. 12.1 g/dL, p=NS | 28.1 vs. 22.1 µg/L, p=NS | 10.0% (7/70) vs. 28.2% (22/78), RR 0.35 (95% CI, 0.16 to 0.78) | - | 0% vs 0%, p=NS
Makrides 2003^74^; Good | Australia; N=430 | 20 mg elemental iron daily starting at 20 weeks’ gestation | 12.7 vs. 12.0 g/dL, MD 0.69 (95% CI, 0.44 to 0.93) | 21 vs. 14 µg/L, MD 7.1 (95% CI, 4.0 to 10.2) | 35% (65/186) vs. 58% (102/176), RR 0.60 (95% CI, 0.48 to 0.76) | 7% vs. 16%, RR 0.45 (95% CI, 0.25 to 0.82) | 3% (6/198) vs. 11% (20/185), RR 0.28 (95% CI, 0.12 to 0.68)
Meier 2003^76^; Fair | U.S.; N=144 | 60 mg elemental iron daily starting at 1st prenatal visit | Adolescents: 12.2 vs. 11.5 g/dL, p=0.024; Adults: 12.1 vs. 11.7 g/dL, p=0.135 | Adolescents: 12.0 vs. 6.2 µg/L, p=0.010; Adults: 12.9 vs. 7.6 µg/L, p=0.027 | - | - | Adolescents: 5% (1/20) vs. 29% (5/17), RR 0.17 (95% CI, 0.02 to 1.32); Adults: 10.5% (4/38) vs. 22.2% (8/36), RR 0.47 (95% CI. 0.16 to 1.44)
Milman 1994, Milman 1991^77,78^; Fair | Denmark; N=248 | 66 mg elemental iron daily starting at 14-16 weeks’ gestation | 12.7 vs. 11.6 g/dL, p<0.0001 | 22 vs. 14 µg/L, p<0.0001 | 6.3% (4/63) vs. 54.4% (31/57), RR 0.12 (95% CI, 0.04 to 0.31) | 0% vs. 14.3%, RR 0.03 (95% CI, 0.00 to 0.57) | 0% (0/63) vs. 17.5% (10/57), RR 0.04 (95% CI, 0.00 to 0.72)
Ouladsahebmadarek, 2011^80^; Fair | Iran; N=960 | 30 mg elemental iron daily starting at 13 weeks’ gestation | 13.5 vs. 12.5 g/dL, p=0.03 | 26.91 vs. 9.26 µg/dL, p=0.048 | - | - | -
Romslo 1983^81^; Fair | Norway; N=52 | 200 mg elemental iron daily starting within 10 weeks’ gestation | 12.6 vs. 11.3 g/dL, p-value NR | 24.0 vs. 6.0 µg/L, p-value NR | 0% (0/22) vs. 65.2% (15/23), RR 0.03 (95% CI, 0.00 to 0.53) | 4.5% vs. 30.4%, RR 0.15 (95% CI, 0.02 to 1.12) | -
Zhao 2015^86^; Fair | China (rural); N=2,371 | 60 mg elemental iron daily starting at enrollment | 12.2 vs. 11.7 g/dL, p<0.001 | 15.3 vs. 11.1 µg/L, p<0.001 | 56.8% (462/815) vs. 77.1% (618/802), RR 0.74 (95% CI, 0.69 to 0.79) | 13.4% (109/814) vs. 25.1% (201/802), RR 0.53 (95% CI, 0.43 to 0.66) | 10.6% (86/814) vs. 21.7% (174/802), RR 0.49 (95% CI, 0.38 to 0.62)
Ziaei 2008^88^; Good | Iran; N=244 | 50 mg elemental iron daily starting at 20 weeks’ gestation | 13.9 vs. 12.8 g/dL, p<0.0001 | 26.2 vs. 19.1 µg/L, p<0.0001 | - | - | -

Abbreviations: CI, confidence interval; MD, mean difference; NS, not significant; RR, relative risk; US, United States.

a Iron deficiency defined as serum ferritin <12 µg/L.

b Anemia defined as hemoglobin <11.0 g/dL.

c Iron deficiency anemia defined as hemoglobin <11.0 g/dL and serum ferritin <12 µg/L.

Note that definitions used in some studies varied slightly from the above definitions.

Bolded values show a statistically significant difference.

Table 6 Effect of Maternal Iron Supplementation vs. Placebo on Maternal Hematologic Outcomes: Postpartum

Study, year; Quality | Timing of measurement | Country; N randomized | Iron supplement dose, formulation, initiation | Hemoglobin, mean | Serum ferritin, mean | Iron deficiency^a^ % | Anemia^b^ % | Iron deficiency anemia^c^ %
Eskeland 1997^68^; Fair | Postpartum, 1 week | Norway; N=90 | 27 mg elemental iron daily starting at 20 weeks’ gestation | - | - | - | 11.5% vs. 20.7%, p=0.25 | -
Eskeland 1997^68^; Fair | Postpartum, 6-10 weeks | Norway; N=90 | 27 mg elemental iron daily starting at 20 weeks’ gestation | - | - | 18% (9/51) (both iron arms) vs. 52% (12/23), RR 0.34 (95% CI, 0.17 to 0.69)^c^ | - | -
Eskeland 1997^68^; Fair | Postpartum, 24 weeks | Norway; N=90 | 27 mg elemental iron daily starting at 20 weeks’ gestation | - | - | 10% (5/48) (both iron arms) vs. 51% (12/23), RR 0.20 (95% CI, 0.08 to 0.50)^c^ | - | -
Liu 2013^72^; Good | Postpartum, 4-6 weeks | China (rural); N=12,513 | 30 mg elemental iron daily starting at <20 weeks’ gestation | 12.4 vs. 12.4 g/dL, MD 0.02 (95% CI, −0.01 to 0.05) | - | - | 26.8% (1547/5779) vs. 27.2% (1568/5765), OR 0.98 (95% CI, 0.93 to 1.05) | -
Makrides 2003^74^; Good | Postpartum, 6 months | Australia; N=430 | 20 mg elemental iron daily starting at 20 weeks’ gestation | 13.5 vs. 13.4 g/dL, MD 0.16 (95% CI, −0.01 to 0.33) | 34 vs. 26 µg/L, MD 7.9 (95% CI, 3.5 to 12.3) | 16% vs. 29%, RR 0.57 (95% CI, 0.38 to 0.84) | 3.7% vs 4.5%, RR 0.82 (95% CI, 0.30 to 2.21) | 2.6% vs 1.7%, RR 1.55 (95% CI, 0.38 to 6.40)
Milman 1994^78^; Fair | Postpartum, 8 weeks | Denmark; N=248 | 66 mg elemental iron daily starting at 14-16 weeks’ gestation | 13.4 vs. 12.9 g/dL, p<0.001; Hb <12.1 g/dL, 3.2% vs. 21.1% | Ferritin ≤20 µg/L: 16.1% vs. 40.4% | - | 3.2% vs. 21.1% | -
Zhao 2015^86^; Fair | Postpartum, 1 day | China (rural); N=2,371 | 60 mg elemental iron daily starting at enrollment | - | - | - | RR 0.71 (95% CI, 0.66 to 0.78) | -

Abbreviations: CI, confidence interval; MD, mean difference; Hb, hemoglobin; OR, odds ratio; RR, relative risk.

a Iron deficiency defined as serum ferritin <12 µg/L.

b Anemia defined as hemoglobin <11.0 g/dL.

c Iron deficiency anemia defined as hemoglobin <11.0 g/dL and serum ferritin <12 µg/L.

Note that definitions used in some studies varied slightly from the above definitions.

Bolded values show a statistically significant difference.

##### IDA

Seven trials (N=4,045) reported incidence of IDA, defined as hemoglobin level less than 11.0 g/dL and serum ferritin level less than 12 or 20 µg/L. The proportion of patients with IDA during the third trimester (Table 4), at delivery (Table 5), or postpartum (Table 6)^66,69,74,76,78,83,86^ ranged from 0 to 12.7 percent in groups receiving supplementation and from 0 to 29 percent in groups receiving placebo.

###### Third Trimester

Three trials, also included in the prior report, found daily iron supplementation was associated with reduced risk of IDA during the third trimester compared with placebo or no supplementation (3 trials; N=660; 9.1% vs. 13.8%; RR, 0.63 [95% CI, 0.41 to 0.97]; I^2^=0%; ARD, −3.86% [95% CI, −7.74% to 0.02%]; Figure 5).^66,69,83^ Doses ranged from 30 to 60 mg elemental iron daily starting at less than 20 weeks’ gestation.

Figure 5 Meta-Analysis: Iron Deficiency Anemia During Third Trimester and at Term

Abbreviations: CI=confidence interval; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Figure 5 is a forest plot of iron deficiency anemia stratified by gestational age with two subgroups. The risk ratio for three studies in the early third trimester subgroup is 0.63 (95% confidence interval 0.41 to 0.97) with an I-squared of 0%. The risk ratio at term subgroup for five populations in four studies is 0.40 (95% confidence interval 0.26 to 0.61) with an I-squared of 20.5%.

###### Term

Four trials found routine iron supplementation during pregnancy was associated with a statistically significant decreased risk of maternal IDA at term compared with placebo or no supplementation (4 trials; N=2,230; 8.6% vs. 19.8%; RR, 0.40 [95% CI, 0.26 to 0.61]; I^2^=20.5%; ARD, −9.59% [95% CI, −16.20% to −2.98%]; Figure 5).^74,76,78,86^ Stratified analyses by HDI country and dose resulted in similar findings (Appendix C Figures 5 and 6; Table 2). Three trials were included in the prior report. Doses ranged from 20 to 66 mg elemental iron starting between 12 and 20 weeks’ gestation. The study from Iran was not included in the pooled analysis due to no events reported for this outcome in either group.

###### Postpartum

One good-quality study from Australia, also included in the prior report (n=383), found no statistically significant difference in rates of IDA at 6 months postpartum for 20 mg iron supplementation started during the second trimester versus placebo (2.6% vs. 1.7%; RR, 1.55 [95% CI, 0.38 to 6.40]).^74^

##### ID

Nine trials (N=16,556) reported incidence of ID, defined as serum ferritin level less than 12 or 20 µg/L (Tables 4–6).^66,68,69,72,74,77,81,83,86^ Seven studies were included in the prior report. Dosing ranged from 20 to 200 mg elemental iron starting in the first or second trimester. Rates of ID varied widely across studies: overall ranges were 0 to 57 percent for those in the supplementation group and 24 to 85 percent for those in the placebo group.

###### Third Trimester

Four trials (three fair-quality, one good-quality) found 30 to 60 mg iron supplementation started in the first trimester was associated with a statistically significant decreased risk of ID in the third trimester versus placebo (4 trials; N=1,220; 40.3% vs. 57.1%; RR, 0.70 [95% CI, 0.53 to 0.92]; I^2^=77.4%; ARD, −16.95% [95% CI, −24.13% to −9.77%]; Figure 6).^66,69,72,83^ Statistical heterogeneity was high for the pooled estimate, but the direction of effect was consistent across studies. Estimates in all studies favored iron supplementation and were statistically significant in three studies, with heterogeneity only in the magnitude of benefit for the pooled estimate. Three studies were included in the prior review, two of which were U.S. trials that included pregnant persons at higher risk for ID, based on both study populations representing WIC participants.

Figure 6 Meta-Analysis: Iron Deficiency During Third Trimester and at Term

Abbreviations: CI=confidence interval; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Figure 6 is a forest plot of iron deficiency stratified by gestational age with two subgroups. The risk ratio for four studies in the early third trimester subgroup is 0.70 (95% confidence interval 0.53 to 0.92) with an I-squared of 77.4%. The risk ratio for the at term subgroup for six studies is 0.47 (95% confidence interval 0.33 to 0.67) with an I-squared of 81.9%.

###### Term

Six trials (five fair- and one good-quality) reported ID at term was associated with 20 to 200 mg iron supplementation started in the first or second trimester versus placebo. Five studies were included in the prior report. Iron supplementation was associated with a reduced risk of ID versus placebo (6 trials; N=2,361; RR, 0.47 [95% CI, 0.33 to 0.67]; I^2^=81.9%; ARD, −34.25% [95% CI, −46.49% to −22.01%]; Figure 6).^68,69,74,77,81,86^ Statistical heterogeneity was also high, but the direction of effect was consistent. Each study showed a statistically significant reduction in risk associated with iron supplementation (RR, 0.03 to 0.74); sample size and precision varied widely (range N=52 to 2,371). Stratified analysis by HDI country (Appendix C Figure 7) and dose (Appendix C Figure 8) resulted in similar findings, with one exception; there were no differences in stratified analyses for the effects of supplementation versus placebo in medium to high HDI countries (RR, 0.57 [95% CI, 0.29 to 1.13]; I^2^=69.5%; Table 2).

###### Postpartum

Two trials also included in the prior report evaluated risk of postpartum ID.^68,74^ One trial from Australia reported 20 mg iron supplementation starting in the second trimester was associated with lower risk of ID at 6 months postpartum versus placebo (16% vs. 29%; RR, 0.57 [95% CI, 0.38 to 0.84]).^74^ A trial from Norway comparing 27 mg iron with placebo starting at 20 weeks’ gestation found significantly lower rates of ID for supplemented pregnant persons at both 6 to 10 weeks postpartum (18% vs. 52%; RR, 0.34 [95% CI, 0.17 to 0.69]) and 24 weeks postpartum (10% vs. 51%; RR, 0.20 [95% CI, 0.08 to 0.50]).^68^

##### Anemia

Nine trials (N=20,330) reported incidence of anemia, defined as hemoglobin level less than 10.0 or 11.0 g/dL in the third trimester and at term, and as hemoglobin level less than 12.0 or 12.1 g/dL for postpartum anemia at 4 weeks to 6 months (two postpartum studies with timing of 1 day to 1 week defined anemia as hemoglobin level <10.0 or 11.0 g/dL)^66,68,72,74,77,81,83,85,86^ (Tables 4–6). Six studies were included in the prior report.^66,68,74,77,81,83^ Supplement dosing ranged from 30 to 200 mg, started during the first or second trimester. The proportion of participants with anemia ranged from zero to 45 percent for those randomized to supplementation and from 4.5 to 61 percent for those randomized to placebo.

###### Third Trimester

Seven trials reported inconsistent results for effects of iron supplementation during pregnancy and risk of anemia during the third trimester.^66,72,74,77,81,83,85^ Five were included in the prior report.^66,74,77,81,83^ Doses ranged from 20 to 200 mg elemental iron starting in the first or second trimester. Iron supplementation was associated with a statistically significant decreased risk of anemia versus placebo (7 studies; N=2,148; 18.1% vs. 26.0%; RR, 0.71 [95% CI, 0.51 to 0.97]; I^2^=64.2%; ARD, −7.97% [95% CI, −15.28% to −0.66%]; Figure 7); statistical heterogeneity was high. Two fair-quality trials (n=275 and 867) conducted in U.S. pregnant persons at higher risk for ID found no statistically significant difference in risk of anemia between iron supplementation and no iron.^66,83^

Figure 7 Meta-Analysis: Anemia During Third Trimester and at Term

Abbreviations: CI=confidence interval; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Figure 7 is a forest plot of anemia stratified by gestational age with two subgroups. The risk ratio for seven studies in the early third trimester subgroup is 0.71 (0.51 to 0.97) with an I-squared of 64.2%. The risk ratio for four studies in the at term subgroup is 0.43 (95% confidence interval 0.26 to 0.72) with an I-squared of 43.7%.

###### Term

Four trials (one good- and three fair-quality) found 20 to 200 mg iron supplementation beginning in the first or second trimester was associated with lower risk of anemia at term versus no iron^74,77,81,86^ (4 trials; N=2,261; 10.9% vs. 22.5%; RR, 0.43 [95% CI, 0.26 to 0.72]; I^2^=43.7%; ARD, −11.73% [95% CI, −14.87% to −8.60%]).^74,77,81,86^ Stratified analysis by HDI country (Appendix C Figure 9) and dose (Appendix C Figure 10) resulted in similar findings.

###### Postpartum

Five trials (two good- and three fair-quality) reported somewhat inconsistent effects of iron supplementation during pregnancy on postpartum anemia, though results favored supplementation in all trials except for one.^68,72,74,78,86^ Due to variability in the timing of when anemia was measured, rates of postpartum anemia were not pooled; however, results did not vary according to when anemia was assessed. A good-quality trial from Australia (n=430) found no difference between 20 mg elemental iron supplementation starting in the second trimester versus placebo in risk of anemia at 6 months postpartum, though the estimate was imprecise and favored supplementation (3.7% vs. 4.5%; RR, 0.82 [95% CI, 0.30 to 2.21]).^74^ However, a good-quality trial from China (n=12,513) found supplementation and placebo were associated with similar risk of anemia at 4 to 6 weeks postpartum (26.8% vs. 27.2%; OR, 0.98 [95% CI, 0.93 to 1.05]).^72^ Three fair-quality trials (N=2,709)^68,77,86^ reported results that favored supplementation, though only one trial from China reported a statistically significant difference in rates of anemia measured 1 day postpartum (RR, 0.71 [95% CI, 0.66 to 0.78]; rates not reported).^86^

##### Hemoglobin

Fifteen trials (four good- and 11 fair-quality; N=20,069) of iron supplementation during pregnancy versus placebo (or another supplement with vs. without iron) reported hemoglobin levels at either the third trimester, delivery, or up to 6 months postpartum.^63,64,66,69,72,74,76,78,80,81,83,85,86,88,89^ Across trials, hemoglobin levels ranged from 11.0 to 13.9 g/dL for those randomized to iron supplementation and from 10.5 to 13.4 g/dL for those randomized to control (Tables 4–6).

###### Third Trimester

Three trials (two good- and one fair-quality; N=1,277) conducted in Australia, Iran, and Ireland found iron supplementation (20, 50, or 120 mg elemental iron daily) was associated with higher third trimester hemoglobin levels versus placebo.^63,74,89^ Differences in hemoglobin levels ranged from 0.4 to 1.2 g/dL; in one of the trials,^63^ the difference was not statistically significant when adjusted for smoking (p=0.25). Two trials from China (one good-quality [n=12,513]^72,75^ and one fair-quality [n=3,929]^85^) reported no differences in hemoglobin level between iron and folate supplementation versus folate alone. The good-quality trial from China reported a very small (<0.1 g/dL) but statistically significant increase in hemoglobin at 24 to 28 weeks’ gestation associated with supplemental iron (n=11,809; mean difference [MD], 0.04 g/dL [95% CI, 0.01 to 0.07]), but no difference at 28 to 32 weeks in a subset of patients (n=562; 12.44 vs. 12.45 g/dL; p>0.05; venous blood). The fair-quality study found the addition of iron supplementation was associated with higher hemoglobin at 28 to 32 weeks (11.01 vs. 10.53 g/dL; MD, 0.50 [95% CI, 0.20 to 0.80]). Two fair-quality trials of higher-risk pregnant persons, both conducted in the United States (n=275 and 867), found no difference in hemoglobin levels between groups (11.7 g/dL with iron vs. 11.6 g/dL with placebo; p=0.499^66^ and 11.4 vs. 11.4 g/dL; p=0.81 for prenatal supplements with vs. without iron^83^).

###### Term

Ten trials (N=5,858) reported hemoglobin levels at term.^63,64,69,74,76,77,80,81,86,88^ The trials were conducted in Australia (one trial), Hong Kong (one trial), China (one trial), Iran (three trials), Europe (three trials), and the United States (one trial [n=144]); sample sizes ranged from 45 to 2,371. Participants received 20 to 200 mg elemental iron daily beginning in the first or second trimester. Hemoglobin levels were higher with iron supplementation in all 10 trials, with differences ranging from 0.2 to 1.7 g/dL; differences were statistically significant in eight trials.^63,64,74,76,77,80,86,88^

###### Postpartum

Three trials (N=13,191) reported mixed results for the association between prenatal iron supplementation versus no iron and postpartum hemoglobin levels. A fair-quality trial from Denmark (n=248) found 66 mg elemental iron supplementation beginning during the second trimester was associated with a small increase in hemoglobin level at 8 weeks postpartum versus placebo (13.4 vs. 12.9 g/dL; p<0.001).^77^ However, two good-quality trials from China (n=11,544) and Australia (n=430) found no differences in postpartum hemoglobin levels with 20 to 30 mg supplemental iron versus no iron starting in the first or second trimester (12.38 vs. 12.36 g/dL; MD, 0.02 [95% CI, −0.01 to 0.05] at 4 to 6 weeks postpartum^72,82^ and 13.5 vs. 13.4 g/dL; MD, 0.16 [95% CI, −0.01 to 0.33] at 6 months postpartum,^74^ respectively).

##### Serum Ferritin

Thirteen trials (N=19,075) reported serum ferritin levels at either the third trimester, delivery, or up to 6 months postpartum (Tables 4–6).^63,64,66,69,72,74,76,78,80,81,83,86,88^ Serum ferritin levels at these time points ranged from 7.4 to 34 µg/L in the supplementation group and from 6.0 to 26 µg/L in the placebo group.

###### Third Trimester

Four trials (N=13,752) reported inconsistent effects of iron supplementation on third trimester ferritin levels.^63,66,72,83^ Two fair-quality trials (N=1,142) of pregnant persons at higher risk for ID conducted in the United States found no difference between 30 mg iron supplementation starting in the first trimester versus placebo measured by third trimester serum ferritin levels (7.4 vs. 7.4 µg/L; p=0.985^66^ and 22.0 vs. 20.3 µg/L; p=0.48^83^). However, a fair-quality trial conducted in Ireland of 120 mg elemental iron daily and a good-quality trial conducted in China of 30 mg daily iron supplementation starting in the first trimester reported increased third trimester ferritin levels versus no iron (32.6 vs. 12.8 µg/L; p=0.04 and 16.7 vs. 11.3 µg/L; p<0.05).^72,75^

###### Term

Nine trials (two good- and seven fair-quality; N=5,761^64,69,74,76,77,80,81,86,88^) reported effects of iron supplementation versus no iron supplementation on ferritin levels at term. The trials were conducted in Hong Kong (one trial), Australia (one trial), Europe (two trials), the United States (one trial), Iran (three trials), and China (one trial), and found 20 to 200 mg elemental iron supplementation beginning in the first or second trimester was associated with increased serum ferritin levels at delivery. The difference favoring iron supplementation ranged from 4.2 to 18 µg/L and was statistically significant in the eight trials that reported a statistical comparison.

###### Postpartum

A good-quality trial from Australia (n=430) found 20 mg elemental iron daily beginning in the second trimester was associated with higher serum ferritin levels versus placebo at 6 months postpartum (34 vs. 26 µg/L; MD, 7.9 [95% CI, 3.5 to 12.3]^74^).

#### Infant Clinical Outcomes

Eleven trials (N=20,435; three good-quality^72,74,89^ and eight fair-quality^63,64,69,76,78,80,81,85^) reported infant birth outcomes, including infant mortality, preterm delivery, small size for gestational age, and low birth weight (Table 7). Similar to the prior report, there were no statistically significant differences between iron supplemented groups versus placebo for infant outcomes.

Table 7 Effect of Maternal Iron Supplementation vs. Placebo on Infant Birth Outcomes

Study, year; Quality | Country; N randomized | Iron supplement dose and formulation, initiation | Preterm delivery^a^ | Small for gestational age^b^ | Low birth weight^c^ | Infant mortality
Barton 1994^63^; Fair | Ireland; N=97 | 120 mg elemental iron daily starting at end of first trimester | - | - | <2,700 g: 9.4% (5/53) vs. 15.9% (7/44), RR 0.59 (95% CI, 0.20 to 1.74) | 1.9% (1/53) vs. 0% (0/44), RR 2.50 (95% CI, 0.10 to 59.88)
Chan 2009^64^; Fair | Hong Kong; N=1,164 | 60 mg elemental iron daily starting at <16 weeks’ gestation | 6.4% (27/419) vs. 6.8% (30/443); RR 0.95 (95% CI, 0.58 to 1.57) | 3.58% (15/419) vs. 7.45% (33/443), OR 0.46 (95% CI, 0.24 to 0.85) | - | -
Falahi 2011^69^; Fair | Iran; N=148 | 60 mg elemental iron daily starting at <20 weeks’ gestation | 3% (2/70) vs. 6.4% (5/78), RR 0.45 (95% CI, 0.09 to 2.22) | - | 3% (2/70) vs. 6.4% (5/78), RR 0.45 (95% CI, 0.09 to 2.22) | -
Liu 2013^72^; Good | China (rural); N=12,513 | 30 mg elemental iron daily starting at <20 weeks’ gestation | 5.7% (340/5,926) vs. 6.0% (353/5,906), RR 0.96 (95% CI, 0.83 to 1.11); Spontaneous preterm birth (20 to 36 weeks): 5.6% vs. 5.7%, RR 0.99 (95% CI, 0.85 to 1.16) | - | 2.2% (129/5,922) vs. 2.1% (125/5,905), RR 1.03 (95% CI, 0.81 to 1.31) | Cases per 1,000 for mortality outcomes; Perinatal mortality (stillbirth + early neonatal): 8.73 vs. 8.76, RR 1.00 (95% CI, 0.68 to 1.46); Stillbirth (28 weeks to delivery): 4.70 vs. 4.72, RR 1.00 (95% CI, 0.59 to 1.68); Early neonatal mortality (birth to 6 days after delivery): 4.05 vs. 4.06, RR 1.00 (95% CI, 0.57 to 1.75); Neonatal mortality (birth to 28 days after delivery): 5.40 vs. 4.91, RR 1.10 (95% CI, 0.67 to 1.82); Infant mortality (first year of life): 7.42 vs. 7.62, RR 0.97 (95% CI, 0.64 to 1.48)
Makrides 2003^74^; Good | Australia; N=430 | 20 mg elemental iron daily starting at 20 weeks’ gestation | - | - | 5.4% (12/216) vs. 4.2% (9/214), RR 1.32 (95% CI, 0.57 to 3.07) | 0.5% (1 case) vs. 0%, p=NS; (infant born at 22 weeks with bilateral intrauterine pneumonia)
Meier 2003^76^; Fair | U.S.; N=144 | 60 mg elemental iron daily starting at 1st prenatal visit | - | - | Adolescents: 0% vs. 0%, p=NS; Adults: 5.4% (2/38) vs. 2.9% (1/36), RR 1.89 (95% CI, 0.18 to 20.00) | 0% vs 0%, p=NS
Milman 1994^78^; Fair | Denmark; N=248 | 66 mg elemental iron daily starting at 14 to 16 weeks’ gestation | - | - | - | -
Ouladsahebmadarek, 2011^80^; Fair | Iran; N=960 | 30 mg elemental iron daily starting at 13 weeks’ gestation | Delivery at 20 to 38 weeks: 3.9% (16/410) vs. 4.8% (18/372), RR 0.81 (95% CI, 0.42 to 1.56) | 14.1% (58/410) vs. 17.5% (65/372), RR 0.81 (95% CI, 0.59 to 1.12) | - | -
Romslo 1983^81^; Fair | Norway; N=52 | 200 mg elemental iron daily starting within 10 weeks’ gestation | - | - | - | -
Zeng 2008^85^; Fair | China (rural); N=3,929 | 60 mg elemental iron daily starting at 14 weeks’ gestation | 4.9% (76/1,537) vs. 6.1% (102/1,666), RR 0.81 (95% CI, 0.61 to 1.08); <34 weeks: 0.98% vs. 1.80%, RR 0.50 (95% CI, 0.27 to 0.94) | 18.9% vs. 18.1%, RR 1.04 (95% CI, 0.89 to 1.22) | 4.5% (66/1,470) vs. 5.3% (82/1,545), RR 0.85 (95% CI, 0.62 to 1.16) | Rates per 1,000:; Stillbirths (≥28 weeks through labor): 30.4 vs. 30.8, RR 1.01 (95% CI, 0.67 to 1.51); All neonatal deaths (within 28 days): 10.7 vs. 20.2, RR 0.53 (95% CI, 0.29 to 0.97); Early neonatal deaths (within 7 days): 6.7 vs. 14.7, RR 0.46 (95% CI, 0.21 to 0.98); Perinatal deaths (stillbirth + early neonatal deaths): 36.9 vs. 45.0, RR 0.84 (95% CI, 0.59 to 1.19)
Ziaei 2007^89^; Good | Iran; N=750 | 50 mg elemental iron daily starting at 20 weeks’ gestation | | 15.4% (57/370) vs. 10.1% (36/357), RR 1.53 (95% CI, 1.03 to 2.26) | - | 0.8% (3/370) vs. 1.7% (6/357), RR 0.48 (95% CI, 0.12 to 1.91)

Abbreviation: CI, confidence interval; NS, not significant; OR, odds ratio; RR, relative risk; US, United States.

a Preterm delivery is defined as <37 weeks.

b Small for gestational age is defined as <10th percentile of birth weight for gestational age.

c Low birth weight is defined as <2,500 g.

Bolded values show a statistically significant difference.

##### Infant Mortality

Infant mortality rates were not a prespecified outcome in any study and event rates were low (<1% to 2%). Six trials (three good- and three fair-quality; N=17,863) evaluated effects of prenatal iron supplements on infant mortality with inconsistent results.^63,72,74,76,89^ Five were included in the prior report. Prenatal iron supplement dosing ranged from 20 to 120 mg beginning in the first or second trimester. Infant mortality rates were not a prespecified outcome in any study and event rates were generally low. Four trials were of nonanemic pregnant persons; the fifth trial (conducted in rural China^85^) did not describe baseline hematologic indices. The largest (n=12,513), good-quality trial from rural China^72^ reported no difference between iron supplementation versus placebo in infant mortality during the first year of life (7.42 vs. 7.62 cases per 1,000; RR, 0.97 [95% CI, 0.64 to 1.48]). However, a post-hoc analysis from a smaller, fair-quality trial (n=3,929) conducted in rural China found iron supplementation was associated with decreased risk of neonatal mortality among live born infants within 28 days of delivery versus controls (1.1% vs. 2.0%; RR, 0.53 [95% CI, 0.29 to 0.97]^85^). Another good-quality trial from Iran (n=750) reported no difference in perinatal mortality between the supplementation and placebo groups (0.8% vs. 1.7%; RR, 0.48 [95% CI, 0.12 to 1.91]), but estimates were imprecise and based on a total of nine events.^89^ Three other trials conducted in Australia (n=430), Ireland (n=97), and the United States (n=144) reported no deaths or one infant death.^63,74,76^

##### Preterm Birth

Five trials (four fair- and one good-quality; N=18,714) conducted in Hong Kong, rural China, and Iran reported the association between supplemental iron versus placebo and risk of preterm birth, defined as delivery at less than 37 weeks.^64,69,72,80,85^ Two studies were included in the prior report.^59,64^ Supplemental dosing ranged from 30 to 60 mg beginning in the first or second trimester. There were no statistically significant differences between prenatal iron supplementation versus placebo in risk of preterm birth (5 trials; N=16,827; 5.5% vs. 6.0%; RR, 0.92 [95% CI, 0.81 to 1.04]; I^2^=0%; Figure 8). There was no statistically significant interaction between country HDI category or iron dose and effects on preterm birth (Appendix C Figures 11 and 12; Table 2).

Figure 8 Meta-Analysis: Preterm Birth

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Figure 8 is a forest plot of preterm birth. The overall risk ratio for 5 studies is 0.92 (95% confidence interval 0.81 to 1.04) with an I-squared of 0%.

##### Small for Gestational Age

Four trials (three fair- and one good-quality; N=6,803) conducted in Hong Kong, rural China, and Iran reported inconsistent findings for effects of prenatal iron supplementation on risk of infants small for gestational age^64,85,89^ or with intrauterine growth restriction.^80^ Both outcomes were defined as less than the 10th percentile of birth weight for gestational age. Iron supplementation dosing ranged from 30 to 60 mg of elemental iron and was initiated between 13 and 20 weeks. There were no statistically significant differences between iron supplementation and placebo for infants small for gestational age (4 trials; N=5,386; 15.3% vs. 15.2%; RR, 0.94 [95% CI, 0.67 to 1.31]; I^2^=75.5%; Figure 9); statistical heterogeneity was high. One trial from Hong Kong found 60 mg iron supplementation versus placebo was associated with decreased risk of having a small for gestational age infant (3.6% vs. 7.5%; RR, 0.48 [95% CI, 0.26 to 0.87]);^64^ the three other trials from medium to high HDI countries showed mixed results. There was no statistically significant interaction between country HDI category or iron dose and effects of supplementation (Appendix C Figures 13 and 14; Table 2).

Figure 9 Meta-Analysis: Small for Gestational Age

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Figure 9 is a forest plot of small for gestational age. The overall risk ratio for four studies is 0.94 (95% confidence interval 0.67 to 1.31) with an I-squared of 75.5%.

##### Low Birth Weight

Six trials (three fair- and three good-quality; N=17,261) conducted in the United States, Iran, Ireland, rural China, and Australia reported the association between iron supplementation and risk of having an infant born with low birth weight, primarily defined as less than 2,500 g.^63,69,72,74,76,85^ Iron supplementation dosing ranged from 20 to 120 mg and was initiated between 12 and 20 weeks of gestation. There were no statistically significant differences for iron supplementation versus placebo in risk of infant low birth weight (6 trials; N=15,591; 2.7% vs. 2.9%; RR, 0.95 [95% CI, 0.79 to 1.14]; I^2^=0.0%; Figure 10), with some imprecision in estimates. There was no statistically significant interaction between country HDI category or iron dose and effects of supplementation (Appendix C Figures 15 and 16; Table 2).

Figure 10 Meta-Analysis: Low Birth Weight

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Figure 10 is a forest plot of low birth weight. The overall risk ratio for six studies is 0.95 (95% confidence interval 0.79 to 1.14) with an I-squared of 0%.

#### Infant Hematologic Outcomes

Two good-quality trials^72,74^ (N=12,943) reported postpartum infant hematologic outcomes. One trial conducted in rural China (n=12,513)^72^ reported infant hemoglobin (mean range, 12.17 to 12.22 g/dL) and anemia (5.0% to 6.9%) outcomes at 6 months and 1 year, and a smaller Australian-based trial (n=430)^74^ reported infant hemoglobin (11.9 to 12.1 g/dL), ferritin (30.8 to 32.5 ug/L), ID (4% to 6%), and IDA (0%) outcomes at 6 months (Appendix B Table 1). No statistically significant differences were found between groups at these time points for any of the indices.

### Key Question 2 What Are the Harms of Routine Iron Supplementation During Pregnancy?

#### Summary

- No trial reported any serious adverse events associated with iron supplementation.
- 12 trials (11 included in Key Question 1) assessed harms of routine iron supplementation during pregnancy; five trials were newly added. Consistent with the prior review, none of the harms were serious or associated with long-term clinical outcomes, and there were mostly no significant differences between groups. Most reported harms included transient gastrointestinal treatment effects such as nausea, constipation, and diarrhea, and some studies reported nonadherence rates.
- One large study in rural China reported a statistically significant difference in gastrointestinal symptoms between the supplementation group and controls (RR, 1.59 [95% CI, 1.28 to 1.97]); the other two studies newly identified for this update reported no statistically significant differences.
- Infant harms were not reported in any study.

#### Evidence

Eleven trials^64,66,68,72,74,76,80,81,83,85,86^ included for Key Question 1 and one additional trial (n=179)^70^ conducted in Iran (total N=22,716) addressed supplementation harms; five trials^70,72,80,85,86^ were added for this update (Table 8; Appendix B Tables 1 and 2).

Table 8 Harms of Maternal Iron Supplementation

Study, year; Quality | Country; N randomized | Iron supplement dose and formulation, initiation | Maternal adverse outcomes | Nonadherence
Chan 2009^64^; Fair | Hong Kong; N=1,164 | 60 mg elemental iron daily starting at <16 weeks’ gestation | “No major adverse events from study drugs” | At 36 weeks: 68% overall (of n=473 with data), p=0.34 between groups
Cogswell 2003^66^; Fair | U.S.; N=275 | 30 mg elemental iron daily starting at <20 weeks’ gestation | Side effects reported at >1 visit from enrollment to week 28: 24.6% vs. 18.5%, p=NS | At week 28: 36.6% vs. 34.8%, p=NS
Eskeland 1997^68^; Fair | Norway; N=90 | 27 mg elemental iron daily starting at 20 weeks’ gestation | No difference in fatigue or other side effects, p=NS | 19% (both iron arms) vs. 18%, p=NS
Jafarbegloo 2015^70^ | Iran; N=179 | 50 mg ferrous sulfate daily starting at 20 weeks’ gestation | At 32-36 weeks’ gestation:; Nausea: 16.1% vs. 14%, p=0.74; Vomiting: 3.2% vs. 10%, p=0.09; Diarrhea: 0% vs. 2%, p=0.17; Constipation: 12.9% vs. 4%, p=0.09; Loss of appetite: 4.3% vs. 4%, p=0.93; Heartburn: 16.1% vs. 8%, p=0.17; Abdominal pain: 2.2% vs. 2%, p=0.30 | -
Liu 2013^72^; Good | China (rural); N=12,513 | 30 mg elemental iron daily starting at <20 weeks’ gestation | Serious adverse events: none reported; Gastrointestinal discomfort (e.g., nausea, vomiting; denominators at 24 to 28 weeks): 3.6% (212/5,913) vs. 2.3% (133/5,896), RR 1.59 (95% CI, 1.28 to 1.97) | 7.2% vs. 6.7%
Makrides 2003^74^; Good | Australia; N=430 | 20 mg elemental iron daily starting at 20 weeks’ gestation | At 36 weeks’ gestation:; Nausea: 29% vs. 28%, RR 1.04 (95% CI, 0.76 to 1.42); Stomach pain: 35% vs. 30%, RR 1.19 (95% CI, 0.89 to 1.58); Heartburn: 68% vs. 69%, RR 0.99 (95% CI, 0.86 to 1.13); Vomiting: 12% vs. 13%, RR 0.89 (95% CI, 0.53 to 1.50); Bowel ≤3 times/week: 4% vs. 1.6%, RR 2.56 (95% CI, 0.69 to 9.51); Rash: 7.5% vs. 6.2%, RR 1.21 (95% CI, 0.58 to 2.51) | 14% vs. 15%, p=NS
Meier 2003^76^; Fair | U.S.; N=144 | 60 mg elemental iron daily starting at 1st prenatal visit | [underlined: Adolescents]:; Nausea: 53% vs. 65%, p=NS; Vomiting: 41% vs. 41%, p=NS; Constipation: 29% vs. 12%, p=NS; Diarrhea: 13% vs. 17%, p=NS; [underlined: Adults]:; Nausea: 63% vs. 53%, p=NS; Vomiting: 35% vs. 21%, p=NS; Constipation: 24% vs. 28%, p=NS; Diarrhea: 14% vs. 24%, p=NS | Adolescents: 4.5% vs. 12.6%, p=0.320; Adults: 2.2% vs. 16.1%, p=0.036
Ouladsahebmadarek, 2011^80^; Fair | Iran; N=960 | 30 mg elemental iron daily starting at 13 weeks’ gestation | No difference in means of complications, including septicemia. | -
Romslo 1983^81^; Fair | Norway; N=52 | 200 mg elemental iron daily starting within 10 weeks’ gestation | No discomfort attributed to the medication was reported. | 45% overall, p=NS
Siega-Riz 2006^83^; Fair | US; N=429 | 30 mg elemental iron daily starting at <20 weeks’ gestation | - | 34% vs. 37%, p=0.27
Zeng 2008^85^; Fair | China (rural); N=3,929 | 60 mg elemental iron daily starting at 14 weeks’ gestation | Withdrawals due to adverse events:; Nausea: 1.6% (31/1,912) vs. 1.3% (26/2,017), RR 1.26 (95% CI, 0.75 to 2.11); Vomiting: 2.1% (40/1,912) vs. 1.4% (28/2,017), RR 1.51 (95% CI, 0.93 to 2.43) | Mean % of days when supplements not consumed: 8.1% vs. 6.6%
Zhao 2015^86^; Fair | China (rural); N=2,371 | 60 mg elemental iron daily starting at enrollment | “Minor adverse symptoms such as nausea, vomiting, diarrhea, or constipation:” 68.4% vs. 68.2% | 14.9% vs. 9.9% (women with complete data, n NR)

Abbreviations: CI, confidence interval; MD, mean difference; NS, not significant; RR, relative risk; U.S., United States

Note: Bolded values show a statistically significant difference.

##### Serious Adverse Events

No trials reported any serious adverse events from iron supplementation.

##### Discontinuation Due to Adverse Events

Nonadherence, a potential marker of intolerability, was similar between supplementation versus placebo in 10 trials (N=21,397). While evidence was lacking on discontinuation of supplements due to adverse effects, adherence or nonadherence was reported and was used as a proxy measure for discontinuation as a harm. Ten studies reported rates of nonadherence. Nonadherence was lower with iron supplementation in adults compared with placebo, but did not reach statistical significance in adolescents compared to placebo in one small (n=111) U.S. trial (2.2% vs. 16.1%; p=0.036 and 4.5% vs. 12.6%; p=0.320, respectively^76^). Nine other trials found no difference in nonadherence to supplementation versus placebo,^64,66,68,72,74,81,83,85,86^ with ranges from 2 to 68 percent; however, most studies reported that adherence/nonadherence data were not available for all included participants.

##### Maternal Gastrointestinal Effects

Six trials^70,72,74,76,85,86^ (N=19,566) reported the association between iron supplementation during pregnancy and risk of gastrointestinal symptoms such as nausea, vomiting, constipation, or diarrhea. Iron supplementation doses ranged from 20 to 60 mg elemental iron. One large (n=12,513) trial conducted in rural China added for this update found 30 mg of elemental iron supplementation beginning in the second trimester was associated with increased risk of gastrointestinal symptoms versus placebo (3.6% vs. 2.3%; RR, 1.59 [95% CI, 1.28 to 1.97]).^72^ However, consistent with findings from the two trials from Australia^74^ and the United States^76^ that were carried forward from the prior report, two newly identified studies from rural China^85,86^ and one newly identified study from Iran^70^ reported no statistically significant differences in rates of various, minor gastrointestinal adverse effects between supplementation and placebo groups.

##### Infant Harms

Infant harms were not reported in any study.

### Key Question 3 In Pregnant Persons With ID, With or Without Anemia, What Is the Association Between Change in Maternal Iron Status (Including Changes in Ferritin or Hemoglobin Level) and Improvement in Newborn and Peripartum Outcomes in U.S.-Relevant Populations?

#### Summary

- No studies in the prior review compared the association in pregnant persons with ID with or without anemia and a change in maternal iron status and clinical outcomes.
- One U.S.-based observational study (n=20,690) added for this update found having a response to iron therapy was associated with reduced risk of preeclampsia and preterm delivery compared with those with untreated anemia or not responding to treatment but did not specifically compare outcomes of responders versus nonresponders.

#### Evidence

The prior review did not include this question for the supplementation framework and did not identify any studies for the screening framework. One fair-quality observational study conducted in the United States that was added for this update compared the association between response to iron supplementation in pregnant persons with ID (with or without anemia) and risk of preeclampsia and preterm delivery (Appendix B Tables 3 and 4).^67^ Patients in a perinatal database were classified as anemic (n=7,416), based on a hemoglobin level less than 11 g/dL for a third trimester delivery or 10.5 g/dL in the second trimester, or a nonanemic reference group (n=13,274). Patients with anemia were further categorized by treatment group (treated or untreated anemic; n=3,402), and among those treated, response to treatment (refractory anemic, n=1,319 or successfully treated, n=2,695). Those who were considered successfully treated or who had a response to treatment were defined as those presenting to labor and delivery with normal hemoglobin levels who reported taking iron supplementation. The dosing, timing, and duration of treatment or iron supplementation was not reported. Most participants were 18 to 35 years of age at delivery (76% to 82%), and Hispanic (43% to 63%) or African American (9% to 24%) race or ethnicity.

Successful response to treatment was associated with reduced risk of preterm birth (adjusted OR, 0.59 [95% CI, 0.47 to 0.72]) and preeclampsia (adjusted OR, 0.75 [95% CI, 0.6 to 0.91]) versus nonanemic persons. Refractory or untreated anemia was also associated with increased risk of preterm birth and preeclampsia (adjusted OR, 1.44 [95% CI, 1.16 to 1.76] and adjusted OR, 1.45 [95% CI, 1.26 to 1.67], respectively) versus no anemia. There were no differences between groups in composite neonatal morbidity.

Methodologic limitations included unclear documentation of ID or use of supplementation and unclear classification and reporting of symptoms. Specifically, the study did not compare outcomes in responders versus nonresponders (separate from untreated patients). In addition, the study classified participants using iron supplementation as anemic, which could have resulted in misclassification; there was a lack of information on dose, timing, or duration of treatment; and there was a lack of reporting on methods of outcome assessment.

## Screening for ID and IDA During Pregnancy

### Key Question 1 What Are the Benefits of Screening for ID and IDA in Asymptomatic Pregnant Persons on Maternal and Infant Health Outcomes?

No randomized trial or observational study compared clinical outcomes between pregnant persons screened and not screened for ID or IDA.

### Key Question 2 What Are the Harms of Screening for ID and IDA in Pregnant Persons?

No randomized trial or observational study compared harms between pregnant persons screened and not screened for ID or IDA.

### Key Question 3 What Are the Benefits of Treatment of ID and IDA During Pregnancy on Maternal and Infant Health Outcomes?

No randomized trial or observational study meeting inclusion criteria compared clinical outcomes between pregnant persons treated versus not treated for ID or IDA.

### Key Question 4 What Are the Harms of Iron Treatment in Pregnant Persons?

No randomized good- or fair-quality trial or observational study meeting inclusion criteria compared harms of treatment for pregnant persons for ID or IDA.

### Key Question 5 In Pregnant Persons With ID, With or Without Anemia, What Is the Association Between Change in Maternal Iron Status (Including Changes in Ferritin or Hemoglobin Level) and Improvement in Newborn and Peripartum Outcomes in U.S.-Relevant Populations?

Evidence on the association between change in maternal iron status and improvement in outcomes is addressed in the supplementation section (Key Question 3).

## Contextual Questions

### Contextual Question 1 What Are the Current Practices in Identifying Pregnant Persons With ID and IDA? Do Current Practices of Identification Differ by Race or Ethnicity, Diagnostic Criteria, Age, Socioeconomic Status, Cultural Factors, Educational Attainment, Insurance Status, or Health Literacy of the Pregnant Person?

A surveillance report from the CDC reported rates of anemia and testing among pregnant participants in WIC from 2008 to 2018.^91^ Across 90 WIC agencies across the United States, rates of anemia increased from 10.1 to 11.4 percent between 2008 and 2018. Among those tested, overall anemia prevalence (>20%) was higher among non-Hispanic Black persons compared with other racial or ethnic groups (7% to 12%) and among persons assessed during the third trimester versus the first or second trimester; for all three trimesters, rates of anemia were highest in Black persons. In 2018, 52.8 percent of all pregnant persons enrolled in WIC received hemoglobin testing during the first trimester of pregnancy, 36.8 percent during the second trimester, and 10.4 percent during the third trimester. Compared with national data, the prevalence of anemia was higher in WIC participants during this time period, although rates varied by state, race, and ethnicity.

A cross-sectional study from New Mexico^92^ reviewed laboratory data from 2018 and 2019 to determine anemia prevalence in a pregnant population (n=985). CBC testing was completed in 91 percent of the sample population during the first trimester and 53.6 percent during the third trimester; 52.8 percent had testing in both the first and second trimesters, 48.8 percent had testing in both the first and third trimester, and 22.7 percent had testing in all three trimesters. Of the 252 persons identified with anemia, 20.6 percent had iron studies ordered, and 79.4 percent did not. For those with an anemia workup, 0.3 percent had an iron panel, 11.5 percent had an iron laboratory alone, and 12.8 percent had a ferritin alone, whereas 3.8 percent had a reticulocyte panel, a CBC, and an iron study panel, suggesting generally low rates of full diagnostic testing for anemia.

A large, cross-sectional study from the United States (n=268,594)^93^ examined racial and ethnic disparities in the use of selected prenatal services among Medicaid recipients in four states. Non-Hispanic Black participants represented 19 to 49 percent of pregnant Medicaid recipients; Hispanic persons accounted for 23 to 50 percent of participants in three states, though comprised only 2.6 percent in the fourth state (Georgia). In all states, less than 2 percent of participants identified as Asian/Pacific Islander. Compared with non-Hispanic White pregnant populations, those identifying as non-Hispanic Black, Hispanic, and Asian/Pacific Islander were significantly less likely (raw ORs, 0.51 to 0.92) to receive a CBC in three of four states surveyed. However, in Georgia, non-Hispanic Black pregnant persons were 1.26 times (95% CI, 1.20 to 1.32) more likely to receive a CBC than non-Hispanic White pregnant persons.^94^ Among pregnancies with a laboratory result for hemoglobin and hemocrit, 99.9 percent also had mean corpuscular volume measured on the same day.

A cross-sectional study from the United States examined the feasibility of surveillance of anemia, ID, and IDA among first-trimester pregnancies in a private health system using electronic health records from 2005 to 2016.^94^ Among the 41,991 pregnancies, 92.7 percent (n=38,925) had a laboratory result for hemoglobin or hematocrit in the electronic health record within the first 14 weeks of pregnancy. The total number of hemoglobin/hematocrit tests per pregnancy in the first trimester ranged from 1 to 20, and characteristics of those screened for anemia differed from those who were not screened. Anemia screening tended to be lower among women who were younger (18–24 years of age) or older (≥35 years of age), were non-Hispanic Black, covered by Medicaid, or had obesity. Screening was lowest among pregnant women missing data on smoking, parity, or multiple gestation status; most (>97%) women missing at least one of these variables had a pregnancy that did not end with a live birth (data not shown). Among pregnancies not screened, a higher proportion ended in the first trimester (37.1%) compared with pregnancies screened for anemia (8.5%; p<0.0001). In this study, overall anemia prevalence was reported as low (2.7% among those screened), but more than 5 times higher among non-Hispanic Black women compared with non-Hispanic White women. These data are consistent with earlier data from NHANES.^19,95^

### Contextual Question 2 What Are Current Practices for the Use of Iron Supplementation During Pregnancy? Do Current Practices Differ by Race or Ethnicity, Age, Diagnostic Criteria, Socioeconomic Status, Cultural Factors, Educational Attainment, Insurance Status, or Health Literacy of the Pregnant Person?

Recommendations for iron supplementation during pregnancy vary by professional organization (Table 1), which may impact current practices. Observational studies on current iron supplementation practices had limitations such as not addressing population characteristics of interest for this Contextual Question or utilizing older data sets.

A large (n=160,482), cross-sectional study of a pregnant Medicaid population^93^ examined racial and ethnic disparities in the use of prescriptions for multivitamin and iron supplements in four states. The study found that non-Hispanic Black pregnant persons were significantly more likely to have filled prescriptions for iron supplements in three states (adjusted ORs, 1.48 to 1.77), as were Hispanic pregnant persons in two of the three states (adjusted ORs, 1.11 and 1.19) than non-Hispanic White persons. However, non-Hispanic Black and Hispanic pregnant persons were significantly less likely to have filled multiple vitamin prescriptions compared with non-Hispanic White pregnant persons in two of the three states (adjusted ORs, 0.69 to 0.91), and Asian/Pacific Islander pregnant persons were less likely in one of the three states (adjusted OR, 0.80).

A U.S.-based cross-sectional study of 1,045 pregnant persons^33^ used NHANES data from 1999 to 2010 to compare those with food security (n=881) to those with food insecurity (n=164), as defined by the U.S. food security survey module, and the use of iron supplements and ID. Compared with the food-secure group, population characteristics of those in the food-insecure group included a higher percentage of Mexican American and other Hispanic individuals, lower poverty income ratio, and less health insurance coverage compared with the food-secure comparison group. Mean dietary iron intake did not differ between groups, but mean supplemental iron intake was 10 mg/day lower (p=0.02), and there was an increased risk of ID based on ferritin values (<12.0 µg/L), transferrin (>4.4 mg/L), or total body iron (<0 mg/kg) among those with food insecurity versus the food-secure group (adjusted OR, 2.90 [95% CI, 1.29 to 6.51]).

A U.S.-based longitudinal birth cohort study^96^ compared nutritional intake and supplement use from the years 2000 to 2001 during pregnancy among 474 immigrants born in Mexico (n=425) versus Mexican-American persons born in the United States (n=49) and according to number of years lived in the United States. All participants had access to free prenatal vitamins, and approximately 90 percent were taking supplements by their second trimester. No differences were seen between the groups in vitamin supplement use before or during pregnancy.

### Contextual Question 3 How Well Do Risk Assessment Tools Identify Pregnant Persons at Increased Risk for IDA?

There is limited evidence available on the accuracy of risk prediction tools to identify pregnant persons at increased risk for IDA. Three studies provided some information regarding prediction rules for ID in pregnancy, including one study from the prior report.^97^

A feasibility study^98^ from Germany (n=200) used a questionnaire to evaluate whether risk of ID can be predicted by diet history and self-reported iron intake and iron losses (e.g., history of blood donation, menstrual history, surgery, history of ID). Participants were enrolled during their first or second trimester. Blood samples showed that 6 percent of study participants had anemia but 39 to 47 percent of participants were iron deficient without anemia, based on transferrin saturation. Incidence of ID increased with gestational age (from 41.3% at less than 20 weeks to 66.7% over 20 weeks’ gestation). In the first analysis, predictors of ID included gestational age greater than 21 weeks, and prepregnancy menstrual blood flow 6 days or longer and use of a high absorption tampon. Details about the final prediction rule or its diagnostic accuracy were not reported.

A prospective cohort study^99^ (n=1,527) from Israel followed pregnant persons undergoing vaginal delivery after 36 weeks to determine a prediction rule for anemia at delivery. Risk factors for anemia at delivery were identified by conducting a secondary analysis of a prospective cohort study database. The study found that the optimal hemoglobin cutoff between 24 and 30 gestational weeks for predicting anemia at delivery using the area under the receiver operating characteristic (AUROC) curve was a hemoglobin level less than 10.5 g/dL. Risk factors for anemia at delivery included hemoglobin level at 24 to 30 weeks and infrequent iron supplement intake. Further analysis demonstrated a hemoglobin cutoff at 24 to 30 weeks less than 10.6 g/dL had a sensitivity of 75 percent and a specificity of 74 percent to predict anemia at delivery. While anemia was considered most likely due to ID, no specific testing was done to determine iron status.

A third cohort study^97^ (n=141) conducted in the United States in a population of primarily Black, urban, pregnant persons in all three trimesters of pregnancy tested whether red blood cell indices could be used to develop a clinical prediction rule to identify patients at increased risk for IDA based on screening (ferritin level <10 ng/dL). The final model used either a hemoglobin level less than 9.7 g/dL or red cell distribution width greater than 15 in persons under 20 weeks of gestation and had a specificity of 96 percent for ID. The study found that a risk score of 2 or higher (on a 4-item scoring system that included an interaction term) was the best predictor of IDA, correctly identifying 74 percent of persons with IDA. However, although specificity was high (88%), sensitivity was poor (45%), resulting in a noninformative positive likelihood ratio (1.1). Discrimination was also modest, with an AUROC curve of 0.66 (95% CI, 0.6 to 0.7). Limitations of this study include evaluation of only urban, Black persons who met criteria for anemia, potentially reducing generalizability of findings.