# Chapter 2 Methods

## Key Questions and Analytic Frameworks

Using the methods developed by the USPSTF,^59^ the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and Key Questions for this update to the 2015 review.^3,4^ Investigators created an analytic framework with the Key Questions and the patient populations, interventions, and outcomes for both routine preventive iron supplementation (Figure 1) and screening (Figure 2).

Figure 1 Analytic Framework and Key Questions for Routine Iron Supplementation During Pregnancy

KQ 1 What are the benefits of routine iron supplementation during pregnancy on maternal and infant health outcomes?
KQ 2 What are the harms of routine iron supplementation during pregnancy?
KQ 3 In pregnant persons with iron deficiency, with or without anemia, what is the association between change in maternal iron status (including changes in ferritin or hemoglobin level) and improvement in newborn and peripartum outcomes in U.S.-relevant populations?

Abbreviation: KQ=Key Question.

The analytic framework depicts the relationship between the population, intervention, outcomes, and harms of supplementation for the prevention of iron deficiency and iron deficiency anemia during pregnancy. The far left of the framework describes the target population as pregnant persons asymptomatic for iron deficiency and iron deficiency anemia. To the right of the population is an arrow which leads to the intervention, routine iron supplementation. Below routine iron supplementation is an oval for harms of screening (Key Question 2). An arrow leads directly from the intervention to a box containing the health outcomes of maternal and infant morbidity and mortality, including birth outcomes, and quality of life (Key Question 1). An arrow to the right of the intervention leads to a rounded edge box containing the intermediate outcome of iron status. A dotted line to the right of iron status represents the connection between iron status and the health outcomes of maternal and infant morbidity and mortality, including birth outcomes, and quality of life (Key Question 3).

Figure 2 Analytic Framework and Key Questions for Screening for Iron Deficiency and Iron Deficiency Anemia During Pregnancy

KQ 1 What are the benefits of screening for iron deficiency and iron deficiency anemia in asymptomatic pregnant persons on maternal and infant health outcomes?
KQ 2 What are the harms of screening for iron deficiency and iron deficiency anemia in pregnant persons?
KQ 3 What are the benefits of treatment of iron deficiency and iron deficiency anemia during pregnancy on maternal and infant health outcomes?
KQ 4 What are the harms of iron treatment in pregnant persons?
KQ 5 In pregnant persons with iron deficiency, with or without anemia, what is the association between change in maternal iron status (including changes in ferritin or hemoglobin level) and improvement in newborn and peripartum outcomes in U.S.-relevant populations?

Abbreviation: KQ=Key Question.

The analytic framework depicts the populations, interventions, outcomes, and harms of interest for screening for iron deficiency and iron deficiency anemia in pregnant persons. The far left of the framework describes the target population as pregnant persons asymptomatic for iron deficiency and iron deficiency anemia. To the right is screening. An arrow leads directly from screening to a box containing the health outcomes of maternal and infant morbidity and mortality, including birth outcomes, and quality of life (Key Question 1). Below screening is an oval for harms of screening (Key Question 2). To the right of screening is a box for iron deficiency. An arrow to the right of iron deficiency represents the intervention, iron treatment, and leads to the intermediate outcome of iron status (Key Question 3). Below the intervention is an oval for harms of iron treatment (Key Question 4). A dotted line to the right of iron status represents the connection between iron status and the health outcomes of maternal and infant morbidity and mortality, including birth outcomes, and quality of life (Key Question 5).

### Key Questions for Routine Iron Supplementation During Pregnancy

Key Question 1 What are the benefits of routine iron supplementation during pregnancy on maternal and infant health outcomes?
Key Question 2 What are the harms of routine iron supplementation during pregnancy?
Key Question 3 In pregnant persons with ID, with or without anemia, what is the association between change in maternal iron status (including changes in ferritin or hemoglobin level) and improvement in newborn and peripartum outcomes in U.S.-relevant populations?

### Key Questions for Screening for ID and IDA During Pregnancy

Key Question 1 What are the benefits of screening for ID and IDA in asymptomatic pregnant persons on maternal and infant health outcomes?
Key Question 2 What are the harms of screening for ID and IDA in pregnant persons?
Key Question 3 What are the benefits of treatment of ID and IDA during pregnancy on maternal and infant health outcomes?
Key Question 4 What are the harms of iron treatment in pregnant persons?
Key Question 5 In pregnant persons with ID, with or without anemia, what is the association between change in maternal iron status (including changes in ferritin or hemoglobin level) and improvement in newborn and peripartum outcomes in U.S.-relevant populations?

## Contextual Questions

In addition, three Contextual Questions were requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology.

Contextual Question 1 What are the current practices in identifying pregnant persons with ID and IDA? Do current practices of identification differ by race or ethnicity, diagnostic criteria, age, socioeconomic status, cultural factors, educational attainment, insurance status, or health literacy?
Contextual Question 2 What are current practices for the use of iron supplementation during pregnancy? Do current practices differ by race or ethnicity, age, diagnostic criteria, socioeconomic status, cultural factors, educational attainment, insurance status, or health literacy of the pregnant person?
Contextual Question 3 How well do risk assessment tools identify pregnant persons at increased risk for IDA?

## Search Strategies

This report updates the previous report for the USPSTF,^3,4^ which had searches through August 19, 2014. We searched Ovid MEDLINE^®^, the Cochrane Database of Systematic Reviews, and the Cochrane Central Register of Controlled Trials from June 1, 2014, to May 24, 2023, for IDA; in addition, to cover the expanded scope of ID without anemia, additional searches began at database inception. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles. Ongoing surveillance was conducted to identify major studies published since May 24, 2023, that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on May 24, 2024, and identified no studies affecting review conclusions.

## Study Selection

All titles, abstracts, and studies identified through searches were independently reviewed by two members of the research team for eligibility against predefined inclusion/exclusion criteria organized by population, intervention, comparator, outcome, timing, and study design for both supplementation and screening frameworks (Appendix A2). Each full-text article was independently reviewed by two members of the research team for inclusion or exclusion on the basis of the eligibility criteria. Disagreements were resolved by discussion and consensus. All results were reviewed and tracked using DistillerSR and EndNote (Thomson Reuters, New York, NY). We excluded non-English–language articles and studies published only as conference abstracts. In accordance with the USPSTF Procedure Manual,^59^ studies assessed as poor quality were excluded. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists included studies, and Appendix A5 lists excluded studies with reasons for exclusion.

## Scope of Review

The population included pregnant adolescent and adults asymptomatic for ID or IDA. We used nongendered terms (e.g., person, individual) to increase inclusivity, except where the data were specified as women or females for the purpose of accuracy. Among the nongendered terms, we used the term pregnant person to characterize the study population that includes pregnant women and other individuals capable of pregnancy and acknowledge the current linguistic complexity and importance of centering inclusion.

Similar to the 2015 review,^3,4^ this review addresses evidence using two distinct frameworks on the effectiveness of routine preventive iron supplementation during pregnancy, and separately, the effectiveness of screening for ID and IDA during pregnancy. For this update, the population was expanded to include populations with ID in addition to those with IDA. For the supplementation framework, the treated population includes those not known to have ID or IDA. For screening, the treated population is screen-detected persons found to have ID or IDA. Studies of nonpregnant persons and patients with known nutritional deficiencies or symptoms of IDA were excluded.

For the supplementation framework, studies required a comparison between oral iron supplementation or iron-fortified foods and placebo or no supplementation. Specific timing for initiation of iron supplementation was not always clearly reported in the studies; therefore, mean baseline gestational age at enrollment and/or gestational age specified in the eligibility criteria were sometimes used for estimating the timing of dose initiation. Due to the availability of good- and fair-quality randomized, controlled trials (RCTs) of supplementation, observational studies were not included for the supplementation framework. Eligible maternal outcomes included clinical and health outcomes (e.g., mortality, health-related quality of life, preeclampsia, postpartum hemorrhage, blood transfusion, postpartum depression, and cesarean delivery rates), as well as hematologic outcomes, including incidence of IDA or ID, and other hematologic indices and ferritin levels. Infant outcomes included clinical and health outcomes (e.g., perinatal mortality, respiratory distress, neonatal intensive care unit admission, low birth weight, small for gestational age, and preterm delivery); infant hematologic indices and ferritin levels were also included. Adverse effects included clinical harms, harms leading to discontinuation, and accidental overdose. Timing of maternal outcomes were during pregnancy, at term, and postpartum; infant outcomes were limited to the first year of life.

An association question evaluating whether a change in iron status results in any changes in health outcomes was included in both the screening (Key Question 5) and supplementation (Key Question 3) frameworks. Studies eligible for this question were required to examine the association between a change in maternal ID or IDA as a result of treatment or supplementation and improved health outcomes.

For the screening framework, studies required a comparison between screening and no screening or treatment versus no treatment for pregnant adolescents or adults with screen-detected ID or IDA. Eligible interventions were routine blood tests (e.g., CBC) and oral or intravenous iron supplementation or iron-fortified foods. Eligible study designs for the screening framework included RCTs or controlled observational studies and large uncontrolled observational studies on harms. The outcomes for the supplementation framework also apply to the screening framework, but also included harms more specific to screening such as overdiagnosis, anxiety, and labeling.

Studies from specialty settings and geographic areas in which the epidemiology and management of ID and IDA may differ substantially from U.S. primary/prenatal care settings were excluded. To inform generalizability to U.S. primary care settings, we categorized studies according to the country where it was conducted, utilizing the 2020 United Nations Human Development Index (HDI) and limited inclusion to high or very high HDI.^60^ Trials from China were included for this update because of reclassification from a medium to a high HDI rating in 2011/2012.^61,62^

Two new Contextual Questions were added to examine issues of equity and health disparities related to current practices to identify persons with ID and IDA, and use of iron supplementation. One Contextual Question on the yield of repeat screening was not carried forward from the prior review, given the lack of evidence on effectiveness of initial routine screening. Contextual Questions were addressed through targeted literature searches to identify key articles to inform the USPSTF. For this update, language was revised to be more inclusive around sex and gender to consider all pregnant populations.

### Data Abstraction and Quality Rating

For studies meeting inclusion criteria, we reviewed and updated data abstraction forms from the prior USPSTF review to summarize pertinent information from each study, including characteristics of study populations, interventions, comparators, outcomes, study designs, settings, and methods (Appendix B). One investigator conducted data abstraction, which was reviewed for completeness and accuracy by another team member. Abstractions from studies included in the prior report were reviewed for accuracy or updated.

Predefined criteria were used to assess the quality of individual controlled trials, systematic reviews, and observational studies by using criteria developed by the USPSTF^59^ as appropriate (Appendix A6); studies were rated as “good,” “fair,” or “poor” per USPSTF criteria, depending on the seriousness of the methodological shortcomings. For each study, quality assessment was performed by two team members. Disagreements were resolved by consensus. Similar to the prior report, poor-quality studies were excluded from the review due to the availability of good- and fair-quality studies.

### Data Synthesis and Analysis

Meta-analyses were updated, and new meta-analyses were conducted for outcomes and comparisons for which there were multiple studies comparable enough to provide a meaningful combined estimate. To determine whether meta-analysis could be meaningfully performed or updated, we considered the similarity between studies in design, patient population, interventions, outcomes, study quality, and setting, and relevance of the outcomes. We conducted meta-analyses to calculate risk ratios (RRs) and 95 percent confidence intervals (CIs) of the effects of routine iron supplementation on incidence of preterm delivery, low birth weight, small for gestational age, hypertensive disorders of pregnancy, cesarean delivery, IDA, ID, and anemia alone. Hematologic values were pooled separately at term and third trimester time points; postpartum time points were not pooled due to variable and less frequent reporting. For intermediate outcomes, data were pooled for risk of ID or IDA, which were considered more informative than changes in individual hematological indices such as ferritin or hemoglobin.

Due to anticipated statistical heterogeneity, meta-analyses to calculate RRs were conducted using the DerSimonian-Laird random effects models with Stata 14 software (StataCorp, Stata Statistical Software: Release 14, College Station, TX, 2015). Statistical heterogeneity was assessed using the I^2^ statistic. Adjusted risk differences (ARDs) were calculated when RRs were statistically significant. Stratified analyses were conducted to assess the sensitivity of results to variations across studies in characteristics, including country HDI rating (defined as very high HDI vs. medium/high HDI [medium noted due to China’s change in rating]), and lower and higher supplementation dosing based on elemental iron doses (defined as ≥60 mg as high and <60 mg as low). We calculated p-values for the interaction of these characteristics and iron supplementation in effects on outcomes. Stratified analyses for ID, IDA, and anemia used the values reported at term. Due to inconsistent reporting of baseline anemia prevalence in the studies, we included baseline hemoglobin levels on forest plots. Stratified analyses are presented in Table 2 and the Appendix C Figures.

Table 2 Summary of Meta-Analyses

Outcome; Subgroup | Subgroup Definition | No. of trials (Total N) | RR (95% CI) and ARD if significant^a^ | I^2^
Maternal Iron Deficiency, at Term; All Trials | NA | 6 (2,361) | 0.47 (0.33 to 0.67); ARD −34 (−46% to −22%) | 81.9%
Maternal Iron Deficiency, at Term; Country; (p=0.597 for interaction) | U.S. or other applicable countries (very high HDI) | 4 (596) | 0.35 (0.18 to 0.65); ARD −44% (−63% to −25%) | 79.3%
Maternal Iron Deficiency, at Term; Country; (p=0.597 for interaction) | Rural China, Iran (medium to high HDI) | 2 (1,765) | 0.57 (0.29 to 1.13) | 69.5%
Maternal Iron Deficiency, at Term; Dose; (p=0.577 for interaction) | Low (<60 mg iron) | 2 (431) | 0.57 (0.46 to 0.69); ARD −32% (−52% to −11%) | 0.0%
Maternal Iron Deficiency, at Term; Dose; (p=0.577 for interaction) | High (≥60 mg iron) | 4 (1,930) | 0.26 (0.09 to 0.77); ARD −36% (−54% to −18%) | 86.0%
Maternal Iron Deficiency, 3rd trimester; All Trials | NA | 4 (1,220) | 0.70 (0.53 to 0.92); ARD −17% (−24% to −10%) | 77.4%
Maternal Iron Deficiency Anemia, at Term; All Trials | NA | 4 (2,230) | 0.40 (0.26 to 0.61); ARD −10% (−16% to −3%) | 20.5%
Maternal Iron Deficiency Anemia, at Term; Country; (p=0.361 for interaction) | U.S. or other applicable countries (very high HDI) | 3 (614) | 0.29 (0.15 to 0.55); ARD −12% (−19% to −6%) | 0.0%
Maternal Iron Deficiency Anemia, at Term; Country; (p=0.361 for interaction) | Rural China (medium to high HDI) | 1 (1,616) | 0.49 (0.38 to 0.62); ARD −5% (−16% to 5%) | NA
Maternal Iron Deficiency Anemia, at Term; Dose; (p=0.371 for interaction) | Low (<60 mg iron) | 1 (383) | 0.28 (0.12 to 0.68); ARD −8% (−13% to −3%) | NA
Maternal Iron Deficiency Anemia, at Term; Dose; (p=0.371 for interaction) | High (≥60 mg iron) | 3 (1,847) | 0.42 (0.24 to 0.71); ARD −11% (−19% to −2%) | 21.0%
Maternal Iron Deficiency Anemia, 3rd Trimester; All Trials | NA | 3 (660) | 0.63 (0.41 to 0.97); ARD −4% (−8% to 0.02%) | 0.0%
Maternal Anemia, at Term; All Trials | NA | 4 (2,261) | 0.43 (0.26 to 0.72); ARD −12% (−15% to −9%) | 43.7%
Maternal Anemia, at Term; Country; (p=0.605 for interaction) | U.S. or other applicable countries (very high HDI) | 3 (645) | 0.22 (0.06 to 0.84); ARD −12% (−19% to −6%) | 49.3%
Maternal Anemia, at Term; Country; (p=0.605 for interaction) | Rural China (medium to high HDI) | 1 (1,616) | 0.53 (0.43 to 0.66); ARD −12% (−15% to −8%) | NA
Maternal Anemia, at Term; Dose; (p=0.953 for interaction) | Low (<60 mg iron) | 1 (393) | 0.45 (0.25 to 0.82); ARD −9% (−15% to −2%) | NA
Maternal Anemia, at Term; Dose; (p=0.953 for interaction) | High (≥60 mg iron) | 3 (1,868) | 0.22 (0.05 to 1.02) | 61.1%
Maternal Anemia, 3rd Trimester; All Trials | NA | 7 (2,148) | 0.71 (0.51 to 0.97); ARD −8% (−15% to −0.66%) | 64.2%
Maternal Hypertensive Disorders of Pregnancy; All Trials | NA | 5 (13,610) | 1.24 (0.75 to 2.06) | 48.0%
Maternal Hypertensive Disorders of Pregnancy; Country; (p=0.640 for interaction) | Ireland (very high HDI) | 1 (97) | 0.83 (0.22 to 3.13) | NA
Maternal Hypertensive Disorders of Pregnancy; Country; (p=0.640 for interaction) | Rural China, Iran (medium to high HDI) | 4 (13,513) | 1.38 (0.74 to 2.56) | 60.9%
Maternal Hypertensive Disorders of Pregnancy; Dose; (p=0.640 for interaction) | Low (<60 mg iron) | 3 (13,365) | 1.35 (0.70 to 2.61) | 71.6%
Maternal Hypertensive Disorders of Pregnancy; Dose; (p=0.640 for interaction) | High (≥60 mg iron) | 2 (245) | 1.02 (0.30 to 3.47) | 0.0%
Maternal Cesarean Delivery; All Trials | NA | 8 (4,919) | 1.01 (0.90 to 1.14) | 42.7%
Maternal Cesarean Delivery; Country; (p=0.025 for interaction) | U.S. or other applicable countries (very high HDI) | 4 (1,562) | 0.85 (0.66 to 1.11) | 23.8%
Maternal Cesarean Delivery; Country; (p=0.025 for interaction) | Rural China, Iran (medium to high HDI) | 4 (3,357) | 1.07 (1.01 to 1.14) | 0.0%
Maternal Cesarean Delivery; Dose; (p=0.235 for interaction) | Low (<60 mg iron) | 4 (2,173) | 1.11 (0.99 to 1.25) | 0.0%
Maternal Cesarean Delivery; Dose; (p=0.235 for interaction) | High (≥60 mg iron) | 4 (2,746) | 0.89 (0.67 to 1.20) | 67.6%
Infant Preterm Birth; All Trials | NA | 5 (16,827) | 0.92 (0.81 to 1.04) | 0.0%
Infant Preterm Birth; Country; (p=0.882 for interaction) | Hong Kong (very high HDI) | 1 (862) | 0.95 (0.58 to 1.57) | NA
Infant Preterm Birth; Country; (p=0.882 for interaction) | Rural China, Iran (medium to high HDI) | 4 (15,965) | 0.92 (0.81 to 1.04) | 0.0%
Infant Preterm Birth; Dose; (p=0.409 for interaction) | Low (<60 mg iron) | 2 (12,614) | 0.95 (0.83 to 1.10) | 0.0%
Infant Preterm Birth; Dose; (p=0.409 for interaction) | High (≥60 mg iron) | 3 (4,213) | 0.83 (0.65 to 1.06) | 0.0%
Infant Low Birth Weight; All Trials | NA | 6 (15,591) | 0.95 (0.79 to 1.14) | 0.0%
Infant Low Birth Weight; Country; (p=0.831 for interaction) | U.S. or other applicable countries (very high HDI) | 3 (601) | 1.02 (0.54 to 1.94) | 0.0%
Infant Low Birth Weight; Country; (p=0.831 for interaction) | Rural China, Iran (medium to high HDI) | 3 (14,990) | 0.95 (0.78 to 1.15) | 0.0%
Infant Low Birth Weight; Dose; (p=0.262 for interaction) | Low (<60 mg iron) | 2 (12,257) | 1.05 (0.83 to 1.33) | 0.0%
Infant Low Birth Weight; Dose; (p=0.262 for interaction) | High (≥60 mg iron) | 4 (3,334) | 0.82 (0.61 to 1.10) | 0.0%
Infant Small for Gestational Age; All Trials | NA | 4 (5,386) | 0.94 (0.67 to 1.31) | 75.5%
Infant Small for Gestational Age; Country; (p=0.214 for interaction) | U.S. or other applicable countries (very high HDI) | 1 (862) | 0.48 (0.26 to 0.87) | NA
Infant Small for Gestational Age; Country; (p=0.214 for interaction) | Rural China, Iran (medium to high HDI) | 3 (4,524) | 1.07 (0.80 to 1.41) | 66.6%
Infant Small for Gestational Age; Dose; (p=0.526 for interaction) | Low (<60 mg iron) | 2 (1,509) | 1.10 (0.59 to 2.05) | 83.3%
Infant Small for Gestational Age; Dose; (p=0.526 for interaction) | High (≥60 mg iron) | 2 (3,877) | 0.75 (0.35 to 1.59) | 83.7%

Abbreviations: ARD=absolute risk difference; CI=confidence interval; HDI=Human Development Index; NA=not applicable; RR=relative risk.

a Bold estimates indicate a statistically significant difference.

Qualitative data were summarized in tables providing ranges, descriptive analysis, and interpretation of the results. Relative risks were calculated when not reported in studies and when available data were sufficient. Study applicability assessments were based on the country in which studies were performed (based on the HDI or other factors), patient demographic characteristics, iron supplementation or dosing regimens, and adherence.

Two independent reviewers assessed the aggregate internal validity (quality) for each Key Question using methods developed by the USPSTF^59^ based on the number, quality, and size of studies; consistency of results between studies; and directness of evidence.^59^ Disagreements were resolved through consensus. A summary of evidence table summarizes the overall quality of evidence for each Key Question.

## USPSTF and AHRQ Involvement

The research team worked with USPSTF members to develop and refine the analytic frameworks, Key Questions, and scope for the final evidence synthesis. AHRQ staff provided oversight for the project, coordinated the systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.

## Expert Review and Public Comment

Key Informants provided input on the draft research plan to identify important target populations and inform the development of the scope and Key Questions. In addition, the draft research plan was posted on the USPSTF website for public comment from April 7, 2022, to May 4, 2022. In response to public comments, the USPSTF made minor edits to improve clarity, including revisions to the scope of the review to include ID in addition to IDA during pregnancy. The Contextual Questions were expanded to address disparities in the diagnosis and management of anemia and their effects on management decisions and health outcomes, in addition to addressing how practices for diagnosis or decisions for supplementation may differ in certain populations.

The draft report was reviewed by content experts and collaborative partners (Appendix A7). No additional studies for the Key Questions were suggested, and reviewers thought the studies included were appropriate. Reviewers recognized the limitations of the evidence base, including the variable dosing of iron supplements, duration of supplementation, and variability in baseline hemoglobin and ferritin levels. Minor edits were made for clarity in the “Introduction” and “Discussion” sections. In addition, the draft report was posted for public comment from February 27, 2024, to March 25, 2024. The comments were reviewed, and minor edits were made to improve clarity, but no changes to the included studies or conclusions were required.