# Chapter 1 Introduction and Background

## Purpose

This systematic review update will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2015 recommendation on screening for and prevention of iron deficiency anemia (IDA) via routine iron supplementation in pregnant persons.^1^ In 2015, the USPSTF concluded that the current evidence was insufficient to assess the balance of benefits and harms of screening for IDA in pregnant persons to prevent adverse maternal health and birth outcomes (I statement).^1^ This was due to the lack of studies evaluating the direct effects of routine screening in asymptomatic pregnant persons on maternal health or birth outcomes, inadequate evidence on the accuracy of screening tests in asymptomatic pregnant persons, and inadequate evidence to evaluate risk prediction tools to identify pregnant persons at increased risk for IDA. There was also inadequate evidence on the treatment of IDA in pregnant persons due to lack of generalizability to U.S. clinical settings in treatment studies due to differential nutritional status or hemoparasite burden.^2^ This was considered a critical gap in the evidence.^2^

In 2015, the USPSTF also concluded that the current evidence was insufficient to assess the balance of benefits and harms of routine preventive iron supplementation for pregnant persons to prevent adverse maternal health and birth outcomes (I statement), based on inadequate evidence on the effect of routine iron supplementation during pregnancy on maternal health or birth outcomes, such as maternal IDA, cesarean delivery, preterm delivery, infant mortality, or low birth weight. The USPSTF found adequate evidence that routine iron supplementation during pregnancy improved intermediate maternal hematologic indexes, such as serum ferritin and hemoglobin levels, and adequate evidence that routine iron supplementation during pregnancy had no effects on the length of gestation and infant Apgar scores at 1 and 5 minutes.

This report updates the 2015 USPSTF review.^3,4^ Similar to the prior review, it synthesizes evidence on the benefits and harms of screening and preventive medications for iron deficiency (ID) and IDA in pregnant persons, and expands the scope by evaluating the effect of supplementation and screening on ID without anemia.

## Condition Background

### Condition Definition

Iron is required in the production of hemoglobin, an essential protein found in red blood cells that transports oxygen throughout the body from the respiratory organs. Over time, iron is stored in the body for use in hemoglobin production. ID occurs when the level of stored iron becomes depleted. IDA occurs when iron levels are sufficiently depleted to produce anemia, characterized by hypochromic and microcytic red blood cells.^5,6^ Progression from ID alone (low iron stores) to IDA is a process that occurs in stages. When iron stores are depleted, IDA can develop with further iron losses.

The Centers for Disease Control and Prevention (CDC)^6^ and the World Health Organization (WHO)^7^ define IDA in pregnancy as ID (serum ferritin level <12 µg/L) with a hemoglobin level of less than 11.0 g/dL (or <110 g/L) and a hematocrit level of less than 33 percent.^8^ ID without anemia can be diagnosed based on ferritin levels, a marker of iron stores, with varying cutoffs depending on the laboratory reference standard.^9^ While the gold standard for documenting ID historically has been iron staining of a bone marrow aspirate smear, bone marrow correlations and international guidelines^8^ support diagnosing ID using ferritin levels and considering an increase in the cutoff from 30 ng/mL to 50 ng/mL.^10,11^

### Etiology and Natural History

Physiological anemia of pregnancy is observed in healthy pregnant persons and occurs as the result of greater expansion of plasma volume relative to the increase in hemoglobin mass and erythrocyte volume associated with pregnancy. This normal physiological change is responsible for a modest decrease in hemoglobin levels and is often referred to as dilutional anemia of pregnancy. Pregnancy-associated changes in plasma volume and red cell mass, normal differences in hemoglobin concentrations, and individual variation can also affect iron stores.

In the recent past, there have been race-based cutoffs for IDA, which are now recognized as a possible contributor to disparities in diagnosis, treatment, and outcomes.^12,13^ Standardized cutoffs across all populations are recommended.^14,15^ While there are disparities in reported prevalence of anemia during pregnancy based on race and ethnicity, the etiology of these differences is unclear (see “Disparities” section below). In light of these issues, using different cutoffs based on race or categorizing race or ethnicity as risk factors for anemia during pregnancy is not recommended.^16^

ID is the most common pathological cause of anemia in pregnancy. Total iron loss associated with pregnancy and lactation is about 1,000 mg. Iron is necessary for both fetal and placental development and to expand the maternal red cell mass. Iron is commonly prescribed as part of a prenatal multivitamin or as a separate supplement based on the assumption that iron stores during pregnancy are not often sufficient to support the physiologic demands of pregnancy.

### Prevalence and Burden of Disease/Illness

During pregnancy there is a higher risk for ID compared with the nonpregnant state because of increased iron needs resulting from growth of the fetus and placenta, increased red cell mass, and the expansion of maternal blood volume, especially as the pregnancy progresses into the third trimester.^6,13,17–19^ Analysis of National Health and Nutrition Examination Survey (NHANES) epidemiological data (n=1,171) from 1999 to 2006 found an overall prevalence of ID in pregnancy near 18 percent, with 5 percent of pregnant persons found to be anemic; prevalence of ID increased from 6.9 to 14.3 to 28.4 percent across the three trimesters.^19^ From 2000 to 2004, reported rates of IDA in a population of low-income, pregnant women from the urban United States were 1.8 percent in the first trimester, 8.2 percent in the second trimester, and 27.4 percent in the third trimester.^18^ Additional estimates of IDA in pregnant persons are not readily available but older data may underestimate the prevalence of ID due to lower ferritin cutoffs than currently accepted; therefore, data are limited.

ID during pregnancy is associated with fatigue, reduced quality of life, and increased risk of postpartum depression^20,21^ in pregnant persons, and higher risk of low birth weight and preterm birth.^22^ Pregnant persons with IDA or ID may experience clinical symptoms of fatigue, weakness, pallor, and in more severe cases, tachycardia or shortness of breath.^23^ In countries where access to nutrition and healthcare is inadequate, severe maternal anemia during pregnancy has been associated with postpartum hemorrhage and higher risk of maternal death.^24,25^

Numerous older observational studies have shown various measures of iron status, including IDA, to be associated with serious negative infant outcomes, including low birth weight,^26–28^ premature birth,^26–31^ and perinatal death;^27^ however, newer studies indicate that the association between iron status and negative outcomes for both pregnant persons and their infants is inconclusive and longer term data are needed.

### Disparities

There are differences in prevalence of IDA according to population characteristics. NHANES data from 1999 to 2006 (n=1,171) found differences in the prevalence of IDA by race, with highest rates among non-Hispanic Black (30%) and Mexican American (24%) pregnant persons and lower rates among White pregnant persons (14%).^19^ In one study, parity of two or more was associated with increased prevalence of ID (28%) compared with parity of zero (12%) or one (17%);^19^ however, no associations were found in pregnant persons with lower educational levels or family income, associated with low socioeconomic status, which are mentioned as risk factors in other sources.^13,18^ Rates of IDA may also differ by socioeconomic status. For example, a study of pregnant persons followed through 6 months postpartum found a higher prevalence of IDA in those with an income eligible for Federal aid, based on a poverty index ratio of less than 130 percent, compared with pregnant persons with incomes above this threshold (10% vs. 2%, respectively).^32^ Importantly, these differences do not address the contribution of nutritional status or other potential underlying contributors to these disparities such as food insecurity^33^ or access to healthcare. IDA in pregnancy can persist into the postpartum period, with an estimated prevalence of 4 percent.^34^ One study and one NHANES analysis found correlations between higher body mass index and decreased iron levels in pregnant persons.^35,36^ Additional information on disparities is provided in Contextual Questions 1 and 2.

### Risk Factors

The most commonly cited risk factors for IDA or ID in pregnancy include eating a diet low in iron-rich foods (e.g., vegan or vegetarian diet), having gastrointestinal issues that affect absorption, or having a short interpregnancy interval.^37^ Tobacco use and living at high altitude may cause an increase in hematocrit and hemoglobin levels and impact interpretation of test results.^6^

### Rationale for Screening/Screening Strategies

Screening asymptomatic pregnant persons for IDA may lead to earlier identification and therefore earlier treatment, which has the potential to prevent serious negative health outcomes. Strategies for screening can include either routine screening or targeted screening based on established risk factors, risk-assessment instruments, or diagnostic tests. Routine screening during pregnancy may occur when individuals first present for prenatal care and can occur during pregnancy depending on local practices.

In most clinical settings, the simplest and most cost-effective measurement of IDA is a complete blood count (CBC), which includes measurements of hemoglobin, hematocrit, mean corpuscular volume, and red blood cell distribution width (a measure of variability in red cell size); however, some data suggest the limited sensitivity of a CBC for IDA in pregnant populations.^38^ Anemia alone (hemoglobin level <11.0 g/dL) is not an ideal screening parameter for IDA since it may not be the best indicator of iron levels and therefore other laboratory parameters such as total iron binding capacity or transferrin saturation may be measured.

Serum ferritin may be useful in screening for ID with or without anemia in pregnant persons;^39^ however, there is variation in thresholds used to define ID during pregnancy.^40^ In one study of pregnant persons,^9^ serum ferritin was found to be a reliable indicator of reduced iron stores, with a sensitivity of 90 percent and specificity of 85 percent when used as a screening tool for ID. Ferritin is an acute phase reactant in the presence of adequate iron stores and can be elevated during inflammatory states, including liver disease, infection, and malignancy.^41^ Changes in inflammatory measures have also been reported during pregnancy.^42^ Serum ferritin may be of limited usefulness when concentrations decrease during late pregnancy, despite the presence of bone marrow iron.^40^

### Interventions: Preventive Supplementation and Treatment

#### Preventive Supplementation

Primary prevention of ID during pregnancy consists of adequate dietary iron intake and routine iron supplementation.^43^ This may include starting an oral low-dose (e.g., 30 mg/day) iron supplement at the beginning of pregnancy or integrating iron-rich foods and foods that enhance iron absorption. Prophylaxis for IDA in higher-risk populations may be accomplished with higher supplemental doses (e.g., 60 to 100 mg elemental iron per day).

#### Treatment

Treatment of ID in pregnancy is the same as that in nonpregnant, postpartum, premenopausal, and postmenopausal persons and begins with increased dietary intake of iron and oral iron supplementation. Pregnant persons with IDA are generally treated with additional oral iron supplements in combination with prenatal vitamins and dietary counseling. The dosage of elemental iron required to treat IDA in adults is 120 mg per day for 3 months. Therapy is continued for 3 months after the anemia is corrected to allow iron stores to become replenished. There are no standard recommendations for followup after initiating therapy for IDA; however, one suggested course is to perform a CBC every 3 months for 1 year.^44,45^

Iron is available orally as ferrous fumarate, ferrous sulfate, or ferrous gluconate and have higher bioavailability than ferrous citrate or sulfate.^46^ Each iron salt provides different amounts of elemental iron (e.g., ferrous sulfate has 20% elemental iron per mg while ferrous fumarate has 33%). Variable formulations and dosing may affect the efficacy and tolerability profile of the product.

Adverse events are typically limited to gastrointestinal tract symptoms that limit the ability or willingness of patients to adhere to the regimen. It is estimated that 10 to 25 percent of patients may report nausea, constipation, epigastric distress, and/or vomiting while taking oral iron, with symptom etiology considered directly related to the dose of elemental iron.^47^ The absorption of iron is inhibited by some food, including tea, foods high in calcium, and antacids, and is enhanced by a more acidic environment.^48^ Therefore, experts usually recommend avoiding dosing with meals or within 2 hours of taking antacids and taking the dose with citrus fruits or ascorbic acid to maximize absorption. However, for patients who experience gastrointestinal adverse effects that affect adherence to the regimen, slowly increasing the dose over several days, reducing the amount of elemental iron taken per dose or daily, or taking the iron with food may improve symptoms. Urine and stool may be darker in color when taking iron, and liquid formulations can cause temporary gray staining of the teeth and gums. Iron can cause important interactions with several drugs.^49,50^

Indications for the use of parenteral iron are the same for pregnant persons as for nonpregnant persons, and has become more common for managing ID, despite some concerns about adverse effects,^51–53^ including allergic reactions and cost. Intravenous iron is generally used to replenish iron stores in selected patients who have not tolerated a trial of oral iron therapy, if oral iron does not effectively increase hemoglobin or ferritin levels,^8^ or for those with severe ID.^54^ Notably, there are no safety data for intravenous iron during the first trimester, but it is considered safe and effective during the second and third trimesters.^55^

### Current Clinical Practice

Rates of screening for IDA and iron supplementation in pregnant persons by clinicians are not well documented and may vary by clinical specialty or society practice standards. Screening may occur as part of routine prenatal care or to screen for anemia in pregnant persons to prepare for cesarean delivery or anticipated blood loss during a complicated delivery. Based on 1996 to 2006 NHANES epidemiological data (n=1,296), 77 percent of pregnant persons reported using a supplement within the previous 30 days, and they most frequently used a multivitamin containing 48 mg of iron.^56^ A summary of current screening and supplementation practices in U.S. populations is included in the Contextual Questions.

### Recommendations of Other Groups

Recommendations of other groups are summarized in Table 1.

Table 1 Recommendations of Other Groups

Organization, year | Recommendations
American Academy of Family Physicians (AAFP), 2013^44^ | All pregnant women should be screened for iron deficiency anemia. Supplemental iron may be given initially, followed by further workup if the patient is not responsive to therapy. In pregnant patients, poor compliance or intolerance should be considered, and parenteral iron may produce a better response.
American College of Obstetricians and Gynecologists (ACOG), 2021^14^ | All pregnant women should be screened for anemia with a complete blood count in the first trimester and again at 24 to 28 weeks of gestation. Patients who meet criteria for anemia based on hematocrit levels less than 33% in the first and third trimesters and less than 32% in the second trimester should be evaluated to determine the cause. Those with iron deficiency anemia should be treated with supplemental iron, in addition to prenatal vitamins.
Centers for Disease Control and Prevention (CDC), 1998^6^ | All pregnant women, at their first prenatal visit, begin taking an oral, low dose (30 mg/day) supplement of iron and be screened for iron deficiency anemia.
National Institute for Health and Care Excellence (NICE), 2000^111^ | Offer pregnant women screening for anemia at the initial appointment and again at 28 weeks. If iron deficiency is identified, then treatment should be considered, but iron supplementation should not be offered routinely to all pregnant women.
National Academy of Medicine (NAM), 1993^13^ | All pregnant women should be screened for iron deficiency anemia at the first prenatal visit and at least once during each subsequent trimester. Nutrition education about diet during pregnancy should be provided at every prenatal visit. When the hemoglobin level is between 9.0 and 10.9 g/dL and the serum ferritin concentration is between 12 and 20 µg/L or the hemoglobin level is 11.0 g/dL or greater and the serum ferritin concentration is 20 µg/L or less, 30 mg of supplemental iron should be provided on a daily basis. The clinician should prescribe 60-120 mg of supplemental iron per day when the hemoglobin level is between 9.0 and 10.9 g/dL and the serum ferritin concentration is less than 12 µg/L.
Network for the Advancement of Patient Blood Management, Haemostasis and Thrombosis, 2018^112^ | Screen pregnant women for anemia during their first visit and at 28 weeks. Offer women in areas of low prevalence for anemia in pregnancy but who may be at increased risk of developing anemia iron supplementation (30-60 mg/day) to prevent the onset of anemia.
Department of Veterans Affairs/Department of Defense (VA/DoD), 2018^58^ | Screen pregnant women for anemia in the first trimester.
World Health Organization (WHO), 2016^58^ | Recommend daily oral iron and folic acid supplementation with 30 mg to 60 mg of elemental iron and 400 µg (0.4 mg) folic acid for pregnant women. Recommend intermittent oral iron and folic acid supplementation with 120 mg of elemental iron and 2,800 µg (2.8 mg) folic acid once if daily iron is not acceptable due to side effects, and in populations with an anemia prevalence among pregnant women of less than 20%.

#### Screening

The American College of Obstetricians and Gynecologists (ACOG),^14^ the U.S. Department of Veterans Affairs/Department of Defense (VA/DoD),^57^ the CDC,^6^ and the American Academy of Family Physicians (AAFP)^44^ recommend that all pregnant persons be screened for anemia at some point during pregnancy. The VA/DoD recommends screening during the first prenatal visit.

The National Academy of Medicine (NAM)^13^ recommends screening for anemia in high-risk pregnant persons during each trimester and at 4 to 6 weeks postpartum. The Canadian Task Force on Preventive Health Care does not have a current recommendation for this topic.

#### Preventive Supplementation

While the CDC^6^ and the WHO^58^ recommend universal iron supplementation in pregnant persons, the VA/DoD states that there is insufficient evidence to recommend for or against universal supplementation.^57^ The NAM,^13^ ACOG,^14^ and AAFP^44^ recommend screening and treatment as necessary in lieu of routine supplementation. The Canadian Task Force on Preventive Health Care does not have a current recommendation for this topic.