# Appendix C Figures

Appendix C Figure 1 Meta-Analysis: Hypertensive Disorders of Pregnancy, Stratified by HDI Country

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; HDI=United Nations Human Development Index; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 1 is a forest plot of hypertensive disorders of pregnancy stratified by Human Development Index ratings with two subgroups. The risk ratio for one study in the very high subgroup is 0.83 (95% confidence interval 0.22 to 3.13) with an I-squared of 0%. The risk ratio for four studies in the medium to high subgroup is 1.38 (95% confidence interval 0.74 to 2.56) with an I-squared of 60.9%. The overall risk ratio is 1.24 (95% confidence interval 0.75 to 2.06) with an I-squared of 48.0%.

Appendix C Figure 2 Meta-Analysis: Hypertensive Disorders of Pregnancy, Stratified by Dose

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 2 is a forest plot of hypertensive disorders stratified by dose with two subgroups. The risk ratio for two studies in the high subgroup is 1.02 (95% confidence interval 0.30 to 3.47) with an I-squared of 0%. The risk ratio for three studies in the low subgroup is 1.35 (95% confidence interval 0.70 to 2.61) with an I-squared of 71.6%. The overall risk ratio is 1.24 (95% confidence interval 0.75 to 2.06) with an I-squared of 48.0%.

Appendix C Figure 3 Meta-Analysis: Cesarean Delivery, Stratified by HDI Country

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; HDI=United Nations Human Development Index; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 3 is a forest plot of cesarean delivery stratified by Human Development Index country with two subgroups. The risk ratio for five studies in very high subgroup is 0.85 (95% confidence interval 0.66 to 1.11) with an I-squared of 23.8%. The risk ratio for four studies in the medium to high subgroup is 1.07 (95% confidence interval 1.01 to 1.14) with an I-squared of 0%. The overall risk ratio is 1.01 (95% confidence interval 0.90 to 1.14) with an I-squared of 42.7%.

Appendix C Figure 4 Meta-Analysis: Cesarean Delivery, Stratified by Dose

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported; U.S.=United States.

Appendix C Figure 4 is a forest plot of cesarean delivery stratified by dose with two subgroups. The risk ratio for five studies in the high subgroup is 0.89 (95% confidence interval 0.67 to 1.20) with an I-squared of 67.6%. The risk ratio for four studies in the low subgroup is 1.11 (95% confidence interval 0.99 to 1.25) with an I-squared of 0%. The overall risk ratio is 1.01 (95% confidence interval 0.90 to 1.14) with an I-squared of 42.7%.

Appendix C Figure 5 Meta-Analysis: Iron Deficiency Anemia at Term, Stratified by HDI Country

Abbreviations: CI=confidence interval; GA, wks=gestational age, weeks; HDI=United Nations Human Development Index; Hgb=hemoglobin; NR=not reported; U.S.=United States.

Appendix C Figure 5 is a forest plot of iron deficiency anemia at term stratified by Human Development Index country with two subgroups. The risk ratio for one study in the medium to high subgroup study is 0.49 (95% confidence interval 0.38 to 0.62) with an I-squared of 0%. The risk ratio for three studies in the very high subgroup is 0.29 (95% confidence interval 0.15 to 0.55) with an I-squared of 0%. The overall risk ratio is 0.40 (95% confidence interval 0.26 to 0.61) with an I-squared of 20.5%.

Appendix C Figure 6 Meta-Analysis: Iron Deficiency Anemia at Term, Stratified by Dose

Abbreviations: CI=confidence interval; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported; U.S.=United Sates

Appendix C Figure 6 is a forest plot of iron deficiency anemia at term stratified by dose. The risk ratio for four studies in the high subgroup is 0.42 (95% confidence interval 0.24 to 0.71) with an I-squared of 21.0%. The risk ratio for one study in the low subgroup is 0.28 (95% confidence interval 0.12 to 0.68) with an I-squared of 0%. The overall risk ratio is 0.40 (95% confidence interval 0.26 to 0.61) with an I-squared of 20.5%.

Appendix C Figure 7 Meta-analysis: Iron Deficiency at Term, Stratified by HDI Country

Abbreviations: CI=confidence interval; GA, wks=gestational age, weeks; HDI=United Nations Human Development Index; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 7 is a forest plot of iron deficiency at term stratified by Human Development Index country with two subgroups. The risk ratio for two studies in the medium to high subgroup is 0.57 (95% confidence interval 0.29 to 1.13) with an I-squared of 69.5%, The risk ratio for four studies in the very high subgroup is 0.35 (95% confidence interval 0.18 to 0.65) with an I-squared of 79.3%, The overall risk ratio is 0.47 (95% confidence interval 0.33 to 0.67) with an I-squared of 81.9%.

Appendix C Figure 8 Meta-Analysis: Iron Deficiency at Term, Stratified by Dose

Abbreviations: CI=confidence interval; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 8 is a forest plot of iron deficiency at term stratified by dose with two subgroups. The risk ratio for four studies in the high subgroup is 0.26 (95% confidence interval 0.09 to 0.77) with an I-squared of 86.0%, The risk ratio for two studies in the low subgroup is 0.57 (95% confidence interval 0.46 to 0.69) with an I-squared of 0%. The overall risk ratio is 0.47 (95% confidence interval 0.33 to 0.67) with an I-squared of 81.9%.

Appendix C Figure 9 Meta-Analysis: Anemia at Term, Stratified by HDI Country

Abbreviations: CI=confidence interval; GA, wks=gestational age, weeks; HDI=United Nations Human Development Index; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 9 is a forest plot of anemia at term stratified by Human Development Index country with two subgroups. The risk ratio for one study in the medium to high subgroup is 0.53 (95% confidence interval 0.43 to 0.66) with an I-squared of 0%. The risk ratio for three studies in the very high subgroup is 0.22 (95% confidence interval 0.06 to 0.84) with an I-squared of 49.3%. The overall risk ratio is 0.43 (95% confidence interval 0.26 to 0.72) with an I-squared of 43.7%.

Appendix C Figure 10 Meta-Analysis: Anemia at Term, Stratified by Dose

Abbreviations: CI=confidence interval; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 10 is a forest plot of anemia at term stratified by dose with two subgroups. The risk ratio for three studies in the high subgroup is 0.22 (95% confidence interval 0.05 to 1.02) with an I-squared of 61.1%. The risk ratio for one study in the low subgroup study is 0.45 (95% confidence interval 0.25 to 0.82) with an I-squared of 0%. The overall risk ratio is 0.43 (95% confidence interval 0.26 to 0.72) with an I-squared of 43.7%.

Appendix C Figure 11 Meta-Analysis: Preterm Birth, Stratified by HDI Country

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; HDI=United Nations Human Development Index; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 11 is a forest plot of preterm birth stratified by Human Development Index country with two subgroups. The risk ratio for one study in the very high subgroup is 0.95 (95% confidence interval 0.58 to 1.57) with an I-squared of 0%. The risk ratio for four studies in the medium to high subgroup is 0.92 (95% confidence interval 0.81 to 1.04) with an I-squared of 0%. The overall risk ratio is 0.92 (95% confidence interval 0.81 to 1.04) with an I-squared of 0%.

Appendix C Figure 12 Meta-Analysis: Preterm Birth, Stratified by Dose

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 12 is a forest plot of preterm birth stratified by dose with two subgroups. The risk ratio for three studies in the high subgroup is 0.83 (95% confidence interval 0.65 to 1.06) with an I-squared of 0%. The risk ratio for two studies in the low subgroup is 0.95 (95% confidence interval 0.83 to 1.10) with an I-squared of 0%. The overall risk ratio is 0.92 (95% confidence interval 0.81 to 1.04) with an I-squared of 0%.

Appendix C Figure 13 Meta-Analysis: Small for Gestational Age, Stratified by HDI Country

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; HDI=United Nations Human Development Index; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 13 is a forest plot of small for gestational age stratified by Human Development Index country with two subgroups. The risk ratio for one study in the very high subgroup is 0.48 (95% confidence interval 0.26 to 0.87) with an I-squared of 0%. The risk ratio for three studies in the medium to high subgroup is 1.07 (95% confidence interval 0.80 to 1.41) with an I-squared of 66.6%. The overall risk ratio is 0.94 (95% confidence interval 0.67 to 1.31) with an I-squared of 75.5%.

Appendix C Figure 14 Meta-Analysis: Small for Gestational Age, Stratified by Dose

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 14 is a forest plot of small for gestational age stratified by dose with two subgroups. The risk ratio for two studies in the high subgroup is 0.75 (95% confidence interval 0.35 to 1.59) with an I-squared of 83.7%. The risk ratio for two studies in the low subgroup is 1.10 (95% confidence interval 0.59 to 2.05) with an I-squared of 83.3%. The overall risk ratio is 0.94 (95% confidence interval 0.67 to 1.31) with an I-squared of 75.5%.

Appendix C Figure 15 Meta-Analysis: Low Birth Weight, Stratified by HDI Country

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; HDI=United Nations Human Development Index; Hgb=hemoglobin; NR=not reported.

Appendix C Figure 15 is a forest plot of low birth stratified by Human Development Index country with two subgroups. The risk ratio for three studies in the very high subgroup is 1.02 (95% confidence interval 0.54 to 1.94) with an I-squared of 0%. The risk ratio for three studies in the medium to high subgroup is 0.95 (95% confidence interval 0.78 to 1.15) with an I-squared of 0%. The overall risk ratio is 0.95 (95% confidence interval 0.79 to 1.14) with an I-squared of 0%.

Appendix C Figure 16 Meta-Analysis: Low Birth Weight, Stratified by Dose

Abbreviations: CI=confidence interval; DL=DerSimonian Laird; GA, wks=gestational age, weeks; Hgb=hemoglobin; NR=not reported; U.S.=United States

Appendix C Figure 16 is a forest plot of low birth stratified by dose with two subgroups. The risk ratio for four studies in the high subgroup is 0.82 (95% confidence interval 0.61 to 1.10) with an I-squared of 0%. The risk ratio for two studies in the low subgroup is 1.05 (95% confidence interval 0.83 to 1.33) with an I-squared of 0%. The overall risk ratio is 0.95 (95% confidence interval 0.79 to 1.14) with an I-squared of 0%.