# Appendix B Evidence and Quality Tables

Appendix B Table 1 Data Abstraction of Iron Supplementation Trials

Appendix B Table 2 Quality Assessment of Iron Supplementation Trials

Appendix B Table 3 Data Abstraction of Association Study

Appendix B Table 4 Quality Assessment of Association Study