# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Database: Ovid MEDLINE

Pregnancy Iron Screening

1. exp pregnancy/
2. exp pregnancy complications/
3. exp Maternal Nutritional Physiological Phenomena/
4. (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat*or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid or (expect* adj3 mother*)).mp.
5. 1 or 2 or 3 or 4
6. exp Mass Screening/ or screen$.mp. or exp Diagnostic Tests, Routine/ or (routin* adj3 (diagnos* or detect*)).mp. or ((routin* or repeat* or frequen*) adj3 (test* or assess* or assay* or status or measur* or (blood adj2 (sampl* or draw*)))).mp.
7. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet*)).mp. or exp Iron Deficiencies/ or exp Anemia, Iron-Deficiency/ or ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 ((an?emi* or (reduc* or low or lower* or inadeq* or insuffic* or lack* or shortag*)) adj3 (h?emoglob* or hgb or h?ematocrit* or rbc* or red blood cell*))).mp.
8. exp iron/bl or exp iron compounds/bl or ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj3 (level* or serum* or blood or status)).mp.
9. 7 or 8
10. 5 and 6 and 9
11. ((screen* or (routin* adj3 (diagnos* or detect*)) or (routin* adj3 (test* or assess* or assay* or measur* or (blood adj2 draw*)))) adj10 (((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or status or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet*)) or ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj10 (an?emi* or (reduc* or defic* or low or lower* or inadeq* or insuffic* or lack* or shortag*)) adj3 (h?emoglob* or hgb or h?ematocrit* or rbc* or (red adj2 cell*) or blood)))).mp.
12. 5 and 11
13. ((pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid* or (expect* adj3 mother*)) adj15 ((screen* or (routin* adj3 (diagnos* or detect*)) or ((routin* or repeat* or frequen*) adj3 (test* or assess* or assay* or measur* or (blood adj2 draw*)))) adj10 (((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or status or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet*)) or ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj10 (an?emi* or (reduc* or defic* or low or lower* or inadeq* or (“not” adj2 (suffic* or adequa*)) or insuffic* or lack* or status or shortag* or deplet*)) adj3 (h?emoglob* or hgb or h?ematocrit* or rbc* or (red adj2 cell*) or blood))))).mp.
14. 10 or 12 or 13
15. limit 14 to english language
16. limit 14 to abstracts
17. 15 or 16

Pregnancy Iron Only Anemia

1. exp Iron/ or exp iron compounds/ or exp iron, dietary/
2. exp Dietary Supplements/
3. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*)).mp.
4. exp Iron, Dietary/ad or exp iron compounds/ad or exp iron/ad
5. 1 and 2
6. 3 or 4 or 5
7. exp pregnancy/
8. (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid).mp.
9. exp pregnancy complications/
10. exp Maternal Nutritional Physiological Phenomena/
11. 7 or 8 or 9 or 10
12. 6 and 11
13. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj7 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*) adj10 (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid)).mp.
14. 12 or 13
15. limit 14 to english language
16. limit 14 to abstracts
17. 15 or 16
18. limit 17 to humans
19. exp Iron/ad, tu or exp iron compounds/ad, tu or exp iron, dietary/ad, tu or exp Iron Deficiencies/dt, th, dh
20. exp Iron/ or exp iron compounds/ or exp iron, dietary/ or exp Iron Deficiencies/
21. exp Dietary Supplements/
22. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*)).mp.
23. 20 and 21
24. 19 or 22 or 23
25. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet* or missing)).mp. or exp Iron Deficiencies/ or exp Anemia, Iron-Deficiency/
26. exp anemia/th, dh, dt, pc
27. 24 and 26
28. exp pregnancy/ or exp pregnancy complications/ or exp Maternal Nutritional Physiological Phenomena/ or (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid* or (expect* adj3 mother*)).mp.
29. 24 and 25 and 28
30. 27 and 28
31. 29 or 30
32. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet* or missing) adj10 (pregnan* or prenatal* or antenatal* or obstetric* or maternal* or trimester* or gestat* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid* or (expect* adj3 mother*))).mp.
33. 31 or 32
34. limit 33 to english language
35. limit 33 to abstracts
36. 34 or 35
37. limit 36 to humans
38. 18 and 37
39. 18 not 38
40. 37 not 38
41. limit 38 to (systematic reviews pre 2019 or systematic reviews)
42. limit 38 to (adaptive clinical trial or controlled clinical trial or pragmatic clinical trial or randomized controlled trial)
43. 42 not 41
44. exp Epidemiologic Studies/
45. exp “Outcome and Process Assessment, Health Care”/
46. exp Comparative Study/
47. 44 or 45 or 46
48. 38 and 47
49. 48 not (42 or 43)
50. 38 not (42 or 43 or 49)
51. limit 39 to (systematic reviews pre 2019 or systematic reviews)
52. limit 39 to (adaptive clinical trial or controlled clinical trial or pragmatic clinical trial or randomized controlled trial)
53. 52 not 51
54. 39 and 47
55. 54 not (51 or 52)
56. 39 not (51 or 52 or 55)
57. limit 40 to (systematic reviews pre 2019 or systematic reviews)
58. limit 40 to (adaptive clinical trial or controlled clinical trial or pragmatic clinical trial or randomized controlled trial)
59. 58 not 57
60. 40 and 47
61. 60 not (57 or 58)
62. 40 not (57 or 58 or 61)

Pregnancy Iron Only Supplementation

1. exp Iron/ or exp iron compounds/ or exp iron, dietary/
2. exp Dietary Supplements/
3. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*)).mp.
4. exp Iron, Dietary/ad or exp iron compounds/ad or exp iron/ad
5. 1 and 2
6. 3 or 4 or 5
7. exp pregnancy/
8. (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid).mp.
9. exp pregnancy complications/
10. exp Maternal Nutritional Physiological Phenomena/
11. 7 or 8 or 9 or 10
12. 6 and 11
13. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj7 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*) adj10 (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid)).mp.
14. 12 or 13
15. limit 14 to english language
16. limit 14 to abstracts
17. 15 or 16
18. limit 17 to humans
19. exp Iron/ad, tu or exp iron compounds/ad, tu or exp iron, dietary/ad, tu or exp Iron Deficiencies/dt, th, dh
20. exp Iron/ or exp iron compounds/ or exp iron, dietary/ or exp Iron Deficiencies/ (168831)
21. exp Dietary Supplements/
22. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*)).mp.
23. 20 and 21
24. 19 or 22 or 23
25. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet* or missing)).mp. or exp Iron Deficiencies/ or exp Anemia, Iron-Deficiency/ [mp=title, book title, abstract, original title, name of substance word, subject heading word, floating sub-heading word, keyword heading word, organism supplementary concept word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms]
26. exp anemia/th, dh, dt, pc
27. 24 and 26
28. exp pregnancy/ or exp pregnancy complications/ or exp Maternal Nutritional Physiological Phenomena/ or (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid* or (expect* adj3 mother*)).mp.
29. 24 and 25 and 28
30. 27 and 28
31. 29 or 30
32. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet* or missing) adj10 (pregnan* or prenatal* or antenatal* or obstetric* or maternal* or trimester* or gestat* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid* or (expect* adj3 mother*))).mp.
33. 31 or 32
34. limit 33 to english language
35. limit 33 to abstracts
36. 34 or 35
37. limit 36 to humans
38. 18 and 37
39. 18 not 38
40. 37 not 38
41. limit 38 to (systematic reviews pre 2019 or systematic reviews)
42. limit 38 to (adaptive clinical trial or controlled clinical trial or pragmatic clinical trial or randomized controlled trial)
43. 42 not 41
44. exp Epidemiologic Studies/
45. exp “Outcome and Process Assessment, Health Care”/
46. exp Comparative Study/
47. 44 or 45 or 46
48. 38 and 47
49. 48 not (42 or 43)
50. 38 not (42 or 43 or 49)
51. limit 39 to (systematic reviews pre 2019 or systematic reviews)
52. limit 39 to (adaptive clinical trial or controlled clinical trial or pragmatic clinical trial or randomized controlled trial)
53. 52 not 51
54. 39 and 47
55. 54 not (51 or 52)
56. 39 not (51 or 52 or 55)
57. limit 40 to (systematic reviews pre 2019 or systematic reviews)
58. limit 40 to (adaptive clinical trial or controlled clinical trial or pragmatic clinical trial or randomized controlled trial)
59. 58 not 57
60. 40 and 47
61. 60 not (57 or 58)
62. 40 not (57 or 58 or 61)

### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Iron/ or exp iron compounds/ or exp iron, dietary/
2. exp Dietary Supplements/
3. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*)).mp.
4. exp Iron, Dietary/ad or exp iron compounds/ad or exp iron/ad
5. 1 and 2
6. 3 or 4 or 5
7. exp pregnancy/
8. (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid).mp.
9. exp pregnancy complications/
10. exp Maternal Nutritional Physiological Phenomena/
11. 7 or 8 or 9 or 10
12. 6 and 11
13. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj7 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*) adj10 (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid)).mp.
14. 12 or 13
15. limit 14 to english language
16. limit 14 to abstracts
17. 15 or 16
18. exp Iron/ad, tu or exp iron compounds/ad, tu or exp iron, dietary/ad, tu or exp Iron Deficiencies/dt, th, dh
19. exp Iron/ or exp iron compounds/ or exp iron, dietary/ or exp Iron Deficiencies/
20. exp Dietary Supplements/
21. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*)).mp.
22. 19 and 20
23. 18 or 21 or 22
24. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet* or missing)).mp.
25. exp anemia/th, dh, dt, pc
26. 23 and 25
27. exp pregnancy/ or exp pregnancy complications/ or exp Maternal Nutritional Physiological Phenomena/ or (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid* or (expect* adj3 mother*)).mp.
28. 23 and 24 and 27
29. 26 and 27
30. 28 or 29
31. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet* or missing) adj10 (pregnan* or prenatal* or antenatal* or obstetric* or maternal* or trimester* or gestat* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid* or (expect* adj3 mother*))).mp.
32. 30 or 31
33. limit 32 to english language
34. limit 32 to abstracts
35. 33 or 34
36. 17 and 35
37. 17 not 36
38. 35 not 36

### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*)).mp.
2. (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid).mp.
3. 1 and 2
4. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj7 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*) adj10 (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid)).mp.
5. 3 or 4
6. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*)).mp.
7. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet* or missing)).mp.
8. [exp pregnancy/ or exp pregnancy complications/ or exp Maternal Nutritional Physiological Phenomena/ or (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid* or (expect* adj3 mother*)).mp.
9. 6 and 7 and 8
10. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet* or missing) adj10 (pregnan* or prenatal* or antenatal* or obstetric* or maternal* or trimester* or gestat* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid* or (expect* adj3 mother*))).mp.
11. 9 or 10
12. 5 and 11
13. 5 not 12
14. 11 not 12
15. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*)).mp.
16. (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid).mp.
17. 15 and 16
18. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj7 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*) adj10 (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid)).mp.
19. 17 or 18
20. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (pill* or tablet* or capsule* or liquid* or syrup* or elixir* or supplemen* or intraven* or parenteral* or oral*)).mp.
21. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet* or missing)).mp.
22. (pregnan* or prenatal* or antenatal* or obstetric* or trimester* or gestat* or maternal* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid* or (expect* adj3 mother*)).mp.
23. 20 and 21 and 22
24. ((iron or ferric or ferrous or ferritin* or fe or “fe2+” or “fe+2” or “fe++”) adj5 (defic* or lack* or insuffic* or (“not” adj2 (suffic* or adequa*)) or inadequa* or scarc* or shortag* or deplet* or missing) adj10 (pregnan* or prenatal* or antenatal* or obstetric* or maternal* or trimester* or gestat* or nulliparous* or nullipara or nulligravid* or primapara or primaparous or primagravid* or unipara or uniparous or unigravid* or multipara or multiparous* or multigravid* or gravid* or (expect* adj3 mother*))).mp.
25. 23 or 24
26. 19 and 25
27. 19 not 26
28. 25 not 26

## Appendix A2 Inclusion and Exclusion Criteria

Framework | PICOTS | Include | Exclude
Routine Iron Supplementation in Pregnancy | Populations | Asymptomatic adults (age ≥18 years) and adolescents (ages 13 to <18 years) regardless of iron status who are pregnant, and their infants | Nonpregnant persons; those with underlying diagnosis or symptoms of anemia; severely malnourished populations not representative of those in the United States
Routine Iron Supplementation in Pregnancy | Interventions | Oral iron supplementation; iron-fortified foods | Nonoral forms of iron
Routine Iron Supplementation in Pregnancy | Comparators | No supplementation; A change in maternal iron deficiency and/or iron deficiency anemia status (KQ 3) | No comparison
Routine Iron Supplementation in Pregnancy | Outcomes | Maternal health outcomes: Mortality; health-related quality of life; preeclampsia (severe), postpartum hemorrhage, blood transfusion; postpartum depression (KQ 1); Maternal intermediate outcomes: Incidence of iron deficiency anemia; Incidence of iron deficiency; hematologic indices and ferritin levels; cesarean delivery rates (KQ 1); Infant health outcomes: Perinatal mortality, respiratory distress, NICU admission; Infant intermediate outcomes: Hematologic indices and ferritin levels; low birth weight, small for gestational age, preterm delivery (KQ 1), More serious harms; harms leading to discontinuation; accidental overdose (KQ 2) | Infant outcomes >1 year of age
Routine Iron Supplementation in Pregnancy | Timing | Long-term outcomes (KQ 1); Short- or long-term outcomes (KQ 2)
Routine Iron Supplementation in Pregnancy | Settings | U.S. primary care–relevant settings
Routine Iron Supplementation in Pregnancy | Study Designs | Randomized, controlled trials, controlled cohort studies, and other controlled observational studies^*^ (KQ 1); Studies from KQ 1 and large uncontrolled observational studies^*^ (KQ 2) | Uncontrolled studies (KQ 1)

* For the supplementation framework, observational studies were not included since randomized, controlled trials were available.

Abbreviations: KQ, Key Question; NICU, neonatal intensive care unit; US, United States.

Framework | PICOTS | Include | Exclude
Screening for Iron Deficiency Anemia in Pregnancy | Populations | Pregnant adolescents and adults and their infants asymptomatic for iron deficiency or iron deficiency anemia (KQs 1 and 2); Pregnant adolescents and adults with iron deficiency anemia and their infants (KQs 3, 4); Pregnant persons with iron deficiency, with or without anemia, and their infants (KQ 5) | Nonpregnant persons; severely malnourished populations not representative of those in the United States; those symptomatic for iron deficiency or iron deficiency anemia
Screening for Iron Deficiency Anemia in Pregnancy | Interventions | Screening for iron deficiency anemia (KQs 1 and 2); Oral or intravenous iron supplementation, iron-fortified foods (KQs 3 and 4) | Nonoral and nonintravenous forms of iron
Screening for Iron Deficiency Anemia in Pregnancy | Comparators | No screening for iron deficiency anemia (KQs 1 and 2); No treatment (KQs 3 and 4); A change in maternal iron deficiency and/or iron deficiency anemia status (KQ 5) | No comparison
Screening for Iron Deficiency Anemia in Pregnancy | Outcomes | Maternal health outcomes: Mortality; health-related quality of life; preeclampsia (severe); postpartum hemorrhage, blood transfusion; postpartum depression (KQs 1, 3, 5); Maternal intermediate outcomes: Cesarean delivery rates (KQs 1, 3, 5); incidence of iron deficiency anemia, incidence of iron deficiency; hematologic indices and ferritin levels (KQ 3); Infant health outcomes: Perinatal mortality, morbidity (NICU admission, respiratory distress); Infant intermediate outcomes: Hematologic indices and ferritin levels; low birth weight, small for gestational age, preterm delivery (KQs 1, 3, 5); Overdiagnosis, anxiety, labeling, etc. (KQ 2); More serious harms; harms leading to discontinuation; overtreatment (KQ 4) | Infant outcomes >1 year of age
Screening for Iron Deficiency Anemia in Pregnancy | Settings | U.S. primary care relevant
Screening for Iron Deficiency Anemia in Pregnancy | Timing | Long-term outcomes (KQs 1 and 3); Short- or long-term outcomes (KQs 2, 4, 5)
Screening for Iron Deficiency Anemia in Pregnancy | Study Designs | Randomized, controlled trials, controlled cohort studies and other controlled observational studies (KQs 1 and 3); Studies included from other KQs and large uncontrolled observational studies (KQs 2 and 4); Association studies (KQ 5) | Uncontrolled studies (KQs 1 and 3)

Abbreviations: KQ=Key Question; NICU, neonatal intensive care unit.

## Appendix A3 Literature Flow Diagram

Note 1: The sum of the number of studies per KQ exceeds the total number of studies because some studies were applicable to multiple KQs.

Note 2: KQ3 in the routine iron supplementation framework and KQ5 in the screening for ID and IDA framework are the same KQ and therefore cover the same evidence.

Abbreviations: ID=iron deficiency, IDA=iron deficiency anemia; KQ=Key Question.

## Appendix A4 List of Included Studies

1 Barton DP, Joy MT, Lappin TR, . Maternal erythropoietin in singleton pregnancies: a randomized trial on the effect of oral hematinic supplementation. Am J Obstet. Gynecol. 1994;170(3):896–901. doi: 10.1016/s0002-9378(94)70305-1. PMID: 8141223.8141223
2 Chan KKL, Chan BCP, Lam KF, . Iron supplement in pregnancy and development of gestational diabetes--a randomised placebo-controlled trial. BJOG. 2009;116(6):789–8. doi: 10.1111/j.1471-0528.2008.02014.x. PMID: 19432567.19432567
3 Chen S, Li N, Mei Z, . Micronutrient supplementation during pregnancy and the risk of pregnancy-induced hypertension: a randomized clinical trial. Clin Nutr. 2019;38(1):146–51. doi: 10.1016/j.clnu.2018.01.029. PMID: 29428785.29428785
4 Cogswell ME, Parvanta I, Ickes L, . Iron supplementation during pregnancy, anemia, and birth weight: a randomized controlled trial. Am J Clin Nutr. 2003;78(4):773–81. doi: 10.1093/ajcn/78.4.773. PMID: 14522736.14522736
5 Detlefs SE, Jochum MD, Salmanian B, . The impact of response to iron therapy on maternal and neonatal outcomes among pregnant women with anemia. Am J Obstet Gynecol MFM. 2022;4(2):100569. doi: 10.1016/j.ajogmf.2022.100569. PMID: 35033748.35033748
6 Eskeland B, Malterud K, Ulvik RJ, . Iron supplementation in pregnancy: is less enough? A randomized, placebo controlled trial of low dose iron supplementation with and without heme iron. Acta Obstet Gynecol Scand. 1997;76(9):822–8. doi: 10.3109/00016349709024359. PMID: 9351406.9351406
7 Falahi E, Akbari S, Ebrahimzade F, . Impact of prophylactic iron supplementation in healthy pregnant women on maternal iron status and birth outcome. Food Nutr Bull. 2011;32(3):213–7. doi: 10.1177/156482651103200305. PMID: 22073795.22073795
8 Jafarbegloo E, Ahmari Tehran H, Dadkhah Tehrani T. Gastrointestinal complications of ferrous sulfate in pregnant women: a randomized double-blind placebo-controlled trial. Iran Red Crescent Med J. 2015 Aug 29;17(8):e15001. doi: 10.5812/ircmj.15001. PMID: 26430520; PMCID: PMC4587092.26430520
9 Li Z, Mei Z, Zhang L, . Effects of prenatal micronutrient supplementation on spontaneous preterm birth: a double-blind randomized controlled trial in China. Am J Epidemiol. 2017;186(3):318–25. doi: 10.1093/aje/kwx094. PMID: 28472219.28472219
10 Liu J-m, Mei Z, Ye R, . Micronutrient supplementation and pregnancy outcomes: double-blind randomized controlled trial in China. JAMA Intern Med. 2013;173(4):276–82. doi: 10.1001/jamainternmed.2013.1632. PMID: 23303315.23303315
11 Liu Y, Li N, Mei Z, . Effects of prenatal micronutrients supplementation timing on pregnancy-induced hypertension: secondary analysis of a double-blind randomized controlled trial. Matern Child Nutr. 2021;17(3):e13157. doi: 10.1111/mcn.13157. PMID: 33594802.33594802
12 Makrides M, Crowther CA, Gibson RA, . Efficacy and tolerability of low-dose iron supplements during pregnancy: a randomized controlled trial. Am J Clin Nutr. 2003;78(1):145–53. doi: 10.1093/ajcn/78.1.145. PMID: 12816784.12816784
13 Mei Z, Serdula MK, Liu J-M, . Iron-containing micronutrient supplementation of Chinese women with no or mild anemia during pregnancy improved iron status but did not affect perinatal anemia. J Nutr. 2014;144(6):943–8. doi: 10.3945/jn.113.189894. PMID: 24744317.24744317
14 Meier PR, Nickerson HJ, Olson KA, . Prevention of iron deficiency anemia in adolescent and adult pregnancies. Clin Med Res. 2003;1(1):29–36. doi: 10.3121/cmr.1.1.29. PMID: 15931282.15931282
15 Milman N, Agger AO, Nielsen OJ. Iron supplementation during pregnancy. Effect on iron status markers, serum erythropoietin and human placental lactogen. A placebo controlled study in 207 Danish women. Dan Med Bull. 1991;38(6):471–6. PMID: 1802636.1802636
16 Milman N, Agger AO, Nielsen OJ. Iron status markers and serum erythropoietin in 120 mothers and newborn infants. Effect of iron supplementation in normal pregnancy. Acta Obstet Gynecol Scand. 1994;73(3):200–4. doi: 10.3109/00016349409023439. PMID: 8122498.8122498
17 Milman N, Byg KE, Agger AO. Hemoglobin and erythrocyte indices during normal pregnancy and postpartum in 206 women with and without iron supplementation. Acta Obstet Gynecol Scand. 2000;79(2):89–98. doi: 10.1034/j.1600-0412.2000.079002089.x. PMID: 10696955.10696955
18 Ouladsahebmadarek E S-M M, Taghavi S, Abbasalizadeh S, Seyedhejazie M. The effect of supplemental iron elimination on pregnancy outcome. Pak J Biol Sci. 2011;23(3):641–5.
19 Romslo I, Haram K, Sagen N, . Iron requirement in normal pregnancy as assessed by serum ferritin, serum transferrin saturation and erythrocyte protoporphyrin determinations. BJOG. 1983;90(2):101–7. doi: 10.1111/j.1471-0528.1983.tb08891.x. PMID: 6824608.6824608
20 Serdula MK, Zhou Y, Li H, . Prenatal iron containing supplements provided to Chinese women with no or mild anemia had no effect on hemoglobin concentration in post-partum women or their infants at 6 and 12 months of age. Eur Journal Clin Nutr. 2019;73(11):1473–9. doi: 10.1038/s41430-018-0365-x. PMID: 30446762.30446762
21 Siega-Riz AM, Hartzema AG, Turnbull C, . The effects of prophylactic iron given in prenatal supplements on iron status and birth outcomes: a randomized controlled trial. Am J Obstet Gynecol. 2006;194(2):512–9. doi: 10.1016/j.ajog.2005.08.011. PMID: 16458655.16458655
22 Wang L, Mei Z, Li H, . Modifying effects of maternal Hb concentration on infant birth weight in women receiving prenatal iron-containing supplements: a randomised controlled trial. Br J Nutr. 2016;115(4):644–9. doi: 10.1017/S0007114515004870. PMID: 26824731.26824731
23 Zeng L, Dibley MJ, Cheng Y, . Impact of micronutrient supplementation during pregnancy on birth weight, duration of gestation, and perinatal mortality in rural western China: double blind cluster randomised controlled trial. BMJ. 2008;337:a2001. doi: 10.1136/bmj.a2001. PMID: 18996930.18996930
24 Zhao G, Xu G, Zhou M, . Prenatal iron supplementation reduces maternal anemia, iron deficiency, and iron deficiency anemia in a randomized clinical trial in rural china, but iron deficiency remains widespread in mothers and neonates. J Nutri. 2015;145(8):1916–23. doi: 10.3945/jn.114.208678. PMID: 26063068.26063068
25 Zhou SJ, Gibson RA, Makrides M. Routine iron supplementation in pregnancy has no effect on iron status of children at six months and four years of age. J Pediatr. 2007;151(4):438–40. doi: 10.1016/j.jpeds.2007.06.001. PMID: 17889086.17889086
26 Zhou SJ, Gibson RA, Crowther CA, Baghurst P, Makrides M. Effect of iron supplementation during pregnancy on the intelligence quotient and behavior of children at 4 y of age: long-term follow-up of a randomized controlled trial. Am J Clin Nutr. 2006 May;83(5):1112–7. doi: 10.1093/ajcn/83.5.1112. PMID: 16685054.16685054
27 Ziaei S, Mehrnia M, Faghihzadeh S. Iron status markers in nonanemic pregnant women with and without iron supplementation. Int J Gynaecol Obstet. 2008;100(2):130–2. doi: 10.1016/j.ijgo.2007.07.027. PMID: 17977537.17977537
28 Ziaei S, Norrozi M, Faghihzadeh S, . A randomised placebo-controlled trial to determine the effect of iron supplementation on pregnancy outcome in pregnant women with haemoglobin > or = 13.2 g/dl. BJOG. 2007;114(6):684–8. doi: 10.1111/j.1471-0528.2007.01325.x. PMID: 17516958.17516958

## Appendix A5 List of Excluded Studies with Reasons for Exclusion

1 Gastrointestinal complications of iron supplement in pregnant women. 2003. Exclusion reason: Not a study.
2 Impact of prenatal vitamin/mineral supplements on perinatal mortality. Impact of iron/folic acid versus multimicronutrient versus folic acid supplements during pregnancy on mortality, morbidity, and complications during pregnancy, labor, and delivery: a randomized controlled trial in China. 2005. Exclusion reason: Not a study.
3 A randomized placebo-controlled trial to determine the effect of iron supplementation on hematological indices in pregnant women with hemoglobin =13.2 g/dl. 2009. Exclusion reason: Not a study.
4 Which iron supplementation regime for pregnant women provides the best maternal and infant outcomes? A randomised controlled trial to compare the impact on birth weight of daily iron-folic acid, twice weekly iron-folic acid and twice weekly multiple micronutrient supplementation for pregnant women in Ha Nam province, Vietnam. 2010. Exclusion reason: Not a study.
5 Impact of iron/folic acid vs folic acid supplements during pregnancy on maternal and child health. Impact of iron/folic acid versus folic acid supplements during pregnancy on maternal and children’s health: a randomized controlled trial in China. 2014. Exclusion reason: Not a study.
6 The effect of iron supplementation in pregnant women with high hemoglobin. The effect of iron supplementation on iron status markers in pregnant women with high hemoglobin. 2014. Exclusion reason: Not a study.
7 Lactoferrin supplementation and iron metabolism in healthy pregnant women. Effect of daily bovine lactoferrin supplementation on fetal development and iron metabolism in healthy pregnant women: a randomized double-blind controlled trial. 2016. Exclusion reason: Not a study.
8 The IRONWOMAN pilot feasibility study: oral versus intravenous iron therapy for iron deficiency anaemia in late pregnancy. The IRONWOMAN pilot feasibility study: a double blind randomised trial to compare feasibility of blinding of intravenous or oral iron replacement to placebo intravenous or oral therapy for iron deficiency anaemia in pregnancy. 2019. Exclusion reason: Ineligible comparator.
9 Effect of ayurvedic medicines in combination with conventional therapy for healthy pregnancy and post partum period. Feasibility of introducing Ayurveda intervention in Reproductive and Child Health (RCH) in PHCs of selected district (Gadchiroli) of Maharashtra - (Effectiveness of Ayurvedic intervention for ante-natal care (Garbhini Paricharya) at primary health care level: a multi centre operational study. 2019. Exclusion reason: Not a study.
10 Role of jeevantyadi avaleha on foetal growth and maternal well-being in second trimester of pregnancy: a randomized controlled clinical trial. 2021. Exclusion reason: Not a study.
11 Aaseth J, Thomassen Y, Ellingsen DG, . Prophylactic iron supplementation in pregnant women in Norway. J Trace Elem Med Biol. 2001;15(2–3):167–74. doi: 10.1016/S0946-672X(01)80062-6. PMID: 11787984. Exclusion reason: Ineligible intervention.11787984
12 Abbas AM, Abdelbadee SA, Alanwar A, . Efficacy of ferrous bis-glycinate versus ferrous glycine sulfate in the treatment of iron deficiency anemia with pregnancy: a randomized double-blind clinical trial. J Matern Fetal Neonatal Med. 2019;32(24):4139–45. doi: 10.1080/14767058.2018.1482871. PMID: 29843553. Exclusion reason: Ineligible comparator.29843553
13 Abdel Moety GAF, Ali AM, Fouad R, . Amino acid chelated iron versus an iron salt in the treatment of iron deficiency anemia with pregnancy: a randomized controlled study. Eur J Obstet Gynecol Reprod Biol. 2017;210:242–6. doi: 10.1016/j.ejogrb.2017.01.003. PMID: 28073037. Exclusion reason: Ineligible comparator.28073037
14 Abdulrehman J, Lausman A, Tang GH, . Development and implementation of a quality improvement toolkit, iron deficiency in pregnancy with maternal iron optimization (IRON MOM): a before-and-after study. PLoS Med. 2019;16(8):e1002867. doi: 10.1371/journal.pmed.1002867. PMID: 31430296. Exclusion reason: Ineligible study design for key question.31430296
15 Abraha I, Bonacini MI, Montedori A, . Oral iron-based interventions for prevention of critical outcomes in pregnancy and postnatal care: an overview and update of systematic reviews. J Evid Based Med. 2019;12(2):155–66. doi: 10.1111/jebm.12344. PMID: 31144465. Exclusion reason: Systematic review used as a source document only to identify individual studies.31144465
16 Abu MA, Borhan AS, Abdul Karim AK, . Comparison between Iberet Folic and Zincofer in treatment of iron deficiency anaemia in pregnancy. Horm Mol Biol Clin Investig. 2020;42(1):49–56. doi: 10.1515/hmbci-2020-0034. PMID: 33781008. Exclusion reason: Ineligible comparator.33781008
17 Afkhami-Ardekani M, Rashidi M. Iron status in women with and without gestational diabetes mellitus. J Diabetes Complications. 2009;23(3):194–8. doi: 10.1016/j.jdiacomp.2007.11.006. PMID: 18413178. Exclusion reason: Ineligible study design for key question.18413178
18 Akyol S, Karatas K, Tunali H. Relationship of iron supplementation during pregnancy with the opsonization and complement components. AJRI. 2014;71(s1):31. doi: 10.1111/aji.12255. Exclusion reason: Not a study.
19 Al RA, Unlubilgin E, Kandemir O, . Intravenous versus oral iron for treatment of anemia in pregnancy: a randomized trial. Obstet Gynecol. 2005;106(6):1335–40. doi: 10.1097/01.AOG.0000185260.82466.b4. PMID: 16319260. Exclusion reason: Ineligible comparator.16319260
20 Alfawaz HA, Khan N, AlOteabi N, . Factors associated with dietary supplement use in Saudi pregnant women. Reprod Health. 2017;14(1):104. doi: 10.1186/s12978-017-0357-7. PMID: 28851385. Exclusion reason: Ineligible intervention.28851385
21 Ali MK, Abbas AM, Abdelmagied AM, . A randomized clinical trial of the efficacy of single versus double-daily dose of oral iron for prevention of iron deficiency anemia in women with twin gestations. J Matern Fetal Neonatal Med. 2017;30(23):2884–9. doi: 10.1080/14767058.2016.1266478. PMID: 27894198. Exclusion reason: Ineligible comparator.27894198
22 Alizadeh L, Salehi L. Is routine iron supplementation necessary in pregnant women with high hemoglobin? Iranian Red Crescent Med J. 2016;18(1):e59314. doi: 10.5812/ircmj.22761. PMID: 26889391. Exclusion reason: Ineligible population.26889391
23 Alizadeh L, Salehi L, Mehraban Z, . Effect of iron supplementation in pregnant women with high hemoglobin on neonatal jaundice: a randomized double-blind clinical trial. IJOGI. 2019;22(4):18–24. doi: 10.22038/IJOGI.2019.13441. Exclusion reason: Not English language.
24 Allen LH, Peerson JM, Maternal Micronutrient Supplementation Study Group. Impact of multiple micronutrient versus iron-folic acid supplements on maternal anemia and micronutrient status in pregnancy. Food Nutr Bull. 2009;30(4 Suppl):S527–32. doi: 10.1177/15648265090304S407. PMID: 20120794. Exclusion reason: Ineligible intervention.20120794
25 Allen LH, Peerson JM, Olney DK. Provision of multiple rather than two or fewer micronutrients more effectively improves growth and other outcomes in micronutrient-deficient children and adults. J Nutr. 2009;139(5):1022–30. doi: 10.3945/jn.107.086199. PMID: 19321586. Exclusion reason: Ineligible intervention.19321586
26 Alwan N, Cade J. Routine iron supplementation in pregnancy: why is the UK different? Perspect Public Health. 2011;131(5):207–8. doi: 10.1177/1757913911419152. PMID: 21999024. Exclusion reason: Not a study.21999024
27 Alwan NA, Greenwood DC, Simpson NAB, . Dietary iron intake during early pregnancy and birth outcomes in a cohort of British women. Hum Reprod. 2011;26(4):911–9. doi: 10.1093/humrep/der005. PMID: 21303776. Exclusion reason: Ineligible intervention.21303776
28 Angulo-Barroso RM, Li M, Santos DCC, . Iron supplementation in pregnancy or infancy and motor development: a randomized controlled trial. Pediatrics. 2016;137(4):e20153547. doi: 10.1542/peds.2015-3547. PMID: 26936859. Exclusion reason: Ineligible population.26936859
29 Aranda N, Ribot B, Garcia E, . Pre-pregnancy iron reserves, iron supplementation during pregnancy, and birth weight. Early Hum Dev. 2011;87(12):791–7. doi: 10.1016/j.earlhumdev.2011.06.003. PMID: 21723050. Exclusion reason: Ineligible comparator.21723050
30 Arija V, Ribot B, Aranda N. Prevalence of iron deficiency states and risk of haemoconcentration during pregnancy according to initial iron stores and iron supplementation. Public Health Nutr. 2013;16(8):1371–8. doi: 10.1017/S1368980013000608. PMID: 23472860. Exclusion reason: Ineligible comparator.23472860
31 Asadi N, Vafaei H, Kasraeian M, . Effects of prophylactic iron supplementation on outcome of nonanemic pregnant women: a non-randomized clinical trial. J Chin Med Assoc. 2019;82(11):840–4. doi: 10.1097/JCMA.0000000000000184. PMID: 31517773. Exclusion reason: Ineligible comparator.31517773
32 Auerbach M, James SE, Nicoletti M, . Results of the first American prospective study of intravenous iron in oral iron-intolerant iron-deficient gravidas. Am J Med. 2017;130(12):1402–7. doi: 10.1016/j.amjmed.2017.06.025. PMID: 28739199. Exclusion reason: Ineligible intervention.28739199
33 Bah A, Wegmuller R, Cerami C, . A double blind randomised controlled trial comparing standard dose of iron supplementation for pregnant women with two screen-and-treat approaches using hepcidin as a biomarker for ready and safe to receive iron. BMC Pregnancy Childbirth. 2016;16(1):157. doi: 10.1186/s12884-016-0934-8. PMID: 27411564. Exclusion reason: Ineligible country.27411564
34 Banhidy F, Acs N, Puho EH, . Iron deficiency anemia: pregnancy outcomes with or without iron supplementation. Nutrition. 2011;27(1):65–72. doi: 10.1016/j.nut.2009.12.005. PMID: 20381313. Exclusion reason: Ineligible intervention.20381313
35 Baraka MA, Steurbaut S, Laubach M, . Iron status, iron supplementation and anemia in pregnancy: ethnic differences. J Matern Fetal Neonatal Med. 2012;25(8):1305–10. doi: 10.3109/14767058.2011.632036. PMID: 22010638. Exclusion reason: Ineligible intervention.22010638
36 Barton JC, Barton JC, Acton RT. Insulin resistance and metabolic syndrome: clinical and laboratory associations in African Americans without diabetes in the hemochromatosis and iron overload screening study. Metab Syndr Relat Disord. 2018;16(6):267–73. doi: 10.1089/met.2018.0036. PMID: 29851359. Exclusion reason: Ineligible population.29851359
37 Bayoumeu F, Subiran-Buisset C, Baka N-E, . Iron therapy in iron deficiency anemia in pregnancy: intravenous route versus oral route. Am J Obstet Gynecol. 2002;186(3):518–22. doi: 10.1067/mob.2002.121894. PMID: 11904617. Exclusion reason: Ineligible comparator.11904617
38 Beard JL. Effectiveness and strategies of iron supplementation during pregnancy. Am J Clin Nutr. 2000;71(5 Suppl):1288S–94S. doi: 10.1093/ajcn/71.5.1288s. PMID: 10799404. Exclusion reason: Not a study.10799404
39 Beard JL, Hendricks MK, Perez EM, . Maternal iron deficiency anemia affects postpartum emotions and cognition. J Nutr. 2005;135(2):267–72. doi: 10.1093/jn/135.2.267. PMID: 15671224. Exclusion reason: Ineligible population.15671224
40 Behboudi-Gandevani S, Safary K, Moghaddam-Banaem L, . The relationship between maternal serum iron and zinc levels and their nutritional intakes in early pregnancy with gestational diabetes. Biol Trace Elem Res. 2013;154(1):7–13. doi: 10.1007/s12011-013-9703-y. PMID: 23743666. Exclusion reason: Ineligible intervention.23743666
41 Bencaiova G, Breymann C. Mild anemia and pregnancy outcome in a Swiss collective. J Pregnancy. 2014;2014:307535. doi: 10.1155/2014/307535. PMID: 25478229. Exclusion reason: Ineligible comparator.25478229
42 Bencaiova G, von Mandach U, Zimmermann R. Iron prophylaxis in pregnancy: intravenous route versus oral route. Eur J Obstet Gynecol Reprod Biol. 2009;144(2):135–9. doi: 10.1016/j.ejogrb.2009.03.006. PMID: 19406557. Exclusion reason: Ineligible comparator.19406557
43 Beyens M-N, Guy C, Ratrema M, . Prescription of drugs to pregnant women in France: the HIMAGE study. Therapie. 2003;58(6):505–11. doi: 10.2515/therapie:2003082. PMID: 15058494. Exclusion reason: Ineligible intervention.15058494
44 Bhatla N, Kaul N, Lal N, . Comparison of effect of daily versus weekly iron supplementation during pregnancy on lipid peroxidation. J Obstet Gynaecol Res. 2009;35(3):438–45. doi: 10.1111/j.1447-0756.2008.00972.x. PMID: 19527380. Exclusion reason: Ineligible intervention.19527380
45 Bhavi SB, Jaju PB. Intravenous iron sucrose v/s oral ferrous fumarate for treatment of anemia in pregnancy. A randomized controlled trial. BMC Pregnancy Childbirth. 2017;17(1):137. doi: 10.1186/s12884-017-1313-9. PMID: 28482869. Exclusion reason: Ineligible comparator.28482869
46 Bloxam DL, Williams NR, Waskett RJ, . Maternal zinc during oral iron supplementation in pregnancy: a preliminary study. Clin Sci (Lond). 1989;76(1):59–65. doi: 10.1042/cs0760059. PMID: 2920535. Exclusion reason: Poor quality.2920535
47 Bo S, Menato G, Villois P, . Iron supplementation and gestational diabetes in midpregnancy. Am J Obstet Gynecol 2009;201(2):158.e1–6. doi: 10.1016/j.ajog.2009.04.049. PMID: 19527900. Exclusion reason: Ineligible intervention.19527900
48 Bokhari F, Derbyshire EJ, Hickling D, . A randomized trial investigating an iron-rich bread as a prophylaxis against iron deficiency in pregnancy. Int J Food Sci Nutr. 2012;63(4):461–7. doi: 10.3109/09637486.2011.634790. PMID: 22081981. Exclusion reason: Ineligible intervention.22081981
49 Bozhinova S, Ivanova I, Lukanova M. How to avoid a haemotransfusion which is not lifesaving? Our experience with administration of intravenous iron to pregnant women and young mothers. Akush Ginekol (Sofiia). 2004;43(6):13–7. PMID: 15669646. Exclusion reason: Ineligible study design for key question.15669646
50 Bresani Salvi CC, Braga MC, Figueiroa JN, . Could the erythrocyte indices or serum ferritin predict the therapeutic response to a trial with oral iron during pregnancy? Results from the Accuracy study for Maternal Anaemia diagnosis (AMA). BMC Pregnancy Childbirth. 2016;16(1):218. doi: 10.1186/s12884-016-1005-x. PMID: 27516193. Exclusion reason: Ineligible intervention.27516193
51 Breymann C. Treatment of iron deficiency anaemia in pregnancy and postpartum with special focus on intravenous iron sucrose complex. J Med Assoc Thai. 2005;88 Suppl 2:S108–9. PMID: 17718296. Exclusion reason: Not a study.17718296
52 Breymann C, Milman N, Mezzacasa A, . Ferric carboxymaltose vs. oral iron in the treatment of pregnant women with iron deficiency anemia: an international, open-label, randomized controlled trial (FER-ASAP). J Perinat Med. 2017;45(4):443–53. doi: 10.1515/jpm-2016-0050. PMID: 27278921. Exclusion reason: Ineligible comparator.27278921
53 Brough L, Rees GA, Crawford MA, . Effect of multiple-micronutrient supplementation on maternal nutrient status, infant birth weight and gestational age at birth in a low-income, multi-ethnic population. Br J Nutr. 2010;104(3):437–45. doi: 10.1017/S0007114510000747. PMID: 20412605. Exclusion reason: Ineligible intervention.20412605
54 Bumrungpert A, Pavadhgul P, Piromsawasdi T, . Efficacy and safety of ferrous bisglycinate and folinic acid in the control of iron deficiency in pregnant women: a randomized, controlled trial. Nutrients. 2022;14(3):452. doi: 10.3390/nu14030452. PMID: 35276810. Exclusion reason: Ineligible comparator.35276810
55 Butler EB. Effect of iron and folic acid on red cell and plasma volume in pregnancy. J Obstet Gynaecol Br Commonw. 1968;75(5):497–510. doi: 10.1111/j.1471-0528.1968.tb00153.x. PMID: 5742694. Exclusion reason: Poor quality.5742694
56 Buytaert G, Wallenburg HC, van Eijck HG, . Iron supplementation during pregnancy. Eur J Obstet Gynecol Reprod Biol. 1983;15(1):11–6. doi: 10.1016/0028-2243(83)90291-5. PMID: 6884561. Exclusion reason: Poor quality.6884561
57 Byg KE, Milman N, Agger AO. Correlations between iron status markers during normal pregnancy in women with and without iron supplementation. Hematology. 1999;4(6):529–39. doi: 10.1080/10245332.1999.11746481. PMID: 27420749. Exclusion reason: Ineligible outcome.27420749
58 Byg KE, Milman N, Hansen S, . Serum ferritin is a reliable, non-invasive test for iron status in pregnancy: comparison of ferritin with other iron status markers in a longitudinal study on healthy pregnant women. Hematology. 2000;5(4):319–25. doi: 10.1080/10245332.2000.11746526. PMID: 11399631. Exclusion reason: Ineligible intervention.11399631
59 Cantlie GS, De Leeuw NK, Lowenstein L. Iron and folate nutrition in a group of private obstetrical patients. Am J Clin Nutr. 1971;24(6):637–41. doi: 10.1093/ajcn/24.6.637. PMID: 5581003. Exclusion reason: Poor quality.5581003
60 Cantor AG, Bougatsos C, Dana T, . Routine iron supplementation and screening for iron deficiency anemia in pregnancy: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2015;162(8):566–76. doi: 10.7326/M14-2932. PMID: 25820661. Exclusion reason: Systematic review used as a source document only to identify individual studies.25820661
61 Cantor AG, Bougatsos C, McDonagh M. Routine iron supplementation and screening for iron deficiency anemia in pregnancy. Ann Intern Med. 2015;163(5):400. doi: 10.7326/L15-5132-2. PMID: 26322708. Exclusion reason: Systematic review used as a source document only to identify individual studies.26322708
62 Casanueva E, Viteri FE, Mares-Galindo M, . Weekly iron as a safe alternative to daily supplementation for nonanemic pregnant women. Arch Med Res. 2006;37(5):674–82. doi: 10.1016/j.arcmed.2005.11.011. PMID: 16740440. Exclusion reason: Ineligible comparator.16740440
63 Caspersen IH, Iglesias-Vazquez L, Abel MH, . Iron status in mid-pregnancy and associations with interpregnancy interval, hormonal contraceptives, dietary factors and supplement use. Br J Nutr. 2021;126(8):1270–80. doi: 10.1017/S0007114521000295. PMID: 33494856. Exclusion reason: Ineligible comparator.33494856
64 Cesar JA, Dumith SdC, Chrestani MAD, . Iron supplementation among pregnant women: results from a population-based survey study. Rev Bras Epidemiol. 2013;16(3):729–36. doi: 10.1590/s1415-790x2013000300016. PMID: 24896285. Exclusion reason: Ineligible comparator.24896285
65 Chatterjee R, Shand A, Nassar N, . Iron supplement use in pregnancy - Are the right women taking the right amount? Clin Nutr. 2016;35(3):741–7. doi: 10.1016/j.clnu.2015.05.014. PMID: 26070630. Exclusion reason: Ineligible intervention.26070630
66 Chavan S, Rana P, Tripathi R, . Comparison of efficacy & safety of iron polymaltose complex & ferrous ascorbate with ferrous sulphate in pregnant women with iron-deficiency anaemia. Indian J Med Res. 2021;154(1):78–84. doi: 10.4103/ijmr.IJMR_1753_18. PMID: 34782532. Exclusion reason: Ineligible comparator.34782532
67 Cheng Y, Li T, He M, . The association of elevated serum ferritin concentration in early pregnancy with gestational diabetes mellitus: a prospective observational study. Eur J Clin Nutr. 2020;74(5):741–8. doi: 10.1038/s41430-019-0542-6. PMID: 31932742. Exclusion reason: Ineligible outcome.31932742
68 Chisholm M. A controlled clinical trial of prophylactic folic acid and iron in pregnancy. BJOG. 1966;73(2):191–6. doi: 10.1111/j.1471-0528.1966.tb05145.x. Exclusion reason: Poor quality.
69 Christian P, Shrestha J, LeClerq SC, . Supplementation with micronutrients in addition to iron and folic acid does not further improve the hematologic status of pregnant women in rural Nepal. J Nutr. 2003;133(11):3492–8. doi: 10.1093/jn/133.11.3492. PMID: 14608063. Exclusion reason: Ineligible country.14608063
70 Christoph P, Schuller C, Studer H, . Intravenous iron treatment in pregnancy: comparison of high-dose ferric carboxymaltose vs. iron sucrose. J Perinat Med. 2012;40(5):469–74. doi: 10.1515/jpm-2011-0231. PMID: 22945271. Exclusion reason: Ineligible comparator.22945271
71 Cochrane KM, Hutcheon JA, Karakochuk CD. Iron deficiency prevalence and supplementation practices among pregnant women: a secondary data analysis from a clinical trial in Vancouver, Canada. J Nutr. 2022;152(10):2238–44. doi: 10.1093/jn/nxac135. PMID: 35687377. Exclusion reason: Ineligible study design for key question.35687377
72 Col Madendag I, Eraslan Sahin M, Madendag Y, . The effect of iron deficiency anemia early in the third trimester on small for gestational age and birth weight: a retrospective cohort study on iron deficiency anemia and fetal weight. Biomed Res Int. 2019;2019:7613868. doi: 10.1155/2019/7613868. PMID: 31886249. Exclusion reason: Ineligible intervention.31886249
73 Colman KS, Pavord S, Roy N. A quality improvement project for the cost-effective management of maternal anaemia. Br J Haematol. 2022;196(2):445–8. doi: 10.1111/bjh.17797. PMID: 34462912. Exclusion reason: Ineligible population.34462912
74 Correia-Santos AM BP K, Erthal Santelli R, Teles Boaventura G, Blondet de Azeredo V. Dietary supplements for the lactating adolescent mother: influence on plasma micronutrients. Nutr Hosp. 2011;26(2):392–8. doi: 10.1590/S0212-16112011000200022. PMID: 21666979. Exclusion reason: Ineligible population.21666979
75 Crispin P, Stephens B, McArthur E, . First trimester ferritin screening for pre-delivery anaemia as a patient blood management strategy. Transfus Apher Sci. 2019;58(1):50–7. doi: 10.1016/j.transci.2018.11.009. PMID: 30545659. Exclusion reason: Ineligible comparator.30545659
76 Cuervo LG, Mahomed K. Treatments for iron deficiency anaemia in pregnancy. Cochrane Database Syst Rev. 2001 (2):CD003094. doi: 10.1002/14651858.CD003094. PMID: 11406073. Exclusion reason: Systematic review used as a source document only to identify individual studies.11406073
77 da Silva CL, Saunders C, Szarfarc SC, . Anaemia in pregnant women before and after the mandatory fortification of wheat and corn flours with iron. Public Health Nutr. 2012;15(10):1802–9. doi: 10.1017/S1368980012001206. PMID: 22578817. Exclusion reason: Ineligible study design for key question.22578817
78 Daru J, Allotey J, Pena-Rosas JP, . Serum ferritin thresholds for the diagnosis of iron deficiency in pregnancy: a systematic review. Transfus Med. 2017;27(3):167–74. doi: 10.1111/tme.12408. PMID: 28425182. Exclusion reason: Systematic review used as a source document only to identify individual studies.28425182
79 Daru J, Cooper NAM, Khan KS. Systematic review of randomized trials of the effect of iron supplementation on iron stores and oxygen carrying capacity in pregnancy. Acta Obstet Gynecol Scand. 2016;95(3):270–9. doi: 10.1111/aogs.12812. PMID: 26509354. Exclusion reason: Systematic review used as a source document only to identify individual studies.26509354
80 Darwish AM, Fouly HA, Saied WH, . Lactoferrin plus health education versus total dose infusion (TDI) of low-molecular weight (LMW) iron dextran for treating iron deficiency anemia (IDA) in pregnancy: a randomized controlled trial. J Matern Fetal Neonatal Med. 2019;32(13):2214–20. doi: 10.1080/14767058.2018.1429396. PMID: 29338568. Exclusion reason: Ineligible comparator.29338568
81 Dawson EB, Albers J, McGanity WJ. Serum zinc changes due to iron supplementation in teen-age pregnancy. Am J Clin Nutr. 1989;50(4):848–52. PMID: 2801591. Exclusion reason: Poor quality.2801591
82 Dawson EB, Albers JH, McGanity WJ. The apparent effect of iron supplementation on serum selenium levels in teenage pregnancy. Biol Trace Elem Res. 2000;77(3):209–17. doi: 10.1385/BTER:77:3:209. PMID: 11204463. Exclusion reason: Poor quality.11204463
83 Dawson EB, McGanity WJ. Protection of maternal iron stores in pregnancy. J Reprod Med. 1987;32(6 Suppl):478–87. PMID: 3612641. Exclusion reason: Poor quality.3612641
84 de Lourdes Flores M, Neufeld LM, Gonzalez-Cossio T, . Multiple micronutrient supplementation and dietary energy intake in pregnant women. Salud Publica Mex. 2007;49(3):190–8. PMID: 17589773. Exclusion reason: Ineligible outcome.17589773
85 Derman RJ, Goudar SS, Thind S, . RAPIDIRON: Reducing Anaemia in Pregnancy in India-a 3-arm, randomized-controlled trial comparing the effectiveness of oral iron with single-dose intravenous iron in the treatment of iron deficiency anaemia in pregnant women and reducing low birth weight deliveries. Trials. 2021;22(1):649. doi: 10.1186/s13063-021-05549-2. PMID: 34556166. Exclusion reason: Ineligible country.34556166
86 Detlefs S, McKinney J, Salmanian B, . 389: Normalization of hemoglobin is associated with a lower rate of preterm birth in anemic patients. Am J Obstet Gynecol. 2020;222(1):S257. doi: 10.1016/j.ajog.2019.11.405. Exclusion reason: Not a study.
87 Devakumar D, Fall CHD, Sachdev HS, . Maternal antenatal multiple micronutrient supplementation for long-term health benefits in children: a systematic review and meta-analysis. BMC Med. 2016;14:90. doi: 10.1186/s12916-016-0633-3. PMID: 27306908. Exclusion reason: Ineligible outcome.27306908
88 Dewey KG, Oaks BM. U-shaped curve for risk associated with maternal hemoglobin, iron status, or iron supplementation. Am J Clin Nutr. 2017;106(Suppl 6):1694S–702S. doi: 10.3945/ajcn.117.156075. PMID: 29070565. Exclusion reason: Systematic review used as a source document only to identify individual studies.29070565
89 Dibley MJ, Titaley CR, d’Este C, . Iron and folic acid supplements in pregnancy improve child survival in Indonesia. Am J Clin Nutr. 2012;95(1):220–30. doi: 10.3945/ajcn.111.022699. PMID: 22170356. Exclusion reason: Ineligible intervention.22170356
90 Duarte AFM, Carneiro ACSV, Peixoto ATBMM, . Oral iron supplementation in pregnancy: current recommendations and evidence-based medicine. Rev Bras Ginecol Obstet. 2021;43(10):782–8. doi: 10.1055/s-0041-1736144. PMID: 34784635. Exclusion reason: Not a study.34784635
91 Ervasti M, Sankilampi U, Heinonen S, . Early signs of maternal iron deficiency do not influence the iron status of the newborn, but are associated with higher infant birthweight. Acta Obstet Gynecol Scand. 2009;88(1):83–90. doi: 10.1080/00016340802595993. PMID: 19140045. Exclusion reason: Ineligible comparator.19140045
92 Etheredge AJ, Premji Z, Gunaratna NS, . Iron supplementation in iron-replete and nonanemic pregnant women in Tanzania: a randomized clinical trial. JAMA Pediatr. 2015;169(10):947–55. doi: 10.1001/jamapediatrics.2015.1480. PMID: 26280534. Exclusion reason: Ineligible country.26280534
93 Fan T, Blitz J. Screening for iron deficiency anemia and iron supplementation in pregnant women to improve maternal health and birth outcomes. Am Fam Physician. 2016;93(2):137–8. PMID: 26926412. Exclusion reason: Not a study.26926412
94 Fatima T, Faridi MMA, Srivastava G. Iron status of exclusively breastfed low-birth-weight infants born to anemic mothers and effect of maternal iron supplementation for 3 versus 6 months: a randomized double-blind placebo control trial. Front Pediatr. 2022;10:880431. doi: 10.3389/fped.2022.880431. PMID: 36034548. Exclusion reason: Ineligible population.36034548
95 Faysal H, Araji T, Ahmadzia HK. Recognizing who is at risk for postpartum hemorrhage: targeting anemic women and scoring systems for clinical use. Am J Obstet Gynecol MFM. 2023;5(2S):100745. doi: 10.1016/j.ajogmf.2022.100745. PMID: 36075528. Exclusion reason: Not a study.36075528
96 Fleming AF, Martin JD, Hahnel R, . Effects of iron and folic acid antenatal supplements on maternal haematology and fetal wellbeing. Med J Aust. 1974;2(12):429–36. doi: 10.5694/j.1326-5377.1974.tb70897.x. PMID: 4431344. Exclusion reason: Poor quality.4431344
97 Forster DA, Wills G, Denning A, . The use of folic acid and other vitamins before and during pregnancy in a group of women in Melbourne, Australia. Midwifery. 2009;25(2):134–46. PMID: 17543431. Exclusion reason: Ineligible intervention.17543431
98 Frith-Terhune AL, Cogswell ME, Khan LK, . Iron deficiency anemia: higher prevalence in Mexican American than in non-Hispanic white females in the third National Health and Nutrition Examination Survey, 1988-1994. Am J Clin Nutr. 2000;72(4):963–8. doi: 10.1093/ajcn/72.4.963. PMID: 11010938. Exclusion reason: Ineligible study design for key question.11010938
99 Fu S, Li F, Zhou J, . The relationship between body iron status, iron intake and gestational diabetes: a systematic review and meta-analysis. Medicine (Baltimore). 2016;95(2):e2383. doi: 10.1097/MD.0000000000002383. PMID: 26765415. Exclusion reason: Ineligible intervention.26765415
100 Fujimori E, Sato APS, Szarfarc SC, . Anemia in Brazilian pregnant women before and after flour fortification with iron. Rev Saude Publica. 2011;45(6):1027–35. doi: 10.1590/s0034-89102011005000078. PMID: 22127652. Exclusion reason: Ineligible study design for key question.22127652
101 Gamad N, Saha PK, Sharma P, . A randomized controlled trial comparing the efficacy, tolerability, and cost of oral iron preparations in iron-deficiency anemia in pregnancy. J Obstet Gynaecol Res. 2021;47(11):3828–41. doi: 10.1111/jog.14999. PMID: 34490696. Exclusion reason: Ineligible comparator.34490696
102 Ghembaza MEA, Louinici A. Adherence to iron supplementation in pregnancy. Malawi Med J. 2017;29(1):66. doi: 10.4314/mmj.v29i1.15. PMID: 28567202. Exclusion reason: Ineligible country.28567202
103 Gilmartin CE, Hoang T, Cutts BA, . Retrospective cohort study comparing the adverse reactions and efficacy of intravenous iron polymaltose with ferric carboxymaltose for iron deficiency anemia. Int J Gynaecol Obstet. 2018;141(3):315–20. doi: 10.1002/ijgo.12476. PMID: 29498039. Exclusion reason: Ineligible population.29498039
104 Giunta G, Giuffrida L, Mangano K, . Influence of lactoferrin in preventing preterm delivery: a pilot study. Mol Med Rep. 2012;5(1):162–6. doi: 10.3892/mmr.2011.584. PMID: 21922138. Exclusion reason: Ineligible intervention.21922138
105 Gomber S, Agarwal KN, Mahajan C, . Impact of daily versus weekly hematinic supplementation on anemia in pregnant women. Indian Pediatr. 2002;39(4):339–46. PMID: 11976463. Exclusion reason: Ineligible comparator.11976463
106 Gomes da Costa A, Vargas S, Clode N, . Prevalence and risk factors for iron deficiency anemia and iron depletion during pregnancy: a prospective study. Acta Med Port. 2016;29(9):514–8. doi: 10.20344/amp.6808. PMID: 28060688. Exclusion reason: Ineligible intervention.28060688
107 Gomes F, Agustina R, Black RE, . Multiple micronutrient supplements versus iron-folic acid supplements and maternal anemia outcomes: an iron dose analysis. Ann N Y Acad Sci. 2022;1512(1):114–25. doi: 10.1111/nyas.14756. PMID: 35218047. Exclusion reason: Ineligible comparator.35218047
108 Goonewardene IMR, Senadheera DI. Randomized control trial comparing effectiveness of weekly versus daily antenatal oral iron supplementation in preventing anemia during pregnancy. J Obstet Gynaecol Res. 2018;44(3):417–24. doi: 10.1111/jog.13546. PMID: 29271022. Exclusion reason: Ineligible comparator.29271022
109 Goonewardene M, Liyanage C, Fernando R. Intermittent oral iron supplementation during pregnancy. Ceylon Med J. 2001;46(4):132–5. doi: 10.4038/cmj.v46i4.6440. PMID: 12164031. Exclusion reason: Ineligible comparator.12164031
110 Govindappagari S, Burwick RM. Treatment of iron deficiency anemia in pregnancy with intravenous versus oral iron: systematic review and meta-analysis. Am J Perinatol. 2019;36(4):366–76. doi: 10.1055/s-0038-1668555. PMID: 30121943. Exclusion reason: Ineligible comparator.30121943
111 Greig AJ, Patterson AJ, Collins CC, . The effects of non-anaemic iron deficiency on cognitive functioning: a double-blinded, placebo controlled trial of iron supplementation in women of childbearing age. A pilot study on acceptability and feasibility. Australasian medical journal. 2011;4(12):787. Exclusion reason: Ineligible population.
112 Guinn NR, Cooter ML, Maisonave Y, . How do I develop a process to effectively treat parturients with iron deficiency anemia? Transfusion. 2020;60(11):2476–81. doi: 10.1111/trf.15930. PMID: 32659040. Exclusion reason: Ineligible comparator.32659040
113 Guler B, Bilgic D, Okumus H, . An investigation of vitamin and mineral supplement recommendation among first-trimester pregnancies. J Perinat Med 2019;47(9):958–62. doi: 10.1515/jpm-2019-0178. PMID: 31622252. Exclusion reason: Ineligible comparator.31622252
114 Gungor ES D N, Mollamahmutoglu L. Maternal serum ferritin and hemoglobin values in patients with gestational diabetes mellitus. Saudi Med J. 2007;28(3):478–80. PMID: 17334491. Exclusion reason: Ineligible study design for key question.17334491
115 Haider BA, Olofin I, Wang M, . Anaemia, prenatal iron use, and risk of adverse pregnancy outcomes: systematic review and meta-analysis. BMJ. 2013;346:f3443. doi: 10.1136/bmj.f3443. PMID: 23794316. Exclusion reason: Systematic review used as a source document only to identify individual studies.23794316
116 Haider BA, Yakoob MY, Bhutta ZA. Effect of multiple micronutrient supplementation during pregnancy on maternal and birth outcomes. BMC Public Health. 2011;11 Suppl 3:S19. doi: 10.1186/1471-2458-11-S3-S19. PMID: 21501436. Exclusion reason: Systematic review used as a source document only to identify individual studies.21501436
117 Han XX, Sun YY, Ma AG, . Moderate NaFeEDTA supplementation improves both hematologic status and oxidative stress in anemic pregnant women. Asia Pac J Clin Nutr. 2011;20(4):514–20. PMID: 22094835. Exclusion reason: Not a study.22094835
118 Han XX, Sun YY, Ma AG, . Moderate NaFeEDTA and ferrous sulfate supplementation can improve both hematologic status and oxidative stress in anemic pregnant women. Asia Pac J Clin Nutr. 2011;20(4):514–20. PMID: 22094835. Exclusion reason: Ineligible population.22094835
119 Hanieh S, Ha TT, Simpson JA, . The effect of intermittent antenatal iron supplementation on maternal and infant outcomes in rural Viet Nam: a cluster randomised trial. PLoS Med. 2013;10(6):e1001470. doi: 10.1371/journal.pmed.1001470. PMID: 23853552. Exclusion reason: Ineligible comparator.23853552
120 Hansen R, Spangmose AL, Sommer VM, . Maternal first trimester iron status and its association with obstetric and perinatal outcomes. Arch Gynecol Obstet. 2022;306(4):1359–71. doi: 10.1007/s00404-022-06401-x. PMID: 35088196. Exclusion reason: Ineligible intervention.35088196
121 Harvey LJ, Dainty JR, Hollands WJ, . Effect of high-dose iron supplements on fractional zinc absorption and status in pregnant women. Am J Clin Nutr. 2007;85(1):131–6. doi: 10.1093/ajcn/85.1.131. PMID: 17209188. Exclusion reason: Poor quality.17209188
122 Hashimoto K, Noguchi S, Morimoto Y, . A1C but not serum glycated albumin is elevated in late pregnancy owing to iron deficiency. Diabetes Care. 2008;31(10):1945–8. doi: 10.2337/dc08-0352. PMID: 18599529. Exclusion reason: Ineligible intervention.18599529
123 Hashimoto K, Osugi T, Noguchi S, . A1C but not serum glycated albumin is elevated because of iron deficiency in late pregnancy in diabetic women. Diabetes Care. 2010;33(3):509–11. doi: 10.2337/dc09-1954. PMID: 20032277. Exclusion reason: Ineligible population.20032277
124 Haugen M, Brantsaeter AL, Alexander J, . Dietary supplements contribute substantially to the total nutrient intake in pregnant Norwegian women. Ann Nutr Metab. 2008;52(4):272–80. doi: 10.1159/000146274. PMID: 18645244. Exclusion reason: Ineligible country.18645244
125 Hess SY, Zimmermann MB, Brogli S, . A national survey of iron and folate status in pregnant women in Switzerland. Int J Vitam Nutr Res. 2001;71(5):268–73. doi: 10.1024/0300-9831.71.5.268. PMID: 11725691. Exclusion reason: Ineligible study design for key question.11725691
126 Hindmarsh PC, Geary MP, Rodeck CH, . Effect of early maternal iron stores on placental weight and structure. Lancet. 2000;356(9231):719–23. doi: 10.1016/s0140-6736(00)02630-1. PMID: 11085691. Exclusion reason: Ineligible intervention.11085691
127 Hoa PT, Khan NC, van Beusekom C, . Milk fortified with iron or iron supplementation to improve nutritional status of pregnant women: an intervention trial from rural Vietnam. Food Nutr Bull. 2005;26(1):32–8. doi: 10.1177/156482650502600104. PMID: 15810797. Exclusion reason: Ineligible outcome.15810797
128 Holly RG. Anemia in pregnancy. Obstet Gynecol. 1955;5(4):562–8. PMID: 14370701. Exclusion reason: Poor quality.14370701
129 Hwang J-Y, Lee J-Y, Kim K-N, . Maternal iron intake at mid-pregnancy is associated with reduced fetal growth: results from Mothers and Children’s Environmental Health (MOCEH) study. Nutr J. 2013;12:38. doi: 10.1186/1475-2891-12-38. PMID: 23547877. Exclusion reason: Ineligible outcome.23547877
130 Hyder SMZ, Persson LA, Chowdhury AMR, . Do side-effects reduce compliance to iron supplementation? A study of daily- and weekly-dose regimens in pregnancy. J Health Popul Nutr. 2002;20(2):175–9. PMID: 12186198. Exclusion reason: Ineligible comparator.12186198
131 Iglesias L, Canals J, Arija V. Effects of prenatal iron status on child neurodevelopment and behavior: a systematic review. Crit Rev Food Sci Nutr. 2018;58(10):1604–14. doi: 10.1080/10408398.2016.1274285. PMID: 28084782. Exclusion reason: Systematic review used as a source document only to identify individual studies.28084782
132 Iglesias Vazquez L, Arija V, Aranda N, . The effectiveness of different doses of iron supplementation and the prenatal determinants of maternal iron status in pregnant Spanish women: ECLIPSES Study. Nutrients. 2019;11(10):2418. doi: 10.3390/nu11102418. PMID: 31658725. Exclusion reason: Ineligible comparator.31658725
133 Imdad A, Bhutta ZA. Routine iron/folate supplementation during pregnancy: effect on maternal anaemia and birth outcomes. Paediatr Perinat Epidemiol. 2012;26 Suppl 1:168–77. doi: 10.1111/j.1365-3016.2012.01312.x. PMID: 22742609. Exclusion reason: Systematic review used as a source document only to identify individual studies.22742609
134 Iqbal S, Ekmekcioglu C. Maternal and neonatal outcomes related to iron supplementation or iron status: a summary of meta-analyses. J Matern Fetal Neonatal Med. 2019;32(9):1528–40. doi: 10.1080/14767058.2017.1406915. PMID: 29207894. Exclusion reason: Systematic review used as a source document only to identify individual studies.29207894
135 Jacobson DL, Neri D, Gaskins A, . Maternal anemia and preterm birth among women living with HIV in the United States. Am J Clin Nutr. 2021;113(6):1402–10. doi: 10.1093/ajcn/nqaa441. PMID: 35104854. Exclusion reason: Ineligible intervention.35104854
136 Janbek J, Sarki M, Specht IO, . A systematic literature review of the relation between iron status/anemia in pregnancy and offspring neurodevelopment. Eur J Clin Nutr. 2019;73(12):1561–78. doi: 10.1038/s41430-019-0400-6. PMID: 30783211. Exclusion reason: Systematic review used as a source document only to identify individual studies.30783211
137 Jaraba SMR, Garces-Palacio IC. Association between violence during pregnancy and preterm birth and low birth weight in Colombia: analysis of the demographic and health survey. Health Care Women Int. 2019;40(11):1149–69. doi: 10.1080/07399332.2019.1566331. PMID: 30874485. Exclusion reason: Ineligible study design for key question.30874485
138 Javadian P, Alimohamadi S, Gharedaghi MH, . Gestational diabetes mellitus and iron supplement; effects on pregnancy outcome. Acta Med Iran. 2014;52(5):385–9. PMID: 24902020. Exclusion reason: Ineligible intervention.24902020
139 Jayasinghe C, Polson R, van Woerden HC, . The effect of universal maternal antenatal iron supplementation on neurodevelopment in offspring: a systematic review and meta-analysis. BMC Pediatr. 2018;18(1):150. doi: 10.1186/s12887-018-1118-7. PMID: 29728086. Exclusion reason: Systematic review used as a source document only to identify individual studies.29728086
140 Jefferds MED, Mei Z, Addo Y, . Iron deficiency in the United States: limitations in guidelines, data, and monitoring of disparities. Am J Public Health. 2022;112(S8):S826–S35. doi: 10.2105/AJPH.2022.306998. PMID: 36288529. Exclusion reason: Not a study.36288529
141 Jia HX, Han JH, Li HZ, . Mineral intake in urban pregnant women from base diet, fortified foods, and food supplements: focus on calcium, iron, and zinc. Biomed Environ Sci. 2016;29(12):898–901. doi: 10.3967/bes2016.120. PMID: 28081751. Exclusion reason: Ineligible country.28081751
142 Jirakittidul P, Sirichotiyakul S, Ruengorn C, . Effect of iron supplementation during early pregnancy on the development of gestational hypertension and pre-eclampsia. Arch Gynecol Obstet. 2018;298(3):545–50. doi: 10.1007/s00404-018-4821-6. PMID: 29951711. Exclusion reason: Ineligible comparator.29951711
143 Jorgensen JM, Ashorn P, Ashorn U, . Effects of lipid-based nutrient supplements or multiple micronutrient supplements compared with iron and folic acid supplements during pregnancy on maternal haemoglobin and iron status. Matern Child Nutr. 2018;14(4):e12640. doi: 10.1111/mcn.12640. PMID: 30047245. Exclusion reason: Ineligible intervention.30047245
144 Jose A, Mahey R, Sharma JB, . Comparison of ferric carboxymaltose and iron sucrose complex for treatment of iron deficiency anemia in pregnancy- randomised controlled trial. BMC Pregnancy Childbirth. 2019;19(1):54. doi: 10.1186/s12884-019-2200-3. PMID: 30717690. Exclusion reason: Ineligible comparator.30717690
145 Juarez-Vazquez J, Bonizzoni E, Scotti A. Iron plus folate is more effective than iron alone in the treatment of iron deficiency anaemia in pregnancy: a randomised, double blind clinical trial. BJOG. 2002;109(9):1009–14. doi: 10.1111/j.1471-0528.2002.01378.x. PMID: 12269674. Exclusion reason: Ineligible comparator.12269674
146 Kamdi SP, Palkar PJ. Efficacy and safety of ferrous asparto glycinate in the management of iron deficiency anaemia in pregnant women. J Obstet Gynaecol. 2015;35(1):4–8. doi: 10.3109/01443615.2014.930098. PMID: 24959663. Exclusion reason: Ineligible comparator.24959663
147 Kant S, Haldar P, Malhotra S, . Intravenous ferric carboxymaltose rapidly increases haemoglobin and serum ferritin among pregnant females with moderate-to-severe anaemia: a single-arm, open-label trial. Natl Med J India. 2020;33(6):324–8. doi: 10.4103/0970-258X.321145. PMID: 34341207. Exclusion reason: Ineligible intervention.34341207
148 Kanu FA, Hamner HC, Scanlon KS, . Anemia among pregnant women participating in the special supplemental nutrition program for women, infants, and children - United States, 2008-2018. MMWR Morb Mortal Wkly Rep. 2022;71(25):813–9. doi: 10.15585/mmwr.mm7125a1. PMID: 35737575. Exclusion reason: Ineligible intervention.35737575
149 Karakoc G, Orgul G, Sahin D, . Is every other day iron supplementation effective for the treatment of the iron deficiency anemia in pregnancy? J Matern Fetal Neonatal Med. 2022;35(5):832–6. doi: 10.1080/14767058.2021.1910666. PMID: 33866933. Exclusion reason: Ineligible comparator.33866933
150 Kataria Y, Wu Y, Horskjaer PdH, . Iron status and gestational diabetes-a meta-analysis. Nutrients. 2018;10(5):621. doi: 10.3390/nu10050621. PMID: 29762515. Exclusion reason: Ineligible intervention.29762515
151 Keats EC, Haider BA, Tam E, . Multiple-micronutrient supplementation for women during pregnancy. Cochrane Database Syst Rev. 2019;3:CD004905. doi: 10.1002/14651858.CD004905.pub6. PMID: 30873598. Exclusion reason: Ineligible comparator.30873598
152 Kemppinen L, Mattila M, Ekholm E, . Gestational iron deficiency anemia is associated with preterm birth, fetal growth restriction, and postpartum infections. J Perinat Med. 2021;49(4):431–8. doi: 10.1515/jpm-2020-0379. PMID: 33554586. Exclusion reason: Ineligible comparator.33554586
153 Khalafallah A, Dennis A, Bates J, . A prospective randomized, controlled trial of intravenous versus oral iron for moderate iron deficiency anaemia of pregnancy. J Intern Med. 2010;268(3):286–95. doi: 10.1111/j.1365-2796.2010.02251.x. PMID: 20546462. Exclusion reason: Ineligible comparator.20546462
154 Khalafallah AA, Hyppa A, Chuang A, . A prospective randomised controlled trial of a single intravenous infusion of ferric carboxymaltose vs single intravenous iron polymaltose or daily oral ferrous sulphate in the treatment of iron deficiency anaemia in pregnancy. Semin Hematol. 2018;55(4):223–34. doi: 10.1053/j.seminhematol.2018.04.006. PMID: 30502851. Exclusion reason: Ineligible comparator.30502851
155 Khambalia AZ, Aimone A, Nagubandi P, . High maternal iron status, dietary iron intake and iron supplement use in pregnancy and risk of gestational diabetes mellitus: a prospective study and systematic review. Diabet Med. 2016;33(9):1211–21. doi: 10.1111/dme.13056. PMID: 26670627. Exclusion reason: Systematic review used as a source document only to identify individual studies.26670627
156 Khambalia AZ, Collins CE, Roberts CL, . High maternal serum ferritin in early pregnancy and risk of spontaneous preterm birth. Br J Nutr. 2015;114(3):455–61. doi: 10.1017/S0007114515001932. PMID: 26146276. Exclusion reason: Ineligible intervention.26146276
157 Khambalia AZ, Collins CE, Roberts CL, . Iron deficiency in early pregnancy using serum ferritin and soluble transferrin receptor concentrations are associated with pregnancy and birth outcomes. Eur J Clin Nutr. 2016;70(3):358–63. doi: 10.1038/ejcn.2015.157. PMID: 26373962. Exclusion reason: Ineligible intervention.26373962
158 Kilbride J B T, Parapia LA, Khoury SA. Iron status, serum folate and B(12) values in pregnancy and postpartum: report from a study in Jordan. Ann Saudi Med. 2000;20(5–6):371–6. doi: 10.5144/0256-4947.2000.371. PMID: 17264625. Exclusion reason: Ineligible study design for key question.17264625
159 King SE, Yeh PT, Rhee DK, . Self-management of iron and folic acid supplementation during pre-pregnancy, pregnancy and postnatal periods: a systematic review. BMJ Glob Health. 2021;6(5):e005531. doi: 10.1136/bmjgh-2021-005531. PMID: 33990359. Exclusion reason: Ineligible comparator.33990359
160 Kinnunen TI, Luoto R, Helin A, . Supplemental iron intake and the risk of glucose intolerance in pregnancy: re-analysis of a randomised controlled trial in Finland. Matern Child Nutr. 2016;12(1):74–84. doi: 10.1111/mcn.12139. PMID: 24995700. Exclusion reason: Ineligible comparator.24995700
161 Korkmaz V, Ozkaya E, Seven BY, . Comparison of oxidative stress in pregnancies with and without first trimester iron supplement: a randomized double-blind controlled trial. J Matern Fetal Neonatal Med. 2014;27(15):1535–8. doi: 10.3109/14767058.2013.863869. PMID: 24199687. Exclusion reason: Ineligible outcome.24199687
162 Krafft A. Iron supplementation in pregnancy. BMJ. 2013;347:f4399. doi: 10.1136/bmj.f4399. PMID: 23843551. Exclusion reason: Not a study.23843551
163 Kumar A, Jain S, Singh NP, . Oral versus high dose parenteral iron supplementation in pregnancy. Int J Gynaecol Obstet. 2005;89(1):7–13. doi: 10.1016/j.ijgo.2005.01.016. PMID: 15777891. Exclusion reason: Ineligible comparator.15777891
164 Lagana AS, Costabile L, Filati P, . Effects of micronised dispersible ferric pyrophosphate combined with alpha-lactalbumin in pregnant women affected by iron deficiency anemia: results from a prospective, double-blind, randomized controlled trial. Eur Rev Med Pharmacol Sci. 2018;22(11):3602–8. doi: 10.26355/eurrev_201806_15187. PMID: 29917215. Exclusion reason: Ineligible comparator.29917215
165 Lao TT, Chan LY, Tam KF, . Maternal hemoglobin and risk of gestational diabetes mellitus in Chinese women. Obstet Gynecol. 2002;99(5 Pt 1):807–12. doi: 10.1016/s0029-7844(02)01941-5. PMID: 11978291. Exclusion reason: Ineligible intervention.11978291
166 Lao TT, Chan PL, Tam KF. Gestational diabetes mellitus in the last trimester - a feature of maternal iron excess? Diabet Med. 2001;18(3):218–23. doi: 10.1046/j.1464-5491.2001.00453.x. PMID: 11318843. Exclusion reason: Ineligible study design for key question.11318843
167 Lao TT, Ho L-F. Impact of iron deficiency anemia on prevalence of gestational diabetes mellitus. Diabetes Care. 2004;27(3):650–6. doi: 10.2337/diacare.27.3.650. PMID: 14988280. Exclusion reason: Ineligible intervention.14988280
168 Lao TT, Tam KF, Chan LY. Third trimester iron status and pregnancy outcome in non-anaemic women; pregnancy unfavourably affected by maternal iron excess. Hum Reprod 2000;15(8):1843–8. doi: 10.1093/humrep/15.8.1843. PMID: 10920115. Exclusion reason: Ineligible intervention.10920115
169 Lao TT, Tse K-Y, Chan LY, . HBsAg carrier status and the association between gestational diabetes with increased serum ferritin concentration in Chinese women. Diabetes Care. 2003;26(11):3011–6. doi: 10.2337/diacare.26.11.3011. PMID: 14578232. Exclusion reason: Ineligible comparator.14578232
170 Lao TT-H, Hui SYA, Wong LL, . Iron deficiency anaemia associated with increased placenta praevia and placental abruption: a retrospective case-control study. Eur J Clin Nutr. 2022;76(8):1172–7. doi: 10.1038/s41430-022-01086-6. PMID: 35301462. Exclusion reason: Ineligible intervention.35301462
171 Lee HS, Kim MS, Kim MH, . Iron status and its association with pregnancy outcome in Korean pregnant women. Eur J Clin Nutr. 2006;60(9):1130–5. doi: 10.1038/sj.ejcn.1602429. PMID: 16639418. Exclusion reason: Ineligible intervention.16639418
172 Lee J-I, Lee J-A, Lim H-S. Effect of time of initiation and dose of prenatal iron and folic acid supplementation on iron and folate nutriture of Korean women during pregnancy. Am J Clin Nutr. 2005;82(4):843–9. doi: 10.1093/ajcn/82.4.843. PMID: 16210715. Exclusion reason: Poor quality.16210715
173 Leslie MS, Park J, Briggs LA, . Is anemia in low income pregnant women related to their infants’ having anemia? A cohort study of pregnant women-infant pairs in the United States. Matern Child Health J. 2020;24(6):768–76. doi: 10.1007/s10995-020-02912-8. PMID: 32303936. Exclusion reason: Ineligible comparator.32303936
174 Lewkowitz AK, Stout MJ, Cooke E, . Intravenous versus oral iron for iron-deficiency anemia in pregnancy (IVIDA): a randomized controlled trial. Am J Perinatol. 2022;39(8):808–15. doi: 10.1055/s-0041-1740003. PMID: 34839481. Exclusion reason: Ineligible comparator.34839481
175 Li HT, Mei Z, Ren A, . Impact of iron-containing micronutrient supplementation on high hemoglobin concentration during pregnancy. FASEB J. 2012;26doi: 10.1096/fasebj.26.1_supplement.1021.2. Exclusion reason: Not a study.
176 Liu JM, Mei Z, Ye R, . Impact of iron-contained micronutrient supplementation on macrosomia and large for gestational age births. FASEB J. 2012;26(1):1021.1. doi: 10.1096/fasebj.26.1_supplement.1021.1. Exclusion reason: Not a study.
177 Liu L, Xiao Y, Zou B, . Study of the significance of iron deficiency indexes and erythrocyte parameters in anemic pregnant women and their newborns. Genet Mol Res. 2015;14(2):3501–8. doi: 10.4238/2015.April.15.14. PMID: 25966117. Exclusion reason: Ineligible intervention.25966117
178 Liu X-N, Pang J. A retrospective study of supplemental iron intake in singleton pregnancy women with risk of developing gestational diabetes mellitus. Medicine (Baltimore). 2018;97(26):e10819. doi: 10.1097/MD.0000000000010819. PMID: 29952938. Exclusion reason: Ineligible comparator.29952938
179 Liu XN, Yang W, Zhang J, . Weekly iron supplementation is effective and safe in pregnant women. FASEB J. 1995;9:A658. Exclusion reason: Not a study.
180 Luis J, Fadel MG, Lau GY, . The effects of severe iron-deficiency anaemia on maternal and neonatal outcomes: a case-control study in an inner-city London hospital. J Obstet Gynaecol. 2016;36(4):473–5. doi: 10.3109/01443615.2015.1085848. PMID: 26399479. Exclusion reason: Ineligible intervention.26399479
181 Ma A, Sun Y, Han X, . A combination of iron and retinol supplementation benefits iron status, IL-2 level, and lymphocyte proliferation in anemic pregnant women. FASEB J. 2011;25. Exclusion reason: Not a study.
182 Ma AG, Schouten EG, Sun YY, . Supplementation of iron alone and combined with vitamins improves haematological status, erythrocyte membrane fluidity and oxidative stress in anaemic pregnant women. Br J Nutr. 2010;104(11):1655–61. doi: 10.1017/S000711451000259X. PMID: 20615267. Exclusion reason: Ineligible outcome.20615267
183 Maats FH, Crowther CA. Patterns of vitamin, mineral and herbal supplement use prior to and during pregnancy. Aust N Z J Obstet Gynaecol. 2002;42(5):494–6. doi: 10.1111/j.0004-8666.2002.00494.x. PMID: 12495093. Exclusion reason: Ineligible outcome.12495093
184 Mabry-Hernandez IR. Screening for iron deficiency anemia--including iron supplementation for children and pregnant women. Am Fam Physician. 2009;79(10):897–8. PMID: 19496390. Exclusion reason: Not a study.19496390
185 Mahomed K. Iron and folate supplementation in pregnancy. Cochrane Database Syst Rev. 2000 (2):CD001135. doi: 10.1002/14651858.CD001135. PMID: 10796246. Exclusion reason: Systematic review used as a source document only to identify individual studies.10796246
186 Mahomed K. Iron supplementation in pregnancy. Cochrane Database Syst Rev. 2000 (2):CD000117. doi: 10.1002/14651858.CD000117. PMID: 10796140. Exclusion reason: Systematic review used as a source document only to identify individual studies.10796140
187 Mahomed K. WITHDRAWN: Iron and folate supplementation in pregnancy. Cochrane Database Syst Rev. 2007 (3):CD001135. doi: 10.1002/14651858.CD001135.pub2. PMID: 17636654. Exclusion reason: Systematic review used as a source document only to identify individual studies.17636654
188 Mandasari M, Hadju V, Ariyandy A. The effect of giving extracted moringa oleifera leaves plus royal jelly supplement on infant weight and length of new born of anemia pregnant woman in Takalar district. EJMCM. 2020;7(7):4952. Exclusion reason: Ineligible population.
189 Mari-Sanchis A, Diaz-Jurado G, Basterra-Gortari FJ, . Association between pre-pregnancy consumption of meat, iron intake, and the risk of gestational diabetes: the SUN project. Eur J Nutr. 2018;57(3):939–49. doi: 10.1007/s00394-017-1377-3. PMID: 28285431. Exclusion reason: Ineligible intervention.28285431
190 Martinez-Galiano JM, Amezcua-Prieto C, Cano-Ibanez N, . Maternal iron intake during pregnancy and the risk of small for gestational age. Matern Child Nutr. 2019;15(3):e12814. doi: 10.1111/mcn.12814. PMID: 30903732. Exclusion reason: Ineligible intervention.30903732
191 McDonagh M, Cantor A, Bougatsos C, . Routine iron supplementation and screening for iron deficiency anemia in pregnant women: a systematic review to update the U.S. Preventive Services Task Force recommendation Agency for Healthcare Research and Quality. U.S. Preventive Services Task Force Evidence Syntheses. 2015. PMID: 2592713625927136. Exclusion reason: Systematic review used as a source document only to identify individual studies.
192 McKenna D, Spence D, Dornan J. A randomised, double-blind, placebo-controlled trial investigating the place of spatone-iron plus as a prophylaxis against iron deficiency in pregnancy. Journal of Obstetrics and Gynaecology. 2002;22(2 Suppl):S45. Exclusion reason: Not a study.
193 McKenna D, Spence D, Haggan SE, . A randomized trial investigating an iron-rich natural mineral water as a prophylaxis against iron deficiency in pregnancy. Clin Lab Haematol. 2003;25(2):99–103. doi: 10.1046/j.1365-2257.2003.00501.x. PMID: 12641613. Exclusion reason: Ineligible outcome.12641613
194 Miles LF, Litton E, Imberger G, . Intravenous iron therapy for non-anaemic, iron-deficient adults. Cochrane Database Syst Rev. 2019;12(12):CD013084. doi: 10.1002/14651858.CD013084.pub2. PMID: 31860749. Exclusion reason: Ineligible population.31860749
195 Milman N, Bergholt T, Eriksen L, . Iron prophylaxis during pregnancy -- how much iron is needed? A randomized dose- response study of 20-80 mg ferrous iron daily in pregnant women. Acta Obstet Gynecol Scand. 2005;84(3):238–47. doi: 10.1111/j.0001-6349.2005.00610.x. PMID: 15715531. Exclusion reason: Ineligible comparator.15715531
196 Milman N, Byg K-E, Bergholt T, . Side effects of oral iron prophylaxis in pregnancy-myth or reality? Acta Haematol. 2006;115(1–2):53–7. doi: 10.1159/000089466. PMID: 16424650. Exclusion reason: Ineligible comparator.16424650
197 Milman N, Byg K-E, Bergholt T, . Body iron and individual iron prophylaxis in pregnancy--should the iron dose be adjusted according to serum ferritin? Ann of Hematol. 2006;85(9):567–73. doi: 10.1007/s00277-006-0141-1. PMID: 16733739. Exclusion reason: Ineligible comparator.16733739
198 Milman N, Jonsson L, Dyre P, . Ferrous bisglycinate 25 mg iron is as effective as ferrous sulfate 50 mg iron in the prophylaxis of iron deficiency and anemia during pregnancy in a randomized trial. J Perinat Med. 2014;42(2):197–206. doi: 10.1515/jpm-2013-0153. PMID: 24152889. Exclusion reason: Ineligible comparator.24152889
199 Milman NT. Iron supplementation in pregnant Danish women revisited: effects on prepartum and postpartum iron deficiency, anemia, serum erythropoietin; including iron status, erythropoietin and anthropometrics in newborns. A randomized, placebo-controlled study. J Neonatal Perinatal Med. 2022;15(4):731–44. doi: 10.3233/NPM-221014. PMID: 35811545. Exclusion reason: Ineligible outcome.35811545
200 Mireku MO, Davidson LL, Boivin MJ, . Prenatal iron deficiency, neonatal ferritin, and infant cognitive function. Pediatrics. 2016;138(6):e20161319. doi: 10.1542/peds.2016-1319. PMID: 27940685. Exclusion reason: Ineligible country.27940685
201 Mitchell EA, Robinson E, Clark PM, . Maternal nutritional risk factors for small for gestational age babies in a developed country: a case-control study. Arch Dis Child Fetal Neonatal Ed. 2004;89(5):F431–5. PMID: 15321964. Exclusion reason: Ineligible intervention.15321964
202 Moin A, Lassi ZS. Can routine screening and iron supplementation for iron deficiency anemia in nonsymptomatic pregnant women improve maternal and infant health outcomes? J Family Med Prim Care. 2015;4(3):333–4. doi: 10.4103/2249-4863.161310. PMID: 26288769. Exclusion reason: Not a study.26288769
203 Morton RE N A, Price K. Iron status in the first year of life. J Pediatr Gastroenterol Nutr. 1998;7(5):707–12. doi: 10.1097/00005176-198809000-00015. PMID: 3183875. Exclusion reason: Ineligible study design for key question.3183875
204 Mukhopadhyay A, Bhatla N, Kriplani A, . Daily versus intermittent iron supplementation in pregnant women: hematological and pregnancy outcome. J Obstet Gynaecol Res. 2004;30(6):409–17. doi: 10.1111/j.1447-0756.2004.00223.x. PMID: 15566454. Exclusion reason: Ineligible comparator.15566454
205 Naess-Andresen M-L, Eggemoen AR, Berg JP, . Serum ferritin, soluble transferrin receptor, and total body iron for the detection of iron deficiency in early pregnancy: a multiethnic population-based study with low use of iron supplements. Am J Clin Nutr. 2019;109(3):566–75. doi: 10.1093/ajcn/nqy366. PMID: 30831600. Exclusion reason: Ineligible intervention.30831600
206 Naess-Andresen M-L, Jenum AK, Berg JP, . Prevalence of postpartum anaemia and iron deficiency by serum ferritin, soluble transferrin receptor and total body iron, and associations with ethnicity and clinical factors: a Norwegian population-based cohort study. J Nutr Sci. 2022;11:e46. doi: 10.1017/jns.2022.45. PMID: 35754987. Exclusion reason: Ineligible intervention.35754987
207 Nojilana B, Norman R, Dhansay MA, . Estimating the burden of disease attributable to iron deficiency anaemia in South Africa in 2000. S Afr Med J. 2007;97(8 Pt 2):741–6. PMID: 17952232. Exclusion reason: Ineligible intervention.17952232
208 Noshiro K, Umazume T, Hattori R, . Hemoglobin concentration during early pregnancy as an accurate predictor of anemia during late pregnancy. Nutrients. 2022;14(4):839. doi: 10.3390/nu14040839. PMID: 35215489. Exclusion reason: Ineligible intervention.35215489
209 Offerhaus P, Fleuren M, Wensing M. Guidelines on anaemia: effect on primary-care midwives in The Netherlands. Midwifery. 2005;21(3):204–11. doi: 10.1016/j.midw.2004.10.005. PMID: 16055242. Exclusion reason: Ineligible study design for key question.16055242
210 Ortiz R, Toblli JE, Romero JD, . Efficacy and safety of oral iron(III) polymaltose complex versus ferrous sulfate in pregnant women with iron-deficiency anemia: a multicenter, randomized, controlled study. J Matern Fetal Neonatal Med. 2011;24(11):1347–52. doi: 10.3109/14767058.2011.599080. PMID: 21859366. Exclusion reason: Ineligible comparator.21859366
211 Oskovi-Kaplan ZA, Kilickiran H, Buyuk GN, . Comparison of the maternal and neonatal outcomes of pregnant women whose anemia was not corrected before delivery and pregnant women who were treated with intravenous iron in the third trimester. Arch Gynecol Obstet. 2021;303(3):715–9. doi: 10.1007/s00404-020-05817-7. PMID: 32990783. Exclusion reason: Ineligible population.32990783
212 Osungbade KO, Oladunjoye AO. Preventive treatments of iron deficiency anaemia in pregnancy: a review of their effectiveness and implications for health system strengthening. J Pregnancy. 2012;2012:454601. doi: 10.1155/2012/454601. PMID: 22848829. Exclusion reason: Ineligible country.22848829
213 Ozer I, Guzel I, Orhan G, . A prospective case control questionnaire study for restless leg syndrome on 600 pregnant women. J Matern Fetal Neonatal Med. 2017;30(24):2895–9. doi: 10.3109/14767058.2016.1170801. PMID: 27019150. Exclusion reason: Ineligible population.27019150
214 Paesano R, Torcia F, Berlutti F, . Oral administration of lactoferrin increases hemoglobin and total serum iron in pregnant women. Biochem Cell Biol. 2006;84(3):377–80. doi: 10.1139/o06-040. PMID: 16936810. Exclusion reason: Ineligible outcome.16936810
215 Palma S, Perez-Iglesias R, Prieto D, . Iron but not folic acid supplementation reduces the risk of low birthweight in pregnant women without anaemia: a case-control study. J Epidemiol Community Health. 2008;62(2):120–4. doi: 10.1136/jech.2006.052985. PMID: 18192599. Exclusion reason: Ineligible study design for key question.18192599
216 Papadopoulou E, Stratakis N, Roumeliotaki T, . The effect of high doses of folic acid and iron supplementation in early-to-mid pregnancy on prematurity and fetal growth retardation: the mother-child cohort study in Crete, Greece (Rhea study). Eur J Nutr. 2013;52(1):327–36. doi: 10.1007/s00394-012-0339-z. PMID: 22430980. Exclusion reason: Ineligible comparator.22430980
217 Parisi F, Berti C, Mando C, . Effects of different regimens of iron prophylaxis on maternal iron status and pregnancy outcome: a randomized control trial. J Matern Fetal Neonatal Med. 2017;30(15):1787–92. doi: 10.1080/14767058.2016.1224841. PMID: 27588568. Exclusion reason: Poor quality.27588568
218 Pasricha S-R. Should we screen for iron deficiency anaemia? A review of the evidence and recent recommendations. Pathology. 2012;44(2):139–47. doi: 10.1097/PAT.0b013e32834e8291. PMID: 22198251. Exclusion reason: Not a study.22198251
219 Pathirathna ML, Wimalasiri KMS, Sekijima K, . Maternal compliance to recommended iron and folic acid supplementation in pregnancy, Sri Lanka: a hospital-based cross-sectional study. Nutrients. 2020;12(11):3266. doi: 10.3390/nu12113266. PMID: 33113819. Exclusion reason: Ineligible intervention.33113819
220 Pena-Rosas JP, De-Regil LM, Dowswell T, . Daily oral iron supplementation during pregnancy. Cochrane Database Syst Rev. 2012;12:CD004736. doi: 10.1002/14651858.CD004736.pub4. PMID: 23235616. Exclusion reason: Systematic review used as a source document only to identify individual studies.23235616
221 Pena-Rosas JP, De-Regil LM, Dowswell T, . Intermittent oral iron supplementation during pregnancy. Cochrane Database Syst Rev. 2012;7(7):CD009997. doi: 10.1002/14651858.CD009997. PMID: 22786531. Exclusion reason: Ineligible comparator.22786531
222 Pena-Rosas JP, De-Regil LM, Garcia-Casal MN, . Daily oral iron supplementation during pregnancy. Cochrane Database Syst Rev. 2015;2015(7):CD004736. doi: 10.1002/14651858.CD004736.pub5. PMID: 26198451. Exclusion reason: Systematic review used as a source document only to identify individual studies.26198451
223 Pena-Rosas JP, De-Regil LM, Gomez Malave H, . Intermittent oral iron supplementation during pregnancy. Cochrane Database Syst Rev. 2015;2015(10):CD009997. doi: 10.1002/14651858.CD009997.pub2. PMID: 26482110. Exclusion reason: Ineligible comparator.26482110
224 Pena-Rosas JP, Nesheim MC, Garcia-Casal MN, . Intermittent iron supplementation regimens are able to maintain safe maternal hemoglobin concentrations during pregnancy in Venezuela. J Nutr. 2004;134(5):1099–104. doi: 10.1093/jn/134.5.1099. PMID: 15113952. Exclusion reason: Ineligible comparator.15113952
225 Pena-Rosas JP, Viteri FE. Effects of routine oral iron supplementation with or without folic acid for women during pregnancy. Cochrane Database Syst Rev. 2006 (3):CD004736. doi: 10.1002/14651858.CD004736.pub2. PMID: 16856058. Exclusion reason: Systematic review used as a source document only to identify individual studies.16856058
226 Pena-Rosas JP, Viteri FE. Effects and safety of preventive oral iron or iron+folic acid supplementation for women during pregnancy. Cochrane Database Syst Rev. 2009 (4):CD004736. doi: 10.1002/14651858.CD004736.pub3. PMID: 19821332. Exclusion reason: Systematic review used as a source document only to identify individual studies.19821332
227 Perez EM, Hendricks MK, Beard JL, . Mother-infant interactions and infant development are altered by maternal iron deficiency anemia. J Nutr. 2005;135(4):850–5. doi: 10.1093/jn/135.4.850. PMID: 15795446. Exclusion reason: Ineligible outcome.15795446
228 Petry CJ, Olga L, Hughes IA, . Associations between maternal iron supplementation in pregnancy and offspring growth and cardiometabolic risk outcomes in infancy and childhood. PLoS One. 2022;17(5):e0263148. doi: 10.1371/journal.pone.0263148. PMID: 35622831. Exclusion reason: Ineligible study design for key question.35622831
229 Petry CJ, Ong KK, Hughes IA, . Associations between maternal iron supplementation in pregnancy and changes in offspring size at birth reflect those of multiple micronutrient supplementation. Nutrients. 2021;13(7):2480. doi: 10.3390/nu13072480. PMID: 34371987. Exclusion reason: Poor quality.34371987
230 Pinho-Pompeu M, Surita FG, Pastore DA, . Anemia in pregnant adolescents: impact of treatment on perinatal outcomes. J Matern Fetal Neonatal Med. 2017;30(10):1158–62. doi: 10.1080/14767058.2016.1205032. PMID: 27354114. Exclusion reason: Ineligible study design for key question.27354114
231 Pratt JJ, Khan KS. Non-anaemic iron deficiency - a disease looking for recognition of diagnosis: a systematic review. Eur J Haematol. 2016;96(6):618–28. doi: 10.1111/ejh.12645. PMID: 26256281. Exclusion reason: Ineligible population.26256281
232 Pritchard JA, Hunt CF. A comparison of the hematologic responses following the routine prenatal administration of intramuscular and oral iron. Surg Gynecol Obstet. 1958;106(5):516–8. PMID: 13556464. Exclusion reason: Poor quality.13556464
233 Puolakka J, Janne O, Pakarinen A, . Serum ferritin as a measure of iron stores during and after normal pregnancy with and without iron supplements. Acta Obstet Gynecol Scand Suppl. 1980;95:43–51. doi: 10.3109/00016348009156379. PMID: 6935911. Exclusion reason: Poor quality.6935911
234 Purcell S, Beckmann M. The utility of routine screening for anaemia at 36 weeks gestation. Aust N Z J Obstet Gynaecol. 2022;62(4):610–3. doi: 10.1111/ajo.13495. PMID: 35170017. Exclusion reason: Ineligible intervention.35170017
235 Qassim A, Gergis RG, Jeffries B, . Use of intravenous iron polymaltose in the management of iron deficiency in pregnancy: a retrospective cohort study. Aust N Z J Obstet Gynaecol. 2018;58(2):163–9. doi: 10.1111/ajo.12645. PMID: 28608544. Exclusion reason: Ineligible study design for key question.28608544
236 Qassim A, Mol BW, Grivell RM, . Safety and efficacy of intravenous iron polymaltose, iron sucrose and ferric carboxymaltose in pregnancy: a systematic review. Aust N Z J Obstet Gynaecol. 2018;58(1):22–39. doi: 10.1111/ajo.12695. PMID: 28921558. Exclusion reason: Systematic review used as a source document only to identify individual studies.28921558
237 Qin Y, Gao M, Jiang W, . Maternal iron deficiency does not affect the iron status of fetuses with congenital heart defects: does it affect heart development? Int J Cardiol 2020;306:89. doi: 10.1016/j.ijcard.2020.01.066. PMID: 32276714. Exclusion reason: Not a study.32276714
238 Quezada-Pinedo HG, Cassel F, Duijts L, . Maternal iron status in pregnancy and child health outcomes after birth: a systematic review and meta-analysis. Nutrients. 2021;13(7):2221. doi: 10.3390/nu13072221. PMID: 34203528. Exclusion reason: Systematic review used as a source document only to identify individual studies.34203528
239 Quezada-Pinedo HG, Cassel F, Muckenthaler MU, . Ethnic differences in adverse iron status in early pregnancy: a cross-sectional population-based study. J Nur Sci. 2022;11:e39. doi: 10.1017/jns.2022.35. PMID: 35720171. Exclusion reason: Ineligible intervention.35720171
240 Rabindrakumar MSK, Wickramasinghe VP, Arambepola C, . Baseline iron and low-grade inflammation modulate the effectiveness of iron supplementation: evidence from follow-up of pregnant Sri Lankan women. Eur J Nutr. 2021;60(2):1101–9. doi: 10.1007/s00394-020-02320-2. PMID: 32613329. Exclusion reason: Ineligible comparator.32613329
241 Rafat D, Rabbani TK, Ahmad J, . Influence of iron metabolism indices on HbA1c in non-diabetic pregnant women with and without iron-deficiency anemia: effect of iron supplementation. Diabetes Metab Syndr. 2012;6(2):102–5. doi: 10.1016/j.dsx.2012.05.011. PMID: 23153978. Exclusion reason: Ineligible outcome.23153978
242 Rahmati S, Azami M, Badfar G, . The relationship between maternal anemia during pregnancy with preterm birth: a systematic review and meta-analysis. J Matern Fetal Neonatal Med. 2020;33(15):2679–89. doi: 10.1080/14767058.2018.1555811. PMID: 30522368. Exclusion reason: Ineligible intervention.30522368
243 Rajendran S, Bobby Z, Habeebullah S, . Differences in the response to iron supplementation on oxidative stress, inflammation, and hematological parameters in nonanemic and anemic pregnant women. J Matern Fetal Neonatal Med. 2022;35(3):465–71. doi: 10.1080/14767058.2020.1722996. PMID: 32079433. Exclusion reason: Ineligible comparator.32079433
244 Ramakrishnan U, Gonzalez-Cossio T, Neufeld LM, . Multiple micronutrient supplementation during pregnancy does not lead to greater infant birth size than does iron-only supplementation: a randomized controlled trial in a semirural community in Mexico. Am J Clin Nutr. 2003;77(3):720–5. doi: 10.1093/ajcn/77.3.720. PMID: 12600867. Exclusion reason: Ineligible comparator.12600867
245 Ramakrishnan U, Gonzalez-Cossio T, Neufeld LM, . Effect of prenatal multiple micronutrient supplements on maternal weight and skinfold changes: a randomized double-blind clinical trial in Mexico. Food Nutr Bull. 2005;26(3):273–80. PMID: 16222918. Exclusion reason: Ineligible outcome.16222918
246 Ramakrishnan U, Grant FK, Goldenberg T, . Effect of multiple micronutrient supplementation on pregnancy and infant outcomes: a systematic review. Paediatr Perinat Epidemiol. 2012;26 Suppl 1:153–67. doi: 10.1111/j.1365-3016.2012.01276.x. PMID: 22742608. Exclusion reason: Systematic review used as a source document only to identify individual studies.22742608
247 Ramakrishnan U, Grant FK, Imdad A, . Effect of multiple micronutrient versus iron-folate supplementation during pregnancy on intrauterine growth. Nestle Nutr Inst Workshop Ser. 2013;74:53–62. doi: 10.1159/000348401. PMID: 23887103. Exclusion reason: Ineligible country.23887103
248 Ramakrishnan U, Nguyen PH, Gonzalez-Casanova I, . Neither preconceptional weekly multiple micronutrient nor iron-folic acid supplements affect birth size and gestational age compared with a folic acid supplement alone in rural Vietnamese women: a randomized controlled trial. J Nutr. 2016;146(7):1445S–52S. doi: 10.3945/jn.115.223420. PMID: 27281806. Exclusion reason: Ineligible population.27281806
249 Ramirez JO, Cabrera SAS, Hidalgo H, . Is preeclampsia associated with restless legs syndrome? Sleep Med. 2013;14(9):894–6. doi: 10.1016/j.sleep.2013.03.013. PMID: 23891236. Exclusion reason: Ineligible intervention.23891236
250 Rasmussen KM, Stoltzfus RJ. New evidence that iron supplementation during pregnancy improves birth weight: new scientific questions. Am J Clin Nutr. 2003;78(4):673–4. PMID: 14522723. Exclusion reason: Not a study.14522723
251 Rawal S, Hinkle SN, Bao W, . A longitudinal study of iron status during pregnancy and the risk of gestational diabetes: findings from a prospective, multiracial cohort. Diabetologia. 2017;60(2):249–57. doi: 10.1007/s00125-016-4149-3. PMID: 27830277. Exclusion reason: Ineligible comparator.27830277
252 Ray S, Neogi SB, Singh R, . Is IV iron sucrose a cost-effective option for treatment of severe anaemia in pregnancy as compared with oral iron? Health Policy Plan. 2021;35(10):1339–46. doi: 10.1093/heapol/czaa110. PMID: 33230561. Exclusion reason: Ineligible outcome.33230561
253 Rayman MP, Barlis J, Evans RW, . Abnormal iron parameters in the pregnancy syndrome preeclampsia. Am J Obstet Gynecol. 2002;187(2):412–8. doi: 10.1067/mob.2002.123895. PMID: 12193935. Exclusion reason: Ineligible intervention.12193935
254 Resseguier A-S, Guiguet-Auclair C, Debost-Legrand A, . Prediction of iron deficiency anemia in third trimester of pregnancy based on data in the first trimester: a prospective cohort study in a high-income country. Nutrients. 2022;14(19):4091. doi: 10.3390/nu14194091. PMID: 36235743. Exclusion reason: Ineligible intervention.36235743
255 Reveiz L, Gyte GM, Cuervo LG, . Treatments for iron-deficiency anaemia in pregnancy. Cochrane Database Syst Rev. 2011 (10):CD003094. doi: 10.1002/14651858.CD003094.pub3. PMID: 21975735. Exclusion reason: Systematic review used as a source document only to identify individual studies.21975735
256 Reveiz L, Gyte GML, Cuervo LG. Treatments for iron-deficiency anaemia in pregnancy. Cochrane Database Syst Rev. 2007 (2):CD003094. doi: 10.1002/14651858.CD003094.pub2. PMID: 17443522. Exclusion reason: Systematic review used as a source document only to identify individual studies.17443522
257 Rezgale R, Pudule I, Cauce V, . Iron status in pregnant women in Latvia: an epidemiological, cross-sectional, multicenter study according to WHO and UK criteria. Medicina (Kaunas). 2022;58(7):955. doi: 10.3390/medicina58070955. PMID: 35888674. Exclusion reason: Ineligible study design for key question.35888674
258 Rezk M, Dawood R, Abo-Elnasr M, . Lactoferrin versus ferrous sulphate for the treatment of iron deficiency anemia during pregnancy: a randomized clinical trial. J Matern Fetal Neonatal Med. 2016;29(9):1387–90. doi: 10.3109/14767058.2015.1049149. PMID: 26037728. Exclusion reason: Ineligible population.26037728
259 Ribot B, Aranda N, Giralt M, . Effect of different doses of iron supplementation during pregnancy on maternal and infant health. Ann Hematol. 2013;92(2):221–9. doi: 10.1007/s00277-012-1578-z. PMID: 23053178. Exclusion reason: Ineligible comparator.23053178
260 Ribot B, Aranda N, Viteri F, . Depleted iron stores without anaemia early in pregnancy carries increased risk of lower birthweight even when supplemented daily with moderate iron. Hum Reprod. 2012;27(5):1260–6. doi: 10.1093/humrep/des026. PMID: 22357769. Exclusion reason: Ineligible comparator.22357769
261 Rioux FM B-P J, Leblanc CP, Vigneau F. Relationship between maternal DHA and iron status and infants’ cognitive performance. Can J Diet Pract Res. 2011;72(2):76. doi: 10.3148/72.2.2011.e140. PMID: 21645426. Exclusion reason: Ineligible study design for key question.21645426
262 Risonar MGD, Rayco-Solon P, Tengco LW, . Effectiveness of a redesigned iron supplementation delivery system for pregnant women in Negros Occidental, Philippines. Public Health Nutr. 2009;12(7):932–40. doi: 10.1017/S1368980008003418. PMID: 18752691. Exclusion reason: Ineligible comparator.18752691
263 Rosser J. Iron supplementation in pregnancy. Pract Midwife. 2001;4(1):10–1. PMID: 12026593. Exclusion reason: Systematic review used as a source document only to identify individual studies.12026593
264 Roztocil A, Charvatova M, Harastova L, . [Anti-anemia therapy with prophylactic administration of Fe2+ in normal pregnancy and its effect on prepartum hematologic parameters in the mother and neonate]. Antianemicka lecba fyziologickych tehotnych a jeji vliv na prepartalni hematologicke parametry matky a novorozence profylaktickym podanim Fe2+. 1994;59(3):130–3. PMID: 8081594. Exclusion reason: Not English language.8081594
265 Rukuni R, Knight M, Murphy MF, . Screening for iron deficiency and iron deficiency anaemia in pregnancy: a structured review and gap analysis against UK national screening criteria. BMC Pregnancy Childbirth. 2015;15:269. doi: 10.1186/s12884-015-0679-9. PMID: 26487281. Exclusion reason: Not a study.26487281
266 Rumiris D, Purwosunu Y, Wibowo N, . Lower rate of preeclampsia after antioxidant supplementation in pregnant women with low antioxidant status. Hypertens Pregnancy. 2006;25(3):241–53. doi: 10.1080/10641950600913016. PMID: 17065044. Exclusion reason: Ineligible intervention.17065044
267 Saha L, Pandhi P, Gopalan S, . Comparison of efficacy, tolerability, and cost of iron polymaltose complex with ferrous sulphate in the treatment of iron deficiency anemia in pregnant women. MedGenMed 2007;9(1):1. PMID: 17435611. Exclusion reason: Ineligible intervention.17435611
268 Salvi CCB, Braga MC, Batista Filho M. Diagnostic accuracy of hemoglobin for iron deficiency in pregnancy: disclosing results of a cited clinical trial. Rev Panam Salud Publica. 2014;36(2):110–6. PMID: 25345532. Exclusion reason: Ineligible population.25345532
269 Sanchez-Gonzalez LR, Castro-Melendez SE, Angeles-Torres AC, . Efficacy and safety of adjuvant recombinant human erythropoietin and ferrous sulfate as treatment for iron deficiency anemia during the third trimester of pregnancy. Eur J Obstet Gynecol Reprod Biol. 2016;205:32–6. doi: 10.1016/j.ejogrb.2016.08.004. PMID: 27566219. Exclusion reason: Ineligible comparator27566219
270 Sandstad B, Borch-Iohnsen B, Andersen GM, . Selective iron supplementation based on serum ferritin values early in pregnancy: are the Norwegian recommendations satisfactory? Acta Obstet Gynecol Scand. 2003;82(6):537–42. doi: 10.1034/j.1600-0412.2003.00139.x. PMID: 12780424. Exclusion reason: Ineligible intervention.12780424
271 Santander Ballestin S, Gimenez Campos MI, Ballestin Ballestin J, . Is supplementation with micronutrients still necessary during pregnancy? A review. Nutrients. 2021;13(9):3134. doi: 10.3390/nu13093134. PMID: 34579011. Exclusion reason: Not a study.34579011
272 Santos DCC A-B R, Li M, Bian Y, Sturza J, Richards B, Lozoff B. Timing, duration, and severity of iron deficiency in early development and motor outcomes at 9 months. Eur J Clin Nutr. 2018;72(3):332–41. doi: 10.1038/s41430-017-0015-8. PMID: 29235557. Exclusion reason: Ineligible study design for key question.29235557
273 Saragih ID, Dimog EF, Saragih IS, . Adherence to Iron and Folic Acid Supplementation (IFAS) intake among pregnant women: a systematic review meta-analysis. Midwifery. 2022;104:103185. doi: 10.1016/j.midw.2021.103185. PMID: 34784576. Exclusion reason: Systematic review used as a source document only to identify individual studies.34784576
274 Schoorl M, Schoorl M, van der Gaag D, . Effects of iron supplementation on red blood cell hemoglobin content in pregnancy. Hematol Rep. 2012;4(4):e24. doi: 10.4081/hr.2012.e24. PMID: 23355942. Exclusion reason: Ineligible comparator.23355942
275 Schuz J, Weihkopf T, Kaatsch P. Medication use during pregnancy and the risk of childhood cancer in the offspring. Eur J Pediatr. 2007;166(5):433–41. doi: 10.1007/s00431-006-0401-z. PMID: 17345098. Exclusion reason: Ineligible population.17345098
276 Seu MMV, Mose JC, Panigoro R, . Anemia prevalence after iron supplementation among pregnant women in midwifes practice of primary health care facilities in eastern Indonesia. Anemia. 2019;2019:1413906. doi: 10.1155/2019/1413906. PMID: 31772773. Exclusion reason: Ineligible comparator.31772773
277 Shah PS, Ohlsson A, Knowledge Synthesis Group on Determinants of Low Birth Weight and Preterm Births. Effects of prenatal multimicronutrient supplementation on pregnancy outcomes: a meta-analysis. CMAJ. 2009;180(12):E99–108. doi: 10.1503/cmaj.081777. PMID: 19506270. Exclusion reason: Ineligible country.19506270
278 Shaheen SO, Gissler M, Devereux G, . Maternal iron supplementation in pregnancy and asthma in the offspring: follow-up of a randomised trial in Finland. Eur Respir J. 2020;55(6):1902335. doi: 10.1183/13993003.02335-2019. PMID: 32139461. Exclusion reason: Not a study.32139461
279 Shankar H, Kumar N, Sandhir R, . Differential iron status and trafficking in blood and placenta of anemic and non-anemic primigravida supplemented with daily and weekly iron folic acid tablets. Indian J Clin Biochem. 2016;35(1):43–53. doi: 10.1007/s12291-018-0794-2. PMID: 32071495. Exclusion reason: Ineligible comparator.32071495
280 Shi G, Zhang Z, Ma L, . Association between maternal iron supplementation and newborn birth weight: a quantile regression analysis. Ital J Pediatr. 2021;47(1):133. doi: 10.1186/s13052-021-01084-7. PMID: 34090489. Exclusion reason: Ineligible intervention.34090489
281 Shin HW, Go DY, Lee SW, . Comparative efficacy and safety of intravenous ferric carboxymaltose and iron sucrose for iron deficiency anemia in obstetric and gynecologic patients: a systematic review and meta-analysis. Medicine (Baltimore). 2021;100(20):e24571. doi: 10.1097/MD.0000000000024571. PMID: 34011020. Exclusion reason: Ineligible population.34011020
282 Shinar S, Skornick-Rapaport A, Maslovitz S. Iron supplementation in twin pregnancy - the benefit of doubling the iron dose in iron deficient pregnant women: a randomized controlled trial. Twin Res Hum Genet. 2017;20(5):419–24. doi: 10.1017/thg.2017.43. PMID: 28829001. Exclusion reason: Ineligible population.28829001
283 Shinar S, Skornick-Rapaport A, Maslovitz S. Iron supplementation in singleton pregnancy: is there a benefit to doubling the dose of elemental iron in iron-deficient pregnant women? A randomized controlled trial. J Perinatol. 2017;37(7):782–6. doi: 10.1038/jp.2017.43. PMID: 28383533. Exclusion reason: Ineligible population.28383533
284 Si S, Shen Y, Xin X, . Hemoglobin concentration and iron supplement during pregnancy were associated with an increased risk of gestational diabetes mellitus. J Diabetes. 2021;13(3):211–21. doi: 10.1111/1753-0407.13101. PMID: 32755052. Exclusion reason: Ineligible outcome.32755052
285 Sifakis S, Angelakis E, Papadopoulou E, . The efficacy and tolerability of iron protein succinylate in the treatment of iron-deficiency anemia in pregnancy. Clin Exp Obstet Gynecol. 2005;32(2):117–22. PMID: 16108396. Exclusion reason: Ineligible comparator.16108396
286 Silva Neto LGR, Santos Neto JED, Bueno NB, . Effects of iron supplementation versus dietary iron on the nutritional iron status: systematic review with meta-analysis of randomized controlled trials. Crit Rev Food Sci Nutr. 2019;59(16):2553–61. doi: 10.1080/10408398.2018.1459469. PMID: 29611716. Exclusion reason: Ineligible comparator.29611716
287 Singh U, Sinha nee Mehrotra S, Gupta HP, . Once a week (200 mg) elemental iron: an effective option for prophylaxis in non-anaemic pregnant women. J Indian Med Assoc. 2011;109(9):654–6. PMID: 22480099. Exclusion reason: Ineligible comparator.22480099
288 Skolmowska D, Glabska D, Kolota A, . Effectiveness of dietary interventions in prevention and treatment of iron-deficiency anemia in pregnant women: a systematic review of randomized controlled trials. Nutrients. 2022;14(15):3023. doi: 10.3390/nu14153023. PMID: 35893877. Exclusion reason: Systematic review used as a source document only to identify individual studies.35893877
289 Sloan NL, Jordan E, Winikoff B. Effects of iron supplementation on maternal hematologic status in pregnancy. Am J Public Health. 2002;92(2):288–93. doi: 10.2105/ajph.92.2.288. PMID: 11818308. Exclusion reason: Ineligible outcome.11818308
290 Souza AId, Batista Filho M, Bresani CC, . Adherence and side effects of three ferrous sulfate treatment regimens on anemic pregnant women in clinical trials. Cad Saude Publica. 2009;25(6):1225–33. doi: 10.1590/s0102-311x2009000600005. PMID: 19503953. Exclusion reason: Ineligible comparator.19503953
291 Stoltzfus RJ. Iron deficiency: global prevalence and consequences. Food Nutr Bull. 2003;24(4 Suppl):S99–103. doi: 10.1177/15648265030244S206. PMID: 17016951. Exclusion reason: Not a study.17016951
292 Stoltzfus RJ aD, M.L. Guidelines for the use of iron supplements to prevent and treat iron deficiency anemia. 1998. Exclusion reason: Not a study.
293 Sun M, Gu T, Wu T, . Variation patterns of hemoglobin levels by gestational age during pregnancy: a cross-sectional analysis of a multi-center retrospective cohort study in China. Nutrients. 2023;15(6):1383. doi: 10.3390/nu15061383. PMID: 36986113. Exclusion reason: Not a study.36986113
294 Sun YY, Ma AG, Yang F, . A combination of iron and retinol supplementation benefits iron status, IL-2 level and lymphocyte proliferation in anemic pregnant women. Asia Pac J Clin Nutr. 2010;19(4):513–9. PMID: 21147712. Exclusion reason: Ineligible duration.21147712
295 Svanberg B, Arvidsson B, Norrby A, . Absorption of supplemental iron during pregnancy - a longitudinal study with repeated bone-marrow studies and absorption measurements. Acta Obstet Gynecol Scand Suppl. 1975;48:87–108. doi: 10.3109/00016347509156332. PMID: 1062910. Exclusion reason: Poor quality.1062910
296 Symington EA, Baumgartner J, Malan L, . Maternal iron-deficiency is associated with premature birth and higher birth weight despite routine antenatal iron supplementation in an urban South African setting: the NuPED prospective study. PLoS One. 2019;14(9):e0221299. doi: 10.1371/journal.pone.0221299. PMID: 31479449. Exclusion reason: Ineligible intervention.31479449
297 Tan HS, Guinn NR, Fuller ME, . The association between intravenous iron for antenatal anemia and postnatal depression: a retrospective cohort study. Arch Gynecol Obstet. 2022;306(5):1477–84. doi: 10.1007/s00404-022-06417-3. PMID: 35129661. Exclusion reason: Ineligible population.35129661
298 Taylor DJ, Mallen C, McDougall N, . Effect of iron supplementation on serum ferritin levels during and after pregnancy. BJOG. 1982;89(12):1011–7. doi: 10.1111/j.1471-0528.1982.tb04656.x. PMID: 7171510. Exclusion reason: Poor quality.7171510
299 Tayyem RF, Allehdan SS, Alatrash RM, . Adequacy of nutrients intake among Jordanian pregnant women in comparison to dietary reference intakes. Int J Environ Res Public Health. 2019;16(18):3440. doi: 10.3390/ijerph16183440. PMID: 31533206. Exclusion reason: Ineligible country.31533206
300 Thompson F, Ghanem M, Conway K, . Intravenous iron and vertical HIV transmission: any connection? AIDS. 2014;28(8):1245–6. doi: 10.1097/QAD.0000000000000220. PMID: 24871353. Exclusion reason: Ineligible outcome.24871353
301 Tiongco RE, Arceo E, Clemente B, . Association of maternal iron deficiency anemia with the risk of gestational diabetes mellitus: a meta-analysis. Arch Gynecol Obstet. 2019;299(1):89–95. doi: 10.1007/s00404-018-4932-0. PMID: 30315412. Exclusion reason: Ineligible population.30315412
302 Titaley CR, Dibley MJ, Roberts CL, . Iron and folic acid supplements and reduced early neonatal deaths in Indonesia. Bull World Health Organ. 2010;88(7):500–8. doi: 10.2471/BLT.09.065813. PMID: 20616969. Exclusion reason: Ineligible study design for key question.20616969
303 Tofail F, Persson LA, El Arifeen S, . Effects of prenatal food and micronutrient supplementation on infant development: a randomized trial from the Maternal and Infant Nutrition Interventions, Matlab (MINIMat) study. Am J Clin Nutr. 2008;87(3):704–11. doi: 10.1093/ajcn/87.3.704. PMID: 18326610. Exclusion reason: Ineligible comparator.18326610
304 Tolkien Z, Stecher L, Mander AP, . Ferrous sulfate supplementation causes significant gastrointestinal side-effects in adults: a systematic review and meta-analysis. PLoS One. 2015;10(2):e0117383. doi: 10.1371/journal.pone.0117383. PMID: 25700159. Exclusion reason: Systematic review used as a source document only to identify individual studies.25700159
305 Tran K, McCormack S. Screening and treatment of obstetric anemia: a review of clinical effectiveness, cost-effectiveness, and guidelines. CADTH. 2019. Exclusion reason: Not a study.
306 Tran TD, Fisher J, Hanieh S, . Antenatal iron supplementation regimens for pregnant women in rural Vietnam and subsequent haemoglobin concentration and anaemia among their infants. PLoS One. 2015;10(4):e0125740. doi: 10.1371/journal.pone.0125740. PMID: 25928545. Exclusion reason: Ineligible comparator.25928545
307 Tran TD, Tran T, Simpson JA, . Infant motor development in rural Vietnam and intrauterine exposures to anaemia, iron deficiency and common mental disorders: a prospective community-based study. BMC Pregnancy Childbirth. 2014;14:8. doi: 10.1186/1471-2393-14-8. PMID: 24401012. Exclusion reason: Ineligible intervention.24401012
308 Uta M, Neamtu R, Bernad E, . The influence of nutritional supplementation for iron deficiency anemia on pregnancies associated with SARS-CoV-2 infection. Nutrients. 2022;14(4):836. doi: 10.3390/nu14040836. PMID: 35215486. Exclusion reason: Ineligible intervention.35215486
309 Van Bogaert LJ. Anaemia and pregnancy outcomes in a South African rural population. J Obstet Gynaecol. 2006;26(7):617–9. doi: 10.1080/01443610600902901. PMID: 17071424. Exclusion reason: Ineligible study design for key question.17071424
310 Van Eijk HG, Kroos MJ, Hoogendoorn GA, . Serum ferritin and iron stores during pregnancy. Clin Chim Acta 1978;83(1–2):81–91. doi: 10.1016/0009-8981(78)90210-3. PMID: 620471. Exclusion reason: Poor quality.620471
311 VanderMeulen H, Strauss R, Lin Y, . The contribution of iron deficiency to the risk of peripartum transfusion: a retrospective case control study. BMC Pregnancy Childbirth. 2020;20(1):196. doi: 10.1186/s12884-020-02886-z. PMID: 32252681. Exclusion reason: Ineligible intervention.32252681
312 Vitale SG, Fiore M, La Rosa VL, . Liposomal ferric pyrophosphate and ascorbic acid supplementation in pregnant women with iron deficiency anaemia: haematochemical, obstetric, neonatal and psychological outcomes in a prospective observational study. Int J Food Sci Nutr. 2022;73(2):221–9. doi: 10.1080/09637486.2021.1950129. PMID: 34238093. Exclusion reason: Ineligible comparator.34238093
313 Viteri FE, Casanueva E, Tolentino MC, . Antenatal iron supplements consumed daily produce oxidative stress in contrast to weekly supplementation in Mexican non-anemic women. Reprod Toxicol. 2012;34(1):125–32. doi: 10.1016/j.reprotox.2012.03.010. PMID: 22507748. Exclusion reason: Ineligible comparator.22507748
314 Wang W, Yan H, Zeng L, . No effect of maternal micronutrient supplementation on early childhood growth in rural western China: 30 month follow-up evaluation of a double blind, cluster randomized controlled trial. Eur J Clin Nutr. 2012;66(2):261–8. doi: 10.1038/ejcn.2011.190. PMID: 22085869. Exclusion reason: Ineligible intervention.22085869
315 Wang Z, Fan H-B, Yang W-W, . Correlation between plasma ferritin level and gestational diabetes mellitus and its impact on fetal macrosomia. J Diabetes Investig. 2018;9(6):1354–9. doi: 10.1111/jdi.12836. PMID: 29542249. Exclusion reason: Ineligible intervention.29542249
316 Wassef A, Nguyen QD, St-Andre M. Anaemia and depletion of iron stores as risk factors for postpartum depression: a literature review. J Psychosom Obstet Gynaecol. 2019;40(1):19–28. doi: 10.1080/0167482X.2018.1427725. PMID: 29363366. Exclusion reason: Ineligible intervention.29363366
317 Watson PE, McDonald BW. The association of maternal diet and dietary supplement intake in pregnant New Zealand women with infant birthweight. Eur J Clin Nutr. 2010;64(2):184–93. doi: 10.1038/ejcn.2009.134. PMID: 19920847. Exclusion reason: Ineligible intervention.19920847
318 Weinberg GA, Friis H, Boelaert JR, . Iron status and the severity of HIV infection in pregnant women. Clin Infect Dis. 2001;33(12):2098–100. doi: 10.1086/324363. PMID: 11712103. Exclusion reason: Not a study.11712103
319 Welke L, Koenig MD, Thomson JL, . Iron metabolism in African American women in the second and third trimesters of high-risk pregnancies. J Obstet Gynecol Neonatal Nurs. 2017;46(1):148–58. doi: 10.1016/j.jogn.2016.06.013. PMID: 27836659. Exclusion reason: Ineligible comparator.27836659
320 Wesstrom J. Safety of intravenous iron isomaltoside for iron deficiency and iron deficiency anemia in pregnancy. Arch Gynecol Obstet. 2020;301(5):1127–31. doi: 10.1007/s00404-020-05509-2. PMID: 32270330. Exclusion reason: Ineligible intervention.32270330
321 Wiegersma AM, Dalman C, Lee BK, . Association of prenatal maternal anemia with neurodevelopmental disorders. JAMA Psychiatry. 2019;76(12):1294–304. doi: 10.1001/jamapsychiatry.2019.2309. PMID: 31532497. Exclusion reason: Ineligible intervention.31532497
322 Wise J. Daily iron during pregnancy improves birth weight. BMJ 2013;346:f3997. doi: 10.1136/bmj.f3997. PMID: 23794273. Exclusion reason: Not a study.23794273
323 Wong L, Smith S, Gilstrop M, . Safety and efficacy of rapid (1,000 mg in 1 hr) intravenous iron dextran for treatment of maternal iron deficient anemia of pregnancy. Am J Hematol. 2016;91(6):590–3. doi: 10.1002/ajh.24361. PMID: 26971581. Exclusion reason: Ineligible population.26971581
324 Wu AC, Lesperance L, Bernstein H. Screening for iron deficiency. Pediatr Rev. 2002;23(5):171–8. doi: 10.1542/pir.23-5-171. PMID: 11986493. Exclusion reason: Ineligible population.11986493
325 Xu S, Wang W, Li Q, . Association of maternal longitudinal hemoglobin with small for gestational age during pregnancy: a prospective cohort study. Nutrients. 2022;14(7):1403. doi: 10.3390/nu14071403. PMID: 35406016. Exclusion reason: Ineligible intervention.35406016
326 Yakar B, Pirincci E, Kaya MO, . Prevalence of anemia and associated risk factors among pregnant women, what is the role of antenatal care in prevention? A cross-sectional study. J Coll Physicians Surg Pak. 2021;31(11):1341–5. doi: 10.29271/jcpsp.2021.11.1341. PMID: 34689494. Exclusion reason: Ineligible study design for key question.34689494
327 Yakoob MY, Bhutta ZA. Effect of routine iron supplementation with or without folic acid on anemia during pregnancy. BMC Public Health. 2011;11 Suppl 3:S21. doi: 10.1186/1471-2458-11-S3-S21. PMID: 21501439. Exclusion reason: Systematic review used as a source document only to identify individual studies.21501439
328 Yan M-X, Zhao Y, Zhao D-D, . The association of folic acid, iron nutrition during pregnancy and congenital heart disease in northwestern China: a matched case control study. Nutrients. 2022;14(21):4541. doi: 10.3390/nu14214541. PMID: 36364804. Exclusion reason: Ineligible comparator.36364804
329 Yang J, Cheng Y, Pei L, . Maternal iron intake during pregnancy and birth outcomes: a cross-sectional study in Northwest China. Br J Nutr. 2017;117(6):862–71. doi: 10.1017/S0007114517000691. PMID: 28393737. Exclusion reason: Ineligible intervention.28393737
330 Yin J, Huo J, Sun J, . [Improved effect of comprehensive nutritional intervention of whole covering for Kazak’s pregnant women, lactating women and infants in Altay farming and stockbreeding region]. Wei Sheng Yan Jiu. 2019;48(1):49–55. PMID: 31032767. Exclusion reason: Not English language.31032767
331 Zaim M, Piselli L, Fioravanti P, . Efficacy and tolerability of a prolonged release ferrous sulphate formulation in iron deficiency anaemia: a non-inferiority controlled trial. Eur J Nutr. 2012;51(2):221–9. doi: 10.1007/s00394-011-0210-7. PMID: 21643774. Exclusion reason: Ineligible population.21643774
332 Zavaleta N, Caulfield LE, Garcia T. Changes in iron status during pregnancy in Peruvian women receiving prenatal iron and folic acid supplements with or without zinc. Am J Clin Nutr. 2000;71(4):956–61. doi: 10.1093/ajcn/71.4.956. PMID: 10731503. Exclusion reason: Ineligible intervention.10731503
333 Zec M, Roje D, Matovinovic M, . Vitamin B12 supplementation in addition to folic acid and iron improves hematological and biochemical markers in pregnancy: a randomized controlled trial. J Med Food. 2020;23(10):1054–9. doi: 10.1089/jmf.2019.0233. PMID: 32302504. Exclusion reason: Ineligible comparator.32302504
334 Zein S, Rachidi S, Awada S, . High iron level in early pregnancy increased glucose intolerance. J Trace Elem Med Biol. 2015;30:220–5. doi: 10.1016/j.jtemb.2014.09.004. PMID: 25441227. Exclusion reason: Ineligible intervention.25441227
335 Zein S, Rachidi Ss, Shami N, . Association between iron level, glucose impairment and increased DNA damage during pregnancy. J Trace Elem Med Biol. 2017;43:52–7. doi: 10.1016/j.jtemb.2016.11.006. PMID: 27916501. Exclusion reason: Ineligible intervention.27916501
336 Zeng L, Yan H, Cheng Y, . Adherence and costs of micronutrient supplementation in pregnancy in a double-blind, randomized, controlled trial in rural western China. Food Nutr Bull. 2009;30(4 Suppl):S480–7. doi: 10.1177/15648265090304S402. PMID: 20120789. Exclusion reason: Ineligible outcome.20120789
337 Zeng L, Yan H, Cheng Y, . Modifying effects of maternal nutrition status on the response to multiple micronutrients supplementation on preterm and neonatal mortality in China. Ann Nutr Metab. 2013;63:859. doi: 10.1159/000354245. PMID: 24051500. Exclusion reason: E824051500
338 Zhang R, Li C, Mi B, . The different effects of prenatal nutrient supplementation on neonatal birth weights between urban and rural areas of northwest China: a crosssectional study. Asia Pac J Clin Nutr. 2018;27(4):875–85. doi: 10.6133/apjcn.102017.01. PMID: 30045434. Exclusion reason: Ineligible intervention.30045434
339 Zhang X, Wu M, Zhong C, . Association between maternal plasma ferritin concentration, iron supplement use, and the risk of gestational diabetes: a prospective cohort study. Am J Clin Nutr. 2021;114(3):1100–6. doi: 10.1093/ajcn/nqab162. PMID: 34019623. Exclusion reason: Ineligible comparator.34019623
340 Zhang Y, Huang X, Chen Z, . Iron deficiency, a risk factor for thyroid autoimmunity during second trimester of pregnancy in China. Endocr Pract. 2020;26(6):595–603. doi: 10.4158/EP-2019-0220. PMID: 31968188. Exclusion reason: Ineligible intervention.31968188
341 Zhang Y, Li Z, Li H, . Maternal haemoglobin concentration and risk of preterm birth in a Chinese population. J Obstet Gynaecol. 2018;38(1):32–7. doi: 10.1080/01443615.2017.1325454. PMID: 28741390. Exclusion reason: Ineligible population.28741390
342 Zhang Y, Lv Y, Sun Y, . The efficiency and safety of Shengxuening tablet on treating and preventing iron deficiency anemia: a systematic review and meta-analysis. Front Pharmacol. 2022;13:1029641. doi: 10.3389/fphar.2022.1029641. PMID: 36408243. Exclusion reason: Ineligible intervention.36408243
343 Zhang Y, Xu S, Zhong C, . Periconceptional iron supplementation and risk of gestational diabetes mellitus: a prospective cohort study. Diabetes Res Clin Pract. 2021;176:108853. doi: 10.1016/j.diabres.2021.108853. PMID: 33961900. Exclusion reason: Ineligible intervention.33961900
344 Zhao G, Xu G, Zhou M, . Prenatal iron supplementation improves maternal but not neonatal iron status: a randomized clinical trial in rural China. Pediatric academic societies (PAS) annual meeting. 2015. Exclusion reason: Not a study.
345 Zhao L, Lian J, Tian J, . Dietary intake of heme iron and body iron status are associated with the risk of gestational diabetes mellitus: a systematic review and meta-analysis. Asia Pac J Clin Nutr. 2017;26(6):1092–106. doi: 10.6133/apjcn.022017.09. PMID: 28917236. Exclusion reason: Systematic review used as a source document only to identify individual studies.28917236
346 Zhou LM, Yang WW, Hua JZ, . Relation of hemoglobin measured at different times in pregnancy to preterm birth and low birth weight in Shanghai, China. Am J Epidemiol. 1998;148(10):998–1006. doi: 10.1093/oxfordjournals.aje.a009577. PMID: 9829872. Exclusion reason: Ineligible comparator.9829872
347 Zhou SJ, Gibson RA, Crowther CA, . Should we lower the dose of iron when treating anaemia in pregnancy? A randomized dose-response trial. Eur J Clin Nutr. 2009;63(2):183–90. doi: 10.1038/sj.ejcn.1602926. PMID: 17928802. Exclusion reason: Ineligible comparator.17928802
348 Zhu B, Liang C, Xia X, . Iron-related factors in early pregnancy and subsequent risk of gestational diabetes mellitus: the Ma’anshan Birth Cohort (MABC) study. Biol Trace Elem Res. 2019;191(1):45–53. doi: 10.1007/s12011-018-1595-4. PMID: 30515713. Exclusion reason: Ineligible intervention.30515713

## Appendix A6 U.S. Preventive Services Task Force Quality Assessment Criteria

### Randomized, Controlled Trials and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  ○ For randomized, controlled trials (RCTs): adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs

Definition of ratings based on above criteria:

Good: Meets all criteria: comparable groups are assembled initially and maintained throughout the study (followup greater than or equal to 80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
Poor: Studies are graded “poor” if any of the following fatal flaws exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Source: U.S. Preventive Services Task Force. Procedure Manual. Appendix VI. Criteria for Assessing Internal Validity of Individual Studies. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual/procedure-manual-appendix-vi-criteria-assessing-internal-validity-individual-studies

## Appendix A7 Expert Reviewers of the Draft Report

Jeanne Conry, MD, PhD, President, International Federation of Gynecology and Obstetrics; President, Environmental Health Leadership Foundation; Chair, U.S. Women’s Preventive Services Initiative

Anjali Kaimal, MD, MAS, Chair of the American Congress of Obstetricians and Gynecologists committee on obstetric clinical practice guidelines; Chief, Division of Maternal-Fetal Medicine; Director, Deborah Kelly Center for Clinical Research in Obstetrics and Gynecology; Obstetrical Director, Multidisciplinary Fetal Care Group

Robert Means, MD, Professor, Department of Internal Medicine, Quillen College of Medicine, East Tennessee State University

Kimberly O’Brien, PhD, Professor, Division of Nutritional Sciences, College of Human Ecology, Cornell University, Ithaca, NY

Federal Partner Reviewers

- National Institute on Minority Health and Health Disparities - 2 reviewers
- Office of Research on Women’s Health - 1 reviewer