# References

1 Curry SJ, Krist AH, Owens DK, . Screening for osteoporosis to prevent fractures: US Preventive Services Task Force recommendation statement. Jama. 2018 Jun 26;319(24):2521–31. doi: 10.1001/jama.2018.7498. PMID: 29946735.29946735
2 U.S. Preventive Services Task Force. Screening for osteoporosis: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2011 Mar 1;154(5):356–64. doi: 10.7326/0003-4819-154-5-201103010-00307. PMID: 21242341.21242341
3 Viswanathan M, Reddy S, Berkman N, . Screening to prevent osteoporotic fractures: an evidence review for the U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Report No.: 15-05226-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; June. 2018.
4 Consensus development conference: diagnosis, prophylaxis, and treatment of osteoporosis. Am J Med. 1993 Jun;94(6):646–50. doi: 10.1016/0002-9343(93)90218-e. PMID: 8506892.8506892
5 Kanis JA, Melton LJ, 3rd, Christiansen C, . The diagnosis of osteoporosis. Journal of Bone & Mineral Research. 1994 Aug;9(8):1137–41. doi: 10.1002/jbmr.5650090802. PMID: 7976495.7976495
6 Kanis JA. Assessment of fracture risk and its application to screening for postmenopausal osteoporosis: synopsis of a WHO report. Osteoporosis international. 1994;4(6):368–81.7696835
7 Looker AC, Wahner HW, Dunn WL, . Updated data on proximal femur bone mineral levels of US adults. Osteoporos Int. 1998;8(5):468–89. doi: 10.1007/s001980050093. PMID: 9850356.9850356
8 Binkley N, Adler R, Bilezikian JP. Osteoporosis diagnosis in men: the T-score controversy revisited. Curr Osteoporos Rep. 2014 Dec;12(4):403–9. doi: 10.1007/s11914-014-0242-z. PMID: 25255867.25255867
9 De Laet CE, van Hout BA, Burger H, . Bone density and risk of hip fracture in men and women: cross sectional analysis. BMJ. 1997 Jul 26;315(7102):221–5. doi: 10.1136/bmj.315.7102.221. PMID: 9253270.9253270
10 Alswat KA. Gender disparities in osteoporosis. J Clin Med Res. 2017 May;9(5):382–7. doi: 10.14740/jocmr2970w. PMID: 28392857.28392857
11 International Society for Clinical Densitometry. Adult positions. Indications for bone mineral density (BMD) testing. Middletown, CT: International Society for Clinical Densitometry, Inc.; 2019. http://www.iscd.org/official-positions/2015-iscd-official-positions-adult/ Accessed 20 May 2021.
12 Kanis JA, World Health Organization Scientific Group. Assessment of osteoporosis at the primary health care level. Technical report. Sheffield, United Kingdom: World Health Organization Collaborating Centre for Metabolic Bone Diseases; 2008.
13 Schuit SC, van der Klift M, Weel AE, . Fracture incidence and association with bone mineral density in elderly men and women: the Rotterdam Study. Bone. 2004 Jan;34(1):195–202. PMID: 14751578.14751578
14 Siris ES, Chen YT, Abbott TA, . Bone mineral density thresholds for pharmacological intervention to prevent fractures. Arch Intern Med. 2004 May 24;164(10):1108–12. doi: 10.1001/archinte.164.10.1108. PMID: 15159268.15159268
15 Trajanoska K, Schoufour JD, de Jonge EAL, . Fracture incidence and secular trends between 1989 and 2013 in a population based cohort: the Rotterdam Study. Bone. 2018 Sep;114:116–24. doi: 10.1016/j.bone.2018.06.004. PMID: 29885926.29885926
16 Sornay-Rendu E, Munoz F, Garnero P, . Identification of osteopenic women at high risk of fracture: the OFELY study. Journal of Bone & Mineral Research. 2005 Oct;20(10):1813–9. doi: 10.1359/jbmr.050609. PMID: 16160738.16160738
17 Lyritis G, Rizou S. A revision in the definition of osteoporosis. J Frailty Sarcopenia Falls. 2016;1(1):01–3. doi: 10.22540/jfsf-01-001.
18 National Institute for Health and Care Excellence. Osteoporosis overview. National Institute for Health and Care Excellence. London, England. 2020. https://www.ncbi.nlm.nih.gov/books/NBK554920/bin/nicecg146guid_pathway1.pdf
19 Siris ES, Adler R, Bilezikian J, . The clinical diagnosis of osteoporosis: a position statement from the National Bone Health Alliance Working Group. Osteoporos Int. 2014 May;25(5):1439–43. doi: 10.1007/s00198-014-2655-z. PMID: 24577348.24577348
20 Kanis JA, McCloskey EV, Harvey NC, . The need to distinguish intervention thresholds and diagnostic thresholds in the management of osteoporosis. Osteoporos Int. 2022 Oct 25. doi: 10.1007/s00198-022-06567-9. PMID: 36282342.36282342
21 Sarafrazi N, Wambogo EA, Shepherd JA. Osteoporosis or low bone mass in older adults: United States, 2017–2018. NCHS Data Brief, no. 45. National Center for Health Statistics. Hyattsville, MD. 2021.
22 QuickStats: percentage* of adults aged ≥50 years with osteoporosis,(†) by race and hispanic origin(§) - United States, 2017-2018. MMWR: Morbidity & Mortality Weekly Report. 2021 May 14;70(19):731. doi: 10.15585/mmwr.mm7019a5. PMID: 33983912.33983912
23 Nazrun AS, Tzar MN, Mokhtar SA, Mohamed IN. A systematic review of the outcomes of osteoporotic fracture patients after hospital discharge: morbidity, subsequent fractures, and mortality. Therapeutics & Clinical Risk Management. 2014;10:937–48. doi: 10.2147/TCRM.S72456. PMID: 25429224.25429224
24 Andrich S, Haastert B, Neuhaus E, . Excess mortality after pelvic fractures among older people. Journal of Bone & Mineral Research. 2017 Sep;32(9):1789–801. doi: 10.1002/jbmr.3116. PMID: 28272751.28272751
25 Hodsman AB, Leslie WD, Tsang JF, Gamble GD. 10-year probability of recurrent fractures following wrist and other osteoporotic fractures in a large clinical cohort: an analysis from the Manitoba Bone Density Program. Arch Intern Med. 2008 Nov 10;168(20):2261–7. doi: 10.1001/archinte.168.20.2261. PMID: 19001204.19001204
26 Hsiao PC, Chen TJ, Li CY, . Risk factors and incidence of repeat osteoporotic fractures among the elderly in Taiwan: a population-based cohort study. Medicine (Baltimore). 2015 Feb;94(7):e532. doi: 10.1097/MD.0000000000000532. PMID: 25700317.25700317
27 Kanis JA, Johansson H, Oden A, . Characteristics of recurrent fractures. Osteoporos Int. 2018 Aug;29(8):1747–57. doi: 10.1007/s00198-018-4502-0. PMID: 29947869.29947869
28 Dyer SM, Crotty M, Fairhall N, . A critical review of the long-term disability outcomes following hip fracture. BMC Geriatr. 2016 Sep 2;16:158. doi: 10.1186/s12877-016-0332-0. PMID: 27590604.27590604
29 Old JL, Calvert M. Vertebral compression fractures in the elderly. Am Fam Physician. 2004 Jan 1;69(1):111–6. PMID: 14727827.14727827
30 Schousboe JT. Mortality after osteoporotic fractures: what proportion is caused by fracture and is preventable? Journal of Bone & Mineral Research. 2017 Sep;32(9):1783–8. doi: 10.1002/jbmr.3216. PMID: 28691759.28691759
31 Kanis JA, Oden A, Johnell O, . The components of excess mortality after hip fracture. Bone. 2003 May;32(5):468–73. doi: 10.1016/s8756-3282(03)00061-9. PMID: 12753862.12753862
32 Bliuc D, Nguyen ND, Milch VE, . Mortality risk associated with low-trauma osteoporotic fracture and subsequent fracture in men and women. JAMA. 2009 Feb 4;301(5):513–21. doi: 10.1001/jama.2009.50. PMID: 19190316.19190316
33 Center JR, Nguyen TV, Schneider D, . Mortality after all major types of osteoporotic fracture in men and women: an observational study. Lancet. 1999 Mar 13;353(9156):878–82. doi: 10.1016/s0140-6736(98)09075-8. PMID: 10093980.10093980
34 Kannegaard PN, van der Mark S, Eiken P, Abrahamsen B. Excess mortality in men compared with women following a hip fracture. National analysis of comedications, comorbidity and survival. Age & Ageing. 2010 Mar;39(2):203–9. doi: 10.1093/ageing/afp221. PMID: 20075035.20075035
35 Lewiecki EM, Chastek B, Sundquist K, . Osteoporotic fracture trends in a population of US managed care enrollees from 2007 to 2017. Osteoporos Int. 2020 Jul;31(7):1299–304. doi: 10.1007/s00198-020-05334-y. PMID: 32062687.32062687
36 Tran T, Bliuc D, van Geel T, . Population-wide impact of non-hip non-vertebral fractures on mortality. Journal of Bone & Mineral Research. 2017 Sep;32(9):1802–10. doi: 10.1002/jbmr.3118. PMID: 28256011.28256011
37 Veronese N, Kolk H, Maggi S. Epidemiology of fragility fractures and social impact. In: Falaschi P, Marsh D, eds. Orthogeriatrics: the management of older patients with fragility fractures. Cham (CH): Springer; 2021:19–34.
38 Wu F, Laslett LL, Wills K, . Effects of individualized bone density feedback and educational interventions on osteoporosis knowledge and self-efficacy: a 12-yr prospective study. J Clin Densitom. 2014 Oct–Dec;17(4):466–72. doi: 10.1016/j.jocd.2014.07.008. PMID: 25220886.25220886
39 Brauer CA, Coca-Perraillon M, Cutler DM, Rosen AB. Incidence and mortality of hip fractures in the United States. JAMA. 2009 Oct 14;302(14):1573–9. doi: 10.1001/jama.2009.1462. PMID: 19826027.19826027
40 Lewiecki EM, Wright NC, Curtis JR, . Hip fracture trends in the United States, 2002 to 2015. Osteoporos Int. 2018 Mar;29(3):717–22. doi: 10.1007/s00198-017-4345-0. PMID: 29282482.29282482
41 Cranney A, Jamal SA, Tsang JF, . Low bone mineral density and fracture burden in postmenopausal women. CMAJ. 2007 Sep 11;177(6):575–80. doi: 10.1503/cmaj.070234. PMID: 17846439.17846439
42 Pasco JA, Seeman E, Henry MJ, . The population burden of fractures originates in women with osteopenia, not osteoporosis. Osteoporos Int. 2006;17(9):1404–9. doi: 10.1007/s00198-006-0135-9. PMID: 16699736.16699736
43 Stone KL, Seeley DG, Lui LY, . BMD at multiple sites and risk of fracture of multiple types: long-term results from the Study of Osteoporotic Fractures. Journal of Bone & Mineral Research. 2003 Nov;18(11):1947–54. doi: 10.1359/jbmr.2003.18.11.1947. PMID: 14606506.14606506
44 Wainwright SA, Marshall LM, Ensrud KE, . Hip fracture in women without osteoporosis. Journal of Clinical Endocrinology & Metabolism. 2005 May;90(5):2787–93. doi: 10.1210/jc.2004-1568. PMID: 15728213.15728213
45 Sanders KM, Nicholson GC, Watts JJ, . Half the burden of fragility fractures in the community occur in women without osteoporosis. When is fracture prevention cost-effective? Bone. 2006 May;38(5):694–700. doi: 10.1016/j.bone.2005.06.004. PMID: 16507356.16507356
46 Sobh MM, Abdalbary M, Elnagar S, . Secondary osteoporosis and metabolic bone diseases. J Clin Med. 2022 Apr 24;11(9):2382. doi: 10.3390/jcm11092382. PMID: 35566509.35566509
47 Fitzpatrick LA. Secondary causes of osteoporosis. Mayo Clin Proc. 2002 May;77(5):453–68. doi: 10.4065/77.5.453. PMID: 12004995.12004995
48 Sowers MR, Zheng H, Greendale GA, . Changes in bone resorption across the menopause transition: effects of reproductive hormones, body size, and ethnicity. Journal of Clinical Endocrinology & Metabolism. 2013 Jul;98(7):2854–63. doi: 10.1210/jc.2012-4113. PMID: 23666961.23666961
49 Kanis JA, Johnell O, Oden A, . Ten year probabilities of osteoporotic fractures according to BMD and diagnostic thresholds. Osteoporos Int. 2001 Dec;12(12):989–95. doi: 10.1007/s001980170006 [doi]. PMID: 11846333.11846333
50 Heaney RP. Bone mass, bone loss, and osteoporosis prophylaxis. Ann Intern Med. 1998 Feb 15;128(4):313–4. PMID: 9471936.9471936
51 Richelson LS, Wahner HW, Melton LJ, 3rd, Riggs BL. Relative contributions of aging and estrogen deficiency to postmenopausal bone loss. N Engl J Med. 1984 Nov 15;311(20):1273–5. doi: 10.1056/NEJM198411153112002. PMID: 6493283.6493283
52 Cummings SR, Nevitt MC, Browner WS, . Risk factors for hip fracture in white women. Study of Osteoporotic Fractures Research Group. N Engl J Med. 1995 Mar 23;332(12):767–73. doi: 10.1056/nejm199503233321202. PMID: 7862179.7862179
53 Poiana C, Capatina C. Osteoporosis and fracture risk in patients with type 2 diabetes mellitus. Acta Endocrinol (Buchar). 2019 Apr–Jun;15(2):231–6. doi: 10.4183/aeb.2019.231. PMID: 31508182.31508182
54 Davie GS, Pal K, Orton E, . Incident Type 2 Diabetes and Risk of Fracture: A Comparative Cohort Analysis Using U.K. Primary Care Records. Diabetes Care. 2021 Jan;44(1):58–66. doi: 10.2337/dc20-1220. PMID: 33148635.33148635
55 Axelsson KF, Litsne H, Kousoula K, . Risk of fracture in adults with type 2 diabetes in Sweden: A national cohort study. PLoS Med. 2023 Jan;20(1):e1004172. doi: 10.1371/journal.pmed.1004172. PMID: 36701363.36701363
56 Drake MT, Murad MH, Mauck KF, . Clinical review. Risk factors for low bone mass-related fractures in men: a systematic review and meta-analysis. Journal of Clinical Endocrinology & Metabolism. 2012 Jun;97(6):1861–70. doi: 10.1210/jc.2011-3058. PMID: 22466344.22466344
57 Liu LH, Chandra M, Gonzalez JR, Lo JC. Racial and ethnic differences in hip fracture outcomes in men. Am J Manag Care. 2017 2017/09;23(9):560–4.29087156
58 Lo JC, Zheng P, Grimsrud CD, . Racial/ethnic differences in hip and diaphyseal femur fractures. Osteoporos Int. 2014 2014/09;25(9):2313–8. doi: 10.1007/s00198-014-2750-1.24964891
59 Hansen D, Pelizzari PM, Pyenson BS. Medicare cost of osteoporotic fractures: 2021 updated report.
60 Lo JC, Chandra M, Lee C, . Bone mineral density in older U.S. Filipino, Chinese, Japanese, and White women. J Am Geriatr Soc. 2020 2020;68(11):2656–61. doi: 10.1111/jgs.16785.33047307
61 Donovan Walker M, Babbar R, Opotowsky AR, . A referent bone mineral density database for Chinese American women. Osteoporos Int. 2006 2006/05/11;17(6):878–87. doi: 10.1007/s00198-005-0059-9.16538554
62 Lo JC, Kim S, Chandra M, Ettinger B. Applying ethnic-specific bone mineral density T-scores to Chinese women in the USA. Osteoporos Int. 2016 Dec;27(12):3477–84. doi: 10.1007/s00198-016-3673-9. PMID: 27468900.27468900
63 Ward RJ, Roberts CC, Bencardino JT, . ACR Appropriateness Criteria(®) osteoporosis and bone mineral density. J Am Coll Radiol. 2017 May;14(5s):S189–s202. doi: 10.1016/j.jacr.2017.02.018. PMID: 28473075.28473075
64 Nelson HD, Haney EM, Chou R, . Screening for osteoporosis. systematic review to update the 2002 U.S. Preventive Services Task Force Recommendation. Evidence Synthesis No. 77. Report No.: 10-05145-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; July. 2010.
65 Kanis JA. Diagnosis of osteoporosis and assessment of fracture risk. Lancet. 2002 Jun 1;359(9321):1929–36. doi: 10.1016/s0140-6736(02)08761-5. PMID: 12057569.12057569
66 Cummings SR, Black D. Bone mass measurements and risk of fracture in Caucasian women: a review of findings from prospective studies. Am J Med. 1995 Feb 27;98(2A):24S–8S. doi: 10.1016/s0002-9343(05)80041-5. PMID: 7709929.7709929
67 Eastell R, Wahner HW, O’Fallon WM, . Unequal decrease in bone density of lumbar spine and ultradistal radius in Colles’ and vertebral fracture syndromes. J Clin Invest. 1989 Jan;83(1):168–74. doi: 10.1172/JCI113854. PMID: 2910906.2910906
68 Melton LJ, 3rd, Atkinson EJ, O’Fallon WM, . Long-term fracture prediction by bone mineral assessed at different skeletal sites. Journal of Bone & Mineral Research. 1993 Oct;8(10):1227–33. doi: 10.1002/jbmr.5650081010. PMID: 8256660.8256660
69 Fuggle NR, Curtis EM, Ward KA, . Fracture prediction, imaging and screening in osteoporosis. Nat Rev Endocrinol. 2019 Sep;15(9):535–47. doi: 10.1038/s41574-019-0220-8. PMID: 31189982.31189982
70 Viswanathan M, Reddy S, Berkman N, . Screening to prevent osteoporotic fractures: updated evidence report and systematic review for the US Preventive Services Task Force. Jama. 2018 Jun 26;319(24):2532–51. doi: 10.1001/jama.2018.6537. PMID: 29946734.29946734
71 Kanis JA, Oden A, Johnell O, . The use of clinical risk factors enhances the performance of BMD in the prediction of hip and osteoporotic fractures in men and women. Osteoporos Int. 2007 Aug;18(8):1033–46. doi: 10.1007/s00198-007-0343-y. PMID: 17323110.17323110
72 Ettinger B, Liu H, Blackwell T, . Validation of FRC, a fracture risk assessment tool, in a cohort of older men: the Osteoporotic Fractures in Men (MrOS) Study. J Clin Densitom. 2012 Jul–Sep;15(3):334–42. doi: 10.1016/j.jocd.2012.01.011. PMID: 22445858.22445858
73 Lo JC, Pressman AR, Chandra M, Ettinger B. Fracture risk tool validation in an integrated healthcare delivery system. Am J Manag Care. 2011 Mar;17(3):188–94. [pii]. PMID: 21504255.21504255
74 Nguyen ND, Frost SA, Center JR, . Development of prognostic nomograms for individualizing 5-year and 10-year fracture risks. Osteoporos Int. 2008 Oct;19(10):1431–44. doi: 10.1007/s00198-008-0588-0. PMID: 18324342.18324342
75 Nguyen ND, Frost SA, Center JR, . Development of a nomogram for individualizing hip fracture risk in men and women. Osteoporos Int. 2007 Aug;18(8):1109–17. doi: 10.1007/s00198-007-0362-8. PMID: 17370100.17370100
76 Lydick E, Cook K, Turpin J, . Development and validation of a simple questionnaire to facilitate identification of women likely to have low bone density. Am J Manag Care. 1998 Jan;4(1):37–48. PMID: 10179905.10179905
77 Kanis JA, Harvey NC, Johansson H, . Overview of fracture prediction tools. J Clin Densitom. 2017 Jul–Sep;20(3):444–50. doi: 10.1016/j.jocd.2017.06.013. PMID: 28716500.28716500
78 FRAX. FRAX® fracture risk assessment tool. Charts to download. UK: University of Sheffield; 2008. https://www.sheffield.ac.uk/FRAX/charts.aspx. Accessed 19 May 2021.
79 Lewiecki EM, Erb SF. Racial disparities and inequalities in the management of patients with osteoporosis. Orthop Nurs. 2022 Mar–Apr 01;41(2):125–34. doi: 10.1097/NOR.0000000000000832. PMID: 35358132.35358132
80 Dawson-Hughes B, Tosteson AN, Melton LJ, 3rd, . Implications of absolute fracture risk assessment for osteoporosis practice guidelines in the USA. Osteoporos Int. 2008 Apr;19(4):449–58. doi: 10.1007/s00198-008-0559-5. PMID: 18292975.18292975
81 Vyas DA, Eisenstein LG, Jones DS. Hidden in plain sight—reconsidering the use of race correction in clinical algorithms. N Engl J Med. 2020 Aug 27;383(9):874–82. doi: 10.1056/NEJMms2004740. PMID: 32853499.32853499
82 Simpson EL, Martyn-St James M, Hamilton J, . Clinical effectiveness of denosumab, raloxifene, romosozumab, and teriparatide for the prevention of osteoporotic fragility fractures: a systematic review and network meta-analysis. Bone. 2020 Jan;130:115081. doi: 10.1016/j.bone.2019.115081. PMID: 31626995.31626995
83 Barrionuevo P, Kapoor E, Asi N, . Efficacy of pharmacological therapies for the prevention of fractures in postmenopausal women: a network meta-analysis. Journal of Clinical Endocrinology & Metabolism. 2019 May 1;104(5):1623–30. doi: 10.1210/jc.2019-00192. PMID: 30907957.30907957
84 LeBoff MS, Greenspan SL, Insogna KL, . The clinician’s guide to prevention and treatment of osteoporosis. Osteoporos Int. 2022 Oct;33(10):2049–102. doi: 10.1007/s00198-021-05900-y. PMID: 35478046.35478046
85 Tosteson AN, Melton LJ, 3rd, Dawson-Hughes B, . Cost-effective osteoporosis treatment thresholds: the United States perspective. Osteoporos Int. 2008 Apr;19(4):437–47. doi: 10.1007/s00198-007-0550-6. PMID: 18292976.18292976
86 Dawson-Hughes B, Looker AC, Tosteson AN, . The potential impact of the National Osteoporosis Foundation guidance on treatment eligibility in the USA: an update in NHANES 2005-2008. Osteoporos Int. 2012 Mar;23(3):811–20. doi: 10.1007/s00198-011-1694-y. PMID: 21717247.21717247
87 Dawson-Hughes B, Looker AC, Tosteson AN, . The potential impact of new National Osteoporosis Foundation guidance on treatment patterns. Osteoporos Int. 2010 Jan;21(1):41–52. doi: 10.1007/s00198-009-1034-7. PMID: 19705046.19705046
88 Kanis JA, Harvey NC, Cooper C, . A systematic review of intervention thresholds based on FRAX: a report prepared for the National Osteoporosis Guideline Group and the International Osteoporosis Foundation. Arch Osteoporos. 2016 Dec;11(1):25. doi: 10.1007/s11657-016-0278-z. PMID: 27465509.27465509
89 Kanis JA, Harvey NC, Johansson H, . FRAX update. J Clin Densitom. 2017 Jul – Sep;20(3):360–7. doi: 10.1016/j.jocd.2017.06.022. PMID: 28732576.28732576
90 Thériault G, Limburg H, Klarenbach S, . Recommendations on screening for primary prevention of fragility fractures. CMAJ. 2023 May 8;195(18):e639–e49. doi: 10.1503/cmaj.221219. PMID: 37156553.37156553
91 Camacho PM, Petak SM, Binkley N, . American Association of Clinical Endocrinologists/American College of Endocrinology clinical practice guidelines for the diagnosis and treatment of postmenopausal osteoporosis—2020 update. Endocr Pract. 2020 May;26(Suppl 1):1–46. doi: 10.4158/gl-2020-0524suppl. PMID: 32427503.32427503
92 French S, Choden S, Schmajuk G. Quality measures and quality improvement initiatives in osteoporosis—an update. Curr Osteoporos Rep. 2019 Dec;17(6):491–509. doi: 10.1007/s11914-019-00547-5. PMID: 31782030.31782030
93 National Committee for Quality Assurance. 2015 state of health care quality table of contents. Washington, DC: National Committee for Quality Assurance; 2015. http://www.ncqa.org/report-cards/health-plans/state-of-health-care-quality/2015-table-of-contents/osteoporosis. Accessed 10 Aug 2016.
94 Centers for Medicare & Medicaid Services. Measures inventory tool. Screening for osteoporosis for women aged 65-85 years of age. Baltimore, MD: Centers for Medicare & Medicaid Services; n.d. https://mdinteractive.com/mips_quality_measure/2022-mips-quality-measure-03920 May 2021.
95 Curtis JR, Sharma P, Arora T, . Physicians’ explanations for apparent gaps in the quality of rheumatology care: results from the US Medicare Physician Quality Reporting System. Arthritis Care Res (Hoboken). 2013 Feb;65(2):235–43. doi: 10.1002/acr.21713. PMID: 22556118.22556118
96 Amarnath AL, Franks P, Robbins JA, . Underuse and overuse of osteoporosis screening in a regional health system: a retrospective cohort study. J Gen Intern Med. 2015 Dec;30(12):1733–40. doi: 10.1007/s11606-015-3349-8. PMID: 25986135.25986135
97 Curtis JR, McClure LA, Delzell E, . Population-based fracture risk assessment and osteoporosis treatment disparities by race and gender. J Gen Intern Med. 2009 Aug;24(8):956–62. doi: 10.1007/s11606-009-1031-8. PMID: 19551449.19551449
98 Choosing Wisely. Bone-density tests. Philadelphia, PA ABIM Foundation; 2016. https://www.choosingwisely.org/patient-resources/bone-density-tests/. Accessed 9 Dec 2022.
99 Good Stewardship Working Group. The “top 5” lists in primary care: meeting the responsibility of professionalism. Arch Intern Med. 2011 Aug 08;171(15):1385–90. doi: 10.1001/archinternmed.2011.231. PMID: 21606090.21606090
100 Centers for Medicare & Medicaid Services. Measures inventory tool. Appropriate use of DXA scans in women under 65 years who do not meet the risk factor profile for osteoporotic fracture (eCQM). Baltimore, MD: Centers for Medicare & Medicaid Services; n.d. https://mdinteractive.com/mips_quality_measure/2022-mips-quality-measure-039. Accessed 20 May 2021.
101 Kale MS, Bishop TF, Federman AD, Keyhani S. “Top 5” lists top $5 billion. Arch Intern Med. 2011 Nov 14;171(20):1856–8. doi: 10.1001/archinternmed.2011.501. PMID: 21965814.21965814
102 Reynolds K, Muntner P, Cheetham TC, . Primary non-adherence to bisphosphonates in an integrated healthcare setting. Osteoporos Int. 2013 Sep;24(9):2509–17. doi: 10.1007/s00198-013-2326-5. PMID: 23595561.23595561
103 Cromer SJ, D’Silva KM, Yu EW, . Secular trends in the pharmacologic treatment of osteoporosis and malignancy-related bone disease from 2009 to 2020. J Gen Intern Med. 2022 Jun;37(8):1917–24. doi: 10.1007/s11606-021-06938-8. PMID: 34100235.34100235
104 United Nations Development Programme. Human Development Index (HDI) ranking. In: Human Development Report 2020: The Next Frontier: Human Development and the Anthropocene. 2020. https://hdr.undp.org/en/content/latest-human-development-index-ranking. Accessed 14 Nov 2022.
105 Kanis JA, Oden A, McCloskey EV, . A systematic review of hip fracture incidence and probability of fracture worldwide. Osteoporos Int. 2012 Sep;23(9):2239–56. doi: 10.1007/s00198-012-1964-3. PMID: 22419370.22419370
106 Sterne JAC, Savović J, Page MJ, . RoB 2: a revised tool for assessing risk of bias in randomised trials. Bmj. 2019 Aug 28;366:l4898. doi: 10.1136/bmj.l4898. PMID: 31462531.31462531
107 Sterne JA, Hernán MA, Reeves BC, . ROBINS-I: a tool for assessing risk of bias in non-randomised studies of interventions. Bmj. 2016 Oct 12;355:i4919. doi: 10.1136/bmj.i4919. PMID: 27733354.27733354
108 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
109 Whiting P, Savović J, Higgins JP, . ROBIS: A new tool to assess risk of bias in systematic reviews was developed. J Clin Epidemiol. 2016 Jan;69:225–34. doi: 10.1016/j.jclinepi.2015.06.005. PMID: 26092286.26092286
110 Venema E, Wessler BS, Paulus JK, . Large-scale validation of the prediction model risk of bias assessment Tool (PROBAST) using a short form: high risk of bias models show poorer discrimination. J Clin Epidemiol. 2021 Oct;138:32–9. doi: 10.1016/j.jclinepi.2021.06.017. PMID: 34175377.34175377
111 Wolff RF, Moons KGM, Riley RD, . PROBAST: a tool to assess the risk of bias and applicability of prediction model studies. Ann Intern Med. 2019 Jan 1;170(1):51–8. doi: 10.7326/M18-1376. PMID: 30596875.30596875
112 Moons KGM, Wolff RF, Riley RD, . PROBAST: a tool to assess risk of bias and applicability of prediction model studies: explanation and elaboration. Ann Intern Med. 2019 Jan 1;170(1):W1–w33. doi: 10.7326/m18-1377. PMID: 30596876.30596876
113 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force procedure manual. U.S. Preventive Services Task Force. Rockville, MD. 2021. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual
114 West SL, Gartlehner G, Mansfield AJ, . Comparative effectiveness review methods: clinical heterogeneity. Methods Research Paper. AHRQ Publication No. 10-EHC070-EF. Rockville MD: Agency for Healthcare Research and Quality; Sept. 2010. https://effectivehealthcare.ahrq.gov/products/clinical-heterogeneity-methods/research
115 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986 Sep;7(3):177–88. PMID: 3802833.3802833
116 Cochrane handbook for systematic reviews of interventions. John Wiley & Sons. Chichester, UK; 12 Nov. 2022. https://training.cochrane.org/handbook/current
117 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
118 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 6;327(7414):557–60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
119 Berkman ND, Lohr KN, Ansari MT, . Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015 Nov;68(11):1312–24. doi: 10.1016/j.jclinepi.2014.11.023. PMID: 25721570.25721570
120 Shepstone L, Lenaghan E, Cooper C, . Screening in the community to reduce fractures in older women (SCOOP): a randomised controlled trial. Lancet. 2018 Feb 24;391(10122):741–7. doi: 10.1016/s0140-6736(17)32640-5. PMID: 29254858.29254858
121 Shepstone L, Fordham R, Lenaghan E, . A pragmatic randomised controlled trial of the effectiveness and cost-effectiveness of screening older women for the prevention of fractures: rationale, design and methods for the SCOOP study. Osteoporos Int. 2012 Oct;23(10):2507–15. doi: 10.1007/s00198-011-1876-7. PMID: 22314936.22314936
122 McCloskey E, Johansson H, Harvey NC, . Management of patients with high baseline hip fracture risk by FRAX reduces hip fractures-a post hoc analysis of the SCOOP study. Journal of Bone & Mineral Research. 2018 Jun;33(6):1020–6. doi: 10.1002/jbmr.3411. PMID: 29480960.29480960
123 Parsons CM, Harvey N, Shepstone L, . Systematic screening using FRAX(®) leads to increased use of, and adherence to, anti-osteoporosis medications: an analysis of the UK SCOOP trial. Osteoporos Int. 2020 Jan;31(1):67–75. doi: 10.1007/s00198-019-05142-z. PMID: 31606826.31606826
124 Merlijn T, Swart KM, van Schoor NM, . The effect of a screening and treatment program for the prevention of fractures in older women: a randomized pragmatic trial. Journal of Bone & Mineral Research. 2019 Nov;34(11):1993–2000. doi: 10.1002/jbmr.3815. PMID: 31220365.31220365
125 Elders PJM, Merlijn T, Swart KMA, . Design of the SALT osteoporosis study: a randomised pragmatic trial, to study a primary care screening and treatment program for the prevention of fractures in women aged 65 years or older. BMC Musculoskelet Disord. 2017 Oct 27;18(1):424. doi: 10.1186/s12891-017-1783-y. PMID: 29078762.29078762
126 Rubin KH, Rothmann MJ, Holmberg T, . Effectiveness of a two-step population-based osteoporosis screening program using FRAX: the randomized Risk-stratified Osteoporosis Strategy Evaluation (ROSE) study. Osteoporos Int. 2018 Mar;29(3):567–78. doi: 10.1007/s00198-017-4326-3. PMID: 29218381.29218381
127 Rubin KH, Holmberg T, Rothmann MJ, . The risk-stratified osteoporosis strategy evaluation study (ROSE): a randomized prospective population-based study. Design and baseline characteristics. Calcif Tissue Int. 2015 Feb;96(2):167–79. doi: 10.1007/s00223-014-9950-8. PMID: 25578146.25578146
128 Rothmann MJ, Möller S, Holmberg T, . Non-participation in systematic screening for osteoporosis-the ROSE trial. Osteoporos Int. 2017 Dec;28(12):3389–99. doi: 10.1007/s00198-017-4205-y. PMID: 28875257.28875257
129 Høiberg MP, Rubin KH, Holmberg T, . Use of antiosteoporotic medication in the Danish ROSE population-based screening study. Osteoporos Int. 2019 Jun;30(6):1223–33. doi: 10.1007/s00198-019-04934-7. PMID: 30911782.30911782
130 Merlijn T, Swart KMA, van der Horst HE, . Fracture prevention by screening for high fracture risk: a systematic review and meta-analysis. Osteoporos Int. 2020 Feb;31(2):251–7. doi: 10.1007/s00198-019-05226-w. PMID: 31838551.31838551
131 Gates M, Pillay J, Nuspl M, . Screening for the primary prevention of fragility fractures among adults aged 40 years and older in primary care: systematic reviews of the effects and acceptability of screening and treatment, and the accuracy of risk prediction tools. Syst Rev. 2023 Mar 21;12(1):51. doi: 10.1186/s13643-023-02181-w. PMID: 36945065.36945065
132 Gates M, Pillay J, Thériault G, . Screening to prevent fragility fractures among adults 40 years and older in primary care: protocol for a systematic review. Syst Rev. 2019 Aug 23;8(1):216. doi: 10.1186/s13643-019-1094-5. PMID: 31443711.31443711
133 Auais M, Angermann H, Grubb M, . The effectiveness and cost-effectiveness of clinical fracture-risk assessment tools in reducing future osteoporotic fractures among older adults: a structured scoping review. Osteoporos Int. 2023 May;34(5):823–40. doi: 10.1007/s00198-022-06659-6. PMID: 36598523.36598523
134 Marques A, Ferreira RJ, Santos E, . The accuracy of osteoporotic fracture risk prediction tools: a systematic review and meta-analysis. Ann Rheum Dis. 2015 Nov;74(11):1958–67. doi: 10.1136/annrheumdis-2015-207907. PMID: 26248637.26248637
135 Beaudoin C, Moore L, Gagné M, . Performance of predictive tools to identify individuals at risk of non-traumatic fracture: a systematic review, meta-analysis, and meta-regression. Osteoporos Int. 2019 Apr;30(4):721–40. doi: 10.1007/s00198-019-04919-6. PMID: 30877348.30877348
136 Jiang X, Gruner M, Tremollieres F, . Diagnostic accuracy of FRAX in predicting the 10-year risk of osteoporotic fractures using the USA treatment thresholds: a systematic review and meta-analysis. Bone. 2017 Jun;99:20–5. doi: 10.1016/j.bone.2017.02.008. PMID: 28274799.28274799
137 Sun X, Chen Y, Gao Y, . Prediction models for osteoporotic fractures risk: a systematic review and critical appraisal. Aging & Disease. 2022 Jul 11;13(4):1215–38. doi: 10.14336/ad.2021.1206. PMID: 35855348.35855348
138 Adami G, Biffi A, Porcu G, . A systematic review on the performance of fracture risk assessment tools: FRAX, DeFRA, FRA-HS. J Endocrinol Invest. 2023 Nov;46(11):2287–97. doi: 10.1007/s40618-023-02082-8. PMID: 37031450.37031450
139 Crandall CJ, Larson JC, Watts NB, . Comparison of fracture risk prediction by the US Preventive Services Task Force strategy and two alternative strategies in women 50-64 years old in the Women’s Health Initiative. Journal of Clinical Endocrinology & Metabolism. 2014;99(12):4514–22. doi: 10.1210/jc.2014-2332. PMID: 25322268.25322268
140 Crandall CJ, Larson J, LaCroix A, . Predicting fracture risk in younger postmenopausal women: Comparison of the Garvan and FRAX risk calculators in the Women’s Health Initiative Study. J Gen Intern Med. 2019 Feb;34(2):235–42. doi: 10.1007/s11606-018-4696-z. PMID: 30334182.30334182
141 Crandall CJ, Larson J, Manson JE, . A comparison of US and Canadian osteoporosis screening and treatment strategies in postmenopausal women. Journal of Bone & Mineral Research. 2019 Apr;34(4):607–15. doi: 10.1002/jbmr.3636. PMID: 30536628.30536628
142 Crandall CJ, Larson J, Cauley JA, . Do additional clinical risk factors improve the performance of Fracture Risk Assessment Tool (FRAX) among postmenopausal women? Findings from the Women’s Health Initiative observational study and clinical trials. JBMR Plus. 2019 Dec;3(12):e10239. doi: 10.1002/jbm4.10239. PMID: 31844827.31844827
143 Crandall CJ, Larson JC, Schousboe JT, . Race and ethnicity and fracture prediction among younger postmenopausal women in the Women’s Health Initiative Study. JAMA Intern. Med. 2023. doi: 10.1001/jamainternmed.2023.1253.
144 Tebe Cordomi C, Del Rio LM, Di Gregorio S, . Validation of the FRAX predictive model for major osteoporotic fracture in a historical cohort of Spanish women. J Clin Densitom. 2013 Apr–Jun;16(2):231–7. doi: 10.1016/j.jocd.2012.05.007. PMID: 22748778.22748778
145 Ettinger B, Ensrud KE, Blackwell T, . Performance of FRAX in a cohort of community-dwelling, ambulatory older men: the Osteoporotic Fractures in Men (MrOS) study. Osteoporos Int. 2013 Apr;24(4):1185–93. doi: 10.1007/s00198-012-2215-3. PMID: 23179575.23179575
146 Gourlay ML, Ritter VS, Fine JP, . Comparison of fracture risk assessment tools in older men without prior hip or spine fracture: the MrOS study. Arch Osteoporos. 2017 Oct 20;12(1):91. doi: 10.1007/s11657-017-0389-1. PMID: 29052793.29052793
147 Hippisley-Cox J, Coupland C. Derivation and validation of updated QFracture algorithm to predict risk of osteoporotic fracture in primary care in the United Kingdom: prospective open cohort study. BMJ. 2012 May 22;344:e3427. doi: 10.1136/bmj.e3427. PMID: 22619194.22619194
148 Hippisley-Cox J, Coupland C. Predicting risk of osteoporotic fracture in men and women in England and Wales: prospective derivation and validation of QFractureScores. BMJ. 2009 Nov 19;339:b4229. doi: 10.1136/bmj.b4229. PMID: 19926696.19926696
149 Gonzalez-Macias J, Marin F, Vila J, Diez-Perez A. Probability of fractures predicted by FRAX(R) and observed incidence in the Spanish ECOSAP Study cohort. Bone. 2012 Jan;50(1):373–7. doi: 10.1016/j.bone.2011.11.006. PMID: 22129640.22129640
150 Cheung EY, Bow CH, Cheung CL, . Discriminative value of FRAX for fracture prediction in a cohort of Chinese postmenopausal women. Osteoporos Int. 2012 Mar;23(3):871–8. doi: 10.1007/s00198-011-1647-5. PMID: 21562875.21562875
151 Tamaki J, Iki M, Kadowaki E, . Fracture risk prediction using FRAX(R): a 10-year follow-up survey of the Japanese Population-Based Osteoporosis (JPOS) Cohort Study. Osteoporos Int. 2011 Dec;22(12):3037–45. doi: 10.1007/s00198-011-1537-x. PMID: 21279504.21279504
152 Ensrud KE, Lui LY, Taylor BC, . A comparison of prediction models for fractures in older women: is more better? Arch Intern Med. 2009 Dec 14;169(22):2087–94. doi: 10.1001/archinternmed.2009.404. PMID: 20008691.20008691
153 Premaor M, Parker RA, Cummings S, . Predictive value of FRAX for fracture in obese older women. Journal of Bone & Mineral Research. 2013 Jan;28(1):188–95. doi: 10.1002/jbmr.1729. PMID: 22890977.22890977
154 Fraser LA, Langsetmo L, Berger C, . Fracture prediction and calibration of a Canadian FRAX(R) tool: a population-based report from CaMos. Osteoporos Int. 2011 Mar;22(3):829–37. doi: 10.1007/s00198-010-1465-1. PMID: 21161508.21161508
155 Langsetmo L, Nguyen TV, Nguyen ND, . Independent external validation of nomograms for predicting risk of low-trauma fracture and hip fracture. CMAJ. 2011 Feb 8;183(2):E107–14. doi: 10.1503/cmaj.100458. PMID: 21173069.21173069
156 Tanaka S, Yoshimura N, Kuroda T, . The Fracture and Immobilization Score (FRISC) for risk assessment of osteoporotic fracture and immobilization in postmenopausal women--a joint analysis of the Nagano, Miyama, and Taiji Cohorts. Bone. 2010 Dec;47(6):1064–70. doi: 10.1016/j.bone.2010.08.019. PMID: 20832514.20832514
157 Leslie WD, Lix LM, Johansson H, . Independent clinical validation of a Canadian FRAX tool: fracture prediction and model calibration. Journal of Bone & Mineral Research. 2010 Nov;25(11):2350–8. doi: 10.1002/jbmr.123. PMID: 20499367.20499367
158 Brennan SL, Leslie WD, Lix LM, . FRAX provides robust fracture prediction regardless of socioeconomic status. Osteoporos Int. 2014 Jan;25(1):61–9. doi: 10.1007/s00198-013-2525-0. PMID: 24190425.24190425
159 Morin S, Tsang JF, Leslie WD. Weight and body mass index predict bone mineral density and fractures in women aged 40 to 59 years. Osteoporos Int. 2009 Mar;20(3):363–70. doi: 10.1007/s00198-008-0688-x. PMID: 18633665.18633665
160 Crandall CJ, Schousboe JT, Morin SN, . Performance of FRAX and FRAX-based treatment thresholds in women aged 40 years and older: the Manitoba BMD registry. Journal of Bone & Mineral Research. 2019 Aug;34(8):1419–27. doi: 10.1002/jbmr.3717. PMID: 30920022.30920022
161 Leslie WD, Majumdar SR, Lix LM, . Direct comparison of FRAX(R) and a simplified fracture risk assessment tool in routine clinical practice: a registry-based cohort study. Osteoporos Int. 2016 Sep;27(9):2689–95. doi: 10.1007/s00198-016-3613-8. PMID: 27108119.27108119
162 Leslie WD, Majumdar SR, Morin SN, . Performance of FRAX in clinical practice according to sex and osteoporosis definitions: the Manitoba BMD registry. Osteoporos Int. 2018 Mar;29(3):759–67. doi: 10.1007/s00198-018-4415-y. PMID: 29404625.29404625
163 Möller S, Skjødt MK, Yan L, . Prediction of imminent fracture risk in Canadian women and men aged 45 years or older: external validation of the Fracture Risk Evaluation Model (FREM). Osteoporos Int. 2022 Jan;33(1):57–66. doi: 10.1007/s00198-021-06165-1. PMID: 34596704.34596704
164 Leslie WD, Möller S, Skjødt MK, . FREM predicts 10-year incident fracture risk independent of FRAX® probability: a registry-based cohort study. Osteoporos Int. 2022 Jul;33(7):1457–63. doi: 10.1007/s00198-022-06349-3. PMID: 35175395.35175395
165 Pressman AR, Lo JC, Chandra M, Ettinger B. Methods for assessing fracture risk prediction models: experience with FRAX in a large integrated health care delivery system. J Clin Densitom. 2011 Oct–Dec;14(4):407–15. doi: 10.1016/j.jocd.2011.06.006. PMID: 21958955.21958955
166 Bolland MJ, Siu AT, Mason BH, . Evaluation of the FRAX and Garvan fracture risk calculators in older women. Journal of Bone & Mineral Research. 2011 Feb;26(2):420–7. doi: 10.1002/jbmr.215. PMID: 20721930.20721930
167 Collins GS, Mallett S, Altman DG. Predicting risk of osteoporotic and hip fracture in the United Kingdom: prospective independent and external validation of QFractureScores. BMJ. 2011 Jun 22;342:d3651. doi: 10.1136/bmj.d3651. PMID: 21697214.21697214
168 Azagra R, Roca G, Martin-Sanchez JC, . [FRAX(R) thresholds to identify people with high or low risk of osteoporotic fracture in Spanish female population]. Med Clin (Barc). 2015 Jan 6;144(1):1–8. doi: 10.1016/j.medcli.2013.11.014. PMID: 24461732.24461732
169 Dagan N, Cohen-Stavi C, Leventer-Roberts M, Balicer RD. External validation and comparison of three prediction tools for risk of osteoporotic fractures using data from population based electronic health records: retrospective cohort study. BMJ. 2017 Jan 19;356:i6755. doi: 10.1136/bmj.i6755. PMID: 28104610.28104610
170 Klop C, de Vries F, Bijlsma JW, . Predicting the 10-year risk of hip and major osteoporotic fracture in rheumatoid arthritis and in the general population: an independent validation and update of UK FRAX without bone mineral density. Ann Rheum Dis. 2016 Dec;75(12):2095–100. doi: 10.1136/annrheumdis-2015-208958. PMID: 26984006.26984006
171 Hippisley-Cox J, Coupland C, Brindle P. The performance of seven QPrediction risk scores in an independent external sample of patients from general practice: a validation study. BMJ Open. 2014 Aug 28;4(8):e005809. doi: 10.1136/bmjopen-2014-005809. PMID: 25168040.25168040
172 Goldshtein I, Gerber Y, Ish-Shalom S, Leshno M. Fracture risk assessment with FRAX using real-world data in a population-based cohort from Israel. Am J Epidemiol. 2018 Jan 1;187(1):94–102. doi: 10.1093/aje/kwx128. PMID: 28520844.28520844
173 Davis WA, Hamilton EJ, Bruce DG, Davis TME. Development and validation of a simple hip fracture risk prediction tool for type 2 diabetes: the Fremantle Diabetes Study phase I. Diabetes Care. 2019 Jan;42(1):102–9. doi: 10.2337/dc18-1486. PMID: 30455327.30455327
174 Azagra R, Zwart M, Aguyé A, . Fracture experience among participants from the FROCAT study: what thresholding is appropriate using the FRAX tool? Maturitas. 2016 Jan;83:65–71. doi: 10.1016/j.maturitas.2015.10.002. PMID: 26546077.26546077
175 Chapurlat R, Bui M, Sornay-Rendu E, . Deterioration of cortical and trabecular microstructure identifies women with osteopenia or normal bone mineral density at imminent and long-term risk for fragility fracture: a prospective study. Journal of Bone & Mineral Research. 2020 May;35(5):833–44. doi: 10.1002/jbmr.3924. PMID: 31821619.31821619
176 Marques A, Lucas R, Simões E, . Do we need bone mineral density to estimate osteoporotic fracture risk? A 10-year prospective multicentre validation study. RMD Open. 2017;3(2):e000509. doi: 10.1136/rmdopen-2017-000509. PMID: 29018567.29018567
177 Desbiens LC, Sidibé A, Beaudoin C, . Comparison of fracture prediction tools in individuals without and with early chronic kidney disease: a population-based analysis of CARTaGENE. Journal of Bone & Mineral Research. 2020 Jun;35(6):1048–57. doi: 10.1002/jbmr.3977. PMID: 32022942.32022942
178 Lu T, Forgetta V, Keller-Baruch J, . Improved prediction of fracture risk leveraging a genome-wide polygenic risk score. Genome Med. 2021 Feb 3;13(1):16. doi: 10.1186/s13073-021-00838-6. PMID: 33536041.33536041
179 Baleanu F, Iconaru L, Charles A, . Independent external validation of FRAX and Garvan fracture risk calculators: a sub-study of the FRISBEE cohort. JBMR Plus. 2021 Sep;5(9):e10532. doi: 10.1002/jbm4.10532. PMID: 34532617.34532617
180 Tebé C, Pallarès N, Reyes C, . Development and external validation of a 1- and 5-year fracture prediction tool based on electronic medical records data: The EPIC risk algorithm. Bone. 2022 Sep;162:116469. doi: 10.1016/j.bone.2022.116469. PMID: 35691583.35691583
181 García-Sempere A, Hurtado I, Peiró S, . Predictive Performance of the FRAX Tool Calibrated for Spain vs. an Age and Sex Model: Prospective Cohort Study with 9082 Women and Men Followed for up to 8 Years. Journal of Clinical Medicine. 2022;11(9). doi: 10.3390/jcm11092409.
182 Kwok T, Khoo CC, Leung J, . Predictive values of calcaneal quantitative ultrasound and dual energy X ray absorptiometry for non-vertebral fracture in older men: results from the MrOS study (Hong Kong). Osteoporos Int. 2012 Mar;23(3):1001–6. doi: 10.1007/s00198-011-1634-x. PMID: 21528361.21528361
183 Hans D, Goertzen AL, Krieg MA, Leslie WD. Bone microarchitecture assessed by TBS predicts osteoporotic fractures independent of bone density: the Manitoba study. Journal of Bone & Mineral Research. 2011 Nov;26(11):2762–9. doi: 10.1002/jbmr.499. PMID: 21887701.21887701
184 Leslie WD, Aubry-Rozier B, Lamy O, Hans D. TBS (trabecular bone score) and diabetes-related fracture risk. Journal of Clinical Endocrinology & Metabolism. 2013 Feb;98(2):602–9. doi: 10.1210/jc.2012-3118. PMID: 23341489.23341489
185 Sund R, Honkanen R, Johansson H, . Evaluation of the FRAX model for hip fracture predictions in the population-based Kuopio Osteoporosis Risk Factor and Prevention Study (OSTPRE). Calcif Tissue Int. 2014 Jul;95(1):39–45. doi: 10.1007/s00223-014-9860-9. PMID: 24792689.24792689
186 Nguyen TV, Center JR, Eisman JA. Bone mineral density-independent association of quantitative ultrasound measurements and fracture risk in women. Osteoporos Int. 2004 Dec;15(12):942–7. doi: 10.1007/s00198-004-1717-z. PMID: 15309384.15309384
187 Robbins J, Aragaki AK, Kooperberg C, . Factors associated with 5-year risk of hip fracture in postmenopausal women. JAMA. 2007 Nov 28;298(20):2389–98. doi: 10.1001/jama.298.20.2389. PMID: 18042916.18042916
188 Sornay-Rendu E, Munoz F, Delmas PD, Chapurlat RD. The FRAX tool in French women: How well does it describe the real incidence of fracture in the OFELY cohort? Journal of Bone & Mineral Research. 2010 Oct;25(10):2101–7. doi: 10.1002/jbmr.106. PMID: 20499352.20499352
189 Tremollieres FA, Pouilles JM, Drewniak N, . Fracture risk prediction using BMD and clinical risk factors in early postmenopausal women: sensitivity of the WHO FRAX tool. Journal of Bone & Mineral Research. 2010 May;25(5):1002–9. doi: 10.1002/jbmr.12. PMID: 20200927.20200927
190 Stewart A, Kumar V, Reid DM. Long-term fracture prediction by DXA and QUS: a 10-year prospective study. Journal of Bone & Mineral Research. 2006 Mar;21(3):413–8. doi: 10.1359/jbmr.051205. PMID: 16491289.16491289
191 Prince RL, Lewis JR, Lim WH, . Adding lateral spine imaging for vertebral fractures to densitometric screening: improving ascertainment of patients at high risk of incident osteoporotic fractures. Journal of Bone & Mineral Research. 2019 Feb;34(2):282–9. doi: 10.1002/jbmr.3595. PMID: 30395687.30395687
192 Black DM, Cauley JA, Wagman R, . The ability of a single BMD and fracture history assessment to predict fracture over 25 years in postmenopausal women: the study of osteoporotic fractures. Journal of Bone & Mineral Research. 2018 Mar;33(3):389–95. doi: 10.1002/jbmr.3194. PMID: 28719727.28719727
193 Agarwal A, Leslie WD, Nguyen TV, . Predictive performance of the Garvan Fracture Risk Calculator: a registry-based cohort study. Osteoporos Int. 2022 Mar;33(3):541–8. doi: 10.1007/s00198-021-06252-3. PMID: 34839377.34839377
194 Iki M, Winzenrieth R, Tamaki J, . Predictive ability of novel volumetric and geometric indices derived from dual-energy X-ray absorptiometric images of the proximal femur for hip fracture compared with conventional areal bone mineral density: the Japanese Population-based Osteoporosis (JPOS) Cohort Study. Osteoporos Int. 2021 May 26;32(11):2289–99. doi: 10.1007/s00198-021-06013-2. PMID: 34041560.34041560
195 Crandall CJ, Larson J, Gourlay ML, . Osteoporosis screening in postmenopausal women 50 to 64 years old: comparison of US Preventive Services Task Force strategy and two traditional strategies in the Women’s Health Initiative. Journal of Bone & Mineral Research. 2014 Jul;29(7):1661–6. doi: 10.1002/jbmr.2174. PMID: 24431262.24431262
196 Pang WY, Inderjeeth CA. FRAX without bone mineral density versus osteoporosis self-assessment screening tool as predictors of osteoporosis in primary screening of individuals aged 70 and older. J Am Geriatr Soc. 2014 Mar;62(3):442–6. doi: 10.1111/jgs.12696. PMID: 24617899.24617899
197 Cass AR, Shepherd AJ. Validation of the Male Osteoporosis Risk Estimation Score (MORES) in a primary care setting. J Am Board Fam Med. 2013 Jul–Aug;26(4):436–44. doi: 10.3122/jabfm.2013.04.120182. PMID: 23833159.23833159
198 Richards JS, Lazzari AA, Teves Qualler DA, . Validation of the osteoporosis self-assessment tool in US male veterans. Journal of clinical densitometry. 2014;17(1):32–7.23489972
199 D’Amelio P, Spertino E, Martino F, Isaia GC. Prevalence of postmenopausal osteoporosis in Italy and validation of decision rules for referring women for bone densitometry. Calcif Tissue Int. 2013 May;92(5):437–43. doi: 10.1007/s00223-013-9699-5. PMID: 23334353.23334353
200 Leslie WD, Lix LM, Johansson H, . Selection of women aged 50-64 yr for bone density measurement. J Clin Densitom. 2013 Oct–Dec;16(4):570–8. doi: 10.1016/j.jocd.2013.01.004. PMID: 23452870.23452870
201 Machado P, Coutinho M, da Silva JA. Selecting men for bone densitometry: performance of osteoporosis risk assessment tools in Portuguese men. Osteoporos Int. 2010 Jun;21(6):977–83. doi: 10.1007/s00198-009-1036-5. PMID: 19727909.19727909
202 Shepherd AJ, Cass AR, Ray L. Determining risk of vertebral osteoporosis in men: validation of the male osteoporosis risk estimation score. J Am Board Fam Med. 2010 Mar–Apr;23(2):186–94. doi: 10.3122/jabfm.2010.02.090027. PMID: 20207929.20207929
203 Jimenez-Nunez FG, Manrique-Arija S, Urena-Garnica I, . Reducing the need for central dual-energy X-ray absorptiometry in postmenopausal women: efficacy of a clinical algorithm including peripheral densitometry. Calcif Tissue Int. 2013 Jul;93(1):62–8. doi: 10.1007/s00223-013-9728-4. PMID: 23608922.23608922
204 Oh SM, Nam BH, Rhee Y, . Development and validation of osteoporosis risk-assessment model for Korean postmenopausal women. Journal of Bone & Mineral Metabolism. 2013 Jul;31(4):423–32. doi: 10.1007/s00774-013-0426-0. PMID: 23420298.23420298
205 McLeod KM, Johnson S, Rasali D, Verma A. Discriminatory performance of the calcaneal quantitative ultrasound and osteoporosis self-assessment tool to select older women for dual-energy x-ray absorptiometry. J Clin Densitom. 2015 Apr–Jun;18(2):157–64. doi: 10.1016/j.jocd.2015.02.006. PMID: 25937306.25937306
206 Cadarette SM, Jaglal SB, Murray TM, . Evaluation of decision rules for referring women for bone densitometry by dual-energy x-ray absorptiometry. JAMA. 2001 Jul 4;286(1):57–63. doi: 10.1001/jama.286.1.57. PMID: 11434827.11434827
207 Chan SP, Teo CC, Ng SA, . Validation of various osteoporosis risk indices in elderly Chinese females in Singapore. Osteoporos Int. 2006;17(8):1182–8. doi: 10.1007/s00198-005-0051-4. PMID: 16699739.16699739
208 Cook RB, Collins D, Tucker J, Zioupos P. Comparison of questionnaire and quantitative ultrasound techniques as screening tools for DXA. Osteoporos Int. 2005 Dec;16(12):1565–75. doi: 10.1007/s00198-005-1864-x. PMID: 15883661.15883661
209 Gourlay ML, Miller WC, Richy F, . Performance of osteoporosis risk assessment tools in postmenopausal women aged 45-64 years. Osteoporos Int. 2005 Aug;16(8):921–7. doi: 10.1007/s00198-004-1775-2. PMID: 16028108.16028108
210 Richy F, Gourlay M, Ross PD, . Validation and comparative evaluation of the osteoporosis self-assessment tool (OST) in a Caucasian population from Belgium. Qjm. 2004 Jan;97(1):39–46. doi: 10.1093/qjmed/hch002. PMID: 14702510.14702510
211 Ben Sedrine W, Devogelaer JP, Kaufman JM, . Evaluation of the simple calculated osteoporosis risk estimation (SCORE) in a sample of white women from Belgium. Bone. 2001 Oct;29(4):374–80. doi: 10.1016/s8756-3282(01)00583-x. PMID: 11595621.11595621
212 Kung AW, Ho AY, Ross PD, Reginster JY. Development of a clinical assessment tool in identifying Asian men with low bone mineral density and comparison of its usefulness to quantitative bone ultrasound. Osteoporos Int. 2005 Jul;16(7):849–55. doi: 10.1007/s00198-004-1778-z. PMID: 15611839.15611839
213 Kung AW, Ho AY, Sedrine WB, . Comparison of a simple clinical risk index and quantitative bone ultrasound for identifying women at increased risk of osteoporosis. Osteoporos Int. 2003 Sep;14(9):716–21. doi: 10.1007/s00198-003-1428-x. PMID: 12897978.12897978
214 Martinez-Aguila D, Gomez-Vaquero C, Rozadilla A, . Decision rules for selecting women for bone mineral density testing: application in postmenopausal women referred to a bone densitometry unit. J Rheumatol. 2007 Jun;34(6):1307–12. PMID: 17552058.17552058
215 Park HM, Sedrine WB, Reginster JY, Ross PD. Korean experience with the OSTA risk index for osteoporosis: a validation study. J Clin Densitom. 2003 Fall;6(3):247–50. doi: 10.1385/jcd:6:3:247. PMID: 14514994.14514994
216 Zimering MB, Shin JJ, Shah J, . Validation of a novel risk estimation tool for predicting low bone density in Caucasian and African American men veterans. J Clin Densitom. 2007 Jul–Sep;10(3):289–97. doi: 10.1016/j.jocd.2007.03.001. PMID: 17459748.17459748
217 Harrison EJ, Adams JE. Application of a triage approach to peripheral bone densitometry reduces the requirement for central DXA but is not cost effective. Calcif Tissue Int. 2006 Oct;79(4):199–206. doi: 10.1007/s00223-005-0302-6. PMID: 16969598.16969598
218 Lynn HS, Woo J, Leung PC, . An evaluation of osteoporosis screening tools for the osteoporotic fractures in men (MrOS) study. Osteoporos Int. 2008 Jul;19(7):1087–92. doi: 10.1007/s00198-007-0553-3. PMID: 18239959.18239959
219 Sinnott B, Kukreja S, Barengolts E. Utility of screening tools for the prediction of low bone mass in African American men. Osteoporos Int. 2006;17(5):684–92. doi: 10.1007/s00198-005-0034-5. PMID: 16523248.16523248
220 Bansal S, Pecina JL, Merry SP, . US Preventative Services Task Force FRAX threshold has a low sensitivity to detect osteoporosis in women ages 50-64 years. Osteoporos Int. 2015 Apr;26(4):1429–33. doi: 10.1007/s00198-015-3026-0. PMID: 25614141.25614141
221 Adler RA, Tran MT, Petkov VI. Performance of the Osteoporosis Self-assessment Screening Tool for osteoporosis in American men. Mayo Clin Proc. 2003 Jun;78(6):723–7. doi: 10.4065/78.6.723. PMID: 12934782.12934782
222 Brenneman SK, Lacroix AZ, Buist DS, . Evaluation of decision rules to identify postmenopausal women for intervention related to osteoporosis. Dis Manag. 2003 Fall;6(3):159–68. doi: 10.1089/109350703322425509. PMID: 14570384.14570384
223 Cadarette SM, McIsaac WJ, Hawker GA, . The validity of decision rules for selecting women with primary osteoporosis for bone mineral density testing. Osteoporos Int. 2004 May;15(5):361–6. doi: 10.1007/s00198-003-1552-7. PMID: 14730421.14730421
224 Cass AR, Shepherd AJ, Carlson CA. Osteoporosis risk assessment and ethnicity: validation and comparison of 2 clinical risk stratification instruments. J Gen Intern Med. 2006 Jun;21(6):630–5. doi: 10.1111/j.1525-1497.2006.00459.x. PMID: 16808748.16808748
225 D’Amelio P, Tamone C, Pluviano F, . Effects of lifestyle and risk factors on bone mineral density in a cohort of Italian women: suggestion for a new decision rule. Calcif Tissue Int. 2005 Aug;77(2):72–8. doi: 10.1007/s00223-004-0253-3. PMID: 16059776.16059776
226 Mauck KF, Cuddihy MT, Atkinson EJ, Melton LJ, 3rd. Use of clinical prediction rules in detecting osteoporosis in a population-based sample of postmenopausal women. Arch Intern Med. 2005 Mar 14;165(5):530–6. doi: 10.1001/archinte.165.5.530. PMID: 15767529.15767529
227 Nguyen TV, Center JR, Pocock NA, Eisman JA. Limited utility of clinical indices for the prediction of symptomatic fracture risk in postmenopausal women. Osteoporos Int. 2004 Jan;15(1):49–55. doi: 10.1007/s00198-003-1511-3. PMID: 14593453.14593453
228 Rud B, Jensen JE, Mosekilde L, . Performance of four clinical screening tools to select peri- and early postmenopausal women for dual X-ray absorptiometry. Osteoporos Int. 2005 Jul;16(7):764–72. doi: 10.1007/s00198-004-1748-5. PMID: 15986263.15986263
229 Oh SM, Song BM, Nam BH, . Development and validation of osteoporosis risk-assessment model for Korean men. Yonsei Med J. 2016 Jan;57(1):187–96. doi: 10.3349/ymj.2016.57.1.187. PMID: 26632400.26632400
230 Gourlay ML, Powers JM, Lui LY, Ensrud KE. Clinical performance of osteoporosis risk assessment tools in women aged 67 years and older. Osteoporos Int. 2008 Aug;19(8):1175–83. doi: 10.1007/s00198-007-0555-1. PMID: 18219434.18219434
231 Geusens P, Hochberg MC, van der Voort DJ, . Performance of risk indices for identifying low bone density in postmenopausal women. Mayo Clin Proc. 2002 Jul;77(7):629–37. doi: 10.4065/77.7.629. PMID: 12108600.12108600
232 Cass AR, Shepherd AJ, Asirot R, . Comparison of the Male Osteoporosis Risk Estimation Score (MORES) with FRAX in identifying men at risk for osteoporosis. Ann Fam Med. 2016 Jul;14(4):365–9. doi: 10.1370/afm.1945. PMID: 27401426.27401426
233 Chen SJ, Chen YJ, Cheng CH, . Comparisons of different screening tools for identifying fracture/osteoporosis risk among community-dwelling older people. Medicine (Baltimore). 2016 May;95(20):e3415. doi: 10.1097/md.0000000000003415. PMID: 27196447.27196447
234 Pecina JL, Romanovsky L, Merry SP, . Comparison of clinical risk tools for predicting osteoporosis in women ages 50-64. J Am Board Fam Med. 2016 Mar–Apr;29(2):233–9. doi: 10.3122/jabfm.2016.02.150237. PMID: 26957380.26957380
235 Diem SJ, Peters KW, Gourlay ML, . Screening for osteoporosis in older men: operating characteristics of proposed strategies for selecting men for BMD testing. J Gen Intern Med. 2017 Nov;32(11):1235–41. doi: 10.1007/s11606-017-4153-4. PMID: 28815485.28815485
236 Jiang X, Good LE, Spinka R, Schnatz PF. Osteoporosis screening in postmenopausal women aged 50-64 years: BMI alone compared with current screening tools. Maturitas. 2016 Jan;83:59–64. doi: 10.1016/j.maturitas.2015.09.009. PMID: 26471931.26471931
237 Williams ST, Lawrence PT, Miller KL, . A comparison of electronic and manual fracture risk assessment tools in screening elderly male US veterans at risk for osteoporosis. Osteoporos Int. 2017 Nov;28(11):3107–11. doi: 10.1007/s00198-017-4172-3. PMID: 28756457.28756457
238 Hamdy RC, Seier E, Whalen K, . FRAX calculated without BMD does not correctly identify Caucasian men with densitometric evidence of osteoporosis. Osteoporos Int. 2018 Apr;29(4):947–52. doi: 10.1007/s00198-017-4368-6. PMID: 29397409.29397409
239 Inderjeeth CA, Raymond WD. Case finding with GARVAN fracture risk calculator in primary prevention of fragility fractures in older people. Archives of Gerontology & Geriatrics. 2020 Jan–Feb;86:103940. doi: 10.1016/j.archger.2019.103940. PMID: 31525558.31525558
240 Chang SF, Yang RS. Optimal analysis to discriminate males’ osteoporosis with simple physiological indicators: a cutoff point study. Am J Mens Health. 2016 Nov;10(6):487–94. doi: 10.1177/1557988315574857. PMID: 25766506.25766506
241 Shuler FD, Scott K, Wilson-Byrne T, . Improving rural bone health and minimizing fracture risk in West Virginia: validation of the World Health Organization FRAX assessment tool as a phone survey for osteoporosis detection. W V Med J. 2016 May–Jun;112(3):84–8. PMID: 27301160.27301160
242 Christodoulou S, Drosos GI, Ververidis A, . Risk assessment instruments for screening bone mineral density in a Mediterranean population. World J Orthop. 2016 Sep 18;7(9):577–83. doi: 10.5312/wjo.v7.i9.577. PMID: 27672571.27672571
243 Erjiang E, Wang T, Yang L, . Utility of osteoporosis self-assessment tool as a screening tool for osteoporosis in Irish men and women: results of the DXA-HIP project. J Clin Densitom. 2021 Oct–Dec;24(4):516–26. doi: 10.1016/j.jocd.2021.03.003. PMID: 33789806.33789806
244 Moon JH, Kim LO, Kim HJ, Kong MH. Evaluation of the predictive index for osteoporosis as a clinical tool to identify the risk of osteoporosis in Korean men by using the Korea National Health and Nutrition Examination Survey data. Korean J Fam Med. 2016 Nov;37(6):346–50. doi: 10.4082/kjfm.2016.37.6.346. PMID: 27900073.27900073
245 Toh LS, Lai PSM, Wu DBC, . A comparison of 6 osteoporosis risk assessment tools among postmenopausal women in Kuala Lumpur, Malaysia. Osteoporos Sarcopenia. 2019 Sep;5(3):87–93. doi: 10.1016/j.afos.2019.09.001. PMID: 31728426.31728426
246 Berry SD, Samelson EJ, Pencina MJ, . Repeat bone mineral density screening and prediction of hip and major osteoporotic fracture. JAMA. 2013 Sep 25;310(12):1256–62. doi: 10.1001/jama.2013.277817. PMID: 24065012.24065012
247 Hillier TA, Stone KL, Bauer DC, . Evaluating the value of repeat bone mineral density measurement and prediction of fractures in older women: the study of osteoporotic fractures. Arch Intern Med. 2007 Jan 22;167(2):155–60. doi: 10.1001/archinte.167.2.155. PMID: 17242316.17242316
248 Leslie WD, Majumdar SR, Morin SN, . Change in Trabecular Bone Score (TBS) with antiresorptive therapy does not predict fracture in women: the Manitoba BMD Cohort. Journal of Bone & Mineral Research. 2017 Mar;32(3):618–23. doi: 10.1002/jbmr.3054. PMID: 27933656.27933656
249 Crandall CJ, Larson J, Wright NC, . Serial Bone Density Measurement and Incident Fracture Risk Discrimination in Postmenopausal Women. JAMA Intern Med. 2020 Sep 1;180(9):1232–40. doi: 10.1001/jamainternmed.2020.2986. PMID: 32730575.32730575
250 Ensrud KE, Lui LY, Crandall CJ, . Repeat Bone Mineral Density Screening Measurement and Fracture Prediction in Older Men: A Prospective Cohort Study. Journal of Clinical Endocrinology & Metabolism. 2022 Aug 18;107(9):e3877–e86. doi: 10.1210/clinem/dgac324. PMID: 35587517.35587517
251 Boonen S, Reginster JY, Kaufman JM, . Fracture risk and zoledronic acid therapy in men with osteoporosis. N Engl J Med. 2012 Nov 1;367(18):1714–23. doi: 10.1056/NEJMoa1204061. PMID: 23113482.23113482
252 Ascott-Evans BH, Guanabens N, Kivinen S, . Alendronate prevents loss of bone density associated with discontinuation of hormone replacement therapy: a randomized controlled trial. Arch Intern Med. 2003 Apr 14;163(7):789–94. doi: 10.1001/archinte.163.7.789. PMID: 12695269.12695269
253 Chesnut CH, 3rd, McClung MR, Ensrud KE, . Alendronate treatment of the postmenopausal osteoporotic woman: effect of multiple dosages on bone mass and bone remodeling. Am J Med. 1995 Aug;99(2):144–52. doi: 10.1016/s0002-9343(99)80134-x. PMID: 7625419.7625419
254 Cummings SR, Black DM, Thompson DE, . Effect of alendronate on risk of fracture in women with low bone density but without vertebral fractures: results from the Fracture Intervention Trial. JAMA. 1998 Dec 23–30;280(24):2077–82. doi: 10.1001/jama.280.24.2077. PMID: 9875874.9875874
255 Quandt SA, Thompson DE, Schneider DL, . Effect of alendronate on vertebral fracture risk in women with bone mineral density T scores of −1.6 to −2.5 at the femoral neck: the Fracture Intervention Trial. Mayo Clin Proc. 2005 Mar;80(3):343–9. doi: 10.4065/80.3.343. PMID: 15757015.15757015
256 Liberman UA, Weiss SR, Broll J, . Effect of oral alendronate on bone mineral density and the incidence of fractures in postmenopausal osteoporosis. the Alendronate Phase III Osteoporosis Treatment Study Group. N Engl J Med. 1995 Nov 30;333(22):1437–43. doi: 10.1056/nejm199511303332201. PMID: 7477143.7477143
257 McClung MR, Geusens P, Miller PD, . Effect of risedronate on the risk of hip fracture in elderly women. Hip Intervention Program Study Group. N Engl J Med. 2001 Feb 1;344(5):333–40. doi: 10.1056/nejm200102013440503. PMID: 11172164.11172164
258 Mortensen L, Charles P, Bekker PJ, . Risedronate increases bone mass in an early postmenopausal population: two years of treatment plus one year of follow-up. Journal of Clinical Endocrinology & Metabolism. 1998 Feb;83(2):396–402. doi: 10.1210/jcem.83.2.4586. PMID: 9467547.9467547
259 Pols HA, Felsenberg D, Hanley DA, . Multinational, placebo-controlled, randomized trial of the effects of alendronate on bone density and fracture risk in postmenopausal women with low bone mass: results of the FOSIT study. Fosamax International Trial Study Group. Osteoporos Int. 1999;9(5):461–8. doi: 10.1007/pl00004171. PMID: 10550467.10550467
260 Reid IR, Brown JP, Burckhardt P, . Intravenous zoledronic acid in postmenopausal women with low bone mineral density. N Engl J Med. 2002 Feb 28;346(9):653–61. doi: 10.1056/NEJMoa011807. PMID: 11870242.11870242
261 Valimaki MJ, Farrerons-Minguella J, Halse J, . Effects of risedronate 5 mg/d on bone mineral density and bone turnover markers in late-postmenopausal women with osteopenia: a multinational, 24-month, randomized, double-blind, placebo-controlled, parallel-group, phase III trial. Clin Ther. 2007 Sep;29(9):1937–49. doi: 10.1016/j.clinthera.2007.09.017. PMID: 18035193.18035193
262 Grey A, Bolland M, Wattie D, . Prolonged antiresorptive activity of zoledronate: a randomized, controlled trial. Journal of Bone & Mineral Research. 2010 Oct;25(10):2251–5. doi: 10.1002/jbmr.103. PMID: 20499349.20499349
263 Grey A, Bolland MJ, Wattie D, . The antiresorptive effects of a single dose of zoledronate persist for two years: a randomized, placebo-controlled trial in osteopenic postmenopausal women. Journal of Clinical Endocrinology & Metabolism. 2009 Feb;94(2):538–44. doi: 10.1210/jc.2008-2241. PMID: 19050050.19050050
264 Ravn P, Clemmesen B, Riis BJ, Christiansen C. The effect on bone mass and bone markers of different doses of ibandronate: a new bisphosphonate for prevention and treatment of postmenopausal osteoporosis: a 1-year, randomized, double-blind, placebo-controlled dose-finding study. Bone. 1996 Nov;19(5):527–33. doi: 10.1016/s8756-3282(96)00229-3. PMID: 8922653.8922653
265 Riis BJ, Ise J, von Stein T, . Ibandronate: a comparison of oral daily dosing versus intermittent dosing in postmenopausal osteoporosis. Journal of Bone & Mineral Research. 2001 Oct;16(10):1871–8. doi: 10.1359/jbmr.2001.16.10.1871. PMID: 11585352.11585352
266 Reginster JY, Wilson KM, Dumont E, . Monthly oral ibandronate is well tolerated and efficacious in postmenopausal women: results from the monthly oral pilot study. Journal of Clinical Endocrinology & Metabolism. 2005 Sep;90(9):5018–24. doi: 10.1210/jc.2004-1750. PMID: 15972582.15972582
267 Hosking D, Adami S, Felsenberg D, . Comparison of change in bone resorption and bone mineral density with once-weekly alendronate and daily risedronate: a randomised, placebo-controlled study. Current Medical Research & Opinion. 2003;19(5):383–94. doi: 10.1185/030079903125002009. PMID: 13678475.13678475
268 Tucci JR, Tonino RP, Emkey RD, . Effect of three years of oral alendronate treatment in postmenopausal women with osteoporosis. Am J Med. 1996 Nov;101(5):488–501. doi: 10.1016/s0002-9343(96)00282-3. PMID: 8948272.8948272
269 Reid IR, Horne AM, Mihov B, . Fracture prevention with zoledronate in older women with osteopenia. N Engl J Med. 2018 Dec 20;379(25):2407–16. doi: 10.1056/NEJMoa1808082. PMID: 30575489.30575489
270 Reid IR, Horne AM, Mihov B, . Anti-fracture efficacy of zoledronate in subgroups of osteopenic postmenopausal women: secondary analysis of a randomized controlled trial. J Intern Med. 2019 Aug;286(2):221–9. doi: 10.1111/joim.12901. PMID: 30887607.30887607
271 Reid IR, Horne AM, Mihov B, . Predictors of fracture in older women with osteopenic hip bone mineral density treated with zoledronate. Journal of Bone & Mineral Research. 2021 Jan;36(1):61–6. doi: 10.1002/jbmr.4167. PMID: 32835417.32835417
272 Grey A, Bolland M, Wong S, . Low-dose zoledronate in osteopenic postmenopausal women: a randomized controlled trial. Journal of Clinical Endocrinology & Metabolism. 2012 Jan;97(1):286–92. doi: 10.1210/jc.2011-2081. PMID: 22072741.22072741
273 Grey A, Bolland M, Mihov B, . Duration of antiresorptive effects of low-dose zoledronate in osteopenic postmenopausal women: a randomized, placebo-controlled trial. Journal of Bone & Mineral Research. 2014 Jan;29(1):166–72. doi: 10.1002/jbmr.2009. PMID: 23761303.23761303
274 Grey A, Bolland MJ, Horne A, . Duration of antiresorptive activity of zoledronate in postmenopausal women with osteopenia: a randomized, controlled multidose trial. CMAJ. 2017 Sep 11;189(36):E1130–E6. doi: 10.1503/cmaj.161207. PMID: 28893875.28893875
275 McClung MR, Bolognese MA, Sedarati F, . Efficacy and safety of monthly oral ibandronate in the prevention of postmenopausal bone loss. Bone. 2009 Mar;44(3):418–22. doi: 10.1016/j.bone.2008.09.011. PMID: 18950736.18950736
276 Bell NH, Bilezikian JP, Bone HG, 3rd, . Alendronate increases bone mass and reduces bone markers in postmenopausal African-American women. Journal of Clinical Endocrinology & Metabolism. 2002 Jun;87(6):2792–7. doi: 10.1210/jcem.87.6.8575. PMID: 12050252.12050252
277 Bone HG, Downs RW, Jr., Tucci JR, . Dose-response relationships for alendronate treatment in osteoporotic elderly women. Alendronate Elderly Osteoporosis Study Centers. Journal of Clinical Endocrinology & Metabolism. 1997 Jan;82(1):265–74. doi: 10.1210/jcem.82.1.3682. PMID: 8989272.8989272
278 Orwoll E, Teglbjaerg CS, Langdahl BL, . A randomized, placebo-controlled study of the effects of denosumab for the treatment of men with low bone mineral density. Journal of Clinical Endocrinology & Metabolism. 2012 Sep;97(9):3161–9. doi: 10.1210/jc.2012-1569. PMID: 22723310.22723310
279 Nakamura T, Matsumoto T, Sugimoto T, Shiraki M. Dose-response study of denosumab on bone mineral density and bone turnover markers in Japanese postmenopausal women with osteoporosis. Osteoporos Int. 2012(3):1131–40. doi: 10.1007/s00198-011-1786-8. PMID: CN-00843289.
280 Cummings SR, San Martin J, McClung MR, . Denosumab for prevention of fractures in postmenopausal women with osteoporosis. N Engl J Med. 2009 Aug 20;361(8):756–65. doi: 10.1056/NEJMoa0809493. PMID: 19671655.19671655
281 Simon JA, Recknor C, Moffett AH, Jr., . Impact of denosumab on the peripheral skeleton of postmenopausal women with osteoporosis: bone density, mass, and strength of the radius, and wrist fracture. Menopause. 2013 Feb;20(2):130–7. doi: 10.1097/gme.0b013e318267f909. PMID: 23010883.23010883
282 McCloskey EV, Johansson H, Oden A, . Denosumab reduces the risk of osteoporotic fractures in postmenopausal women, particularly in those with moderate to high fracture risk as assessed with FRAX. Journal of Bone & Mineral Research. 2012 Jul;27(7):1480–6. doi: 10.1002/jbmr.1606. PMID: 22431426.22431426
283 Palacios S, Kalouche-Khalil L, Rizzoli R, . Treatment with denosumab reduces secondary fracture risk in women with postmenopausal osteoporosis. Climacteric. 2015;18(6):805–12. doi: 10.3109/13697137.2015.1045484. PMID: 26029985.26029985
284 Lewiecki EM, Miller PD, McClung MR, . Two-year treatment with denosumab (AMG 162) in a randomized phase 2 study of postmenopausal women with low BMD. Journal of Bone & Mineral Research. 2007 Dec;22(12):1832–41. doi: 10.1359/jbmr.070809. PMID: 17708711.17708711
285 Bone HG, Bolognese MA, Yuen CK, . Effects of denosumab on bone mineral density and bone turnover in postmenopausal women. Journal of Clinical Endocrinology & Metabolism. 2008 Jun;93(6):2149–57. doi: 10.1210/jc.2007-2814. PMID: 18381571.18381571
286 Koh JM, Chung DJ, Chung YS, . Assessment of denosumab in Korean postmenopausal women with osteoporosis: randomized, double-blind, placebo-controlled trial with open-label extension. Yonsei Med J. 2016 Jul;57(4):905–14. doi: 10.3349/ymj.2016.57.4.905. PMID: 27189284.27189284
287 McClung M, Miller P, Recknor C, . Zoledronic acid for the prevention of bone loss in postmenopausal women with low bone mass: a randomized controlled trial. Obstetrics & Gynecology. 2009 Nov;114(5):999–1007. doi: 10.1097/AOG.0b013e3181bdce0a. PMID: 20168099.20168099
288 Chapurlat RD, Laroche M, Thomas T, . Effect of oral monthly ibandronate on bone microarchitecture in women with osteopenia-a randomized placebo-controlled trial. Osteoporos Int. 2013 Jan;24(1):311–20. doi: 10.1007/s00198-012-1947-4. PMID: 22402673.22402673
289 Bauer DC, Black D, Ensrud K, . Upper gastrointestinal tract safety profile of alendronate: the fracture intervention trial. Arch Intern Med. 2000 Feb 28;160(4):517–25. doi: 10.1001/archinte.160.4.517. PMID: 10695692.10695692
290 Cummings SR, Schwartz AV, Black DM. Alendronate and atrial fibrillation. N Engl J Med. 2007 May 3;356(18):1895–6. doi: 10.1056/NEJMc076132. PMID: 17476024.17476024
291 McClung MR, Wasnich RD, Recker R, . Oral daily ibandronate prevents bone loss in early postmenopausal women without osteoporosis. Journal of Bone & Mineral Research. 2004 Jan;19(1):11–8. doi: 10.1359/jbmr.0301202. PMID: 14753731.14753731
292 Tanko LB, Felsenberg D, Czerwinski E, . Oral weekly ibandronate prevents bone loss in postmenopausal women. J Intern Med. 2003 Aug;254(2):159–67. doi: 10.1046/j.1365-2796.2003.01174.x. PMID: 12859697.12859697
293 Thiebaud D, Burckhardt P, Kriegbaum H, . Three monthly intravenous injections of ibandronate in the treatment of postmenopausal osteoporosis. Am J Med. 1997 Oct;103(4):298–307. doi: 10.1016/s0002-9343(97)00249-0. PMID: 9382122.9382122
294 Johnell O, Scheele WH, Lu Y, . Additive effects of raloxifene and alendronate on bone density and biochemical markers of bone remodeling in postmenopausal women with osteoporosis. Journal of Clinical Endocrinology & Metabolism. 2002 Mar;87(3):985–92. doi: 10.1210/jcem.87.3.8325. PMID: 11889149.11889149
295 Shiraki M, Fukunaga M, Kushida K, . A double-blind dose-ranging study of risedronate in Japanese patients with osteoporosis (a study by the Risedronate Late Phase II Research Group). Osteoporos Int. 2003 May;14(3):225–34. doi: 10.1007/s00198-002-1369-9. PMID: 12730746.12730746
296 Adachi JD, Faraawi RY, O’Mahony MF, . Upper gastrointestinal tolerability of alendronate sodium monohydrate 10 mg once daily in postmenopausal women: a 12-week, randomized, double-blind, placebo-controlled, exploratory study. Clin Ther. 2009 Aug;31(8):1747–53. doi: 10.1016/j.clinthera.2009.08.016. PMID: 19808133.19808133
297 Cryer B, Binkley N, Simonelli C, . A randomized, placebo-controlled, 6-month study of once-weekly alendronate oral solution for postmenopausal osteoporosis. Am J Geriatr Pharmacother. 2005 Sep;3(3):127–36. doi: 10.1016/s1543-5946(05)80019-4. PMID: 16257815.16257815
298 Eisman JA, Rizzoli R, Roman-Ivorra J, . Upper gastrointestinal and overall tolerability of alendronate once weekly in patients with osteoporosis: results of a randomized, double-blind, placebo-controlled study. Current Medical Research & Opinion. 2004 May;20(5):699–705. doi: 10.1185/030079904125003548. PMID: 15140336.15140336
299 Greenspan S, Field-Munves E, Tonino R, . Tolerability of once-weekly alendronate in patients with osteoporosis: a randomized, double-blind, placebo-controlled study. Mayo Clin Proc. 2002 Oct;77(10):1044–52. doi: 10.4065/77.10.1044. PMID: 12374248.12374248
300 Greenspan SL, Resnick NM, Parker RA. Combination therapy with hormone replacement and alendronate for prevention of bone loss in elderly women: a randomized controlled trial. JAMA. 2003 May 21;289(19):2525–33. doi: 10.1001/jama.289.19.2525. PMID: 12759324.12759324
301 Reid IR, Horne AM, Mihov B, . Effects of zoledronate on cancer, cardiac events, and mortality in osteopenic older women. Journal of Bone & Mineral Research. 2020 Jan;35(1):20–7. doi: 10.1002/jbmr.3860. PMID: 31603996.31603996
302 Devogelaer JP, Broll H, Correa-Rotter R, . Oral alendronate induces progressive increases in bone mass of the spine, hip, and total body over 3 years in postmenopausal women with osteoporosis. Bone. 1996 Feb;18(2):141–50. doi: 10.1016/8756-3282(95)00436-x. PMID: 8833208.8833208
303 Watts NB, Roux C, Modlin JF, . Infections in postmenopausal women with osteoporosis treated with denosumab or placebo: coincidence or causal association? Osteoporos Int. 2012 Jan;23(1):327–37. doi: 10.1007/s00198-011-1755-2. PMID: 21892677.21892677
304 McClung MR, Lewiecki EM, Cohen SB, . Denosumab in postmenopausal women with low bone mineral density. N Engl J Med. 2006 Feb 23;354(8):821–31. doi: 10.1056/NEJMoa044459. PMID: 16495394.16495394
305 Pazianas M, Abrahamsen B, Eiken PA, . Reduced colon cancer incidence and mortality in postmenopausal women treated with an oral bisphosphonate—Danish National Register Based Cohort Study. Osteoporos Int. 2012 Nov;23(11):2693–701. doi: 10.1007/s00198-012-1902-4. PMID: 22392160.22392160
306 Rubin KH, Möller S, Choudhury A, . Cardiovascular and skeletal safety of zoledronic acid in osteoporosis observational, matched cohort study using Danish and Swedish health registries. Bone. 2020 May;134:115296. doi: 10.1016/j.bone.2020.115296. PMID: 32097760.32097760
307 Lee YK, Byun DW, Jung SM, . Bisphosphonates use and risk of subtrochanteric and diaphyseal femur fractures in Korea: results from the National Claim Registry. Calcif Tissue Int. 2019 Mar;104(3):313–9. doi: 10.1007/s00223-018-0493-2. PMID: 30446771.30446771
308 Kern LM, Powe NR, Levine MA, . Association between screening for osteoporosis and the incidence of hip fracture. Ann Intern Med. 2005 Feb 1;142(3):173–81. PMID: 15684205.15684205
309 Barr RJ, Stewart A, Torgerson DJ, Reid DM. Population screening for osteoporosis risk: a randomised control trial of medication use and fracture risk. Osteoporos Int. 2010 Apr;21(4):561–8. doi: 10.1007/s00198-009-1007-x [doi]. PMID: 19565176.19565176
310 Azagra R, Zwart M, Encabo G, . Rationale of the Spanish FRAX model in decision-making for predicting osteoporotic fractures: an update of FRIDEX cohort of Spanish women. BMC Musculoskelet Disord. 2016 Jun 17;17:262. doi: 10.1186/s12891-016-1096-6. PMID: 27317560.27317560
311 Jain RK, Weiner M, Polley E, . Electronic Health Records (EHRs) Can Identify Patients at High Risk of Fracture but Require Substantial Race Adjustments to Currently Available Fracture Risk Calculators. J Gen Intern Med. 2023 Dec;38(16):3451–9. doi: 10.1007/s11606-023-08347-5. PMID: 37715097.37715097
312 Pluskiewicz W, Werner A, Bach M, . Optimal fracture prediction thresholds for therapy onset, established from FRAX and Garvan algorithms: a longitudinal observation of the population representative female cohort from the RAC-OST-POL Study. Arch Osteoporos. 2023 Nov 16;18(1):136. doi: 10.1007/s11657-023-01346-3. PMID: 37973685.37973685
313 Zwart M, Azagra-Ledesma R, Saez M, . Predictive capacity of FRAX in a spanish region with a hip fracture rate close to the national mean. BMC Musculoskelet Disord. 2023 Jul 15;24(1):577. doi: 10.1186/s12891-023-06670-w. PMID: 37454058.37454058
314 Theriault G, Reynolds D, Pillay JJ, . Expanding the measurement of overdiagnosis in the context of disease precursors and risk factors. BMJ Evid Based Med. 2023 Jan 10. doi: 10.1136/bmjebm-2022-112117. PMID: 36627178.36627178
315 Fryar CD, Gu Q, Ogden CL. Anthropometric reference data for children and adults: United States 2007–2010. Vital and Health Statistics. Series 11, Number 252. Washington, DC: U.S. Department of Health and Human Services; October. 2012. http://www.cdc.gov/nchs/data/series/sr_11/sr11_252.pdf
316 Centre for Metabolic Bone Diseases. FRAX calculation tool. UK: University of Sheffield. https://www.sheffield.ac.uk/FRAX/tool.aspx?country=9. Accessed 14 Nov 2022.
317 Gourlay ML, Fine JP, Preisser JS, . Bone-density testing interval and transition to osteoporosis in older women. N Engl J Med. 2012 Jan 19;366(3):225–33. doi: 10.1056/NEJMoa1107142 [doi]. PMID: 22256806.22256806
318 Ayers C, Kansagara D, Lazur B, . Effectiveness and safety of treatments to prevent fractures in people with low bone mass or primary osteoporosis: a living systematic review and network meta-analysis for the American College of Physicians. Ann Intern Med. 2023 Jan 3. doi: 10.7326/m22-0684. PMID: 36592455.36592455
319 Qaseem A, Hicks LA, Etxeandia-Ikobaltzeta I, . Pharmacologic treatment of primary osteoporosis or low bone mass to prevent fractures in adults: a living clinical guideline from the American College of Physicians. Ann Intern Med. 2023 Jan 3. doi: 10.7326/m22-1034. PMID: 36592456.36592456
320 U. S. Preventive Services Task Force. Interventions to prevent falls in community-dwelling older adults: US Preventive Services Task Force recommendation statement. JAMA. 2024 Jul 2;332(1):51–7. doi: 10.1001/jama.2024.8481. PMID: 38833246.38833246
321 Bala Y, Chapurlat R, Cheung AM, . Risedronate slows or partly reverses cortical and trabecular microarchitectural deterioration in postmenopausal women. Journal of Bone & Mineral Research. 2014 Feb;29(2):380–8. doi: 10.1002/jbmr.2101 [doi]. PMID: 24115129.24115129
322 Kanis JA. Welcome to FRAX^®^. UK: World Health Organization Collaborating Centre for Metabolic Bone Diseases, University of Sheffield, UK n.d. https://www.shef.ac.uk/FRAX/. Accessed 14 Nov 2022.
323 Kanis JA, McCloskey E, Johansson H, . FRAX((R)) with and without bone mineral density. Calcif Tissue Int. 2012 Jan;90(1):1–13. doi: 10.1007/s00223-011-9544-7. PMID: 22057815.22057815
324 Reid HW, Selvan B, Batch BC, Lee RH. The break in FRAX: Equity concerns in estimating fracture risk in racial and ethnic minorities. J Am Geriatr Soc. 2021 Sep;69(9):2692–5. doi: 10.1111/jgs.17316. PMID: 34124772.34124772
325 National Institute for Health and Care Excellence. Osteoporosis: assessing the risk of fragility fracture. Clinical guideline [CG146]. Chapter 1. Guidance London: National Institute for Health and Care Excellence; 2012. https://www.nice.org.uk/guidance/cg146/chapter/1-Guidance#targeting-risk-assessment. Accessed 20 May 2021.
326 Eastell R, Rosen CJ, Black DM, . Pharmacological management of osteoporosis in postmenopausal women: an Endocrine Society clinical practice guideline. Journal of Clinical Endocrinology & Metabolism. 2019 May 1;104(5):1595–622. doi: 10.1210/jc.2019-00221. PMID: 30907953.30907953
327 Morin SN, Feldman S, Funnell L, . Clinical practice guideline for management of osteoporosis and fracture prevention in Canada: 2023 update. Cmaj. 2023 Oct 10;195(39):E1333–e48. doi: 10.1503/cmaj.221647. PMID: 37816527.37816527
328 American College of Obstetricians and Gynecologists. Osteoporosis Prevention, Screening, and Diagnosis: ACOG Clinical Practice Guideline No. 1. Obstetrics & Gynecology. 2021 Sep 1;138(3):494–506. doi: 10.1097/aog.0000000000004514. PMID: 34412075.34412075
329 American Academy of Family Physicians. Osteoporosis screening to prevent fractures. Leawood, KS: American Academy of Family Physicians; 2021. https://www.aafp.org/family-physician/patient-care/clinical-recommendations/all-clinical-recommendations/osteoporosis.html. Accessed 20 May 2021.
330 Lim LS, Hoeksema LJ, Sherin K, ACPM Prevention Practice Committee. Screening for osteoporosis in the adult U.S. population: ACPM position statement on preventive practice. Am J Prev Med. 2009 Apr;36(4):366–75. doi: 10.1016/j.amepre.2009.01.013. PMID: 19285200.19285200
331 Watts NB, Adler RA, Bilezikian JP, . Osteoporosis in men: an Endocrine Society clinical practice guideline. Journal of Clinical Endocrinology & Metabolism. 2012 Jun;97(6):1802–22. doi: 10.1210/jc.2011-3045. PMID: 22675062.22675062
332 Shoback D, Rosen CJ, Black DM, . Pharmacological management of osteoporosis in postmenopausal women: an Endocrine Society guideline update. Journal of Clinical Endocrinology & Metabolism. 2020 Mar 1;105(3). doi: 10.1210/clinem/dgaa048. PMID: 32068863.32068863
333 Gregson CL, Armstrong DJ, Bowden J, . UK clinical guideline for the prevention and treatment of osteoporosis. Arch Osteoporos. 2022 Apr 5;17(1):58. doi: 10.1007/s11657-022-01061-5. PMID: 35378630.35378630
334 North American Menopause Society. Management of osteoporosis in postmenopausal women: the 2021 position statement of The North American Menopause Society. Menopause. 2021 Sep 1;28(9):973–97. doi: 10.1097/gme.0000000000001831. PMID: 34448749.34448749
335 UK National Screening Committee. Adult screening programme: osteoporosis. 2019. https://view-health-screening-recommendations.service.gov.uk/osteoporosis/. Accessed February 8, 2023.
336 Colón-Emeric CS, Colón-Emeric CS, Pieper CF, . Can historical and functional risk factors be used to predict fractures in community-dwelling older adults? Development and validation of a clinical tool. Osteoporosis International. 2002 2002/12/01;13(12):955–61. doi: 10.1007/s001980200133.12459938
337 American Bone Health. 10-year fracture risk calculator. Raleigh, NC: American Bone Health; n.d. https://americanbonehealth.org/about-the-abh-fracture-risk-calculator/. Accessed 30 Nov 2022.
338 Kanis JA, Oden A, Johansson H, . FRAX® and its applications to clinical practice. Bone. 2009 2009/05/01;44(5):734–43. doi: 10.1016/j.bone.2009.01.373.19195497
339 Kanis JA, Johansson H, Harvey NC, McCloskey EV. A brief history of FRAX. Arch Osteoporos. 2018 Oct 31;13(1):118. doi: 10.1007/s11657-018-0510-0. PMID: 30382424.30382424
340 Kanis JA, Johansson H, Oden A, . The effects of a FRAX revision for the USA. Osteoporos Int. 2010 Jan;21(1):35–40. doi: 10.1007/s00198-009-1033-8 [doi]. PMID: 19705047.19705047
341 Kanis JA, McCloskey EV, Johansson H, . Development and use of FRAX in osteoporosis. Osteoporos Int. 2010 Jun;21 Suppl 2:S407–13. doi: 10.1007/s00198-010-1253-y [doi]. PMID: 20464374.20464374
342 Melton LJ, 3rd, Crowson CS, O’Fallon WM. Fracture incidence in Olmsted County, Minnesota: comparison of urban with rural rates and changes in urban rates over time. Osteoporos Int. 1999;9(1):29–37. doi: 10.1007/s001980050113. PMID: 10367027.10367027
343 Kanis JA, Cooper C, Dawson-Hughes B, . FRAX and ethnicity. Osteoporos Int. 2020 Nov;31(11):2063–7. doi: 10.1007/s00198-020-05631-6. PMID: 32888046.32888046
344 Lewiecki EM, Wright NC, Singer AJ. Racial disparities, FRAX, and the care of patients with osteoporosis. Osteoporos Int. 2020 Nov;31(11):2069–71. doi: 10.1007/s00198-020-05655-y. PMID: 32980922.32980922
345 Doubeni CA, Simon M, Krist AH. Addressing systemic racism through clinical preventive service recommendations from the US Preventive Services Task Force. Jama. 2021 Feb 16;325(7):627–8. doi: 10.1001/jama.2020.26188. PMID: 33492333.33492333
346 Wright NC, Chen L, Saag KG, . Racial disparities exist in outcomes after major fragility fractures. J Am Geriatr Soc. 2020 Aug;68(8):1803–10. doi: 10.1111/jgs.16455. PMID: 32337717.32337717
347 Borak J, Fiellin M, Chemerynski S. Who is Hispanic? Implications for epidemiologic research in the United States. Epidemiology. 2004 2004;15(2):240–4.15127918
348 ClinRisk. QFracture-2016 risk calculator. 2016.
349 Scotland’s Census. Scotland’s census at a glance: Ethnic groups. 2021. https://www.scotlandscensus.gov.uk/census-results/at-a-glance/ethnicity/. Accessed 13 Jan, 2022.
350 Northern Ireland Statistics and Research Agency. 2011 Census—key statistics for northern ireland. 2017. https://www.nisra.gov.uk/publications/2011-census-key-statistics-northern-ireland. Accessed 13 Jan 2023.
351 Aspinall PJ. Who is ‘Black African’ in Britain? Challenges to official categorisation of the Sub-Saharan African origin population. African Identities. 2011 2011/02;9(1):33–48. doi: 10.1080/14725843.2011.530443.
352 Landman J, Cruickshank J. A review of ethnicity, health and nutrition-related diseases in relation to migration in the United Kingdom. Public Health Nutri. 2001 2001/04;4(2b):647–57. doi: 10.1079/PHN2001148.
353 Araujo AB, Travison TG, Harris SS, . Race/ethnic differences in bone mineral density in men. Osteoporos Int. 2007 2007/07;18(7):943–53. doi: 10.1007/s00198-006-0321-9.17340219
354 Barrett-Connor E, Siris ES, Wehren LE, . Osteoporosis and fracture risk in women of different ethnic groups. J Bone Mine Res. 2005 2005/02;20(2):185–94. doi: 10.1359/JBMR.041007.
355 Looker AC, Sarafrazi Isfahani N, Fan B, Shepherd JA. Trabecular bone scores and lumbar spine bone mineral density of US adults: comparison of relationships with demographic and body size variables. Osteoporos Int. 2016 2016/08/01;27(8):2467–75. doi: 10.1007/s00198-016-3550-6.26952009
356 Nam HS, Shin MH, Zmuda JM, . Race/ethnic differences in bone mineral densities in older men. Osteoporos Int. 2010 2010/12;21(12):2115–23. doi: 10.1007/s00198-010-1188-3.20204598
357 Nam H-S, Kweon S-S, Choi J-S, . Racial/ethnic differences in bone mineral density among older women. J Bone Mine Res. 2013 2013/03/01;31(2):190–8. doi: 10.1007/s00774-012-0402-0.
358 Nelson Da, Jacobsen G, Barondess Da, Parfitt Am. Ethnic differences in regional bone density, hip axis length, and lifestyle variables among healthy black and white men. J Bone Mine Res. 1995 1995;10(5):782–7. doi: 10.1002/jbmr.5650100515.
359 Noel SE, Mangano KM, Griffith JL, . Prevalence of osteoporosis and low bone mass among Puerto Rican older adults. Journal of Bone & Mineral Research. 2018 Mar;33(3):396–403. doi: 10.1002/jbmr.3315. PMID: 29044768.29044768
360 Tracy JK, Meyer WA, Flores RH, . Racial differences in rate of decline in bone mass in older men: the Baltimore men’s osteoporosis study. J Bone Mine Res. 2005 2005/07;20(7):1228–34. doi: 10.1359/JBMR.050310.
361 George A, Tracy JK, Meyer WA, . Racial differences in bone mineral density in older men. J Bone Mine Res. 2003 2003/12;18(12):2238–44. doi: 10.1359/jbmr.2003.18.12.2238.
362 Popp KL, Hughes JM, Martinez-Betancourt A, . Bone mass, microarchitecture and strength are influenced by race/ethnicity in young adult men and women. Bone. 2017 2017/10;103:200–8. doi: 10.1016/j.bone.2017.07.014.28712877
363 Nelson DA, Barondess DA, Hendrix SL, Beck TJ. Cross-sectional geometry, bone strength, and bone mass in the proximal femur in black and white postmenopausal women. J Bone Mine Res. 2000 2000;15(10):1992–7. doi: 10.1359/jbmr.2000.15.10.1992.
364 Peacock M, Buckwalter KA, Persohn S, . Race and sex differences in bone mineral density and geometry at the femur. Bone. 2009 2009/08;45(2):218–25. doi: 10.1016/j.bone.2009.04.236.19394455
365 Misra M, Ackerman KE, Bredella MA, . Racial differences in bone microarchitecture and estimated strength at the distal radius and distal tibia in older adolescent girls: a cross-sectional study. J Racial Ethn Health Disparities. 2017 2017/08;4(4):587–98. doi: 10.1007/s40615-016-0262-8.27387309
366 Cauley JA, Lui L-Y, Stone KL, . Longitudinal study of changes in hip bone mineral density in caucasian and African-American women: bone loss by ethnicity and age. J Am Geriatr Soc. 2005 2005/02;53(2):183–9. doi: 10.1111/j.1532-5415.2005.53101.x.15673339
367 Zheng X-y, Zhou Z, Gao Y, . Racial differences and factors associated with low femoral neck bone mineral density: an analysis of NHANES 2005–2014 data. Arch Osteoporos. 2021 2021/01/06;16(1):9. doi: 10.1007/s11657-020-00850-0.33409707
368 Morton DJ, Barrett-Connor E, Kritz-Silverstein D, . Bone mineral density in postmenopausal Caucasian, Filipina, and Hispanic women. Int J Epidemiol. 2003 2003/02;32(1):150–6. doi: 10.1093/ije/dyg024.12690028
369 Gong G, Haynatzki G, Haynatzka V, . Bone mineral density of recent African immigrants in the United States. Journal of the National Medical Association. 2006 2006/05;98(5):746–52.16749650
370 Melton Iii LJ, Marquez MA, Achenbach SJ, . Variations in bone density among persons of African heritage. Osteoporos Int. 2002 2002/07;13(7):551–9. doi: 10.1007/s001980200072.12111015
371 Demeke T, El-Gawad GA, Osmancevic A, . Lower bone mineral density in Somali women living in Sweden compared with African-Americans. Arch Osteoporos. 2015 2015;10:208. doi: 10.1007/s11657-015-0208-5.25693756
372 Aspray TJ, Prentice A, Cole TJ, . Low bone mineral content is common but osteoporotic fractures are rare in elderly rural Gambian women. J Bone Mine Res. 1996 1996;11(7):1019–25. doi: 10.1002/jbmr.5650110720.
373 Dibba B, Prentice A, Laskey MA, . An investigation of ethnic differences in bone mineral, hip axis length, calcium metabolism and bone turnover between West African and Caucasian adults living in the United Kingdom. Ann Hum Biol. 1999 1999/06;26(3):229–42. doi: 10.1080/030144699282732.10355494
374 Daniels ED, Pettifor JM, Schnitzler CM, . Differences in mineral homeostasis, volumetric bone mass and femoral neck axis length in black and white South African women. Osteoporos Int. 1997 1997;7(2):105–12. doi: 10.1007/BF01623684.9166389
375 Wright NC, Looker AC, Saag KG, . The recent prevalence of osteoporosis and low bone mass in the United States based on bone mineral density at the femoral neck or lumbar spine. Journal of Bone & Mineral Research. 2014 Nov;29(11):2520–6. doi: 10.1002/jbmr.2269. PMID: 24771492.24771492
376 Finkelstein JS, Lee M-LT, Sowers M, . Ethnic variation in bone density in premenopausal and early perimenopausal women: effects of anthropometric and lifestyle factors. Journal of Clinical Endocrinology & Metabolism. 2002;87(7):3051–56. doi: 10.1210/jcem.87.7.8480.12107200
377 Harvey NC, Glüer CC, Binkley N, . Trabecular bone score (TBS) as a new complementary approach for osteoporosis evaluation in clinical practice. Bone. 2015 Sep;78:216–24. doi: 10.1016/j.bone.2015.05.016. PMID: 25988660.25988660
378 Putman MS, Yu EW, Lee H, . Differences in skeletal microarchitecture and strength in African-American and white women. Journal of Bone & Mineral Research. 2013 Oct;28(10):2177–85. doi: 10.1002/jbmr.1953 [doi]. PMID: 23572415.23572415
379 Theobald TM, Cauley JA, Gluer CC, . Black-white differences in hip geometry. Study of Osteoporotic Fractures Research Group. Osteoporos Int. 1998 1998;8(1):61–7. doi: 10.1007/s001980050049.9692079
380 Jain RK, Narang DK, Hans D, Vokes TJ. Ethnic differences in trabecular bone score. J Clin Densitom. 2017 Apr–Jun;20(2):172–9. doi: 10.1016/j.jocd.2016.04.003. PMID: 27160503.27160503
381 Marshall LM, Zmuda JM, Chan BK, . Race and ethnic variation in proximal femur structure and BMD among older men. J Bone Mine Res. 2008 2008/01;23(1):121–30. doi: 10.1359/jbmr.070908.
382 Walker MD, Liu XS, Stein E, . Differences in bone microarchitecture between postmenopausal Chinese-American and white women. J Bone Mine Res. 2011 2011/07;26(7):1392–8. doi: 10.1002/jbmr.352.
383 Leslie WD, Lix LM, Morin SN, . Hip axis length is a FRAX - and bone density-independent risk factor for hip fracture in women. Journal of Clinical Endocrinology & Metabolism. 2015 2015/05;100(5):2063–70. doi: 10.1210/jc.2014-4390.25751108
384 Cummings SR, Cauley JA, Palermo L, . Racial differences in hip axis lengths might explain racial differences in rates of hip fracture. Study of Osteoporotic Fractures Research Group. Osteoporos Int. 1994 1994/07;4(4):226–9. doi: 10.1007/BF01623243.7949753
385 Mikhail MB, Vaswani AN, Aloia JF. Racial differences in femoral dimensions and their relation to hip fracture. Osteoporos Int. 1996 1996;6(1):22–4. doi: 10.1007/BF01626533.8845595
386 Clark P, Tesoriero LJ, Morton DJ, . Hip axis length variation: its correlation with anthropometric measurements in women from three ethnic groups. Osteoporos Int. 2008 2008/09;19(9):1301–6. doi: 10.1007/s00198-008-0572-8.18301856
387 Greendale GA, Young JT, Huang M-H, . Hip axis length in mid-life Japanese and Caucasian U.S. residents: no evidence for an ethnic difference. Osteoporos Int. 2003 2003/06/01;14(4):320–5. doi: 10.1007/s00198-002-1367-y.12730747
388 Shumway-Cook A, Ciol MA, Hoffman J, . Falls in the Medicare population: incidence, associated factors, and impact on health care. Phys Ther. 2009 2009/04;89(4):324–32. doi: 10.2522/ptj.20070107.19228831
389 Kiely DK, Kim DH, Gross AL, . Fall risk is not black and white. J Health Dispar Res Pract. 2015 2015;8(3):72–84.26855845
390 Faulkner KA, Cauley JA, Zmuda JM, . Ethnic differences in the frequency and circumstances of falling in older community-dwelling women. J Am Geriatr Soc. 2005 2005;53(10):1774–9. doi: 10.1111/j.1532-5415.2005.53514.x.16181179
391 Amarnath ALD, Franks P, Robbins JA, . Underuse and overuse of osteoporosis screening in a regional health system: A retrospective cohort study. Journal of General Internal Medicine. 2015 2015/12;30(12):1733–40. doi: 10.1007/s11606-015-3349-8.25986135
392 Gourlay ML, Callahan LF, Preisser JS, Sloane PD. Osteoporosis preventive care in white and black women in community family medicine settings. Southern Medical Journal. 2007 2007/07;100(7):677–82. doi: 10.1097/SMJ.0b013e318038d45e.17639746
393 Hamrick I, Cao Q, Agbafe-Mosley D, Cummings DM. Osteoporosis healthcare disparities in postmenopausal women. J Womens Health (Larchmt). 2012 Dec;21(12):1232–6. doi: 10.1089/jwh.2012.3812 [doi]. PMID: 23140203.23140203
394 Lou Y, Edmonds SW, Jones MP, . Predictors of bone mineral density testing among older women on Medicare. Osteoporos Int. 2016 Dec;27(12):3577–86. doi: 10.1007/s00198-016-3688-2. PMID: 27358177.27358177
395 Miller RG, Ashar BH, Cohen J, . Disparities in osteoporosis screening between at-risk african-american and white women. J Gen Intern Med. 2005 2005/09;20(9):847–51. doi: 10.1111/j.1525-1497.2005.0157.x.16117754
396 Mudano AS, Casebeer L, Patino F, . Racial disparities in osteoporosis prevention in a managed care population. Southern Medical Journal. 2003 2003/05;96(5):445–51. doi: 10.1097/01.SMJ.0000053918.93363.B0.12911182
397 Neuner JM, Zhang X, Sparapani R, . Racial and socioeconomic disparities in bone density testing before and after hip fracture. J Gen Intern Med. 2007 2007/09;22(9):1239–45. doi: 10.1007/s11606-007-0217-1.17594131
398 Cunningham TD, Di Pace BS, Ullal J. Osteoporosis treatment disparities: a 6-year aggregate analysis from national survey data. Osteoporos Int. 2014 2014/09/01;25(9):2199–208. doi: 10.1007/s00198-014-2747-9.24899101
399 Hamrick I, Whetstone LM, Cummings DM. Racial disparity in treatment of osteoporosis after diagnosis. Osteoporos Int. 2006 2006/11/01;17(11):1653–8. doi: 10.1007/s00198-006-0178-y.16871433
400 Lin C-W, Karaca-Mandic P, McCullough JS, Weaver L. Access to oral osteoporosis drugs among female Medicare part D beneficiaries. Womens Health Issues. 2014 2014;24(4):e435–e45. doi: 10.1016/j.whi.2014.04.002.24837398
401 Block AE, Solomon DH, Cadarette SM, . Patient and physician predictors of post-fracture osteoporosis management. J Gen Intern Med. 2008 2008/09;23(9):1447–51. doi: 10.1007/s11606-008-0697-7.18584260
402 Boytsov NN, Crawford AG, Hazel-Fernandez LA, . Patient and provider characteristics associated with optimal post-fracture osteoporosis management. Am J Med Qual. 2017 Nov/Dec;32(6):644–54. doi: 10.1177/1062860617691123. PMID: 28693331.28693331
403 Keshishian A, Boytsov N, Burge R, . Examining the treatment gap and risk of subsequent fractures among females with a fragility fracture in the US Medicare population. Osteoporos Int. 2017 Aug;28(8):2485–94. doi: 10.1007/s00198-017-4072-6. PMID: 28536737.28536737
404 Mikuls TR, Saag KG, George V, . Racial disparities in the receipt of osteoporosis related healthcare among community-dwelling older women with arthritis and previous fracture. J Rheumatol 2005;32(5):870–5.15868624
405 Solomon DH, Brookhart MA, Gandhi TK, . Adherence with osteoporosis practice guidelines: a multilevel analysis of patient, physician, and practice setting characteristics. Am J Med. 2004 Dec;117(12):919–24. doi: 10.1016/j.amjmed.2004.06.040.15629730
406 Curtis JR, Westfall AO, Allison JJ, . Longitudinal patterns in the prevention of osteoporosis in glucocorticoid-treated patients. Arthritis & Rheumatism. 2005 2005/08;52(8):2485–94. doi: 10.1002/art.21194.16052570
407 Ruiz-Esteves KN, Teysir J, Schatoff D, . Disparities in osteoporosis care among postmenopausal women in the United States. Maturitas. 2022 Feb;156:25–9. doi: 10.1016/j.maturitas.2021.10.010. PMID: 35033230.35033230
408 Burgess DJ, Fu SS, van Ryn M. Why do providers contribute to disparities and what can be done about it? J Gen Intern Med. 2004 Nov;19(11):1154–9. doi: 10.1111/j.1525-1497.2004.30227.x. PMID: 15566446.15566446
409 Sale JEM, Bogoch E, Hawker G, . Patient perceptions of provider barriers to post-fracture secondary prevention. Osteoporosis International. 2014 2014/11/01;25(11):2581–9. doi: 10.1007/s00198-014-2804-4.25082555
410 Neuman MD, Kennelly AM, Tosi LL. Breakout session: sex/gender and racial/ethnic disparities in the care of osteoporosis and fragility fractures. Clinical Orthopaedics & Related Research. 2011 2011/07;469(7):1936–40. doi: 10.1007/s11999-011-1859-1.21424834
411 van Ryn M, Burke J. The effect of patient race and socio-economic status on physicians’ perceptions of patients. Social Science. 2000 2000:16.
412 Mossey JM. Defining racial and ethnic disparities in pain management. Clinical Orthopaedics & Related Research. 2011 2011/07;469(7):1859–70. doi: 10.1007/s11999-011-1770-9.21249483
413 Ashana DC, D’Arcangelo N, Gazarian PK, . “Don’t talk to them about goals of care”: understanding disparities in advance care planning. Journals of Gerontology. Series A: Biological Sciences & Medical Sciences. 2021 2021/03/29;77(2):339–46. doi: 10.1093/gerona/glab091.
414 Zallman L, Ma J, Xiao L, Lasser KE. Quality of US primary care delivered by resident and staff physicians. Journal of General Internal Medicine. 2010 2010/11;25(11):1193–7. doi: 10.1007/s11606-010-1456-0.20645018
415 Wieland ML, Jaeger TM, Bundrick JB, . Resident physician perspectives on outpatient continuity of care. Journal of Graduate Medical Education. 2013 2013/12/01;5(4):668–73. doi: 10.4300/JGME-05-04-40.24455021
416 Essien UR, He W, Ray A, . Disparities in quality of primary care by resident and staff physicians: is there a conflict between training and equity? Journal of General Internal Medicine. 2019 2019/07;34(7):1184–91. doi: 10.1007/s11606-019-04960-5.30963439
417 Unson CG, Siccion E, Gaztambide J, . Nonadherence and osteoporosis treatment preferences of older women: a qualitative study. J Womens Health. 2003 2003/12;12(10):1037–45. doi: 10.1089/154099903322643965.
418 Bailey ZD, Krieger N, Agénor M, . Structural racism and health inequities in the USA: evidence and interventions. The Lancet. 2017 2017/04/08;389(10077):1453–63. doi: 10.1016/S0140-6736(17)30569-X.
419 Wright NC, Melton ME, Sohail M, . Race plays a role in the knowledge, attitudes and beliefs of women with osteoporosis. J Racial Ethn Health Disparities. 2019 2019/08;6(4):707–18. doi: 10.1007/s40615-019-00569-w.30747331
420 U.S. Preventive Services Task Force. Policies and Procedure Manual, Appendix VI. Criteria for Assessing Internal Validity of Individual Studies. Rockville, MD: U.S. Preventive Services Task Force; 2017. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual/procedure-manual-appendix-vi-criteria-assessing-internal-validity-individual-studies. Accessed 18 January 2023.
421 Harris RP, Helfand M, Woolf SH, . Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3S):21–35. doi: 10.1016/S0749-3797(01)00261-6.
422 Chanplakorn P, Lertudomphonwanit T, Daraphongsataporn N, . Development of prediction model for osteoporotic vertebral compression fracture screening without using clinical risk factors, compared with FRAX and other previous models. Arch Osteoporos. 2021 Jun 3;16(1):84. doi: 10.1007/s11657-021-00957-y. PMID: 34085107.34085107
423 Agarwal A, Baleanu F, Moreau M, . External validation of FRISBEE 5-year fracture prediction models: a registry-based cohort study. Arch Osteoporos. 2022 Dec 23;18(1):13. doi: 10.1007/s11657-022-01205-7. PMID: 36564674.36564674
424 Takano Y, Furune S, Miyai Y, . Drug-induced thrombocytopenia associated with trastuzumab in a patient with HER2-positive recurrent gastric cancer. International Cancer Conference Journal. 2022;11(1):67–70. doi: 10.1007/s13691-021-00520-z.35116219
425 Unnanuntana A, Ashfaq K, Ton QV, . The effect of long-term alendronate treatment on cortical thickness of the proximal femur. Clinical Orthopaedics & Related Research. 2012 Jan;470(1):291–8. doi: 10.1007/s11999-011-1985-9 [doi]. PMID: 21773861.21773861
426 Crandall CJ. Risk assessment tools for osteoporosis screening in postmenopausal women: a systematic review. Curr Osteoporos Rep. 2015 Oct;13(5):287–301. doi: 10.1007/s11914-015-0282-z. PMID: 26233285.26233285
427 Chao AS, Chen FP, Lin YC, . Application of the World Health Organization Fracture Risk Assessment Tool to predict need for dual-energy X-ray absorptiometry scanning in postmenopausal women. Taiwan J Obstet Gynecol. 2015 Dec;54(6):722–5. doi: 10.1016/j.tjog.2015.10.005. PMID: 26700992.26700992
428 Kirilova E, Kirilov N, Bischoff F. Predictive ability of the osteoporosis self-assessment tool for assessing the risk of osteoporosis. Revmatologiia (Bulgaria). 2019;27(3):3–9.
429 Fogelman I, Ribot C, Smith R, . Risedronate reverses bone loss in postmenopausal women with low bone mass: results from a multinational, double-blind, placebo-controlled trial. BMD-MN Study Group. Journal of Clinical Endocrinology & Metabolism. 2000 May;85(5):1895–900. doi: 10.1210/jcem.85.5.6603. PMID: 10843171.10843171
430 Abrahamsen B, Pazianas M, Eiken P, . Esophageal and gastric cancer incidence and mortality in alendronate users. Journal of Bone & Mineral Research. 2012 Mar;27(3):679–86. doi: 10.1002/jbmr.1481. PMID: 22113985.22113985
431 Black DM, Geiger EJ, Eastell R, . Atypical femur fracture risk versus fragility fracture prevention with bisphosphonates. N Engl J Med. 2020 Aug 20;383(8):743–53. doi: 10.1056/NEJMoa1916525. PMID: 32813950.32813950
432 Cardwell CR, Abnet CC, Cantwell MM, Murray LJ. Exposure to oral bisphosphonates and risk of esophageal cancer. JAMA. 2010 Aug 11;304(6):657–63. doi: 10.1001/jama.2010.1098. PMID: 20699457.20699457
433 Chiang CH, Huang CC, Chan WL, . Oral alendronate use and risk of cancer in postmenopausal women with osteoporosis: a nationwide study. Journal of Bone & Mineral Research. 2012 Sep;27(9):1951–8. doi: 10.1002/jbmr.1645. PMID: 22532232.22532232
434 Choi D, Choi S, Chang J, Park SM. Exposure to oral bisphosphonates and risk of gastrointestinal cancer. Osteoporos Int. 2020 Apr;31(4):775–82. doi: 10.1007/s00198-020-05327-x. PMID: 32034451.32034451
435 Kim SH, Lee YK, Kim TY, . Incidence of and risk for osteonecrosis of the jaw in Korean osteoporosis patients treated with bisphosphonates: a nationwide cohort-study. Bone. 2021 Feb;143:115650. doi: 10.1016/j.bone.2020.115650. PMID: 32956854.32956854
436 Lee WY, Sun LM, Lin MC, . A higher dosage of oral alendronate will increase the subsequent cancer risk of osteoporosis patients in Taiwan: a population-based cohort study. PLoS One. 2012;7(12):e53032. doi: 10.1371/journal.pone.0053032. PMID: 23300854.23300854
437 Nordström P, Bergman J, Ballin M, . Bone-specific drugs and osteonecrosis of sites other than the jaw: a nationwide cohort study. Journal of Bone & Mineral Research. 2020 Sep;35(9):1703–10. doi: 10.1002/jbmr.4040. PMID: 32379370.32379370
438 Passarelli MN, Newcomb PA, LaCroix AZ, . Oral bisphosphonate use and colorectal cancer incidence in the women’s health initiative. Journal of Bone & Mineral Research. 2013 Sep;28(9):2043–8. doi: 10.1002/jbmr.1930. PMID: 23519920.23519920
439 Rodríguez AJ, Ernst MT, Nybo M, . Oral bisphosphonate use reduces cardiovascular events in a cohort of Danish patients referred for bone mineral density. Journal of Clinical Endocrinology & Metabolism. 2020 Oct 1;105(10). doi: 10.1210/clinem/dgaa481. PMID: 32717068.32717068
440 Thadani SR, Ristow B, Blackwell T, . Relationship of bisphosphonate therapy and atrial fibrillation/flutter: outcomes of Sleep Disorders in Older Men (MrOS Sleep) study. Chest. 2016 May;149(5):1173–80. doi: 10.1016/j.chest.2015.11.022. PMID: 26836889.26836889
441 Vestergaard P. Occurrence of gastrointestinal cancer in users of bisphosphonates and other antiresorptive drugs against osteoporosis. Calcif Tissue Int. 2011 Dec;89(6):434–41. doi: 10.1007/s00223-011-9539-4. PMID: 22002678.22002678
442 Wang JC, Chien WC, Chung CH, . Adverse cardiovascular effects of nitrogen-containing bisphosphonates in patients with osteoporosis: a nationwide population-based retrospective study. Int J Cardiol. 2016 Jul 15;215:232–7. doi: 10.1016/j.ijcard.2016.04.088. PMID: 27128537.27128537
443 Yang HY, Huang JH, Chiu HW, . Vitamin D and bisphosphonates therapies for osteoporosis are associated with different risks of atrial fibrillation in women: a nationwide population-based analysis. Medicine (Baltimore). 2018 Oct;97(43):e12947. doi: 10.1097/md.0000000000012947. PMID: 30412111.30412111
444 Yuh DY, Chang TH, Huang RY, . The national-scale cohort study on bisphosphonate-related osteonecrosis of the jaw in Taiwan. J Dent. 2014 Oct;42(10):1343–52. doi: 10.1016/j.jdent.2014.05.001. PMID: 24907558.24907558
445 Thomsen K, Ryg J, Matzen L, . Choice of osteoporosis guideline has important implications for the treatment decision in elderly women referred to a fall clinic. Dan Med J. 2014 Dec;61(12):A4980. PMID: 25441734.25441734
446 Tarantino U, Rao C, Tempesta V, . Hip fractures in the elderly: the role of cortical bone. Injury. 2016 Oct;47 Suppl 4:S107–s11. doi: 10.1016/j.injury.2016.07.058. PMID: 27558243.27558243
447 Baccaro LF, De Souza Santos Machado V, Costa-Paiva L, . Factors associated with osteoporosis in Brazilian women: a population-based household survey. Arch Osteoporos. 2013;8(1–2).
448 Torgerson DJ, Donaldson C, Russell IT, Reid DM. Hormone replacement therapy: compliance and cost after screening for osteoporosis. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 1995 Mar;59(1):57–60. doi: 10.1016/0028-2243(94)02002-v. PMID: 7781863.7781863
449 Koh LKH, Ben Sedrine W, Torralba TP, . A simple tool to identify Asian women at increased risk of osteoporosis. Osteoporosis International. 2001;12(8):699–705. doi: DOI 10.1007/s001980170070. PMID: WOS:000171206900011.11580084
450 Bazzocchi A, Ponti F, Diano D, . Trabecular bone score in healthy ageing. Br J Radiol. 2015 Aug;88(1052):20140865. doi: 10.1259/bjr.20140865 [doi]. PMID: 26148778.26148778
451 Frost SA, Nguyen ND, Center JR, . Timing of repeat BMD measurements: development of an absolute risk-based prognostic model. Journal of Bone & Mineral Research. 2009 Nov;24(11):1800–7. doi: 10.1359/jbmr.090514. PMID: 19419321.19419321
452 Gourlay ML, Overman RA, Fine JP, . Baseline age and time to major fracture in younger postmenopausal women. Menopause. 2015 Jun;22(6):589–97. doi: 10.1097/GME.0000000000000356 [doi]. PMID: 25349960.25349960
453 Looker AC, Sarafrazi Isfahani N, Fan B, Shepherd JA. FRAX-based estimates of 10-year probability of hip and major osteoporotic fracture among adults aged 40 and over: United States, 2013 and 2014. Natl Health Stat Report. 2017 Mar(103):1–16. PMID: 28459415.28459415
454 Chotiyarnwong P, McCloskey EV, Harvey NC, . Is it time to consider population screening for fracture risk in postmenopausal women? A position paper from the International Osteoporosis Foundation Epidemiology/Quality of Life Working Group. Arch Osteoporos. 2022 Jun 28;17(1):87. doi: 10.1007/s11657-022-01117-6. PMID: 35763133.35763133
455 US Census Bureau. American Community Survey 2016–2020 5-Year Data Release. Washington, DC: U.S. Census Bureau; 2022.
456 Bolland MJ, Grey A. Disparate outcomes from applying U.K. and U.S. osteoporosis treatment guidelines. Journal of Clinical Endocrinology & Metabolism. 2010 Apr;95(4):1856–60. doi: 10.1210/jc.2009-2157. PMID: 20147581.20147581
457 McCloskey E, Kanis JA, Johansson H, . FRAX-based assessment and intervention thresholds--an exploration of thresholds in women aged 50 years and older in the UK. Osteoporos Int. 2015 Aug;26(8):2091–9. doi: 10.1007/s00198-015-3176-0. PMID: 26077380.26077380
458 Kanis JA, Johansson H, Harvey NC, . An assessment of intervention thresholds for very high fracture risk applied to the NOGG guidelines: a report for the National Osteoporosis Guideline Group (NOGG). Osteoporos Int. 2021 Apr 4. doi: 10.1007/s00198-021-05942-2. PMID: 33813622.33813622
459 Shane E, Burr D, Abrahamsen B, . Atypical subtrochanteric and diaphyseal femoral fractures: second report of a task force of the American Society for Bone and Mineral Research. Journal of Bone & Mineral Research. 2014 Jan;29(1):1–23. doi: 10.1002/jbmr.1998. PMID: 23712442.23712442
460 Adler RA, El-Hajj Fuleihan G, Bauer DC, . Managing osteoporosis in patients on long-term bisphosphonate treatment: report of a task force of the American Society for Bone and Mineral Research. Journal of Bone & Mineral Research. 2016 Jan;31(1):16–35. doi: 10.1002/jbmr.2708. PMID: 26350171.26350171
461 Lu L, Lu L, Zhang J, Li J. Potential risks of rare serious adverse effects related to long-term use of bisphosphonates: an overview of systematic reviews. Journal of Clinical Pharmacy & Therapeutics. 2020 Feb;45(1):45–51. doi: 10.1111/jcpt.13056. PMID: 31608489.31608489
462 Dennison EM, Cooper C, Kanis JA, . Fracture risk following intermission of osteoporosis therapy. Osteoporos Int. 2019 Sep;30(9):1733–43. doi: 10.1007/s00198-019-05002-w. PMID: 31175404.31175404
463 Fink HA, MacDonald R, Forte ML, . Long-term drug therapy and drug discontinuations and holidays for osteoporosis fracture prevention: a systematic review. Ann Intern Med. 2019 Jul 2;171(1):37–50. doi: 10.7326/m19-0533. PMID: 31009947.31009947
464 Won SH, Ahn S, Ji E, . Hip and subtrochanteric or femoral shaft fractures after bisphosphonate use in Korean women, using Korean national sample cohort. J Korean Med Sci. 2020 Jun 29;35(25):e193. doi: 10.3346/jkms.2020.35.e193. PMID: 32597040.32597040
465 Lo JC, Grimsrud CD, Ott SM, . Atypical femur fracture incidence in women increases with duration of bisphosphonate exposure. Osteoporos Int. 2019 Dec;30(12):2515–20. doi: 10.1007/s00198-019-05112-5. PMID: 31555883.31555883
466 Lo JC, Neugebauer RS, Ettinger B, . Risk of complete atypical femur fracture with oral bisphosphonate exposure beyond three years. BMC Musculoskelet Disord. 2020 Dec 3;21(1):801. doi: 10.1186/s12891-020-03672-w. PMID: 33272248.33272248
467 Bone HG, Wagman RB, Brandi ML, . 10 years of denosumab treatment in postmenopausal women with osteoporosis: results from the phase 3 randomised FREEDOM trial and open-label extension. Lancet Diabetes Endocrinol. 2017 Jul;5(7):513–23. doi: 10.1016/s2213-8587(17)30138-9. PMID: 28546097.28546097
468 Ruggiero SL, Dodson TB, Fantasia J, . American Association of Oral and Maxillofacial Surgeons position paper on medication-related osteonecrosis of the jaw--2014 update. Journal of Oral & Maxillofacial Surgery. 2014 Oct;72(10):1938–56. doi: 10.1016/j.joms.2014.04.031. PMID: 25234529.25234529
469 Anastasilakis AD, Pepe J, Napoli N, . Osteonecrosis of the jaw and antiresorptive agents in benign and malignant diseases: a critical review organized by the ECTS. Journal of Clinical Endocrinology & Metabolism. 2022 Apr 19;107(5):1441–60. doi: 10.1210/clinem/dgab888. PMID: 34922381.34922381
470 Everts-Graber J, Reichenbach S, Gahl B, . Risk factors for vertebral fractures and bone loss after denosumab discontinuation: a real-world observational study. Bone. 2021 Mar;144:115830. doi: 10.1016/j.bone.2020.115830. PMID: 33359006.33359006
471 Tanaka S, Mizutani H, Tsuruya E, . Long-term safety and effectiveness of denosumab in Japanese patients with osteoporosis: 3-year post-marketing surveillance study. Journal of Bone & Mineral Metabolism. 2021 May;39(3):463–73. doi: 10.1007/s00774-020-01180-4. PMID: 33387064.33387064
472 Tsourdi E, Zillikens MC, Meier C, . Fracture risk and management of discontinuation of denosumab therapy: a systematic review and position statement by ECTS. Journal of Clinical Endocrinology & Metabolism. 2020 Oct 26. doi: 10.1210/clinem/dgaa756. PMID: 33103722.33103722
473 Brown JP, Roux C, Torring O, . Discontinuation of denosumab and associated fracture incidence: analysis from the Fracture Reduction Evaluation of Denosumab in Osteoporosis Every 6 Months (FREEDOM) trial. Journal of Bone & Mineral Research. 2013 Apr;28(4):746–52. doi: 10.1002/jbmr.1808 [doi]. PMID: 23109251.23109251
474 Cummings SR, Ferrari S, Eastell R, . Vertebral fractures after discontinuation of denosumab: a post hoc analysis of the randomized placebo-controlled FREEDOM trial and its extension. Journal of Bone & Mineral Research. 2018 Feb;33(2):190–8. doi: 10.1002/jbmr.3337. PMID: 29105841.29105841
475 McClung MR, Wagman RB, Miller PD, . Observations following discontinuation of long-term denosumab therapy. Osteoporos Int. 2017 May;28(5):1723–32. doi: 10.1007/s00198-017-3919-1. PMID: 28144701.28144701
476 Anastasilakis AD, Polyzos SA, Makras P, . Clinical features of 24 patients with rebound-associated vertebral fractures after denosumab discontinuation: systematic review and additional cases. Journal of Bone & Mineral Research. 2017 Jun;32(6):1291–6. doi: 10.1002/jbmr.3110. PMID: 28240371.28240371
477 Burckhardt P, Faouzi M, Buclin T, Lamy O. Fractures after denosumab discontinuation: a retrospective study of 797 cases. Journal of Bone & Mineral Research. 2021 May 19;36:1717–28. doi: 10.1002/jbmr.4335. PMID: 34009703.34009703
478 Lyu H, Yoshida K, Zhao SS, . Delayed denosumab injections and fracture risk among patients with osteoporosis: a population-based cohort study. Ann Intern Med. 2020 Oct 6;173(7):516–26. doi: 10.7326/m20-0882. PMID: 32716706.32716706
479 Tripto-Shkolnik L, Fund N, Rouach V, . Fracture incidence after denosumab discontinuation: real-world data from a large healthcare provider. Bone. 2020 Jan;130:115150. doi: 10.1016/j.bone.2019.115150. PMID: 31715340.31715340