# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Howard Tracer, MD, AHRQ Medical Officer and Brandy Peaker, MD, MPH, former AHRQ Medical Officer; Tracy Wolff, MD, MPH, AHRQ Scientific Director for the USPSTF; current and former members of the U.S. Preventive Services Task Force; expert peer reviewers Carolyn Crandall, MD, MS, MACP, Kristine Ensrud, MD, MPH, Guylene Theriault, MD, CCFP, and one reviewer who wishes to remain anonymous. In addition, we thank several federal partner reviewers including two from the Centers for Disease Control and Prevention National Center for Injury Prevention and Control Division of Injury Prevention, one from the National Institute on Aging, and three from the National Institute of Arthritis and Musculoskeletal and Skin Diseases. We also thank Megan Van Noord, MSIS, librarian; Sharon Barrell, MA, and Mary Gendron, BA, editors; Teyonna Downing and Michelle Bogus, publications specialists; and Kayla Giger, research assistant. The authors also acknowledge the contributions of Corrine V. Evans, MPP, and Eric S. Johnson, PhD, to the Prediction model study Risk Of Bias Assessment Tool (PROBAST) ratings for the Fracture Risk Assessment Tool (FRAX^®^) and QFracture Development Cohorts that appear in Appendix G of this report.