# Chapter 4 Discussion

## Summary of Evidence

Table 3 summarizes the evidence synthesized in this report by KQ and provides our EPC’s assessment of the strength of evidence (SOE) and applicability. Compared with the prior review on this topic,^3^ our certainty as reflected in our SOE ratings has increased as a result of new direct evidence for KQ 1. Whereas our previous SOE rating for KQ 1 was insufficient for mortality and fracture outcomes except hip (which was rated as low SOE for benefit in the prior review), in this update we rated MOF and hip fracture outcomes as moderate SOE for benefit, osteoporotic fractures as low SOE for benefit, and mortality as low for no effect. We continue to grade the direct evidence as insufficient for harms of screening (KQ 3) but have identified additional data on overdiagnosis for consideration compared with the prior review.

Table 3 Summary of Evidence Screening for Osteoporosis to Prevent Fracture

Key Question | Intervention or Test/Outcome | No. of Studies (No. of Participants) | Summary of Findings | Consistency and Precision | Limitations | Strength of Evidence | Applicability
1 Benefits of Screening | Fractures | 3 RCTs^120–129^ (42,009 using ROSE per protocol 1 population); 3 SRs^120,^ ^124,^ ^126,^ ^130–133^ | Hip fractures pooled RR, 0.83 (95% CI, 0.73 to 0.93); ARD, 5 fewer per 1,000 (95% CI, from 7 fewer to 2 fewer); MOF pooled RR, 0.94 (95% CI, 0.88 to 0.99); ARD, 6 fewer per 1,000 (95% CI, from 12 fewer to 1 fewer); Osteoporotic fractures pooled RR, 0.95 (95% CI, 0.91 to 1.01); ARD, 6 fewer per 1,000 (95% CI, from 11 fewer to 1 more); Estimates from SRs consistent. | Consistent, precise for hip and MOF, imprecise for osteoporotic fracture | Modest screening uptake and adherence to treatment among those treated; contamination in control groups; followup for only 3.7 to 5 years | Moderate^*^ for benefit on MOF and hip fracture; Low^†^ for benefit on osteoporotic fractures | Two-stage screening used by 2 studies; European women age 60 years or older at high baseline fracture risk; extensive screening battery (imaging, labs, falls assessment) used in 1 study
1 Benefits of Screening | Mortality | 3 RCTs^120–129^ ^120,^ ^124,^ ^126^ (57,633); 1 SR^131,^ ^132^ | Pooled RR, 0.99 95% CI, 0.95 to 1.04); ARD, 1 fewer per 1,000; (95% CI, from 5 fewer to 4 more); Estimates from SR consistent. | Consistent, imprecise | Same as above | Low^†^ for no effect | Same as above
2a Predictive Accuracy of Risk Assessment Instruments | Calibration (MOF and Hip Fracture) | Two SRs^131,^ ^132,^ ^137^ and 25 cohorts reported in 40 articles^72,^ ^73,^ ^139,^ ^141–158,^ ^160,^ ^161,^ ^163–173,^ ^176,^ ^177,^ ^181,^ ^311–313^ (Unable to estimate precisely due to overlap in reporting for some cohorts) | Reported for 6 instruments: FRAX, FREM, FRC, Garvan, OST, QFracture; FRAX (28 articles from 20 unique cohorts): reasonably calibrated in some cohorts and poorly calibrated in other cohorts.; Too few studies and outcomes reported for instruments other than FRAX. | Varied by instrument | All studies high risk of bias | Low^‡^ for FRAX for poor to modest calibration; Insufficient^§^ for FRC, FREM, Garvan, OST, QFracture | Studies included postmenopausal women and men
2a Predictive Accuracy of Risk Assessment Instruments | Discrimination (MOF and Hip Fracture) | Four SRs^134–137^ 16 cohorts published in 25 articles^73,^ ^139–143,^ ^146,^ ^159,^ ^160,^ ^163,^ ^165,^ ^172–181,^ ^311,^ ^312^ (Unable to estimate precisely due to overlap in reporting for some cohorts) | Reported for 11 instruments: EPIC, FRAX, FRC, FREM Garvan Fracture Risk Calculator, ORAI, OSIRIS, OST, QFracture, SCORE, WHI Prediction Model.; AUC range; Younger women (<65): 0.52 to 0.71; Women: 0.63 to 0.89; Men: 0.63 to 0.93; Mixed sex: 0.61 to 0.88; FRAX, FRC, and Garvan instruments with BMD had higher AUCs compared with same instrument without BMD.; AUCs higher for prediction of hip fracture compared with MOF for FRAX, FRC and QFracture, and Garvan. | Varied by instrument | All studies high risk of bias for development cohorts and for external validation cohorts | Low^ǁ^ for FRAX, FRC, Garvan, QFracture for poor to modest discrimination; Insufficient^§^ for EPIC, FREM, OST, SCORE, WHI | Studies included postmenopausal women and men, but not for all instruments
2b Predictive Accuracy of BMD | Calibration (MOF and Hip Fracture) | 4 articles from 4 unique cohorts^146,^ ^150,^ ^185,^ ^192^ (18,145) | Consistent calibration measures not reported across studies; calibration poor in some studies and good in others for prediction of MOF or hip fracture. | Inconsistent; unable to judge precision | Not the primary aim of any study; not enough fracture events in some studies, particularly for hip fractures | Insufficient^¶^ | Cohorts include both men and women; persons with known osteoporosis or on treatment excluded from some cohorts; BMD typically measured at FN
2b Predictive Accuracy of BMD | Discrimination (MOF and Hip Fracture) | 18 articles from 16 unique cohorts^146,^ ^150,^ ^151,^ ^154,^ ^156,^ ^157,^ ^166,^ ^172,^ ^175,^ ^176,^ ^179,^ ^183,^ ^185,^ ^187,^ ^189,^ ^190,^ ^193,^ ^194^(101,446) | AUC range; MOF: 0.60 to 0.80 (13 cohorts; 15 estimates); Hip: 0.64 to 0.86 (12 cohorts; 14 estimates); Threshold T-score <−2.5; Sn MOF: 17.5% to 51.3% (5 studies); Sn Hip: 25.0% to 66.7% (5 studies); Sp MOF: 70.9% to 95.4% (3 studies); Sp Hip: 88.6% to 94.0% (4 studies) | Inconsistent, precise | 10 analyses were high ROB; predictive accuracy of BMD not the primary aim of any study | Low^ǁ^ for poor to modest discrimination | Same as above
2c Diagnostic Accuracy (Women and Men) | FRAX/Discrimination | MOF risk 15 studies from 12 unique cohorts^141,^ ^143,^ ^195,^ ^196,^ ^200,^ ^220,^ ^232–239,^ ^241^ (37,756/85% women); Hip fx risk 3 studies from 3 unique cohorts^196,^ ^233,^ ^239^ (1,710/52% women) | MOF (9.3% or 8.4% risk threshold); Women ages 50–64 (3 estimates); AUC: 0.55 to 0.62; Sn: 5% to 49%; Sp: 63% to 96%; Men (2 estimates); AUC: 0.62 to 0.79; Sn: 39% to 59%; Sp: 59% to 89%; MOF (>20% risk threshold); Women age ≥60 (1 estimate); AUC: 0.71 (95% CI, 0.60 to 0.82); Sn: 17%; Sp: 96%; Men (1 estimate); Sn: 0%; Sp: 99%; Mixed sex (1 estimate); AUC: 0.76 (95% CI, 0.71 to 0.81); MOF (various thresholds or no threshold); Women ages 50–64 (2 estimates); AUC: 0.64 to 0.72; Men (1 estimate); AUC: 0.62; Mixed sex (1 estimate); AUC: 0.68 (95% CI, 0.63 to 0.72); Hip (>3% risk threshold); Women age ≥60 (1 estimate); AUC: 0.75 (95% CI, 0.65 to 0.86); Sn: 83%; Sp: 54%; Men (1 estimate); AUC: 0.86 (95% CI, 0.73 to 0.98); Sn: 80%; Sp: 71%; Mixed sex (1 estimate); AUC: 0.70 (95% CI, 0.64 to 0.75) | Inconsistent; precise | Heterogeneity in BMD sites measured; all but 1 fair quality because of unclear methods for patient selection and risk for selection bias, lack of blinding of index or reference test results, unclear BMD reference range used for T-score, unclear interval between risk assessment and BMD measurement | Low^ǁ^ for poor to modest discrimination | Men and post-menopausal women from community or clinic-based populations; FRAX risk assessment without BMD input into calculation; some studies used EHR data to determine FRAX risks
2c Diagnostic Accuracy | OST/Discrimination | 31 studies from 29 cohorts^143,^ ^159,^ ^195,^ ^196,^ ^198–201,^ ^203,^ ^205,^ ^208–210,^ ^214,^ ^216–219,^ ^221,^ ^223,^ ^225,^ ^228,^ ^230,^ ^231,^ ^234–237,^ ^240,^ ^242,^ ^243^ (80,592/82% women) | AUC (95% CI) or range:; Women (20 estimates): 0.32 to 0.89; Women ages 50 to 64 (3 estimates): 0.63 to 0.75; Men (10 estimates): 0.63 to 0.89; Mixed sex (1 estimate): 0.76 (0.71 to 0.82); At a score threshold of <2:; Women (11 estimates); Sn range: 53% to 95%; Sp range: 37% to 72%; Women ages 50 to 64 (3 estimates); Sn range: 56% to 79%; Sp range: 56% to 70%; Men (7 estimates); Sn range: 62% to 89%; Sp range: 36% to 74% | Inconsistent; precise | All but 1 fair quality; similar limitations as for FRAX above | Low^ǁ^ for poor to modest discrimination | Men and post-menopausal women from community or clinic-based populations
2c Diagnostic Accuracy (Women) | Other risk assessments/Discrimination | 29 studies from 26 cohorts^195,^ ^199,^ ^203,^ ^204,^ ^206–211,^ ^213–215,^ ^217,^ ^222–228,^ ^230,^ ^231,^ ^233,^ ^234,^ ^236,^ ^239,^ ^242,^ ^245^ (30,621) | AUC range: 0.32 to 0.87 (25 estimates); Across various thresholds:; Sn: 28% to 100% (24 estimates); Sp: 5% to 100% (24 estimates) | Inconsistent; precision varies by instrument | All fair quality, similar limitations as for FRAX above | Low^ǁ^ for poor to modest discrimination (ABONE, NOF, ORAI, OSIRIS, OSTA, SCORE); Insufficien^¶^ (AMMEB, Garvan FRC, SOFSURF) | Postmenopausal women from community and clinic-based populations
2c Diagnostic Accuracy (Men) | Other risk Assessments/Discrimination | 21 studies^196–198,^ ^201,^ ^202,^ ^212,^ ^216,^ ^218,^ ^219,^ ^221,^ ^229,^ ^232,^ ^233,^ ^235,^ ^237,^ ^238,^ ^240,^ ^241,^ ^243,^ ^244^ ^196–198,^ ^201,^ ^202,^ ^212,^ ^216,^ ^218,^ ^219,^ ^221,^ ^229,^ ^232,^ ^233,^ ^235,^ ^237,^ ^238,^ ^240,^ ^241,^ ^243,^ ^244^ (24,258) | AUC range: 0.64 to 0.88 in the studies exclusively enrolling men and evaluating instruments developed specifically for men;; AUC range: 0.62 to 0.94 from the male population component of the studies with mixed populations. | Inconsistent, precision varies by instrument | All but 1 study fair quality; similar limitations as for FRAX above | Low^ǁ^ for poor to modest discrimination (FRAX, MORES, MOST, OST, OSTA); Insufficient^¶^ (ABONE, Garvan FRC, MSCORE, ORAI, OSIRIS, SCORE, VA-FARA) | Men mostly from clinic-based populations
2d Repeat Screening | BMD at baseline and repeat BMD | 5 studies^246–250^ (19,957) | Predictive accuracy of repeat BMD at 4 to 8 years after initial BMD was similar to predictive accuracy of initial BMD for predicting MOF and hip fractures over followup of 8 to 11 years after repeat BMD. | Consistent; precise | Two studies were poor quality; 3 were fair quality; indirect evidence | Moderate^#^ for no added value of repeat DXA | 1 study exclusively in men; 1 study with 40% men; mean age 60 to 75 years across studies
3 Harms of Screening | Anxiety | 1 RCT^120^ (12,483) | No difference in anxiety between screening and control participants over 5 years (P=0.515). | Single study, consistency unknown; Precision unknown | Fair-quality pragmatic trial; only modest uptake and adherence of intervention | Insufficient^§^ | Two-stage screening approach in U.K. women ages 70 to 85 years
3 Harms of Screening | Overdiagnosis | 1 SR^131^ (NA) | Based on data from 2 included RCTs, overdiagnosis estimated to range from 11.8% to 24.1%. | Single review, consistency unknown; Precision unknown | Good quality SR; however, included RCTs are fair quality; method for estimating overdiagnosis for being labeled as “high risk” is evolving | Insufficient (based on extrapolations) | Two-stage screening in U.K. women ages 70 to 85 years in 1 study; Dutch women age 60 years or older at high baseline fracture risk and used extensive screening battery (imaging, labs, falls assessment) in other study
4 Benefits of Treatment | Bis-phosphonates Vertebral Fx (clinical and radiographic) | 10 RCTs^251–254,^ ^256,^ ^258,^ ^260,^ ^261,^ ^269,^ ^277^ (9,015) | Pooled RR, 0.51 (95% CI, 0.39 to 0.66); ARD, 18 fewer per 1,000 (95% CI, from 23 fewer to 13 fewer) | Consistent, precise | Most studies fair quality; evidence dominated by 3 of the larger studies; 5 studies had zero events in at least 1 study arm | Moderate^*^ for benefit | Only 1 study in men; the rest were in mostly White post-menopausal women with low bone mass or osteoporosis
4 Benefits of Treatment | Bis-phosphonates Nonvertebral Fx | 13 RCTs^251,^ ^252,^ ^254,^ ^256–261,^ ^268,^ ^269,^ ^272,^ ^277^ (20,929) | Pooled RR, 0.81 (95% CI, 0.74 to 0.88); ARD, 28 fewer per 1,000 (95% CI, from 38 fewer to 18 fewer) | Consistent, precise | Most studies fair quality, evidence dominated by 6 larger studies; 2 studies had zero events in at least 1 arm | Moderate^*^ for benefit | Only 1 study in men; the rest were in mostly White post-menopausal women with low bone mass or osteoporosis
4 Benefits of Treatment | Bis-phosphonates Hip Fx | 6 RCTs^254,^ ^256–259,^ ^269^ (12,055) | Pooled RR, 0.67 (95% CI, 0.45 to 1.0); ARD, 3 fewer per 1,000 (95% CI, from 5 fewer to 0 fewer) | Consistent, imprecise | Most studies fair quality; none were powered to evaluate hip fractures; 1 study had zero events in at least 1 arm | Low^†^ for benefit | All studies in mostly White postmenopausal women with low bone mass or osteoporosis
4 Benefits of Treatment | Bis-phosphonates Mortality | 6 RCTs^251,^ ^264–266,^ ^269,^ ^275^ (3,714) | Pooled RR, 0.71 (95% CI, 0.49 to 1.05); ARD, 10 fewer per 1,000 (95% CI, from 17 fewer to 2 more) | Consistent, imprecise | Same as above | Low^†^ for benefit | Only 1 study in men, the rest were in mostly White post-menopausal women with low bone mass or osteoporosis
4 Benefits of Treatment | Denosumab Vertebral Fx | 4 RCTs^278–280,^ ^285^ (8,179) | Evidence base dominated by; FREEDOM study (n=7,808 women), RR, 0.32 (95% CI, 0.26 to 0.41), ARD, 48 fewer per 1,000 participants (95% CI, from 52 fewer to 42 fewer); All other studies with 0 to 1 event per arm; pooled RR across all 4 RCTs, 0.33 (95% CI, 0.26 to 0.41); ARD, 44 fewer per 1,000 persons (95% CI, from 49 fewer to 39 fewer) | Consistent, precise | All studies fair quality; evidence dominated by 1 study; outcome included both clinical and asymptomatic morphometric fractures | Moderate^*^ for benefit | Post-menopausal women with osteoporosis or low bone mass; 1 study was only in men but had only 1 fracture event
4 Benefits of Treatment | Denosumab Nonvertebral Fx | 3 RCTs^278,^ ^280,^ ^285^ (8,382) | Evidence base dominated by FREEDOM study (n=7,808 women), RR, 0.80 (95% CI, 0.67 to 0.95); ARD, 15 fewer per 1,000 participants (95% CI, from 24 fewer to 4 fewer); Across all 3 RCTs, pooled RR, 0.80 (95% CI, 0.68 to 0.94), ARD, 14 fewer per 1,000 (95% CI, from 23 fewer to 4 fewer) | Consistent, imprecise | Fair quality studies; evidence dominated by 1 large study | Low^†^ for benefit | Postmenopausal women with osteoporosis or low bone mass; 1 trial was only in men but had only 3 events
4 Benefits of Treatment | Densoumab Hip Fx | 2 RCTs^278,^ ^280^ (8,050) | Evidence base dominated by; FREEDOM study (n=7,808 women), 0.7% vs. 1.1%; RR, 0.60 (95% CI, 0.37 to 0.97), ARD, 4 fewer per 1,000 (95% CI, from 7 fewer to 0 fewer); 0 events in the other trial involving 242 men; Across both studies, pooled RR, 0.61 (95% CI, 0.38 to 0.99), ARD 4 fewer per 1,000 (95% CI, from 7 fewer to 0 fewer) | Consistent, imprecise | Fair quality; large trial with uncertainties in random-ization/allocation concealment, blinding, and attrition; no events in the other trial | Low^†^ for benefit | Postmenopausal women with osteoporosis or low bone mass; smaller trial was only in men but had no fracture events
4 Benefits of Treatment | Denosumab Mortality | 5 RCTs^278,^ ^280,^ ^284–286^ (8,828) | Pooled RR, 0.79 (95% CI, 0.58 to 1.07); ARD, 4 fewer per 1,000 (95% CI, from 9 fewer to 1 more) | Consistent, imprecise | Fair quality; some un-certainties in randomization for 3 studies, allocation concealment in 4 studies, and attrition and blinding in 2 studies | Low^†^ for benefit | Postmenopausal women with osteoporosis or low bone mass; 1 trial only in men but had only 2 events
5 Harms of Treatment | Bis-phosphonates Discontinuations due to AEs | 27 RCTs^252–254,^ ^256–261,^ ^264,^ ^266–268,^ ^272,^ ^275–277,^ ^288,^ ^291–294,^ ^296–299,^ ^302^ (18,617) | Based on 24 RCTs:; Pooled RR, 1.00 (95% CI, 0.92 to 1.08);; ARD, 0 fewer per 1,000 (95% CI, from 9 fewer to 9 more) | Consistent, precise | Most studies fair quality, none powered for this outcome | Moderate^*^ for no effect | Mostly White postmenopausal women with low bone mass or osteoporosis
5 Harms of Treatment | Bis-phosphonates SAEs | 22 RCTs^251,^ ^257,^ ^259–261,^ ^264,^ ^266–268,^ ^272,^ ^275,^ ^276,^ ^287,^ ^288,^ ^291–293,^ ^295–297,^ ^299,^ ^302^ (13,878) | Based on 21 RCT comparisons:; Pooled RR, 0.97 (95% CI, 0.91 to 1.04);; ARD, 6 fewer per 1,000 (95% CI, from 18 fewer to 8 more) | Consistent, precise | Most studies fair quality, none powered for this outcome, not long enough to detect rare harms | Moderate^†^ for no effect | Only 1 study exclusively in men, the rest were in mostly White post-menopausal women with low bone mass or osteoporosis
5 Harms of Treatment | Bis-phosphonates Upper GI AEs | 26 RCTs^252,^ ^256–259,^ ^261,^ ^264,^ ^266–269,^ ^272,^ ^275,^ ^276,^ ^289,^ ^291–300,^ ^302^ (22,280) | Pooled RR, 1.02 (95% CI, 0.98 to 1.06); ARD, 5 more per 1,000 (95% CI, from 5 fewer to 16 more) | Consistent, precise | Most studies fair quality, none powered for this outcome | Moderate^*^ for no effect | Mostly White postmenopausal women with low bone mass or osteoporosis
5 Harms of Treatment | Denosumab Discontinuations due to AEs | 5 RCTs^278,^ ^280,^ ^284–286^ (8,826) | Pooled RR, 1.16 (95% CI, 0.87 to 1.54); ARD, 3 more per 1,000 (95% CI, from 3 fewer to 11 more) | Consistent, imprecise | Fair quality; some un-certainties in random-ization for 3 studies, allocation concealment in 4 studies, and attrition and blinding in 2 studies. | Low^†^ for no effect | Postmenopausal women with osteoporosis or low bone mass
5 Harms of Treatment | Denosumab Serious AEs | 6 RCTs^278–280,^ ^284–286^ (8,934) | Pooled RR, 1.04 (95% CI, 0.97 to 1.12); ARD, 9 more per 1,000 (95% CI, from 7 fewer to 28 more) | Consistent, imprecise | Fair quality; some uncertainty for allocation concealment in all studies, random-ization in 4 studies, and attrition and masking in 2 studies; not large enough or long enough to detect rare harms | Low^†^ for no effect | Postmenopausal women with osteoporosis or low bone mass
5 Harms of Treatment | Denosumab Upper GI AEs | 4 RCTs^279,^ ^280,^ ^284–286^ (932) | Pooled RR, 2.18 (95% CI, 0.74 to 6.46); ARD, 14 more per 1,000 (95% CI, from 3 fewer to 66 more) | Consistent, imprecise | Fair quality; some uncertainty for allocation concealment in all studies, randomiza-tion in 3 studies, and attrition and masking in 1 study | Low^†^ for harm | Postmenopausal women with osteoporosis or low bone mass

* Rated down 1 level for study limitations.

† Rated down 1 level for imprecision and 1 level for study limitations.

‡ Rated down 1 level for inconsistency and 1 level for study limitations.

§ Not enough data to evaluate SOE.

ǁ Downgraded 1 level for study limitations and 1 level for inconsistency.

¶ Downgraded 1 level for study limitations, 1 level for inconsistency, and 1 level for imprecision.

# Downgraded 1 level for study limitations, including indirectness as these study designs did not directly compare a strategy of repeat screening with single screening.

Abbreviations: ABONE=Age, Bone, No Estrogen instrument; AE=adverse event; AMMEB=Age, years after Menopause, age at Menarche Index; ARD=absolute risk difference; AUC=area under the curve; BMD=bone mineral density; CI=confidence interval; DXA=dual-energy X-ray absorptiometry; EHR=electronic health record; FN=femoral neck; FRAX=Fracture Risk Assessment Tool; FRC=Fracture Risk Calculator; FREEDOM=Fracture Reduction Evaluation of Denosumab in Osteoporosis Every 6 Months; Fx=fracture; GI=gastrointestinal; KQ=key question; MOF=major osteoporotic fracture; MORES=Male Osteoporosis Risk Estimation Score; MOST=Male Osteoporosis Screening Tool; MSCORE=Male Simple Calculated Osteoporosis Risk Estimation; NA=not available; NOF=National Osteoporosis Foundation tool; ORAI=Osteoporosis Risk Assessment Instrument; OSIRIS=OSteoporosis Index of RISk; OST=Osteoporosis Self-Assessment Tool; OSTA=OST for Asians; RCT=randomized, controlled trial; ROB=risk of bias; ROSE=Risk-stratified Osteoporosis Strategy Evaluation; RR=relative risk; SAE=serious adverse event; SCORE=Simple Calculated Osteoporosis Risk Estimation; Sn=sensitivity; SOFSURF=Study of Osteoporotic Fractures Research Group Study Utilizing Risk Factors; Sp=specificity; U.S. Preventive Services Task Force; VA-FARA=Veterans Affairs Fracture Absolute Risk Assessment; vs.=versus; WHI, Womens Health Initiative Prediction Model.

We identified some new evidence related to treatment benefits (KQ 4) and harms (KQ 5) in this update. Our SOE ratings for treatment benefits (KQ 4) remained largely the same as the prior review: low to moderate SOE for benefit across multiple fracture outcomes for both bisphosphonates and denosumab. For treatment harms (KQ 5), we graded the evidence for each outcome separately as compared to the prior report; with low (denosumab) to moderate (bisphosphonates) SOE for both discontinuations due to adverse events and serious adverse events and moderate SOE for no effect on upper GI adverse events for bisphosphonates and low SOE for increased upper GI adverse events for denosumab. As in the prior report, we note that the evidence included for KQ 5 is not sufficient for evaluating the effect of treatment on very rare harms such as osteonecrosis of the jaw, atypical femur fractures, rebound vertebral fractures, or harms that may emerge after prolonged duration of treatment.

The scope of the KQs on accuracy changed between the prior report and the current update so direct SOE comparisons are not possible. Further, in this update we rated SOE for specific instruments and among subpopulations wherever possible, further limiting a direct comparison with the prior review’s SOE ratings.

### Benefits and Harms of Screening (KQs 1 and 3)

For this update, we included three trials (ROSE, SOS, and SCOOP) providing direct evidence for screening. All studies were pragmatic in nature, relying on participants’ PCPs to initiate further evaluation and treatment in response to positive screening tests. As with most trials of screening, the proportion of participants who received treatment was a relatively small proportion of those randomized. We found moderate SOE for a small absolute benefit of screening on hip fractures (5 fewer per 1,000 screened) and MOF (6 fewer per 1,000 screened) and low SOE for osteoporotic fractures (5 fewer per 1,000 screened). The absolute magnitude of benefit observed is similar to that observed for hip fracture prevention from treatment with bisphosphonates or denosumab in persons with known osteoporosis, but smaller than the benefit observed for vertebral or nonvertebral fracture prevention. These estimates are based on pooling with the per-protocol population from the ROSE trial, which is methodologically most similar to the study designs used in SCOOP and SOS. Our sensitivity analysis using the ROSE ITT population (Appendix E.1 Figure 1) predictably led to smaller estimates of absolute effect and that do not exclude a null effect because of the large proportion of participants (nearly 40%) who were included in the analysis without receiving the intervention.

The only individually statistically significant fracture reduction outcome was for hip fractures (a secondary endpoint) in the SCOOP trial. This finding was unexpected given that hip fractures are a subset of MOF and are much rarer events than other fractures. The study authors suggested that because they used the 10-year estimated hip fracture risk to determine recommendations for DXA, they were perhaps preferentially targeting persons more likely to suffer hip fractures than other fracture types. The hip fracture outcome may be spurious or biased because the relative magnitude of effect is inconsistent with findings for the other fracture outcomes, which occurred with much higher frequency. It is also a relatively large relative reduction, considering few participants were actually treated with medication. However, the authors reported a post hoc analysis in which only participants with the highest percentile of FRAX baseline hip probability benefited from screening,^122^ and findings from the ROSE trial also suggested that most of the benefit with respect to MOF could be attributed to reductions in hip fracture.

All three trials enrolled individuals at high risk for fracture. The SOS trial enrolled a higher risk population (43% had prior fractures) than ROSE and SCOOP and conducted a more extensive battery of tests as its screening intervention. Further, the populations in all three studies were likely at higher risk of fracture than an average screening population in the United States. For example, a 65-year-old White woman in the United States of average height (159.7 cm) and weight (75.6 kg) based on 2015–2018 NHANES data^315^ with no additional clinical risk factors has a 10-year risk of MOF of 8.2 percent and a hip fracture risk of 1.0 percent according to FRAX (without BMD input).^316^ These risks are well below the mean FRAX-estimated risks in the SCOOP, ROSE, and SOS study populations (MOF risks ranged from 19% to 24.6%; hip fracture risks ranged from 6.7% to 11.6%). If one considers that individuals with the risk factors of glucocorticoid use, rheumatoid arthritis, secondary osteoporosis, or prior fracture are not in the target population for screening (i.e., DXA testing would be indicated for these individuals as part of disease management), then the highest estimated risk possible for a 65-year-old White woman of average height and weight and unknown BMD without such risks but with all other FRAX-specified risks (i.e., smoking, alcohol use, parental hip fracture) is 19 percent for MOF and 2.9 percent for hip fracture. Those risks increase slightly for women with lower BMIs and decrease slightly for those with higher BMIs. For a 65-year-old Black woman with the same height, weight, and risks, the highest possible risk is 8.9 percent (MOF) and 1.3 percent (hip), which is well below the risk of women in the included trials. One of the SRs included for KQ 1 also reviewed the acceptability of screening by patients and reported women who are low risk based on age have a high intention of getting screened; however, no studies report on the intentions of higher-risk women.^131^ The ROSE trial authors analyzed subjects who declined DXA testing and reported a higher level of comorbidities and health behaviors that also portend a higher fracture risk, suggesting a selection bias toward healthy individuals.^128^ Thus, achieving population-level benefits of screening likely requires implementation strategies to ensure it is reaching those at highest risk.

We judged the SOE as low for no effect on mortality because of imprecision and study limitations. Only one trial reported on a single harm outcome (anxiety);^120^ no differences were observed between groups. We judged the strength of evidence for these anxiety harms as insufficient because of study limitations related to modest uptake and adherence, and because of a single study body of evidence. One of the included SRs reported estimates for overdiagnosis of between 118 and 241 per 1,000 women screened. We assessed the SOE for overdiagnosis as insufficient, primarily because of study limitations in the underlying RCTs included in the SR and evolving methods for estimating this harm, which involves extrapolation. Overdiagnosis for identifying a high-risk probability is conceptually different than overdiagnosis of overt conditions (e.g., cancer), and the exact methods to estimate overdiagnosis in this context are still evolving and will generally be limited by less than perfect calibration of risk prediction instruments.^314^

Another consideration is the applicability of the screening interventions used in these trials. The 2018 USPSTF strategy recommends universal BMD assessment in women age 65 years or older and a two-staged approach (formal risk assessment followed by BMD) for postmenopausal women younger than age 65 years. A two-staged approach was used with FRAX in SCOOP and ROSE for women of all ages; however, country-specific FRAX prediction models were used with thresholds unique to each study. SCOOP used an age-dependent hip fracture risk threshold to offer DXA, which varied from 5.2 to 8.4 percent, whereas ROSE offered DXA to participants above a 15 percent MOF risk threshold, regardless of age. If a two-stage approach were replicated in the United States, it is not entirely clear what thresholds should be used and whether thresholds should be fixed or vary based on age or other factors. It is also not clear how patient values and preferences about getting screened should be incorporated. The implications of using fixed risk thresholds vs. age-dependent thresholds are addressed further in Contextual Question 5 in Appendix F.2. In brief, fixed thresholds may result in over or under screening or treatment while age-dependent thresholds may be difficult to use in practice. In contrast to SCOOP and ROSE, the SOS trial used an intensive intervention consisting of DXA, vertebral fracture assessment (imaging test), FRAX (country specific), fall risk assessment, and laboratory evaluation to evaluate for secondary causes of osteoporosis for women allocated to screening. Whether such an intensive intervention is feasible in usual primary care settings in the United States is not clear, nor is it clear whether the intensity of the intervention is warranted because this intervention had a similar magnitude of benefit compared with the less intensive interventions used in SCOOP and ROSE.

### Accuracy (KQ 2)

Although this update includes more direct evidence for the benefits of screening compared with the prior review for older postmenopausal women, it may still be useful to consider the indirect evidence pathway for screening given the limitations and applicability of the direct evidence and because direct evidence for men and younger postmenopausal women is lacking entirely. Currently the USPSTF recommends universal DXA testing in women beginning at age 65 years, without regard to clinical risks. Because most fragility fractures occur in persons without osteoporosis, accurate risk assessment instruments could help identify the highest risk persons for subsequent risk reduction treatment, including but not limited to pharmacotherapy. However, because pharmacotherapy trials to date have not enrolled persons based on fracture risk, the role of such instruments with respect to decisions about DXA screening and treatment remains unclear.

#### Predictive Accuracy

The evidence for predictive accuracy of risk assessments and BMD measurement was very heterogeneous; further, it was poor methodologic quality. This poor quality partly reflects increased rigor of design and reporting standards for prognostic studies in recent years. The predictive accuracy of some risk assessment instruments (KQ 2a) appears to be similar to that of BMD alone (KQ 2b). Although many measures of accuracy exist, most studies reported discrimination measures only and specifically AUC.

We rated the SOE for the predictive accuracy of risk assessment instruments for discrimination as either low (FRAX, FRC, Garvan, QFracture) or insufficient (OST, WHI) and for calibration as low for FRAX and insufficient for all others evaluated. Accuracy appears higher for instruments that can incorporate a BMD input (FRAX, Garvan, FRC); however, this may not be particularly useful when considering such instruments as the first assessment step for determining who to refer for further DXA testing in a two-stage screening approach. Thus, for USPSTF consideration, our findings related to instruments without a BMD input are likely the most applicable to decision making.

A particular challenge to using risk assessment instruments in practice is determining the risk threshold to apply for clinical action. The evidence in this update suggests that multiple instruments can reasonably predict MOF or hip fractures at various thresholds, but the inconsistency of findings across the evidence base limits a strong conclusion about the use of a specific instrument at a specific threshold. Commonly applied thresholds (3% for hip fracture risk and 20% for MOF risk) were derived as thresholds for considering treatment (not screening) and were based on a cost-effectiveness analysis.^80,^ ^85^ We note that the predictive accuracy of more complex risk assessment instruments involving multiple clinical or demographic risks appears to be similar to the accuracy of simpler assessments with fewer risks.

We rated the SOE for the predictive accuracy of BMD alone as low for discrimination outcomes because results were inconsistent and study quality was poor, and we rated the SOE for calibration outcomes as insufficient because the evaluation of BMD alone as a predictor was not the primary study aim for any of these studies, so authors reported limited calibration information. Discriminative accuracy varied widely among the different cohorts when considering BMD as a continuous measure; it appears better for hip prediction than for MOF, which could be explained by the fact that FN was the site most often used for measuring BMD, but also because MOF is a heterogenous outcome compared with hip fracture. Predictive accuracy in men appears to be similar or better than in women, though we note that the men enrolled in studies of accuracy may not be generalizable to the general primary care population as they may have been identified from referrals for BMD testing, specialty care, or primary care clinics caring for medically complex patients, such as VA settings. BMD alone is already used in practice for clinical decision making related to treatment; however, the evidence in this update confirms that the T-score threshold defining osteoporosis (<−2.5) is not very sensitive and is only modestly specific for predicting future fragility fracture. This appears particularly true among younger women, but the evidence for this group is limited.

#### Diagnostic Accuracy

Given that the evidence base for pharmacotherapy is based on treating persons with osteoporosis or low bone mass, the accuracy of risk assessment instruments to identify which persons are likely to be candidates based on BMD is critical. Like the evidence base for predictive accuracy, the evidence base for the diagnostic accuracy of various risk assessment instruments (KQ 2c) was very heterogeneous in terms of populations evaluated, reference standards used, and score thresholds evaluated. Accuracy as evaluated by AUC was modest to good, but sensitivity and specificity ranges within and across studies were wide. We rated the SOE for discrimination outcomes for FRAX, OST, and OSTA as low in both women and men. For women, we rated the SOE as low for ABONE, NOF, ORAI, OSIRIS, and SCORE and insufficient for AMMEB, Garvan, and SOFSURF. For men, we rated the SOE as low for MORES and MOST and insufficient for ABONE, Garvan, MSCORE, ORAI, OSIRIS, SCORE, and VA-FARA. To be used in clinical practice, thresholds need to be established to determine a positive screening test. Many studies evaluated alternative thresholds than the ones established in development cohorts to optimize sensitivity in their population. In some cases, the alternative thresholds may have involved a slight tweak to the score threshold, but in other studies it may have involved a much larger adjustment to the threshold. A test whose threshold is not robust across a spectrum of populations may not be suitable for widespread use.

#### Repeat Screening

We did not identify any direct evidence (KQ 1) evaluating a strategy of repeat screening. As part of our assessment of the indirect evidence (KQ 2d), we did identify studies comparing the predictive accuracy of repeat screening with DXA BMD after 4 to 8 years with a baseline DXA BMD and we rated the SOE as moderate for similar predictive accuracy (Table 3). Further evidence from contextual question 1 (Appendix F.1) provides evidence from studies evaluating the time taken for women to transition across various BMD categories. In an analysis of the SOF cohort of postmenopausal women age 65 years or older, it took on average 17 years for 10 percent of women with a normal BMD at baseline to transition to an osteoporotic range, and a similar figure was observed for women with T-scores between −1.0 and −1.49.^317^ The transition interval decreased for women with T-scores between −1.50 and −1.99 (4.7 years) at baseline and women with T-scores between −2.0 and −2.49 (1.1 years) at baseline.^317^ Several other studies have attempted to identify optimal screening intervals by assessing the time to transition to osteoporosis or a 10 percent fracture risk and the time for 1 percent of women to transition to an actual fracture event. These authors estimate various intervals, but a pattern of shorter intervals with advancing age is consistent across studies.

#### Considerations Regarding Race-Based Prediction Models

Of special note are the findings related to using FRAX in women younger than age 65 years with the MOF risk thresholds suggested by the USPSTF’s current (8.4%) or past (9.3%) recommendation. Analyses of this threshold in three unique cohorts suggested poor sensitivity and only modest specificity. A further concern with these thresholds is that they represent the risks for a 65-year-old White woman of average height and weight. This benchmark was selected by the USPSTF based on its existing recommendation that women age 65 years or older should be screened with DXA. However, if the goal is to use the risk of a 65-year-old woman with no other clinical risks as a benchmark, then the risk for any given individual may be more fairly evaluated against the risk of a 65-year-old of the same height, weight, and race. For example, the estimated risk for a younger Black woman could be evaluated against the risk for a 65-year-old Black woman (equivalent to 4.2% for BMI of 25.0 kg/m^2^). Such an approach would solve issues inherent in using a fixed threshold based on risk of a White woman; however, across the population, it would result in persons of varying fracture risks being referred for DXA. Further, this approach is likely not feasible to implement in time-constrained primary care settings. The issue related to referral of persons with varying fracture risk is already inherent in the recommendation for universal DXA screening in women at age 65 years. MOF risks for women with a BMI of 25 kg/m^2^ vary between a low of 4.2 percent (Black woman, no other clinical risk) and 22 percent (White woman with parental history, smoking, and alcohol use). See Appendix F.2 Contextual Question 5 for additional information concerning use of fixed thresholds with risk assessment tools.

For further consideration is whether a race-based prediction model should be used for clinical decision making at all. The United States is one of only a few countries that use FRAX calibrated for specific racial groups; other countries with multiethnic populations (e.g., Canada, United Kingdom) use one race-neutral FRAX calculator. Race-informed prediction models do not accommodate multiracial individuals or the underlying heterogeneity in risk that exists within a single racial group. Other race-neutral prediction models with fewer inputs appear to be as accurate or more accurate than FRAX or similarly complex assessments. However, challenges remain as to what the appropriate threshold for decision making would be for these instruments and whether it should vary for different populations or clinical contexts.

### Benefits and Harms of Treatment

Treatment of osteoporosis is well established in clinical practice. We found moderate SOE for treatment with bisphosphonates for the primary prevention of vertebral and nonvertebral fractures and low SOE for benefit on hip fractures and mortality. We analyzed studies of bisphosphonates as a class; however, it is important to note that not all drugs in the class have demonstrated efficacy with respect to hip fracture outcomes. We found moderate SOE for denosumab with respect to the primary prevention of vertebral fractures and low SOE for nonvertebral fractures, hip fractures, and mortality. An SR and network meta-analysis^318^ in support of the January 2023 clinical practice guideline on pharmacotherapy issued by the American College of Physicians^319^ found similar conclusions regarding bisphosphonate and denosumab treatment with respect to fracture outcomes; however, this review included a broader scope that did not limit to primary prevention populations and did not exclude poor-quality studies. We rated serious adverse events and discontinuations due to adverse event outcomes as either low or moderate SOE for no effect comparing active drug (bisphosphonate or denosumab) and placebo. For upper GI adverse events, we rated the evidence as moderate SOE for no effect for bisphosphonates and low for harm for denosumab.

We identified several applicability concerns with this body of evidence. Of the studies that reported fracture or mortality outcomes, a minority specifically required T-scores less than −2.5; the rest enrolled participants with T-scores spanning the range considered low bone mass and osteoporosis or low bone mass only. All but one study of denosumab and one study of bisphosphonates were conducted in postmenopausal women. Although studies of abaloparatide, teriparatide, and romosozumab were eligible for inclusion for men, we did not identify any such studies because studies of those agents were conducted among populations with prior fracture or with secondary osteoporosis; these populations were not eligible for inclusion in this update review. For this update, we identified only one study published since the prior review (the other five studies newly included in this update were published between 1996 and 2012 and we identified them through handsearches of systematic reviews identified in the current update). Because treatment is now standard of care for osteoporosis, we think future placebo-controlled trials are unlikely. Future updates for this topic may want to consider the treatment benefit and harm evidence as foundational.^318^

## Limitations of the Evidence

We note several limitations with the three trials included for KQ 1. First, they were all pragmatic trials conducted among older European women (median ages, 71 to 76 years) using interventions that included non-U.S. fracture prediction models. The proportion of persons eligible who participated was low (about one-third) in one trial^120^ with evidence of healthy selection bias, and the receipt of the screening intervention was suboptimal in the other two trials (55% in ROSE^126^ and 76% in SOS^124^). The three trials were underpowered because the observed proportion of women with treatment indications and who adhered to treatment were lower than expected and because of contamination in control arms from secular trends in screening and treatment. For all these reasons, the estimate of benefits from these trials probably represents the lower bounds of screening efficacy for the eligible population. Yet, these findings may reflect the real-world effectiveness of a systematic screening program. It is not clear whether similar findings would be observed if screening were offered entirely through the participant’s PCP office, which is a model more applicable to USPSTF considerations. Although these estimates represent the lower bounds of efficacy, it is not entirely clear that the findings are applicable to populations with lower fracture risk or U.S. settings given the use of country-specific FRAX prediction models and the thresholds for action (i.e., further screening with DXA or treatment) used in these trials. As described earlier, the women in these trials represented a population with a higher risk than we might expect to encounter in a primary prevention population of women with a screening indication based on age alone. Whether it is possible to conduct a large-scale trial of screening among women age 65 years or older in the United States given that universal screening with DXA is a common practice is not clear.

Although we identified many studies for the KQ on accuracy, heterogeneity in populations, thresholds used, and incomplete reporting precluded robust conclusions. For both predictive and diagnostic accuracy, a number of studies were conducted using retrospectively assembled datasets of persons referred for BMD, some of whom may already have a diagnosis of osteoporosis or take medication or may have had a prior fracture. Many predictive accuracy studies focused only on discrimination outcomes and did not report sufficient information about calibration. Some used proxy data for selected risk factors or omitted those factors if data were not available, or participants were observed for fewer years than the duration used in the risk model development studies. Further, it is unclear whether data on FRAX from other countries is applicable to the U.S. setting given that FRAX is calibrated to each country’s fracture incidence. We tried to mitigate this issue by limiting the KQs on predictive accuracy to countries with similar hip fracture incidence as the United States (moderate incidence). The diagnostic accuracy studies varied in how the DXA reference standard was measured (e.g., different anatomic sites for T-score, different reference range used to calculate T-scores from raw BMD measure).

The major limitation in the treatment literature for primary prevention is that few studies include men, and studies enrolled persons based on BMD T-scores and not fracture risk. Although data suggest treatments are probably safe compared with placebo, few studies eligible for this update review were sufficiently designed to report on rare or duration-dependent harms such as osteonecrosis of the jaw, atypical femur fractures, or rebound vertebral fractures.

A concern across the evidence for all KQs relates to the lack of diverse populations enrolled in studies. Many studies did not report the race or ethnicity of enrolled populations, and those that did mostly enrolled exclusively or vast majority White populations. Given the differences in fracture incidence among persons of different races and ethnicities in the United States, studies enrolling sufficient numbers from diverse populations are needed to determine the applicability of findings in different populations.

## Future Research Needs

Because the predictive accuracy of most risk assessment instruments is similar to that of BMD alone, trials that randomize participants to fracture risk assessment vs. DXA for screening and then treat based on fracture risk or T-score would provide direct evidence for comparing such screening strategies and would address a gap about whether pharmacotherapy based on fracture risk is effective for reducing fractures. It is not clear what screening strategy should be evaluated in such trials, including whether the focus should be on identifying osteoporosis to treat with medication or whether a more comprehensive screening strategy to address a broader set of fracture determinants should be evaluated. Further, if a country-specific risk assessment tool, such as FRAX, is used, then trials conducted in the United States using the U.S. version of FRAX would ensure applicability of findings to U.S. settings. In addition, future trials of screening should specify harm outcomes a priori and use adequate ascertainment methods. In the absence of future trials offering direct evidence, decision analyses could help fill in gaps regarding optimal starting and stopping stages for women or identifying optimal screening approaches; however, it is not clear whether enough screening trial evidence exists for robust inputs into such analyses.

Rigorously designed research on instruments for fracture risk prediction or osteoporosis identification that are applicable to general, unselected primary care populations and that are feasible for use in such settings is needed. Thoughtful consideration for whether and how race is used in such instruments is critical as is research associated with selecting thresholds for action resulting from the use of such instruments in practice. Whether the focus of future research should be on improving existing instruments, such as with the addition of fall history or propensity, on developing new instruments, or on improving provider and patient understanding and decision making from the use of current instrument is unclear.

Given that treatment of osteoporosis in older, screen-detected women without contraindications is considered standard of care, it is unlikely that future placebo-controlled trials of treatment in such populations will be conducted for ethical reasons. However, research that evaluates treatment of osteoporosis among screen-detected men and younger women without known clinical risks would likely have equipoise. To date, most studies that have enrolled men or younger women focus on persons with a history of prior fracture or who have underlying medical conditions or take medications associated with secondary osteoporosis.

Our search of trial registries identified three ongoing studies (Appendix H) but none that appear to address the specific research needs described in this section.

## Limitations of the Review

This review focused on only one aspect of fracture prevention, which was to identify and pharmacologically treat osteoporosis. We did not evaluate comprehensive approaches to fracture prevention that might include screening, counseling, medication, physical therapy, and other interventions to prevent falls or improve physical function in older adults. Preventing falls is addressed by a separate USPSTF recommendation.^320^

This review did not address the use of DXA testing as part of disease management in persons with a history of fragility fracture or medical conditions or medications associated with secondary osteoporosis. DXA testing in such persons is clinically indicated along with other medical tests or interventions for risk mitigation. Thus, we do not consider DXA testing in such individuals as screening, so results from this review cannot be applied to such populations.

We did not evaluate the comparative effectiveness and harms of alternative pharmacotherapies, and we did not evaluate evidence concerning duration of treatment or temporary drug holidays. For treatment benefits and harms, we focused on studies for primary prevention and did not include trials conducted predominantly amond persons with secondary osteoporosis or history of fragility fracture. Our review scope was not comprehensive for evaluting rare harms of treatment; several authors have reported on these harms using study designs broader than what we used for the KQs in this update (Appendix F, Contextual Questions 6 and 7).

Our review was limited to English-language publications published in peer-reviewed journals and conducted in very highly developed countries. We did not include conference abstracts or data from completed but unpublished studies posted in trial registries.

## Conclusions

Screening in older, higher-risk women was associated with a small absolute risk reduction in hip fractures and MOF compared with usual care. Screening strategies varied and no direct evidence evaluated screening using DXA alone or screening in women younger than age 65 years or in men. Risk assessment instruments and BMD at the hip or spine has poor to modest discrimination in men and older women for predicting fracture and studies of calibration were limited. For identifying osteoporosis, risk assessment instruments had modest to good accuracy in men and modest accuracy in older women. In women younger than age 65 years, risk assessment instruments had poor predictive (fracture) and diagnostic (osteoporosis) discrimination. Treatment of osteoporosis with FDA-approved bisphosphonates or denosumab was associated with reductions in vertebral, nonvertebral, and hip fractures with no increase in discontinuations due to adverse events or serious adverse events compared with placebo in studies conducted over one to several years’ duration; however, data about rare and longer-term harms were limited from the evidence included in this update.