# Chapter 3 Results

## Results of Literature Searches

We included 145 unique studies published in 195 articles for this update review (Figure 2). Three RCTs and three SRs (published in 14 articles) reported direct evidence for the benefits of screening (KQ 1).^120–133^ One RCT (published in 2 articles)^120,^ ^121^ and one SR^131,^ ^132^ reported on direct evidence for the harms of screening. Six SRs^131,^ ^134–138^ and 30 cohort studies (published in 49 articles)^72,^ ^73,^ ^139–181^ reported on the accuracy (discrimination or calibration or both) of various risk assessment instruments for predicting fracture (KQ 2a). Twenty-two unique cohorts (published in 28 articles) reported on the accuracy of BMD for predicting fracture (KQ 2b).^15,^ ^146,^ ^150,^ ^151,^ ^154,^ ^156,^ ^157,^ ^160–162,^ ^166,^ ^172,^ ^175,^ ^176,^ ^179,^ ^182–194^ Findings from 43 unique cohorts published in 54 articles reported on the diagnostic accuracy of fracture risk assessment instruments for identifying osteoporosis as defined by a BMD T-score of less than −2.5 (KQ 2c).^141,^ ^143,^ ^159,^ ^195–245^ Five studies reported information relevant to the determination of screening intervals (KQ 2d).^246–250^ Twenty-seven RCTs (published in 36 articles) reported on the benefits of treatment.^251–286^ Lastly, 40 RCTs in 48 articles^251–254,^ ^256–269,^ ^272–280,^ ^284–304^ and three controlled cohorts studies^305–307^ reported on the harms of treatment. A list of studies for which we reviewed the full-text article but excluded is provided in Appendix C along with the reason for exclusion. Note that although studies may have multiple reasons for exclusion, we only recorded one reason.

Figure 2 Literature Flow Diagram

Abbreviations: HDI=human development index; KQ=key question’ RCT=randomized, controlled trial; SR=systematic review; U.S.=United States.

This figure is a flowchart that summarizes the search and selection of articles. We identified 14,345 records through electronic database searches and 38 records by hand search for screening at the title and abstract level. This resulted in a total of 14,383 titles and abstracts screened after removing duplicates. A total of 13,849 of these were excluded during title and abstract review. One hundred seventy-one records from the previous review were rescreened. Resulting in a total of 705 articles assessed for eligibility at full-text review. After full-text review, 510 were excluded: 16 for ineligible publication type or language, 33 for ineligible population, 131 for ineligible study design or timing, 22 for ineligible geographic setting, 85 for ineligible intervention, 65 for ineligible comparator, 69 for ineligible or no outcome, 30 for not in very high human development index country, 34 were superseded by new evidence or duplicates, and after quality assessment, 25 studies were excluded for high risk of bias. One hundred ninety-five articles representing 145 studies were included in the synthesis of the systematic review. Three randomized, controlled trials and 3 systematic reviews in 14 publications for KQ 1. Thirty cohorts and 6 systematic reviews in 56 publications were identified for KQ 2a. Twenty-two studies in 28 articles were included for KQ 2b. Forty-three studies in 54 articles were identified for KQ 2c. Five studies were identified for KQ 2d. One randomized controlled trial and one systematic review in four articles were identified for KQ 3. Twenty-seven randomized controlled trials in 36 articles were identified for KQ 4. Forty randomized controlled trials and 3 cohorts in 51 articles were identified for KQ 5.

### KQ 1 Does Screening for Fracture Risk or Osteoporosis Reduce Fractures or Fracture-Related Morbidity or Mortality in Adults?

We identified three pragmatic, fair-quality RCTs (published in 10 articles) that evaluated screening compared with no screening in older European women.^120–129^ In this section, we provide a summary of the study characteristics and findings from these trials. Detailed study, population, and intervention characteristics are described in Appendix D Table 1 with additional narrative description in Appendix E.1 and detailed outcomes in Appendix D Table 8. In addition, we identified three good-quality SRs^130–133^ that included these three trials. One of these SRs^131,^ ^132^ was conducted in support of the CTPHC’s 2023 recommendation on screening for primary prevention of fragility fractures.^90^ Details about the included SRs are in Appendix D Table 9 with SR quality ratings in Appendix D Tables 23–27.

#### Study Characteristics

We identified three fair-quality, pragmatic RCTs (Table 1): the Risk-stratified Osteoporosis Strategy Evaluation (ROSE) study (N=34,229 randomized population; N=18,605 per protocol 1 analysis population),^126–129^ the Screening in the Community to Reduce Fractures in Older Women (SCOOP) study (N=12,483 randomized),^120–123^ and the Stichting Artsen Laboratorium en Trombosedienst (SALT) Osteoporosis Study (SOS) (N=11,032 randomized).^124,^ ^125^ ROSE and SOS are new to this update. All three RCTs randomized persons to screening vs. usual care (i.e., no systematic screening) and reported clinical fracture outcomes. All three RCTs included older European women (median ages, 71 to 76 years) who we presumed to be predominantly White (exact racial and ethnicity characteristics not reported in two of the three trials). Other inclusion and exclusion criteria varied across studies. Among those enrolled, the mean or median 10-year FRAX-estimated risk of MOF was 19 percent in SCOOP, 20 percent in ROSE, and 24.6 percent in SOS; the 10-year estimated hip fracture risks were 8.5 percent, 6.7 percent, and 11.6 percent, respectively.^120,^ ^124,^ ^126^ The proportion of participants with a prior fracture was 12.6 percent in ROSE, 22 percent in SCOOP, and 43 percent in SOS; however, there was significant variability in the definition and reporting of prior fractures between trials.^120,^ ^124,^ ^126^

Table 1 Summary of Randomized, Controlled Trials of Screening for Fracture Risk or Osteoporosis (KQs 1 and 3)

Author, Year; Trial Name, Registry No. | Recruitment Setting | Mean Age (SD) | N (%) Female | Intervention Groups; (N Randomized) | Summary of Results | Study Quality
Rubin et al, 2017^126,^ ^127^; ROSE, NCT01388244 | Civic registries in southern Denmark | Median 71 [IQR 68, 76] | 34,229 (100) | Screening: FRAX without BMD assessment with invitation to DXA and VFA if 10-year FRAX MOF risk ≥15%; results sent to the participant and PCP with treatment recommendations based on national guidelines (17,072); Routine care: no contact after completion of baseline data collection, usual care guided by PCP (17,157) | aSHR (95% CI) at median followup 5.0 years; - MOF (primary study endpoint): 0.99 (0.92 to 1.06); - Hip fracture: 1.00 (0.89 to 1.13); - All osteoporotic fractures excluding some sites:^*^ 1.00 (0.95 to 1.06); - Mortality NR | Fair
Shepstone et al, 2018^120,^ ^121^; SCOOP, ISRCTN 55814835 | General practice clinics in the U.K. | Screening: 75.5 (4.2); Routine Care: 75.5 (4.1) | 12,483 (100) | Screening: FRAX without BMD assessment; if high-risk based on 10-year FRAX hip risk ≥age-specific threshold, then invitation to DXA; if below threshold, then letter sent to participants and PCPs confirming low risk status; DXA results sent to participant and PCP with participant’s revised FRAX risk (including BMD information), age-specific treatment thresholds, and recommendation to discuss treatment if above threshold (6,233); Routine care: letter informing PCP of patient’s participation in the study; usual care guided by PCP (6,250) | aHR (95% CI) at 5 years followup; - All clinical fractures excluding some sites^†^ without regard to trauma: 0.94 (0.86 to 1.03); - Hip fracture: 0.72 (0.59 to 0.89); - All clinical fractures including all sites: 0.94 (0.86 to 1.03); - All-cause mortality: 1.05 (0.93 to 1.19) | Fair
Merlijn et al, 2019^124,^ ^125^; SOS; NTR2430 | General practice registeries in the Netherlands; only women with 1 or more clinical risks^ǂ^ were recruited | 75.0 (6.7) | 11,032 (100) | Screening: FRAX without BMD assessment, DXA, VFA, fall risk assessment, and blood chemistries to exclude secondary osteoporosis; women with treatment indications based on results (FRAX with BMD risk above age-dependent threshold, T-score <−2, or prevalent vertebral fracture) had referral to PCP for personalized treatment advice including medication, evaluation for secondary osteoporosis, fall prevention, and calcium/vitamin D supplementation; PCPs were provided group education on the study protocol and treatment options (N=5,516); Routine care: wait-list placement for screening intervention; notification to participant and PCP of indication for DXA or VFA if clinical risks present based on existing Dutch guidelines, usual care guided by PCP (N=5,405) | aHR (95% CI) at mean followup 3.7 years; - Any clinical fracture: 0.97 (0.87 to 1.08); - Hip fracture: 0.91 (0.71 to 1.15); - Major osteoporotic fracture: 0.91 (0.80 to 1.04); - Any osteoporotic fracture: 0.91 (0.81 to 1.03); - All-cause mortality: 1.03 (0.91 to 1.17) | Fair

* Excluding fingers, toe, skull, and face.

† Excluding hands, feet, nose, skull, or cervical vertebrae.

ǂ Clinical risk factors: previous fracture after age 50, parental hip fracture, BMI <19 kg/m^2^, rheumatoid arthritis, menopause <45 years, malabsorption syndrome, chronic liver disease, type 1 diabetes, immobility.

Abbreviations: aHR=adjusted hazard ratio; aSHR=adjusted subhazard ratio; BMD=bone mineral density; BMI=body mass index; CI=confidence interval; DXA=dual-energy X-ray absorptiometry; FRAX=Fracture Risk Assessment Tool; IQR=interquartile range; ISRCTN=International Standard Randomised Controlled Trial Registry; KQ=key question; MOF=major osteoporotic fracture; N=number of participants; NCT=National Clinical Trial; NR=not reported; NTR=Dutch National Trial Register; PCP=primary care provider; ROSE=Risk-stratified Osteoporosis Strategy Evaluation; SCOOP=Screening in the Community to Reduce Fractures in Older Women; SD=standard deviation; SOS=Stichting Artsen Laboratorium enTrombosedienst (SALT) Osteoporosis Study; U.K.=United Kingdom; VFA=vertebral fracture assessment.

Two RCTs (SCOOP^120^ and ROSE^124^) used a two-step screening intervention consisting of a FRAX risk assessment (without BMD input) on participants randomized to screening, then invited those with a high fracture risk score (≥15% risk for MOF in ROSE; at or above the age-based hip risk threshold in SCOOP) for DXA. In both studies, DXA results and treatment recommendations were shared with the participant and their PCP, who made final decisions about treatment. In contrast, SOS included women already known to have at least one clinical risk factor for osteoporosis and conducted a DXA, vertebral fracture assessment, blood chemistries, falls risk assessment, and FRAX without BMD input on all participants randomized to screening.^124^ The FRAX risk was recalculated with BMD information, and results of all tests and recommendations were provided to the participant’s PCP. The comparison group in all three studies was routine care as guided by the participant’s PCP.

We rated study quality of the three primary research studies as fair largely because of issues related to contamination in the control groups, poor to modest adherence in the intervention groups, and lack of blinding, which was not feasible because of the pragmatic nature of the trials (Appendix D Tables 18–22).

In addition to the three primary studies that we included in our analysis, we identified three SRs.^130–133^ The SR authored by Merlijn et al^130^ included the same three RCTs that we included in our analysis. The SR authored by Gates et al was performed in support of the CTFPHC recommendation and included two additional studies.^131^ One of these additional studies^308^ was excluded in the previous USPSTF SR on this topic^3^ for an ineligible study design as it was a nonconcurrent cohort study. The other additional study was an RCT of population-based screening with DXA compared with usual care in women ages 45 to 54 years (Aberdeen Prospective Osteoporosis Screening Study).^309^ Women with DXA results in the lowest quartile of the first 1,000 persons screened were considered “high risk,” and their results were shared with their PCPs, who were advised to offer hormone replacement therapy when the woman reached menopause assuming no contraindications.^309^ This study was excluded in the previous USPSTF SR on this topic^3^ for poor quality. Further, the treatment intervention used in this study is no longer standard practice in the United States. The SR authored by Auais et al included the same three RCTs, plus 11 additional studies focused on cost or qualitative research studies.^133^

#### Findings

All three included RCTs confirmed fractures through medical records or radiology reports and were powered for evaluating differences in any fracture (SCOOP, SOS) or MOF (ROSE). SOS also reported MOF outcomes and a broader composite of osteoporotic fractures, while SCOOP reported osteoporotic fractures excluding those of the hand, foot, skull, or cervical vertebrae. All three studies reported hip fractures as secondary outcomes.

The impact of screening on fracture and mortality outcomes is depicted in Figure 3. For fracture outcomes, we used the per-protocol results from the ROSE trial in our quantitative synthesis because this comparison was the most methodologically comparable with the intention to treat (ITT) analytic results in the SCOOP and SOS trials. Randomization in the SCOOP and SOS trials occurred after collection of the data that were needed to calculate a baseline FRAX score. The ROSE trial randomized participants prior to mailing the questionnaire used to collect information required to calculate baseline FRAX and nearly 40 percent of those randomized did not return the baseline questionnaire and so could not be included in subsequent steps of the screening intervention. The pooled RR for the effect of screening on hip fractures was 0.83 (95% CI, 0.73 to 0.93; 3 RCTs; 42,009 participants; I^2^=0.0%), and the pooled RR for MOF was 0.94 (95% CI, 0.88 to 0.99; 3 RCTs; 42,009 participants; I^2^=0.0%) (Figure 3). When we removed SCOOP from the MOF analysis, the pooled RR estimate was 0.93 (95% CI, 0.86 to 1.00; see note in Figure 3). The pooled estimates for “all” fractures or “osteoporotic” fractures favored screening but were not statistically significant (Figure 3). The ARDs across these outcomes ranged from 5 to 6 fewer fractures per 1,000 participants for screening compared with usual care. No significant association was observed for all-cause mortality; we calculated a pooled RR of 0.99 (95% CI, 0.95 to 1.04; 3 studies; 57,633 participants; I^2^=0%), which corresponds to an absolute effect of 1 fewer death per 1,000 persons screened (95% CI, from 5 fewer to 4 more).^120,^ ^124,^ ^126^

Figure 3 Randomized, Controlled Trials of Screening vs. Usual Care—Fracture and Mortality Outcomes (KQ 1)

Note: This analysis used the first per-protocol data from the ROSE trial for the fracture outcomes because these data reflect a similar study design as the intention to treat (ITT) data reported in SCOOP and SOS. Appendix E.1 Figure 1 provides a sensitivity analysis using the ITT data from the ROSE trial for the fracture outcomes. The data for mortality is the ITT population for ROSE because per-protocol data for ROSE was not reported.

* SCOOP reported an outcome entitled “Osteoporotic Fractures,” which was defined as clinical fractures excluding hand, foot, skull, or cervical vertebrae. This definition differs from the definition of MOF used by the other two studies (hip, clinical vertebral, distal forearm, and humerus); as such, we have included SCOOP “Osteoporosis” outcome in the estimate for both “Osteoporotic Fractures” and for “MOF” in this figure. The RR estimate for MOF without SCOOP included is 0.93 (95% CI, 0.86 to 1.00); Absolute Effect: 6 fewer (from 12 fewer to 0 fewer). It is also not clear that fractures associated with trauma were excluded from SCOOP.

Abbreviations: ARD=absolute risk difference; AUC=area under the curve; CI=confidence interval; DL=DerSimonian & Laird estimator for pooling estimates; FRAX=Fracture Risk Assessment Tool; F/U=followup; KQ=key question; MOF=major osteoporotic fracture; N/n=number; NR=not reported; PriorFx=prior fracture; ROSE=Risk-stratified Osteoporosis Strategy Evaluation; SCOOP=Screening in the Community to Reduce Fractures in Older Women; SOS=Stichting Artsen Laboratorium en Trombosedienst (SALT) Osteoporosis Study; vs.=versus; y=year.

This figure depicts a forest plot of randomized controlled trials reporting the impact of screening on fracture and mortality outcomes for three trials, the Screening in the Community to Reduce Fractures in Older Women (SCOOP) trial, the Stichting Artsen Laboratorium en Trombosedienst (SALT) Osteoporosis Study (SOS) trial, and the Risk-stratified Osteoporosis Strategy Evaluation (ROSE) trial. The pooled risk ratio for the effect of screening on all fractures was 0.96 with a 95 percent confidence interval of 0.90 to 1.02. This was based on results from the SOS and SCOOP trials and represents an absolute risk difference of 6 fewer per 1,000 persons screened with a confidence interval of 14 fewer to 3 more. The pooled risk ratio for the effect of screening on osteoporotic fractures was 0.95 with a confidence interval of 0.91 to 1.01. This was based on all three trials and represents an absolute risk difference of 6 fewer per 1,000 persons screened with a confidence interval of 11 fewer to 1 more. The pooled risk ratio for major osteoporotic fractures was 0.94 with a 95 percent confidence interval of 0.88 to 0.99. This was based on all 3 trials and represents an absolute risk difference of 6 fewer per 1,000 persons screened with a confidence interval from 12 fewer to 1 fewer. However, for this outcome, the SCOOP trial includes a figure note conveying that the outcome reported for SCOOP uses a different definition called “osteoporotic fractures” than the other two trials. The pooled risk ratio for the effect of screening on hip fractures was 0.83 with a 95 percent confidence interval of 0.73 to 0.93 based on all three trials. This represents an absolute risk difference of 5 fewer per 1,000 persons screened with a confidence interval from 7 fewer to 2 fewer. The pooled risk ratio for the effect of screening on mortality was 0.99 with a 95 percent confidence interval of 0.95 to 1.04. This was based on all three trials and represents an absolute risk difference of 1 fewer per 1,000 persons screened with a confidence interval of 5 fewer to 4 more. The I-squared statistic for each of the four pooled outcomes was 0 percent. Data for the individual studies depicted in Figure 3 are detailed in Table 1 and in Appendix D Tables 1 and 8.

Except for one outcome in the SCOOP trial, the authors did not observe any statistically significant differences in any reported fracture outcomes (“all,” osteoporotic, MOF, or hip) or mortality outcomes in the three trials over the years of followup, which ranged from 3.7 to 5 years. The SCOOP trial reported a statistically significant reduction in hip fractures in the screening vs. control group (adjusted hazard ratio [aHR], 0.72 [95% CI, 0.59 to 0.89]), which was a prespecified secondary endpoint.^120^ We also conducted a sensitivity analysis (Appendix E Figure E.1-1) for osteoporotic, MOF, and hip fracture outcomes using the ROSE ITT analytic sample. In this analysis, the pooled RRs for osteoporotic, MOF, and hip fractures moved closer to the null effect and were no longer statistically significant for MOF and hip fracture compared with our main analysis that used the per-protocol analytic sample.

The fracture results reported in the three SRs^130–133^ that we identified were consistent with our pooled findings using the ROSE per-protocol analytic sample (Appendix D Table 9). The pooled estimate for all-cause mortality reported in one of the SRs^131^ was also similar to our estimate.

#### Findings in Specific Populations

All three RCTs conducted subgroup analyses. In the ROSE trial, authors carried out three subgroup analyses by age (65 to 69 years, 70 to 74 years, and 75 years or older) and reported no significant effect modification by age (results not shown by authors).^126^ ROSE authors also adjusted for differences in baseline characteristics such as prior fracture and found no significant effect modification. In SOS, authors adjusted analyses for significant differences in baseline characteristics and observed no significant interaction effect with age, history of fracture after age 50 years, or recent fracture for the primary outcome of all fractures (p=0.60, 0.48, and 0.34, respectively).^124^ In SCOOP, authors observed a significant interaction effect with baseline FRAX risk (as a continuous measure) for hip fracture (p=0.02), but not for other fracture outcomes, after controlling for baseline characteristics.^120^ A related finding was observed in the second per-protocol analysis for ROSE; authors observed that most of the between-group differences in MOF events were driven by differences in the hip fracture component of that composite outcome.

### KQ 2 Accuracy of Screening Strategies

### KQ 2a Predictive Accuracy of Osteoporosis and Fracture Risk Assessment Instruments

#### Summary

Thirty cohort studies (published in 49 articles^72,^ ^73,^ ^139–181,^ ^310–313^) and six SRs^131,^ ^134–138^ reported on the accuracy (discrimination or calibration or both) of 11 risk assessment instruments for predicting fracture (KQ 2a). We judged all of the SRs to be good quality; however, authors of SRs generally rated the included primary studies as poor quality, and we also evaluated all of the primary studies we included as poor quality. We relied primarily on findings reported by the SRs, supplemented by results from the primary studies.

Two SRs^131,^ ^132,^ ^137^ and 25 cohorts reported in 40 articles^72,^ ^73,^ ^139,^ ^141–158,^ ^160,^ ^161,^ ^163–173,^ ^176,^ ^177,^ ^181,^ ^311–313^ reported on calibration outcomes for six risk assessment models (FRAX, Fracture Risk Evaluation Model [FREM], FRC, Garvan, Osteoporosis Self-Assessment Tool [OST], QFracture) for the prediction of MOF, hip fracture, or both. Calibration results were heterogenous with no discernible patterns with respect to instrument, age, or sex.

Six SRs^131,^ ^132,^ ^134–138^ and 16 cohorts published in 25 articles^73,^ ^139–143,^ ^146,^ ^159,^ ^160,^ ^163,^ ^165,^ ^172–181,^ ^311,^ ^312^ reported on the discriminative accuracy of 11 risk assessment models (EPIC, FRAX, FRC, FREM, Garvan, ORAI, OSIRIS, OST, QFracture, SCORE, Women’s Health Initiative [WHI] Prediction Model) to predict MOF or hip fracture or both using primarily AUC. Findings were heterogenous, spanning a range considered poor accuracy (AUC, 0.52) to very good accuracy (AUC, 0.93); however, most were between 0.60 and 0.80. Sources of heterogeneity in AUC estimates likely include age and source of population evaluated, variation in outcome definitions, and differences in analytic methods used by authors. Discrimination was largely similar in men and women. For risk assessment instruments with the option to include BMD as an input (FRAX, FRC, Garvan), the predictive accuracy was improved when BMD was included compared with when it was not included. Further, some instruments (FRAX, FRC, Garvan, QFracture) had higher accuracy for predicting hip fracture than for predicting MOF. Few studies reported sensitivity or specificity of specific risk thresholds. In one cohort of U.S. women ages 50 to 64 years, a FRAX risk threshold of 9.3 percent had a 26 percent sensitivity and 83 percent specificity to predict MOF.^139^

#### Study Characteristics

Six good-quality SRs reported on the predictive accuracy (calibration, discrimination, or both) of various risk assessment instruments.^131,^ ^132,^ ^134–138^ Five were new to this update.^131,^ ^132,^ ^135–138^ Three SRs^134,^ ^135,^ ^138^ reported only discrimination outcomes, two SRs^136,^ ^137^ reported both discrimination and calibration outcomes, and one SR^131,^ ^132^ primarily focused on calibration outcomes and included discrimination outcomes that were reported in the previous USPSTF review on this topic.^3^ Some primary research studies included in the three SRs reporting only discrimination outcomes reported calibration outcomes, and we have included these calibration data as new in this update. Detailed study and population information for the primary research studies is in Appendix D Table 2, and detailed information about the included SRs is in Appendix D Table 12.

We observed substantial overlap of included studies across the included SRs. Marques et al, published in 2015, used search dates through September 2014 and included 45 studies; however, accuracy data were not reported from all studies that were included.^134^ Jiang et al, published in 2017, used search dates through July 2016 but only focused on the predictive accuracy of the FRAX instrument, so only seven studies were included.^136^ Beaudoin et al, published in 2019, used search dates through August 2017^135^and included 53 studies.^135^ Sun et al, published in 2022, used search dates through April 2021 and included 68 studies of 70 prediction models and 138 reports of external validation.^137^ The review by Gates et al (in support of the CTFPHC) was published in 2023 and included search dates through June 2021 and included 59 articles from 32 unique cohorts.^131,^ ^132^ The most recent review, Adami et al, included search dates through December 2020 and included 43 articles; however, this review was focused exclusively on FRAX and two less commonly used risk assessment instruments (FRA-HA and DeFRA).^138^ We note that most of these reviews included some studies from the development cohorts used to develop the risk assessment instruments, were conducted in countries that we excluded from this update as not very highly developed per the United Nations’ Human Development Programme Index^104^ (e.g., China), or were conducted in countries with a different category of hip fracture incidence than the United States (e.g., Denmark, high incidence).^105^ Detailed study quality ratings for the SRs are in Appendix D Tables 33–37. We did not evaluate the risk of bias for the primary studies included in these SRs. However, we note that authors of the most recent and comprehensive SRs judged their included studies as nearly all high risk of bias.^131,^ ^137^

In addition to the SRs, we identified 30 cohorts (published in 49 articles^72,^ ^73,^ ^139–181,^ ^310–313^) that reported discrimination, calibration, or both and that (with some exceptions) were either not included in the SRs or were published subsequent to the search dates covered by the SRs. Several of these studies reported data for more than one risk assessment instrument. We assessed nearly all studies as poor quality (i.e., high risk of bias) (Appendix D Tables 28–32) for all instruments evaluated because either no fracture risk model development study has been performed (e.g., OST), or the original model development studies were assessed as high risk of bias (see Appendix G) and the external validation analyses included in this update had risk of bias related to patient selection bias, missing data for risk factors or outcomes, and deviations in how risks and outcomes were ascertained as compared with the development cohort.

Of the 30 primary research cohorts, 13 articles were published representing five unique U.S. cohorts.^72,^ ^73,^ ^139–143,^ ^145,^ ^146,^ ^152,^ ^153,^ ^165,^ ^311^ One of these U.S. cohorts^72,^ ^145,^ ^146^ was exclusively among men, one was conducted in a mixed-sex population,^311^ and the rest were exclusively in women. The remaining cohorts were from Canada, Australia, New Zealand, Japan, Israel, Belgium, France, Portugal, Poland, and Spain. Most were exclusively women, but 11 cohorts included mixed populations of men and women, and in some cases, results were reported separately for men and women. The mean or median age ranged from approximately 50 years to 75 years. Cohorts were either retrospectively assembled based on clinical or administrative healthcare use data, such as BMD registries, electronic health records, or billing claims data; or data were collected in prospective, population-based epidemiologic studies or clinical trials, sometimes but not always focused on osteoporosis.

#### Findings

##### Calibration

Detailed calibration findings from the included SRs and the primary research studies are reported in Appendix D Table 11.

The Gates et al SR (in support of the CTFPHC) synthesized calibration findings for FRAX (with and without BMD), Garvan (with and without BMD), QFracture, FRISC, and FRC (with and without BMD).^131,^ ^132^ For FRAX, authors stratified results by study risk of bias. Authors concluded with very low certainty that FRAX demonstrated poor performance among the high risk of bias studies (13 studies for hip fracture without BMD, 12 studies for MOF without BMD, 13 studies for hip fracture with BMD, and 16 studies for MOF with BMD). The authors concluded with low (hip fractures, 3 studies) and moderate (MOF, 3 studies) certainty that FRAX without BMD may be well-calibrated among the three studies with unclear risk of bias that were specifically evaluating external validations of the FRAX-Canada model.^131,^ ^132^ Further, authors concluded with low certainty that FRAX with BMD may perform poorly for hip fractures (3 studies) but had moderate certainty that it was probably well-calibrated for MOF (3 studies).^131,^ ^132^

Authors of the Sun et al SR reported that calibration measures were only reported by primary study authors for 33 (24%) of the 138 models evaluated, and 31 (22%) showed “good fitness.”^137^ However, the SR authors reported only 22 (16%) used suitable methods for measuring calibration.

Of the primary research studies we identified, 25 cohorts were described in 40 articles^72,^ ^73,^ ^139,^ ^141–158,^ ^160,^ ^161,^ ^163–173,^ ^176,^ ^177,^ ^181,^ ^311–313^ that reported on calibration. Most focused on FRAX calibration. In the WHI cohort, the overall observed vs. expected ratio for FRAX was 1.0 (range of 0.76 to 1.15 across risk categories), and the calibration slope was 1.04.^139^ For hip fracture, the overall observed-to-expected ratio was 1.0 (range, 0.27 to 1.63 across risk categories), and the calibration slope was 1.59, with significant overprediction at the lowest risk categories and significant underprediction at the three highest categories.^139^ Calibration appeared similar when stratified by race and ethnicity in the two analyses among women ages 50 to 64 years that reported data by race or ethnicity.^141,^ ^143^ Data from the other two U.S. cohorts of women were somewhat limited; FRAX appeared to underestimate risk in older age groups^165^ and underestimate risk in women with obesity.^152,^ ^153^ Data from the male U.S. cohort (MrOs) were also somewhat limited; one analysis suggested the risk of MOF (with or without BMD) was overestimated and the risk of hip fracture (with BMD) was underestimated.^145^ In the other analysis of the MrOs cohort, the Hosmer-Lemeshow goodness-of-fit values suggested poor calibration for both MOF and hip fracture.^146^ Data related to the calibration of other instruments were limited and are reported in Appendix D Table 11.

##### Discrimination

Six SRs^131,^ ^132,^ ^134–138^ and 16 cohorts published in 25 articles^73,^ ^139–143,^ ^146,^ ^159,^ ^160,^ ^163,^ ^165,^ ^172–181,^ ^311,^ ^312^ not included in one or more of the SRs (with some exceptions) reported discrimination outcomes (AUC, sensitivity, specificity). Detailed findings are in Appendix D Table 10 (primary studies) and Table 12 (SRs). Figures 4a (women), 4b (men), and 4c (mixed-sex) summarize predictive discrimination with respect to AUC outcomes organized by instrument and by whether results were obtained from SRs or primary research studies. The AUCs varied widely depending on instrument, inclusion of BMD input as a risk, fracture type predicted, age range of the population evaluated, and whether authors were reporting the overall AUC (maximum AUC possible over all potential thresholds) or an AUC associated with a specific threshold. Of the three instruments that can assess risk with or without a BMD input (FRAX, FRC, Garvan), models with BMD generally reported higher AUCs than the same model without the inclusion of BMD. Studies evaluated FRAX, FRC, Garvan, and QFracture in men, women, and mixed-sex populations, and findings appeared similar across these populations. OST and WHI were only evaluated in women. Of the four instruments predicting risk for both MOF and hip fracture (FRAX, FRC, Garvan, QFracture), predictive accuracy appeared generally higher for prediction of hip fracture than MOF. For studies reporting outcomes specifically for women ages 50 to 64 years, the AUCs ranged from 0.52 to 0.71 across instruments. For the other studies of women (not reporting by age), the AUCs ranged from 0.63 to 0.89. For studies reporting outcomes for men, the AUCs ranged from 0.63 to 0.93. For studies reporting outcomes for mixed-sex populations, the AUCs ranged from 0.61 to 0.88.

Figure 4a Accuracy of Risk Instruments for Predicting Major Osteoporotic Fractures and Hip Fractures in Women (KQ 2a)

Abbreviations: AUC=area under the curve; BMD=bone mineral density; CI=confidence interval; FRAX=Fracture Risk Assessment Tool; FRC=Fracture Risk Calculator; FREM=Fracture Risk Evaluation Model; KQ=key question; MOF=major osteoporotic fracture; NR=not reported; ORAI=Osteoporosis Risk Assessment Instrument; OSIRIS=OSteoporosis Index of RISk; OST=Osteoporosis Self-Assessment Tool; SCORE=Simple Calculated Osteoporosis Risk Evaluation; SR=systematic reviews; WHI=Women’s Health Initiative.

This figure depicts a summary of predictive discrimination with respect to area under the curve (AUC) outcomes organized by instrument and by whether results were obtained from systematic reviews or primary research studies. AUC outcomes for nine instruments are shown in the figure: Fracture Risk Assessment Tool (FRAX), Fracture Risk Calculator (FRC), Fracture Risk Evaluation Model (FREM), Garvan, Osteoporosis Risk Assessment Instrument (ORAI), OSteoporosis Index of RISk (OSIRIS), Osteoporosis Self-Assessment Tool (OST), QFracture, Simple Calculated Osteoporosis Risk Evaluation (SCORE), and Women’s Health Initiative (WHI). FRAX, FRC, and Garvan are shown with and without bone mineral density (BMD) inputs. In studies among younger women, the AUCs ranged from 0.54 to 0.71 across instruments. For the other studies of women (not reporting by age), the AUC ranged from 0.63 to 0.89.

Figure 4b Accuracy of Risk Instruments for Predicting Major Osteoporotic Fractures and Hip Fractures in Men (KQ 2a)

Abbreviations: AUC=area under the curve; BMD=bone mineral density; CI=confidence interval; EPIC=Escala de Prediccion de fracturas Implementable en historia Clínica electronica - fracture prediction scale implementable in electronic medical record; FRAX=Fracture Risk Assessment Instrument; FREM=Fracture Risk Evaluation Model; KQ=key question; MOF=major osteoporotic fracture; NR=not reported; SR=systematic reviews.

This figure depicts a summary of predictive discrimination with respect to area under the curve (AUC) outcomes organized by instrument and by whether results were obtained from systematic reviews (SRs) or primary research studies. AUC outcomes for five instruments are shown in the figure: Escala de Prediccion de fracturas Implementable en historia Clínica electronica (EPIC), Fracture Risk Evaluation Model (FREM), Fracture Risk Assessment Tool (FRAX), Garvan, and QFracture. FRAX and Garvan are shown with and without bone mineral density (BMD) input. AUCs ranged from 0.63 to 0.93 across instruments.

Figure 4c Accuracy of Risk Instruments for Predicting Major Osteoporotic Fractures and Hip Fractures in Mixed-Sex Populations (KQ 2a)

Abbreviations: AUC=area under the curve; BMD=bone mineral density; CI=confidence interval; FRAX=Fracture Risk Assessment Instrument; FRC=Fracture Risk Calculator; KQ=key question; MOF=major osteoporotic fracture; NR=not reported; SR=systematic reviews.

This figure depicts a summary of predictive discrimination with respect to area under the curve (AUC) outcomes organized by instrument and by whether results were obtained from systematic reviews (SRs) or primary research studies. AUC outcomes for four instruments are shown in the figure: Fracture Risk Assessment Tool (FRAX), Fracture Risk Calculator (FRC), Garvan, and QFracture. FRAX, FRC, and Garvan are shown with and without bone mineral density (BMD) input. AUCs ranged from 0.61 to 0.88 across instruments.

Compared with the number of studies reporting AUC outcomes, fewer studies reported on sensitivity and specificity, and across studies the thresholds evaluated varied. FRAX was the most commonly reported-on instrument. In the WHI cohort of women ages 50 to 64 years not taking osteoporosis medication (n=62,492), the sensitivity of FRAX without BMD input for MOF risk greater than 9.3 percent was 26 percent, and the specificity was 83 percent.^139^ In a cohort of Spanish women (n=1,090), the sensitivity of a 5 percent threshold was 61 percent, and the specificity was 72 percent.^174^ For MOF with BMD input, the sensitivity of a fracture risk of 20 percent or higher was 20 percent, and the specificity was 93 percent in the Manitoba BMD registry cohort (n=54,459).^160^ From the same cohort, the sensitivity was 62 percent and specificity 79 percent for a fracture risk of 3 percent or higher for prediction of hip fracture with BMD input.

With respect to instruments other than FRAX, sensitivity and specificity varied. One study reported on the sensitivity (83%) and specificity (65%) of a 3 percent risk threshold for QFracture in predicting hip fracture in an Australian cohort of men and women ages 40 to 89 years with diabetes (n=1,251).^173^ Two studies reported on the sensitivity and specificity of OST at a score threshold of less than 2. Among women ages 50 to 64 years from the WHI cohort (n=99,431), the sensitivity was 40 percent, and the specificity was 61 percent.^139^ In an analysis of women ages 40 to 59 years from the Manitoba BMD registry, the sensitivity was 46 percent, and the specificity was 62 percent (n=8,254).^159^

The studies reporting on the predictive accuracy in the MrOs cohort of men (n=5,200) selected risk thresholds equivalent to a sensitivity of 90 percent for all instruments evaluated (FRAX, Garvan, QFracture), precluding a comparison with findings from other cohorts.^146^ No studies reported on the sensitivity or specificity for the FRC.

Accuracy outcomes by race and ethnicity. Accuracy results stratified by race or ethnicity were only reported by one cohort published in three articles.^140,^ ^142,^ ^143^ The WHI cohort, which was 89 percent White, reported findings for FRAX, Garvan Fracture Risk Calculator, and OST stratified by White, African American, Hispanic, and Asian race or ethnicity. However, results were only reported for women ages 50 to 64 years. CIs for AUC estimates were largely overlapping for the various race and ethnicity subgroups, precluding any conclusions about differences in predictive accuracy by race or ethnicity.

### KQ 2b Predictive Accuracy of BMD Measurement for Incident Fractures

#### Summary

Twenty-eight publications from 22 unique cohorts, a third of which we deemed poor quality, reported on the accuracy of BMD measurement (typically at the FN) for prediction of incident fractures.^15,^ ^146,^ ^150,^ ^151,^ ^154,^ ^156,^ ^157,^ ^160–162,^ ^166,^ ^172,^ ^175,^ ^176,^ ^179,^ ^182–194^ Most studies were conducted among women, and the mean age of participants varied from 49 years to 75 years with followup for incident fractures of 8 to 12 years, although some had shorter or longer followups. Four cohorts reported at least one type of calibration outcome, but few reported detailed information or the same information to allow for comparison across studies.^146,^ ^150,^ ^185,^ ^192^ Thirteen unique cohorts reported on the discrimination of BMD as a continuous variable for predicting MOF with AUCs ranging from 0.60 to 0.80.^146,^ ^150,^ ^151,^ ^154,^ ^156,^ ^157,^ ^166,^ ^172,^ ^175,^ ^176,^ ^179,^ ^183,^ ^189,^ ^190,^ ^193^ Twelve cohorts reported AUC outcomes for predicting hip fracture ranging from 0.64 to 0.86.^146,^ ^150,^ ^151,^ ^154,^ ^157,^ ^166,^ ^172,^ ^176,^ ^179,^ ^183,^ ^185,^ ^187,^ ^193,^ ^194^ Substantial heterogeneity precluded quantitative synthesis, but the AUC estimates for hip fracture appeared higher than the estimates for MOF. Fewer studies reported sensitivity and specificity and thresholds varied. Discrimination outcomes for men appeared similar to estimates for the overall body of evidence, which was predominantly in women. Discrimination outcomes for women younger than age 65 years were limited to two studies.^160,^ ^190^

#### Study Characteristics

Twenty-eight publications from 22 unique cohorts reported on the accuracy of BMD measurement for prediction of incident fractures.^15,^ ^146,^ ^150,^ ^151,^ ^154,^ ^156,^ ^157,^ ^160–162,^ ^166,^ ^172,^ ^175,^ ^176,^ ^179,^ ^182–194^ Individual study details are in Appendix D Table 3. We assessed 10 of these analyses (covering 7 unique cohorts) as poor quality.^15,^ ^151,^ ^156,^ ^175,^ ^176,^ ^179,^ ^185,^ ^186,^ ^189,^ ^194^ The rest were fair quality. Detailed study quality ratings are in Appendix D Tables 38–42. Three unique cohorts were from the United States;^146,^ ^187,^ ^192^ the rest were from Canada (2 cohorts^154,^ ^157,^ ^160–162,^ ^183,^ ^184,^ ^193^), countries in Europe (8 cohorts^15,^ ^175,^ ^176,^ ^179,^ ^185,^ ^188–190^), countries in Asia (5 cohorts^150,^ ^151,^ ^156,^ ^182,^ ^194^), Australia (2 cohorts^186,^ ^191^), New Zealand (1 cohort^166^), or Israel (1 cohort^172^).

Most analyses used data collected from prospective, population-based epidemiologic studies focused either on bone health, osteoporosis, or aging generally. The exceptions were an analysis based on the WHI (United States) that used data from both the clinical trial and observational study components,^187^ an analysis based on electronic health data and administrative billing data collected through usual care in Israel,^172^ and a provincial BMD registry with administrative billing data in Canada.^157,^ ^160–162,^ ^183,^ ^193^ The cohort sample sizes varied from 400 to 68,730 persons, and the mean age of included persons varied from 49 years to 75 years. Two cohorts were exclusively men,^146,^ ^182^ four cohorts included both men and women,^15,^ ^154,^ ^157,^ ^161,^ ^162,^ ^176,^ ^193^ and the rest were exclusively women. Only persons with available BMD measurements were included in the reported analyses; other inclusion/exclusion criteria varied across cohorts. For example, some of the reported analyses excluded persons who were known to be taking antiosteoporosis medication^146,^ ^150,^ ^151,^ ^161,^ ^166,^ ^189,^ ^191,^ ^193^ or who were known to have secondary osteoporosis or metabolic bone disease,^156^ while other cohorts allowed persons on treatment or did not specify treatment status. Similarly, the proportion of persons with a history of fracture at baseline enrollment also varied and was reported using different definitions. Among the studies conducted exclusively or mostly in women that reported mean T-score at the FN at baseline, T-scores ranged from −1.0 to −1.5. The two studies conducted exclusively in men did not report baseline T-scores.^146,^ ^182^ Among the studies reporting the prevalence of osteoporosis at baseline, the range was 4.9 to 31.7 percent.

#### Findings

Individual cohort findings are in Appendix D Table 13. Across these cohorts, incident fractures were reported over a followup ranging from 4 to 25 years; however, followup of 8 to 12 years was most common because many studies also evaluated the predictive accuracy of fracture risk assessments designed to predict fracture over a 10-year time period. In the cohorts reporting on men, the incidence of MOF was 3.7 to 10.7 percent, and the incidence of hip fracture ranged from 1.5 to 4.2 percent over a followup of 5.4 to 15.8 years. Among the cohorts reporting on women, the incidence of MOF ranged from 3.3 to 15.0 percent, and the incidence of hip fracture ranged from 0.5 to 15.9 percent over followup of 4.5 to 25 years. In addition to differences in length of followup, the anatomic site of BMD measurement varied across studies; FN was most commonly used, but some studies reported outcomes based on measurement at the TH or LS or based on the lowest measurement from the FN, TH, or LS.

##### Calibration

Four cohorts reported at least one type of calibration outcome, but few reported detailed information or the same information to allow for comparison across studies (Appendix E.2 Table 1).^146,^ ^150,^ ^185,^ ^192^ Only two cohorts reported goodness-of-fit outcomes (poor in 1 cohort^185^ and good in the other^146^). Only one cohort reported calibration plots, which showed a dose-response effect across quartiles of predicted risk but no other information to interpret the calibration.^150^ One cohort reported hip and nonvertebral fractures after 25 years; participants in the highest quartile of BMD had lower incidence of fractures compared with those in the lower quartile of BMD.^192^ Lastly, one study reported the observed-to-expected ratio for hip fracture (0.83 [95% CI, 0.65 to 1.04]), suggesting poor calibration.^185^

##### Discrimination

Twenty-six articles reporting on 20 unique cohorts reported discrimination outcomes (Figure 5).^15,^ ^146,^ ^150,^ ^151,^ ^154,^ ^156,^ ^157,^ ^160–162,^ ^166,^ ^172,^ ^175,^ ^176,^ ^179,^ ^183–191,^ ^193,^ ^194^ Thirteen unique cohorts reported on the discrimination of BMD as a continuous variable for predicting MOF with AUCs ranging from 0.60 to 0.80.^146,^ ^150,^ ^151,^ ^154,^ ^156,^ ^157,^ ^166,^ ^172,^ ^175,^ ^176,^ ^179,^ ^183,^ ^189,^ ^190,^ ^193^ Twelve unique cohorts reported AUC outcomes for predicting hip fracture ranging from 0.64 to 0.86.^146,^ ^150,^ ^151,^ ^154,^ ^157,^ ^166,^ ^172,^ ^176,^ ^179,^ ^183,^ ^185,^ ^187,^ ^193,^ ^194^ Substantial heterogeneity precluded quantitative synthesis, but the AUC estimates for hip fracture appeared higher than the estimates for MOF.

Figure 5 Accuracy of Bone Mineral Density for Predicting Major Osteoporotic Fractures and Hip Fractures (KQ 2b)

■=women; ●= men; ▲=mixed population of men and women

Abbreviations: AUC=area under the curve; CI=confidence interval; KQ=key question; MBR=Manitoba BMD Registry; MOF=major osteoporotic fracture; N/n=number; NR=not reported.

This figure depicts area under the curve (AUC) outcomes of bone mineral density (BMD) for predicting fractures. Squares represent studies among women, circles represent studies among men, and triangles indicate studies of mixed population of men and women. The top portion of the figure shows results for BMD predicting major osteoporotic fracture from 14 studies. The range of AUC outcomes based on femoral neck BMD site was from 0.60 to 0.80. The lower portion of the figure shows results for BMD predicting hip fracture from 13 studies. The range of AUC outcomes based on femoral neck BMD site was from 0.64 to 0.86.

Fewer studies reported sensitivity and specificity outcomes. In studies that used a BMD T-score of less than −2.5 as the threshold for a positive test, the sensitivity ranged from 17.5 to 51.3 percent for MOF^150,^ ^160–162,^ ^175^ and from 25.0 to 66.7 percent for hip fractures.^15,^ ^150,^ ^160,^ ^162,^ ^187^ The specificity for MOF ranged from 70.9 to 95.4 percent^160,^ ^161,^ ^175^ and from 88.6 to 94.0 percent for hip fractures.^15,^ ^160,^ ^162,^ ^187^

Discrimination outcomes in younger women. Only two studies reported on the discrimination of BMD alone specifically in younger women.^160,^ ^190^ In one population-based prospective cohort study of women ages 45 to 54 years in the United Kingdom, the AUC for predictive accuracy of continuous BMD at the FN was 0.64 (95% CI, 0.63 to 0.66) over a followup of 3 to 12 years; sensitivity and specificity were not reported.^190^ In a BMD registry from Manitoba, Canada, the prediction of MOF, based on a T-score less than −2.5, had a sensitivity of 6.7 percent for women ages 40 to 49 years, 9.7 percent for women ages 50 to 59 years, and 18.5 percent for women ages 60 to 69 years compared with 30.1 percent for women ages 70 to 79 years and 49 percent for women age 80 years or older.^160^ Similarly, specificity decreased from 98 percent in women ages 40 to 49 years to 69 percent for women age 80 years or older.^160^ For the prediction of hip fractures, a similar pattern was observed with the lowest sensitivity for women ages 40 to 49 years (19%) and the highest sensitivity for women age 80 years or older (54%).^160^

Discrimination outcomes in men. Only one study that exclusively enrolled men reported discrimination outcomes.^146^ In this retrospective analysis of participants in a community-based population study of mostly White men age 65 years or older, the AUC for continuous BMD over a followup of 15.8 years was 0.76 (95% CI, 0.71 to 0.80) for the prediction of MOF and was very similar for the prediction of hip fracture (0.76 [95%, CI, 0.721 to 0.81]).^146^ The T-score threshold cutoff associated with a sensitivity of 90 percent for MOF prediction was −0.21 and for hip fracture was −0.36; both used a young, White female reference range for T-scores.^146^

Three analyses reported outcomes separately for women and men from within the same study.^15,^ ^162,^ ^176^ One analysis reported data from three population-based cohort studies in Portugal (N=1,897). Marques et al reported AUC estimates in men that were higher for prediction of both MOF (0.80 vs. 0.66) and hip fracture (0.82 vs. 0.68).^176^ In Trajanoska et al, a population-based study from the Netherlands (N=11,052), AUCs were not reported, but the sensitivity was lower in men (20% vs. 38%) and specificity was higher (94% vs. 91%) for the prediction of hip fracture over 11 years of followup based on a threshold T-score of less than −2.5.^15^ A similar pattern was observed for nonvertebral fractures. In data from the Manitoba BMD registry, sensitivity was also lower in men compared with women for the prediction of MOF (18% vs. 28%) and the prediction of hip fracture (31% vs. 43%), while the specificities were very similar for each fracture type between sexes (89% for women, 92% for men).^162^

Two studies reported on mixed-sex populations of men and women;^154,^ ^157^ these estimates appear similar to the estimates from studies that exclusively analyzed women or men with AUCs ranging from 0.66 to 0.68 for MOF prediction and 0.76 to 0.80 for hip fracture prediction.

Accuracy outcomes by race and ethnicity. Of the studies reporting the race or ethnicity of participants, studies enrolled exclusively or predominantly White participants (89% or more). No studies reported calibration or discrimination outcomes by race or ethnicity.

### KQ 2c Diagnostic Accuracy of Risk Assessment Instruments for Identifying Osteoporosis

#### Summary

Forty-three unique cohorts (published in 54 articles) reported on diagnostic test accuracy of 15 risk assessment instruments for identifying osteoporosis.^141,^ ^143,^ ^159,^ ^195–245^ More than half of the studies enrolled populations with a mean age between 60 and 69 years and studies included women, men, or both. Differences in reference standards, risk assessment score thresholds, and study populations precluded a quantitative synthesis. In women, AUCs ranged from 0.32 to 0.87 across 35 articles evaluating 11 instruments (Figure 6a). Five articles reported results from three independent cohorts that retrospectively evaluated the accuracy of a FRAX MOF risk threshold of 8.4 percent or 9.3 percent in women ages 50 to 64 years; AUCs ranged from 0.55 to 0.62. In men, AUCs ranged from 0.62 to 0.94 across 18 articles evaluating 12 instruments (Figure 6b). Three articles reported on accuracy among mixed populations of men and women for the FRAX, OST, or Garvan Fracture Risk Calculator (Figure 6c).^196,^ ^239,^ ^241^ Findings in these studies were consistent with the findings reported for men and women separately. Several studies reported findings stratified by age, but few studies reported findings stratified by race or ethnicity.

Figure 6a Accuracy of Risk Assessment Instruments for Identifying Osteoporosis in Women (KQ 2c)

Note: This plot depicts the range of AUC estimates (line with no symbol) from across 2 or more studies OR a single study point estimate and 95% CI when only one study reported an AUC estimate. The number of studies (k) in AUC, sensitivity, and specificity columns is provided when the estimate reported was from a fewer number of studies than what is reported in the second column. Not all studies reported all three outcomes. Unless otherwise indicated, populations generally included postmenopausal women (>45, >50, >55, >60 years), but in some cases women as young as 40 years without regard to menopausal status were enrolled.

* Thresholds evaluated included ≥1.5, ≥2, ≥3.

^†^ Does not include one study that was an extreme outlier.^245^

^ǂ^ MOF risk ≥8.4 percent (2018 USPSTF recommendation) or 9.3 percent (2011 USPSTF recommendation).

^§^ The most common threshold was ≥9, but threshold varied from 8 to 20; the sensitivities and specificities reflect estimates from across all score thresholds.

^ǁ^ Score thresholds for sensitivity and specificity varied from <−3 to <1.5.

^¶^ The most common threshold was <2, but thresholds evaluated included ≤1, <0, ≤−1, <−2.9, and some studies did not report threshold because they only reported AUC.

^#^ Excluding two outliers (AUC 0.32^199^ and 0.22).^225^

** The most common threshold was <2, but also included studies that did not report threshold (AUC only) and threshold of ≤1.

^††^ The most common threshold was ≤−1, but also included <0, <−1, ≤−2.

^ǂǂ^ The most common threshold evaluated was ≥6, but other thresholds included >7, ≥7, ≥8, ≥11, ≥12, ≥20.75, and some studies where no threshold (AUC only) was reported were also evaluated.

^§§^ The most common threshold evaluated was ≥6, but >6, >7, and ≥7 were also evaluated.

^ǁǁ^ Thresholds evaluated included ≥1, >1.7, ≥0.

Abbreviations: ABONE=Age, Bone, No Estrogen; AMMEB=Age, years after Menopause, age at MEnarche; AUC=area under the curve; CI=confidence interval; FRAX=Fracture Risk Assessment Tool; KQ=key question; MOF=major osteoporotic fracture; OF=osteoporotic fractures; N/n=number; NR=not reported; NOF=National Osteoporosis Foundation; ORAI=Osteoporosis Risk Assessment Instrument; OSIRIS=OSteoporosis Index of RISk; OST=Osteoporosis Self-Assessment Tool; OSTA=OST for Asians; SCORE=Simple Calculated Osteoporosis Risk Estimation; Sn=sensitivity; SOFSURF=Study of Osteoporotic Fractures Research Group Study Utilizing Risk Factors; Sp=specificity; USPSTF=U.S. Preventive Services Task Force.

This figure depicts results for diagnostic test accuracy of risk assessment instruments for identifying osteoporosis in women. The plot depicts the range of area under the curve (AUC) estimates from across two or more studies, or a single study point estimate and 95 percent confidence interval when only one study reported an AUC estimate. Results for 11 instruments are shown in this figure: Age, Bone, No Estrogen (ABONE), Age, MEnopause, Menarche, BMI (AMMEB), Fracture Risk Assessment Tool (FRAX), Garvan Fracture Risk Calculator, National Osteoporosis Foundation (NOF) tool, ORAI, OSteoporosis Index of RISk (OSIRIS), Osteoporosis Self-Assessment Tool (OST), OST for Asians (OSTA), Simple Calculated Osteoporosis Risk Estimation (SCORE), and Study of Osteoporotic Fractures Research Group Study Utilizing Risk Factors (SOFSURF). Across instruments, the AUC ranged from 0.32 to 0.87. In five studies reporting on accuracy of risk assessment instruments specifically for women younger than age 65, the AUC ranged from 0.55 to 0.62.

Figure 6b Accuracy of Risk Assessment Instruments for Identifying Osteoporosis in Men (KQ 2c)

Note: This plot depicts the range of AUC estimates (line with no symbol) from across 2 or more studies OR a single study point estimate and 95% CI when only one study reported an AUC estimate. The number of studies (k) in AUC, sensitivity, and specificity columns is provided when the estimate reported was from a fewer number of studies than what is reported in the second column. Not all studies reported all three outcomes.

* MOF risk ≥8.4 percent (2018 USPSTF recommendation) or 9.3 percent (2011 USPSTF recommendation).

^†^ Threshold ≤26 for U.S. participants; ≤21 for Hong Kong participants.

^ǂ^ In a separate cohort of 134 African Americans derived from a convenience sample, the sensitivity was either 93 percent or 100 percent and the specificity was either 73 percent or 79 percent depending on whether a Caucasian or African American reference range was used to calculate T-scores. See Appendix D Table 13 for details.

^§^ The most common threshold evaluated was <2; however, the following thresholds were also evaluated: ≤6, <3, <1, <0.99, <0, ≤0, <−1, ≤−2, and several studies that did not report thresholds because they only reported AUC.

^ǁ^ The most common threshold evaluated was ≤−1, but <2, ≤1, ≤0, and <0.5 were also evaluated.

Abbreviations: ABONE=Age, Bone, No Estrogen; AUC=area under the curve; CI=confidence interval; FRAX=Fracture Risk Assessment Tool; KQ=key question; MOF=major osteoporotic fracture; MORES=Male Osteoporosis Risk Estimation Score; MOST=Male Osteoporosis Screening Tool; MSCORE=Male Simple Calculated Osteoporosis Risk Estimation; OF=osteoporotic fractures; N/n=number; NR=not reported; ORAI=Osteoporosis Risk Assessment Instrument; OST=Osteoporosis Self-Assessment Tool; OSTA=OST for Asians; SCORE=Simple Calculated Osteoporosis Risk Estimation; Sn=sensitivity; Sp=specificity; USPSTF=U.S. Preventive Services Task Force; VA-FARA=Veterans Affairs Fracture Absolute Risk Assessment.

This figure depicts results for diagnostic test accuracy of risk assessment instruments for identifying osteoporosis in men. The plot depicts the range of area under the curve (AUC) estimates from across two or more studies, or a single study point estimate and 95 percent confidence interval when only one study reported an AUC estimate. Results for 12 instruments are shown in this figure. Four of them were developed specifically for men: Male Osteoporosis Risk Estimation Score (MORES), the Male Osteoporosis Screening Tool (MOST), the Male Simple Calculated Osteoporosis Risk Estimation (MSCORE), and Veterans Affairs Fracture Absolute Risk Assessment (VA-FARA). The AUCs ranged from 0.64 to 0.88 for these instruments. For the other eight instruments (Age, Bone, No Estrogen [ABONE], Fracture Risk Assessment Tool [FRAX], Garvan Fracture Risk Calculator, Osteoporosis Risk Assessment Instrument [ORAI], OSteoporosis Index of RISk [OSIRIS], Osteoporosis Self-Assessment Tool [OST], OST for Asians [OST-A], and Simple Calculated Osteoporosis Risk Evaluation [SCORE]). the AUCs ranged from 0.62 to 0.94.

Figure 6c Accuracy of Risk Assessment Instruments for Identifying Osteoporosis in Mixed-Sex Populations (KQ 2c)

* Used empirically derived, age-based thresholds.

Abbreviations: CI=confidence interval; FRAX=Fracture Risk Assessment Tool; k=number of studies; KQ=key question; MOF=major osteoporotic fracture; OF=osteoporotic fractures; OST=Osteoporosis Self-Assessment Tool; N =number; NR=not reported; Sn=sensitivity; Sp=specificity.

This figure depicts results for diagnostic test accuracy of risk assessment instruments for identifying osteoporosis in mixed-sex populations. The plot lines depict a single study point estimate and 95 percent confidence interval. Results for three instruments are shown in this figure: Fracture Risk Assessment Tool (FRAX) Garvan, and Osteoporosis Self-Assessment Tool (OST). The AUCs ranged from 0.68 to 0.76.

#### Study Characteristics

We identified 54 articles reporting on diagnostic test accuracy of risk assessment instruments for identifying osteoporosis (Appendix D Table 4) from 43 unique cohorts.^141,^ ^159,^ ^195–245^ Sixteen studies^197,^ ^198,^ ^201,^ ^202,^ ^212,^ ^216,^ ^218,^ ^219,^ ^221,^ ^229,^ ^232,^ ^235,^ ^237,^ ^238,^ ^240,^ ^244^ were conducted exclusively in men, three studies^196,^ ^239,^ ^241^ were conducted among a mixed population of men and women (proportion of women ranged from 45% to 87%) but did not report results separately for men and women, and two studies^233,^ ^243^ included men and women but reported results separately by sex; the rest of the studies were conducted exclusively in women. The mean age across studies ranged from 50.5 to 80.4 years, with just over half of the studies enrolling populations with a mean age between 60 and 69 years. We rated one study^205^ as good quality; the rest were fair quality. Detailed study quality ratings are in Appendix D Tables 43–47. Common risk-of-bias issues included lack of consecutive or random enrollment of patients, no information about blinding of index and reference tests, and lack of information about interval between risk assessment and DXA testing. Further, about a third of studies were conducted on data collected during usual care from persons referred for DXA; the rest of the studies recruited persons from healthcare settings or were population-based cohort studies. Twenty-two analyses were conducted in U.S. cohorts.^141,^ ^143,^ ^195,^ ^197,^ ^198,^ ^202,^ ^216,^ ^219–222,^ ^224,^ ^226,^ ^230–232,^ ^234–238,^ ^241^

Fifteen unique risk assessment instruments were evaluated as index tests for identifying osteoporosis. Most instruments were originally developed to identify persons at high risk for osteoporosis; however, three instruments (FRAX, Garvan, and the [underlined: V]eterans [underlined: A]ffairs [underlined: F]racture [underlined: A]bsolute [underlined: R]isk [underlined: A]ssessment [VA-FARA]) were originally designed as fracture risk prediction instruments.^141,^ ^195,^ ^196,^ ^200,^ ^220,^ ^232–239,^ ^241^ Authors evaluated instruments against a reference standard of a T-score based on DXA BMD measurement most commonly at the FN, but many studies also used measurements at the TH or LS or against the lowest T-score from across the three sites. Methods used to determine discrimination varied; authors either computed AUC across the range of all possible threshold (i.e., “continuous” or “overall” AUC) or computed AUC with respect to a specific threshold, or both.

#### Findings

Studies reported discrimination outcomes including AUC, sensitivity, and specificity to describe the accuracy of these risk assessments for identifying osteoporosis. Some studies reported accuracy outcomes for more than one risk assessment instrument for the same study population, and some studies reported sensitivity and specificity outcomes using different risk assessment score thresholds, often prespecified but sometimes empirically derived to maximize sensitivity. In some cases, results for women and men were presented separately, and in other cases results for the “mixed” population of men and women were reported as one estimate. This heterogeneity precluded a quantitative synthesis of accuracy results.

The instrument most commonly evaluated was the [underlined: O]steoporosis [underlined: S]elf-assessment [underlined: T]ool (OST), which was reported in 26 unique cohorts from 31 articles.^143,^ ^159,^ ^195,^ ^196,^ ^198–201,^ ^203,^ ^205,^ ^208–210,^ ^214,^ ^216–219,^ ^221,^ ^223,^ ^225,^ ^228,^ ^230,^ ^231,^ ^234–237,^ ^240,^ ^242,^ ^243^ Other instruments reported in more than 10 articles included the [underlined: O]steoporosis [underlined: R]isk [underlined: A]ssessment [underlined: I]nstrument (ORAI) reported in 21 unique cohorts in 22 articles,^199,^ ^203,^ ^206–210,^ ^214,^ ^217,^ ^223–228,^ ^230,^ ^231,^ ^233,^ ^234,^ ^236,^ ^242,^ ^245^ the [underlined: S]imple [underlined: C]alculated [underlined: O]steoporosis [underlined: R]isk [underlined: E]stimation (SCORE) reported in 18 cohorts in 20 articles,^195,^ ^203,^ ^206–211,^ ^217,^ ^222,^ ^224,^ ^226,^ ^228,^ ^230,^ ^231,^ ^233,^ ^234,^ ^236,^ ^242,^ ^245^ and FRAX reported from 12 unique cohorts in 15 articles.^141,^ ^195,^ ^196,^ ^200,^ ^220,^ ^232–239,^ ^241^ A summary of findings is depicted in Figures 6a (women), 6b (men), and 6c (mixed populations) with detailed findings in Appendix D Table 14. A detailed narrative description of findings organized by risk assessment instrument is in Appendix E.3.

##### Accuracy in Women

We identified 28 unique cohorts (reported in 35 articles) for 11 risk assessment instruments evaluated in populations that were exclusively women or that reported results separately for women (Figure 6a).^141,^ ^143,^ ^159,^ ^195,^ ^199,^ ^200,^ ^203–211,^ ^213–215,^ ^217,^ ^220,^ ^222–228,^ ^230,^ ^231,^ ^233,^ ^234,^ ^236,^ ^242,^ ^243,^ ^245^ The instruments evaluated in women included [underlined: A]ge, [underlined: B]one, [underlined: N]o [underlined: E]strogen (ABONE), [underlined: A]ge, [underlined: ME]nopause, [underlined: M]enarche, BMI (AMMEB), FRAX, Garvan, National Osteoporosis Foundation tool (NOF), ORAI, [underlined: OS]teoporosis [underlined: I]ndex of [underlined: RIS]k (OSIRIS), OST, OST for [underlined: A]sians (OSTA), SCORE, and [underlined: S]tudy of [underlined: O]steoporotic [underlined: F]ractures Research Group [underlined: S]tudy [underlined: U]tilizing Risk Factors (SOFSURF). Across instruments, the AUC ranged from 0.32 to 0.87, excluding one study that we deemed an outlier because of extreme values.^245^ Sensitivity ranged from 5 to 100 percent, and specificity ranged from 0 to 100 percent; however, these ranges represent different score thresholds, some of which were prespecified and some of which were empirically derived to maximize sensitivity. A detailed description of findings for each risk assessment instrument is in Appendix E.3.

##### Accuracy in Women Younger Than Age 65 Years

Several articles reported on accuracy of risk assessment instrument specifically among women ages 50 to 64 years (selected parts of Figure 6a). Five articles^141,^ ^195,^ ^220,^ ^234,^ ^236^ reported results from three independent cohorts that retrospectively evaluated the accuracy of the USPSTF’s present (8.4%) or former (9.3%) suggested FRAX MOF risk threshold for DXA screening in women younger than age 65 years. The AUC in these studies ranged from 0.55 to 0.62, sensitivity ranged from 5 to 49 percent and specificity ranged from 63 to 96 percent. In one study from the WHI (N=8,134), the sensitivity was 5 percent among women ages 50 to 54 years, 17 percent among women ages 55 to 59 years, and 49 percent among women ages 60 to 64 years.^141^ The sensitivities of FRAX for the USPSTF’s suggested threshold reported by the other included articles ranged from 24 to 37 percent. The specificity across these five studies ranged from 63.4 to 95.8 percent. In addition to reporting on the accuracy of a specific FRAX risk threshold, two studies using data from the WHI also reported the AUC of FRAX when treated continuously without respect to a specific risk threshold; the AUC was 0.59 for MOF^140^ and was 0.68 for hip.^143^

Several articles also reported on the accuracy of other risk assessment instruments among women younger than age 65 years. Six cohorts (in 8 articles^143,^ ^159,^ ^195,^ ^200,^ ^209,^ ^228,^ ^234,^ ^236^) reported an AUC for OST of 0.63 to 0.83, six cohorts^195,^ ^209,^ ^226,^ ^228,^ ^234,^ ^236^ reported an AUC of 0.58 to 0.87 for SCORE, and five cohorts^209,^ ^226,^ ^228,^ ^234,^ ^236^ reported an AUC for ORAI of 0.60 to 0.84.

##### Accuracy in Men

We identified six studies for four risk assessment instruments that were developed exclusively for men (Figure 6b).^197,^ ^202,^ ^216,^ ^218,^ ^232,^ ^237^ The [underlined: M]ale [underlined: O]steoporosis [underlined: R]isk [underlined: E]stimation [underlined: S]core (MORES, 2 cohorts in 3 articles^197,^ ^202,^ ^232^), the [underlined: M]ale [underlined: O]steoporosis [underlined: S]creening [underlined: T]ool (MOST, 1 cohort^218^), the [underlined: M]ale [underlined: S]imple [underlined: C]alculated [underlined: O]steoporosis [underlined: R]isk [underlined: E]stimation (MSCORE, 1 cohort^216^) and the VA-FARA (1 cohort^237^). In these studies, AUCs ranged from 0.64 to 0.88. These estimates were similar to those observed for other non-male specific risk assessment instruments (e.g., OST) evaluated within these cohorts.

We also identified studies evaluating other risk instruments that were not developed specifically for men (Figure 6b). These included the ABONE, FRAX, Garvan, ORAI, OSIRIS, OST, OSTA, and SCORE. Across these other instruments, the AUCs ranged from 0.62 to 0.94.^198,^ ^201,^ ^212,^ ^216,^ ^218,^ ^219,^ ^221,^ ^229,^ ^232,^ ^233,^ ^235,^ ^237,^ ^238,^ ^240,^ ^243,^ ^244^ A detailed description of findings for each risk assessment instrument is in Appendix E.3.

##### Accuracy in Mixed-Sex Populations

Three studies reported on accuracy among mixed populations of men and women for FRAX, OST, and Garvan (Figure 6c).^196,^ ^239,^ ^241^ Findings in these studies were consistent with the findings reported for men and women separately.

##### Accuracy by Age

In addition to the studies related to FRAX for women younger than age 65 years discussed above, nine cohorts reported in 11 articles reported findings on other instruments stratified by age.^159,^ ^195,^ ^198,^ ^200,^ ^209,^ ^221,^ ^226,^ ^228,^ ^234,^ ^236,^ ^240^ Three cohorts reported findings exclusively among men^198,^ ^221,^ ^240^ for the OST instrument, while eight articles reported findings exclusively among women for the NOF, ORAI, OST, and SCORE instruments.^159,^ ^195,^ ^200,^ ^209,^ ^226,^ ^228,^ ^234,^ ^236^

Among women, the AUCs in the studies reporting by age ranged from 0.58 to 0.87 across instruments. Sensitivity ranged from 44 to 100 percent, and specificity ranged from 10 to 81 percent, but score thresholds used to determine sensitivity and specificity varied by study, precluding direct comparisons. Meaningful differences in findings by age were observed for the same instrument evaluated by different studies. For example, in a population-based sample of postmenopausal women from the Rochester, MN, region (N=202), authors reported age-stratified results for the women ages 45 to 64 years and the women age 65 years or older for the NOF, ORAI, and SCORE. Differences in AUCs and sensitivity between age strata were small with overlapping CIs, suggesting no meaningful differences between age groups.^226^ However, large differences in specificity were observed for ORAI and SCORE, with specificity across the three instruments ranging from 0 to 8 percent in the older women and from 19 to 69 percent in the younger women.^226^ Yet, in a study published 10 years later from the same clinical setting among women ages 50 to 64 years (N=290) and using the same score thresholds that were used in the earlier study, the AUCs reported for ORAI and SCORE were more than 0.2 units lower than those reported in the earlier study for both instruments, and sensitivity was also meaningfully lower (sensitivity 99% and 100% for ORAI and SCORE, respectively, vs. 52% and 74% in the later study).^234^ However, these differences may be partially explained by the use of a different reference standard in the later study (BMD at the FN or LS vs. BMD at the FN only used in the earlier study).

One study conducted among Caucasian women (N=4,025) referred for DXA in a single Belgian city reported discrimination stratified by age (45 to 64 years, 65 years or older).^209^ In this study, the AUCs for ORAI, OST, and SCORE were similar in both age strata (range, 0.75 to 0.76); however, the authors chose different scoring thresholds to determine a positive test for the different age groups, precluding a direct comparison of sensitivity between age groups.^209^

In a study of men enrolled from specialty clinics in Veterans Affairs (VA) settings (N=181), the AUCs for the OST instrument ranged from 0.70 to 0.99 across four age categories from 50 to 59 years to 80 years or older; however, there was not a clear linear trend: the lowest AUC was in the age group 70 to 79 years and the highest was in the age group 80 years or older.^221^ In a separate study of men enrolled from four VA sites (N=518), the sensitivity of the OST was higher and specificity was lower among men older than age 65 years compared with younger men at both of the score thresholds reported (OST≤6, OST≤0).^198^ In another study among men referred for DXA at an academic health center in Taiwan (N=834), the AUCs for the OST instrument were similar among men younger than age 65 years (0.66) and men age 65 years or older (0.68).^240^

##### Accuracy by Race or Ethnicity

Six cohorts reported findings stratified by race or ethnicity.^140,^ ^142,^ ^143,^ ^198,^ ^202,^ ^216,^ ^221,^ ^224^ Four of the six cohorts were men, and three of those studies were among men recruited from VA clinical settings. Substantial heterogeneity with respect to instruments, score thresholds used, and racial categories evaluated precludes any definitive conclusion about differences in accuracy by race or ethnicity. In one VA study (N=518), the sensitivity of the OST was higher and the specificity lower for both score thresholds reported (OST≤6, OST≤0) among Caucasians compared with African Americans; for example, sensitivity for the less than 0 threshold was 25 percent in African Americans and 42 percent in Caucasian participants, and specificity was 87 percent and 85 percent, respectively.^198^ In another VA study (N=197), authors reported on accuracy data for MSCORE, OST, and the reduced MSCORE.^216^ The sensitivity of these instruments was higher and specificity was lower for African Americans compared with Caucasians, but only when using a Caucasian reference range for calculating T-scores from raw BMD measurements (which is the standard method for calculating T-scores for persons of all races).^216^ Outcomes were similar when an African American reference range was used.^216^ In the third VA study (N=181), the AUCs reported for White persons (0.85) were reasonably similar to the AUCs reported for Black persons (0.80).^221^ In an analysis of U.S. NHANES data (N=2,944 men age 50 years or older), authors reported on the accuracy of MORES for White, African American, Mexican American, and “other” race and ethnicities.^202^ Across the groups, sensitivity ranged from 60 percent (White) to 95 percent (other), and specificity ranged from 55 percent (other) to 69 percent (White).^202^

Two cohorts reported on differences in accuracy by race and ethnicity among women. In a cohort of postmenopausal women identified from a university-based family practice (N=226), AUCs were similar for Hispanic and African American persons compared with the full study population for the ORAI and SCORE instruments; sensitivities and specificities varied but were quite imprecise, precluding any definitive conclusions about differences by race or ethnicity.^224^ Among women ages 50 to 64 years in the WHI cohort, no discernible pattern of differences in AUC were observed between AUC estimates among persons of different race or ethnicity for the FRAX, Garvan, and OST instruments.^140,^ ^142,^ ^143^

### KQ 2d What Is the Evidence to Determine Screening Intervals, and How Do These Intervals Vary by Baseline or Current Individual Fracture Risk?

#### Study Characteristics

We identified three new cohort studies^248–250^ for this update for a total of five included studies for this KQ.^246–250^ We rated two as poor quality^247,^ ^248^ and the rest as fair quality; detailed study quality ratings are in Appendix D Tables 48–52. Study characteristics are detailed in Appendix D Table 5 and findings are detailed in Appendix D Table 15.^246–248^ Four studies were conducted among U.S. cohorts (Framingham Osteoporosis Study,^246^ WHI,^249^ MrOs,^250^ SOF^247^) and the fifth study used data from the Manitoba BMD registry in Canada.^248^ The mean age of participants was 60 in the Manitoba cohort,^248^ 66 in the WHI cohort,^249^ and 72 to 74 years in the other three cohorts. The Framingham Cohort was 61 percent women,^246^ MrOs was 100 percent men,^250^ and the rest were exclusively women.

All studies used a similar design that evaluated the accuracy of a fracture risk prediction model based on an initial BMD measurement and a repeat BMD measurement at a subsequent interval, which ranged from 4 to 8 years across studies. Followup for fracture ascertainment occurred for 8 to 11 years after the second BMD measurement. Notably, because of this study design, authors excluded participants who experienced a fracture event during the interval between the initial and repeat BMD test.

#### Findings

In four of the five studies, authors reported similar accuracy when comparing models including only the initial BMD compared with models based on the change in BMD or in models that included both initial BMD and change in BMD. As an illustrative example, the AUC for baseline BMD for predicting MOF in the SOF cohort was 0.68 (95% CI, 0.66 to 0.71), the AUC for BMD change (as a % of initial) was 0.63 (95% CI, 0.61 to 0.66), and the AUC for a model combining initial BMD and change in BMD had an AUC of 0.69 (95% CI, 0.66 to 0.71).^250^ In the fifth study, authors reported no association between change in spine, TH, or FN BMD and MOF (HRs, 0.93 to 1.02 per SD increase in BMD, all statistically nonsignificant).^248^

### KQ 3 What Are the Harms of Screening for Fracture Risk or Osteoporosis?

Of the three RCTs included for KQ 1, only the SCOOP trial reported on harms of screening.^120,^ ^121^ Study and population characteristics for the SCOOP trial are detailed in the KQ 1 section.

Anxiety was assessed using the Strait-Trait Anxiety Inventory-Short Form at repeated intervals over the 5-year study period.^120,^ ^121^ Authors observed no difference in anxiety between screening participants (both those deemed low risk and those deemed high risk who were invited to DXA testing) and the control group participants (p=0.515) (Appendix D Table 8).

The included SR for KQ 1 conducted to inform the CTFPHC recommendation on screening for primary prevention of fractures reported on overdiagnosis.^131,^ ^132^ Based on the data reported in the SCOOP and SOS RCTs, the SR authors estimated the proportion of participants overdiagnosed ranged from 11.8 to 24.1 percent.^131,^ ^132^ The method for calculating overdiagnosis in context of being labeled as “high risk” was described in detail in a companion publication and was characterized as evolving by review authors.^314^

### KQ 4 What Is the Effectiveness of Pharmacotherapy With Selected FDA-Approved Medications on Fracture Incidence and Fracture-Related Morbidity and Mortality?

We identified 21 RCTs (reported in 27 articles^251–277^) comparing bisphosphonates (alendronate, ibandronate, risedronate, or zoledronic acid) with placebo and six RCTs (reported in 9 articles^278–286^) comparing denosumab with placebo that reported fracture, mortality, or both. Two RCTs of alendronate,^276,^ ^277^ two RCTs of zoledronic acid,^269–274^ one RCT of ibandronate,^275^ and two RCTs of denosumab^278,^ ^286^ were new to this update. Three RCTs were good quality;^251,^ ^254,^ ^255,^ ^269–271^ the rest were fair quality. Detailed study quality ratings are in Appendix D Tables 53–57. A summary of study characteristics is in Table 2 with additional narrative description in Appendix E.4. One RCT of zoledronic acid^251^ and one study of denosumab^278^ were conducted exclusively in men; three studies (all evaluating bisphosphonates) included men, but the proportions comprised between 1 and 8 percent of the enrolled population.^295,^ ^298,^ ^299^ The rest were conducted exclusively among postmenopausal women. T-score criteria for enrollment across studies varied, but only six required T-scores in the osteoporotic range. The rest enrolled participants with T-scores spanning the range considered low bone mass and osteoporosis or low bone mass only. Detailed study characteristics are in Appendix D Table 6, and detailed study findings are in Appendix D Table 16.

Table 2 Randomized, Placebo-Controlled Trials of Treatment for Osteoporosis (KQs 4 and 5)

Author, Year | Study Quality | Total N | % Female | Mean Age (SD) | Race/Ethnicity | % With Prior Fracture^*^ | T-Score Inclusion Criteria | Dose and Duration | Key Question
Alendronate
Adachi et al, 2009^296^ | Fair | 438 | 100% | 65.5 (NR) | 89% White, 8% Hispanic, 3% Asian, 1% Black | 6.8% | <−2.0 | 10 mg per day; 3 months | KQ 5
Ascott-Evans et al, 2003^252^ | Fair | 144 | 100% | 57.3 (6.6) | 91.7% White, 8.3% other | 0% | LS <−1.5 and >−3.5 | 10 mg per day; 1 year | KQ 4, KQ 5
Bell et al, 2002^276^ | Fair | 65 | 100% | 66 (NR) | 100% African American | NR | LS <−1.75 | 10 mg per day; 2 years | KQ 4, KQ 5
Bone et al, 1997^277^ | Fair | 359 | 100% | 71 (NR) | 97% White | 34% to 42% | ≤−2.0 | 1, 2.5, or 5 mg per day; 2 years | KQ 4, KQ 5
Chesnut et al, 1995^253^ | Fair | 188 | 100% | 62.9 (6.1) | 97.9% White, 2.1% Asian | 0% | NR; mean T-score −1.1 | Various;^†^ 2 years | KQ 4, KQ 5
Cryer et al, 2005^297^ | Fair | 454 | 100% | 65 (10) | 91% White, 2% Black, 1% Asian, 5% Hispanic, 1% Native American, 1% other | NR | Any site <−2.0 and >−3.5 | 70 mg weekly; 6 months | KQ 5
Cummings et al, 1998^254^; Bauer et al, 2000^289^; Cummings et al, 2007^290^; Quandt et al, 2005^255^; FIT | Good | 4,432^ǂ^ | 100% | 67.6 (6.2) | 97% White | 0%^ǂ^ | FN <−1.6 | 5 mg per day for 2 years, then 10 mg per day for 1 year; 3 years | KQ 4, KQ 5
Devogelaer et al, 1996^302^ | Fair | 516 | 100% | 62 (NR) | NR | NR | LS ≤−2.5 | 5, 10, 20^§^ mg per day; 3 years | KQ 5
Eisman et al, 2004^298^ | Good | 449 | 93%-96% | 63.6 (NR) | 65.7% White, 18% Asian, 12% Hispanic, 5% other | NR | NR; mean T-score NR | 70 mg weekly; 3 months | KQ 5
Greenspan et al, 2002^299^ | Fair | 450 | 92% | 67 (NR) | 96% White | NR | NR; mean T-score NR | 70 mg weekly; 3 months | KQ 5
Greenspan et al, 2003^300^ | Good | 186 | 100% | 71.5 (NR) | NR | 0% | NR; mean T-score −1.7 | 10 mg per day; 3 years | KQ 5
Hosking et al, 2003^267^ | Fair | 549^ǁ^ | 100% | 69 (NR) | 99.5% Caucasian | 48.5% | LS or TH <−2.5 or both <−2.0 | 70 mg weekly; 1 year | KQ 4, KQ 5
Johnell et al, 2002^294^ | Fair | 331 | 100% | 63.6 (NR) | 95% White | NR | FN <−2.0 | 10 mg per day; 1 year | KQ 5
Liberman et al, 1995^256^ | Fair | 994 | 100% | 64 (NR) | 87.4% White, 0.4% Black, 12.2% other | 21% | LS <−2.5 | 5 or 10 mg per day; 3 years; 20 mg per day for 2 years followed by 5 mg/day for 1 year | KQ 4, KQ 5
Pols et al, 1999^259^ | Fair | 1,908 | 100% | 62.8 (7.5) | 94% White | NR | NR; mean T-score | 10 mg per day; 1 year | KQ 4, KQ 5
Tucci et al, 1996^268^ | Fair | 478 | 100% | 64 (NR) | 91% White, 8% Asian | NR | LS <−2.5 | 5 mg, 10 mg, or 20 mg per day for 2 years followed by 5 mg per day; 3 years | KQ 4, KQ 5
Ibandronate
Chapurlat et al, 2013^288^ | Fair | 148 | 100% | 62.7 (5.0) | NR | NR | LS or TH <−1.0 and >−2.5 | 150 mg per month; 2 years | KQ 5
McClung et al, 2009^275^ | Fair | 160 | 100% | 53 (NR) | NR | 0% | LS <−1.0 and >−2.5 with TH or FN >−2.5 | 150 mg per month; 1 year | KQ 4, KQ 5
McClung et al, 2004^291^ | Fair | 653 | 100% | 58.2 (8.6) | NR | 0% | LS <−1.0 and >−2.5 | 0.5 mg, 1.0 mg, or 2.5 mg per day; 2 years | KQ 5
Ravn et al, 1996^264^ | Fair | 180 | 100% | 65 (NR) | 100% White | 0% | NR; mean T-score −1.7 | 0.25 mg, 0.50 mg, 1.0 mg, 2.5 mg, or 5.0 mg per day; 1 year | KQ 4, KQ 5
Reginster et al, 2005^266^ | Fair | 144 | 100% | 65.7 (NR) | NR | NR | NR; mean T-score −0.3 to −1.9 | Various;^¶^ 3 months | KQ 4, KQ 5
Riis et al, 2001^265^ | Fair | 240 | 100% | 66.8 (4.9) | NR | NR | LS or FN <−2.5 | 2.5 mg per day or intermittent cyclic dose; 2 years | KQ 4, KQ 5
Tanko et al, 2003^292^ | Fair | 630 | 100% | 55 (NR) | NR | 0% | LS ≥−2.5 | 5 mg, 10 mg, or 20 mg weekly; 2 years | KQ 5
Thiebaud et al, 1997^293^ | Fair | 126 | 100% | 64 (NR) | NR | 0% | LS <−2.5 | 0.25, 0.5 mg, 1.0, or 2.0 mg every 3 months; 1 year | KQ 5
Risedronate
Hosking et al, 2003^267^ | Fair | 549^ǁ^ | 100% | 69 (NR) | 99.5% Caucasian | 48.5% | LS or TH <−2.5 or both <−2.0 | 5 mg daily; 3 months | KQ 4, KQ 5
McClung et al, 2001^257^ | Fair | 9,331 | 100% | NR, all age 70 or older | 98% White | 39% to 44% | FN <−4 or <−3 with risk factor for hip fracture | 2.5 or 5 mg per day; years | KQ 4, KQ 5
Mortensen et al, 1998^258^ | Fair | 111 | 100% | 52.1 (3.9) | 100% White | 0% | Z-score >−2.0; mean T-score −1.1 | 5 mg cyclic or 5 mg per day; 2 years | KQ 4, KQ 5
Shiraki et al, 2003^295^ | Fair | 211 | 99% | 60.3 (NR) | 100% Japanese | Mean prevalent vertebral fractures: 0.3 (SD 0.8) | LS <−2.5 without vertebral fracture; <−1.5 with vertebral fracture | 1 mg, 2.5 mg, or 5 mg per day; 8 months | KQ 5
Valimaki et al, 2007^261^ | Fair | 170 | 100% | 65.9 (6.8) | 100% White | NR | LS >−2.5 and <−1 and proximal femur ≤−1 | 5 mg per day; 2 years | KQ 4, KQ 5
Zoledronic Acid
Boonen et al, 2012^251^ | Good | 1,199 | 0% | Median 66 | 94% White, 1% Black, 1% Asian, 0.5% other | 32% | TH or FN ≤−1.5 | 5 mg every year; 2 years | KQ 4, KQ 5
Grey et al, 2010^262^; Grey et al, 2009^263^ | Fair | 50 | 100% | 62 (8) | NR | 42% | LS or TH <−1 and >−2 | 5 mg; single dose with 3 year followup | KQ 5
Grey et al, 2012^272^; Grey et al, 2014^273^; Grey et al, 2017^274^ | Fair | 180 | 100% | 66 (9) | NR | 14% to 21% | LS or TH <−1 and >−2.5 | 1 mg, 2.5 mg, 5 mg; single dose | KQ 4, KQ 5
McClung et al, 2009^287^ | Fair | 581 | 100% | 59.6 to 60.5 | NR | 0% | LS −1.0 and −2.5 and FN >−2.5 | 5 mg single dose or 5 mg yearly for 2 years; 2 years | KQ 5
Reid et al, 2002^260^ | Fair | 351 | 100% | 65 (7) | 95% White | 0% | LS <−2.0 | Various;^#^ 1 year | KQ 4, KQ 5
Reid et al, 2018^269^; Reid et al, 2019^270^; Reid et al, 2020^301^; Reid et al, 2021^271^ | Good | 2,000 | 100% | 71 (5.1) | 95% European, 0.02% Maori, 0.01% Pacific Islander, 0.02% East Asian, 0.005% Indian, 0.002% other | 23.7% | TH or FN −1.0 to −2.5 | 5 mg every 18 months; 6 years | KQ 4, KQ 5
Denosumab
Bone et al, 2008^285^ | Fair | 332 | 100% | 59.4 (7.5) | NR | 0% | LS or TH between −1 and −2.5 | 60 mg every 6 months; 3 years | KQ 4, KQ 5
Cummings et al, 2009^280^; Watts et al, 2012^303^; Simon et al, 2013^281^; McCloskey et al, 2012^282^; Palacios et al, 2015^283^; FREEDOM | Fair | 7,808 | 100% | 72.3 (5.2) | NR | 50% | LS or TH <−2.5 but >−4.0 | 60 mg every 6 months; 3 years | KQ 4, KQ 5
Koh et al, 2016^286^ | Fair | 135 | 100% | 67.0 (4.9) | NR | 23% to 30% | TH or LS <−2.5 and ≥−4.0 | 60 mg; single dose with 6 month followup | KQ 4, KQ 5
Lewiecki et al, 2007^284^; McClung et al, 2006^304^ | Fair | 365 | 100% | 62.5 (8.1) | 86.2% White, 9.5% Hispanic, 2.9% Black, 1.5% other | 0% | LS −1.8 to −4.0 or FN −1.8 to −3.5 | Various;^**^ 2 years | KQ 4, KQ 5
Nakamura et al, 2012^279^ | Fair | 226 | 100% | 65.1 (6.8) | 100% Japanese | 34% | LS −2.5 to −4.0 or FN or TH −2.5 to −3.5 | Various;^††^ 1 year | KQ 4, KQ 5
Orwoll et al, 2012^278^; ADAMO | Fair | 242 | 0% | 65.0 (9.8) | 94.2% White | 39.3% | LS or FN −2.0 to −3.5;^ǂǂ^ or LS or FN −1.0 to −3.5^ǂǂ^ with prior MOF | 60 mg every 6 months; 2 years | KQ 4, KQ 5

* Studies define this in varying ways: any fracture, fracture after age 50, fragility fracture, and vertebral fracture only.

† 5 mg/day or 10 mg/day or 40 mg/day for 3 months, then 2.5 mg/day for 21 months; 20 mg/day for 1 year, then placebo for 1 year; 40 mg/day for 1 year, then placebo for 1 year.

ǂ Only the portion of the enrolled population without prior vertebral fracture was used for this review.

§ Dosage was 20 mg for first 2 years and lowered to 5 mg in the final year.

ǁ Includes the alendronate, risedronate, and placebo arms.

¶ 50 mg per month; 50 mg for the first month, then 100 mg for months 2–3; 100 mg per month; 150 mg per month.

# 0.25 mg every 3 months, 0.5 mg every 3 months, 1 mg every 3 months, 4 mg every 1 year, 2 mg every 6 months.

** 6 mg, 14 mg, or 30 mg every 3 months; 14 mg, 60 mg, 100 mg, or 210 mg every 6 months.

†† 14 mg, 60 mg, or 100 mg every 6 months.

ǂǂ T-scores based on male reference range.

Abbreviations: ADAMO= Study to Compare the Efficacy and Safety of DenosumAb Versus Placebo in Males With Osteoporosis; FIT=Fracture Intervention Trial; FN=femoral neck; FREEDOM=Fracture Reduction Evaluation of Denosumab in Osteoporosis Every 6 Months KQ=key question; LS=lumbar spine; MOF=major osteoporotic fracture; N/n= number; NR=not reported; SD=standard deviation; TH=total hip.

#### Bisphosphonates: Findings

The findings from included trials evaluating the benefits of bisphosphonates compared with placebo for the outcomes of vertebral fractures, nonvertebral fractures, hip fractures, and mortality are summarized in this section and depicted in Figure 7. Findings were consistent for each outcome when alternative pooling methods or alternative doses other than FDA-approved doses were used (Appendix E.4 Table 1). One study of alendronate,^276^ one study of zoledronic acid,^262^ and one study of ibandronate^275^ reported fractures other than vertebral, nonvertebral, and hip; these findings are reported in Appendix D Table 16.^262^

Figure 7 Results of Randomized, Placebo-Controlled Trials of Treatment for Osteoporosis, Fractures, Mortality, and Harms (KQs 4 and 5)

▲=Bisphosphonate; ■=Denosumab

* Although multiple studies reported, the evidence base is dominated by one large (N=7,808) study.

^†^ We conducted a sensitivity analysis limiting to studies reporting clinical vertebral fractures (4 studies) and the pooled RR was 0.44 (95% CI, 0.24 to 0.79; 2,373 participants, I^2^=0%).

Abbreviations: AE=adverse event; ARD=absolute risk difference; CI=confidence interval; GI=gastrointestinal; KQ=key question; N/n=number; RR=relative risk.

This figure depicts pooled estimates of risk ratios for benefits and harms of treatment with bisphosphonates and denosumab for osteoporosis. For treatment with bisphosphonates, the pooled risk ratio for hip fracture was 0.67 with a 95 percent confidence interval of 0.45 to 1.00. This is based on 6 studies and represents an absolute risk difference of 3 fewer per 1,000 persons with a confidence interval of 5 fewer to 0 fewer. For treatment with denosumab, the pooled risk ratio for hip fracture was 0.61 with a 95 percent confidence interval of 0.38 to 0.99. This is based on 2 studies and represents an absolute risk difference of 4 fewer per 1,000 persons with a confidence interval of 7 fewer to 0 fewer. For treatment with bisphosphonates, the pooled risk ratio for vertebral fracture was 0.51 with a 95 percent confidence interval of 0.39 to 0.66. This is based on 10 studies and represents an absolute risk difference of 18 fewer per 1,000 persons with a confidence interval of 23 fewer to 13 fewer. For treatment with denosumab, the pooled risk ratio for vertebral fracture was 0.33 with a 95 percent confidence interval of 0.26 to 0.41. This is based on 3 studies and represents an absolute risk difference of 44 fewer per 1,000 persons with a confidence interval of 49 fewer to 39 fewer. For treatment with bisphosphonates, the pooled risk ratio for nonvertebral fracture was 0.81 with a 95 percent confidence interval of 0.74 to 0.88. This is based on 13 studies and represents an absolute risk difference of 28 fewer per 1,000 persons with a confidence interval of 38 fewer to 18 fewer. For treatment with denosumab, the pooled risk ratio for nonvertebral fracture was 0.80 with a 95 percent confidence interval of 0.68 to 0.94. This is based on 3 studies and represents an absolute risk difference of 14 fewer per 1,000 persons with a confidence interval of 23 fewer to 4 fewer. For treatment with bisphosphonates, the pooled risk ratio for mortality was 0.71 with a 95 percent confidence interval of 0.49 to 1.05. This is based on 6 studies and represents an absolute risk difference of 10 fewer per 1,000 persons with a confidence interval of 17 fewer to 2 more. For treatment with denosumab, the pooled risk ratio for mortality was 0.79 with a 95 percent confidence interval of 0.58 to 1.07. This is based on 5 studies and represents an absolute risk difference of 4 fewer per 1,000 persons with a confidence interval of 9 fewer to 1 more. For treatment with bisphosphonates, the pooled risk ratio for discontinuations due to adverse events was 1.00 with a 95 percent confidence interval of 0.92 to 1.08. This is based on 24 studies and represents an absolute risk difference of 0 fewer per 1,000 persons with a confidence interval of 9 fewer to 9 more. For treatment with denosumab, the pooled risk ratio for discontinuations due to adverse events was 1.16 with a 95 percent confidence interval of 0.87 to 1.54. This is based on 5 studies and represents an absolute risk difference of 3 more per 1,000 persons with a confidence interval of 3 fewer to 11 more. For treatment with bisphosphonates, the pooled risk ratio for serious adverse events was 0.97 with a 95 percent confidence interval of 0.0.91 to 1.04. This is based on 21 studies and represents an absolute risk difference of 6 fewer per 1,000 persons with a confidence interval of 18 fewer to 8 more. For treatment with denosumab, the pooled risk ratio for serious adverse events was 1.04 with a 95 percent confidence interval of 0.97 to 1.12. This is based on 6 studies and represents an absolute risk difference of 9 more per 1,000 persons with a confidence interval of 7 fewer to 28 more. For treatment with bisphosphonates, the pooled risk ratio for upper gastrointestinal adverse events was 1.02 with a 95 percent confidence interval of 0.97 to 1.06. This is based on 26 studies and represents an absolute risk difference of 5 fewer per 1,000 persons with a confidence interval of 8 fewer to 16 more. For treatment with denosumab, the pooled risk ratio for gastrointestinal adverse events was 2.18 with a 95 percent confidence interval of 0.74 to 6.46. This is based on 4 studies and represents an absolute risk difference of 14 more per 1,000 persons with a confidence interval of 3 fewer to 66 more.

##### Vertebral Fracture

The impact of bisphosphonates on vertebral fracture outcomes reported in 10 trials is summarized in Appendix E.4 Figure 1.^251–254,^ ^256,^ ^258,^ ^260,^ ^261,^ ^269,^ ^277^ These studies reported a mix of clinical vertebral fractures, radiographic vertebral fractures, or both. Five of these trials compared alendronate with placebo,^252–254,^ ^256,^ ^277^ two compared risedronate with placebo,^258,^ ^261^ and three compared zoledronic acid with placebo.^251,^ ^260,^ ^269^ The pooled RR for FDA-approved dosages was 0.51 (95% CI, 0.39 to 0.66; 10 RCTs; 9,015 participants; I^2^=0%). This corresponds to an ARD of 18 fewer vertebral fractures per 1,000 participants treated (95% CI, from 23 fewer to 13 fewer). One study comparing alendronate with placebo showed a statistically significant reduction in vertebral fractures (1.9% vs. 3.5%; RR, 0.55 [95% CI, 0.38 to 0.80]),^254^ and two studies comparing zoledronic acid with placebo showed a statistically significant reduction in vertebral fractures (1.5% vs. 4.6%; RR, 0.33 [95% CI, 0.16 to 0.70];^251^ 2.3% vs. 4.9%; RR, 0.47 [95% CI, 0.29 to 0.76]).^269^ Seven trials were not powered to evaluate vertebral fractures and individually found no statistically significant differences in reported vertebral fracture outcomes.^252,^ ^253,^ ^256,^ ^258,^ ^260,^ ^261,^ ^277^ Five studies reported zero vertebral fracture events in at least one study arm.^252,^ ^253,^ ^258,^ ^260,^ ^261^

We conducted a sensitivity analysis based on type of vertebral fracture (Appendix E.4 Table 2). Four studies reported clinical vertebral fractures,^252,^ ^253,^ ^261,^ ^269^ three of which reported zero events in both study arms. The pooled RR for clinical vertebral fractures comparing treatment with placebo was 0.44 (95% CI, 0.24 to 0.79; 4 RCTs; 2,373 participants; I^2^=0%). Six studies reported radiographic vertebral fractures,^251,^ ^254,^ ^256,^ ^258,^ ^260,^ ^269,^ ^277^ two of which reported zero events in at least one study arm. The pooled RR for radiographic vertebral fractures comparing treatment with placebo was 0.51 (95% CI, 0.39 to 0.66; 7 RCTs; 8,642 participants; I^2^=0%).

##### Nonvertebral Fracture

The impact of bisphosphonates on nonvertebral fracture outcomes reported in 13 trials is summarized in Appendix E.4 Figure 2.^251,^ ^252,^ ^254,^ ^256–261,^ ^268,^ ^269,^ ^272,^ ^277^ Six of these studies compared alendronate with placebo,^252,^ ^254,^ ^256,^ ^259,^ ^268,^ ^277^ three compared risedronate with placebo,^257,^ ^258,^ ^261^ and four compared zoledronic acid with placebo.^251,^ ^260,^ ^269,^ ^272^ The pooled RR was 0.81 (95% CI, 0.74 to 0.88; 13 RCTs; 20,929 participants; I^2^=0%). This corresponds to an ARD of 28 fewer nonvertebral fractures per 1,000 participants treated (95% CI, from 38 fewer to 18 fewer). Two studies reported zero events in at least one study arm.^252,^ ^258^ Eleven trials were not powered to evaluate nonvertebral fractures. Three trials individually reported a statistically significant benefit of active medication compared with placebo.^257,^ ^259,^ ^269^ These studies included one evaluating alendronate (2.0% vs. 3.9%; RR, 0.52 [95% CI, 0.30 to 0.89]),^259^ one evaluating risedronate (9.4% vs. 11.2%; RR, 0.84 [95% CI, 0.74 to 0.95]),^257^ and one evaluating zoledronic acid (10.1% vs. 14.8%; RR, 0.68 [95% CI, 0.54 to 0.87]).^269^

##### Hip Fractures

The impact of bisphosphonates on hip fracture outcomes in six trials is summarized in Appendix E.4 Figure 3.^254,^ ^256–259,^ ^269^ Three of these studies compared alendronate with placebo,^254,^ ^256,^ ^259^ two compared risedronate with placebo,^257,^ ^258^ and one compared zoledronic acid with placebo.^269^ We identified no trials of ibandronate that reported hip fracture outcomes. The pooled RR was 0.67 (95% CI, 0.45 to 1.00; 6 RCTs; 12,055 participants; I^2^=0%). This corresponds to an ARD of 3 fewer hip fractures per 1,000 participants treated (95% CI, from 5 fewer to 0 fewer). One study reported zero events in both study arms.^258^ None of the trials were powered to look at hip fractures as benefits, and none found statistically significant differences in reported hip fracture outcomes.

##### Mortality

The impact of bisphosphonates on mortality outcomes reported in six trials is summarized in Appendix E.4 Figure 4.^251,^ ^264–266,^ ^269,^ ^275^ Four of these studies compared ibandronate with placebo^264–266,^ ^275^ and two compared zoledronic acid with placebo.^251,^ ^269^ The pooled RR was 0.71 (95% CI, 0.49 to 1.05; 6 RCTs; 3,714 participants, I^2^=0%). This corresponds to an ARD of 10 fewer deaths per 1,000 participants (95% CI, from 17 fewer to 2 more). Three studies reported zero events in at least one study arm.^264,^ ^266,^ ^275^ None of the trials were powered to look at mortality as benefits, and none found statistically significant differences in mortality outcomes.

#### Bisphosphonates: Findings for Specific Populations of Interest

Only one trial of a bisphosphonate agent was conducted among men.^251^ This trial reported on the effectiveness of zoledronic acid in 1,199 men with mean FN T-scores of −2.2. Men were eligible to participate if they had a T-score of −1.5 or less (based on the device-specific reference values for men). The authors found a reduced risk of morphometric vertebral fractures in the treatment arm (1.5% vs. 4.6%; RR, 0.33 [95% CI, 0.16 to 0.70]) but no significant difference in nonvertebral fractures (0.9% vs. 1.3%; RR 0.65 [95% CI, 0.21 to 1.97]).^251^

One study new to this update reported similar effectiveness of zoledronic acid compared with placebo among persons stratified by baseline BMD as well as when stratified by baseline fracture risk as measured by FRAX (hip and MOF) and the Garvan Fracture Risk Calculator.^269^

The study population of one large multicenter trial investigated the impact of risedronate on hip fractures in a study population with 41 percent of participants having a prior vertebral fracture at baseline. When including all participants in the study population, the pooled RR for bisphosphonates was 0.72 (95% CI, 0.58 to 0.91; 18,740 participants; I^2^=0%). When including only participants ages 70 to 79 years without prior vertebral fracture, the pooled RR for bisphosphonates was 0.67 (95% CI, 0.45 to 1.00; 12,057 participants).^257^

#### Denosumab: Findings

The findings from included trials studying the benefits of denosumab compared with placebo are summarized in this section and include outcomes of vertebral fractures, nonvertebral fractures, hip fractures, and mortality (Figure 7). One trial was conducted exclusively in men;^278^ the rest were conducted exclusively in postmenopausal women. Findings were consistent for each outcome when alternative pooling methods or alternative doses other than FDA-approved doses were used (Appendix E.4 Table 3).

##### Fractures

The impact of denosumab on fracture outcomes reported in five trials^278–280,^ ^284,^ ^285^ are summarized in Appendix E.4 Figure 5. Four studies^278,^ ^279,^ ^284,^ ^285^ were not powered to look at fractures as outcomes, and events were rare in both study arms of these trials (range, 0 to 7 fracture events) such that the pooled RRs were dominated by results of the large FREEDOM trial.^278,^ ^279,^ ^284,^ ^285^ Authors of the FREEDOM trial (N=7,808) reported a statistically significant difference in incident radiographic vertebral fractures (2.3% vs. 7.2%; RR, 0.32 [95% CI, 0.26 to 0.41]), incident clinical vertebral fractures (0.8% vs. 2.5%; RR 0.31 [95% CI, 0.20 to 0.47]), nonvertebral fractures (6.1% vs. 7.5%; RR, 0.80 [95% CI, 0.67 to 0.95]), and hip fractures (0.7% vs. 1.1%; RR, 0.60 [95% CI, 0.37 to 0.97]).^280,^ ^303^ These correspond to an ARD of 48 fewer per 1,000 participants (95% CI, from 52 fewer to 42 fewer) for radiographic vertebral fractures, 17 fewer per 1,000 participants (95% CI, from 20 fewer to 13 fewer), 15 fewer per 1,000 participants (95% CI, from 24 fewer to 4 fewer) for nonvertebral fractures, and 4 fewer per 1,000 participants (95% CI, from 7 fewer to 0 fewer) for hip fractures. The FREEDOM study also reported significant reductions in multiple new vertebral fractures compared with placebo (see Appendix D Table 16).^280,^ ^303^

We conducted a sensitivity analysis based on type of vertebral fracture (Appendix E.4 Table 4). Two studies reported clinical vertebral fractures,^278,^ ^280^ one of which reported zero events in the intervention arm. The pooled RR for clinical vertebral fractures was 0.31 (95% CI, 0.21 to 0.47; 7,635 participants; I^2^=0%). One study evaluated radiographic vertebral fractures^285^ but only reported one event in the placebo arm.

##### Mortality

Five trials reported mortality outcomes, but none were powered for this outcome.^280,^ ^284–286^ In the largest of the trials (FREEDOM, N=7,762 for this outcome) mortality was 1.8 percent in the denosumab arm compared with 2.3 percent in the placebo arm (calculated RR, 0.78 [95% CI, 0.57 to 1.06]).^280^ Deaths were rare in the other four trials; one trial^285^ reported zero deaths in the denosumab and placebo arms, and three trials^278,^ ^284,^ ^286^ reported one death each in the denosumab arms. The pooled RR was 0.79 (95% CI, 0.58 to 1.07; 5 RCTs; 8,828 participants; I^2^=0%) (Appendix E.4 Figure 6). This corresponds to an ARD of 4 fewer deaths per 1,000 participants treated (95% CI, from 9 fewer to 1 more).

#### Denosumab: Findings for Specific Populations of Interest

Authors of the FREEDOM trial reported on a preplanned analysis evaluating the effectiveness of denosumab as a function of baseline fracture risk.^280,^ ^282^ A linear model demonstrated no significant interaction between treatment effect and baseline fracture risk (p=0.72). However, analyses using a cubic spline function suggested a relationship (p<0.001). Compared with placebo, there was increasing efficacy of denosumab as baseline fracture risk increased between 5 percent and 18 percent with a leveling off (to slight decrease) in efficacy at baseline risks higher than 18 percent.

### KQ 5 What Are the Harms Associated With Selected FDA-Approved Medications?

We identified 40 RCTs (reported in 48 articles^251–254,^ ^256–269,^ ^272–280,^ ^284–304^) comparing bisphosphonates (alendronate, ibandronate, risedronate, or zoledronic acid) or denosumab with placebo that assessed harm outcomes. In addition, we identified three controlled cohort studies evaluating bisphosphonates compared with placebo.^305–307^ We evaluated five RCTs as good quality;^251,^ ^254,^ ^269,^ ^289,^ ^290,^ ^298,^ ^300,^ ^301^ the rest of the RCTs and the controlled cohort studies were fair quality.

#### Bisphosphonates: Overview of the Evidence From RCTs

Thirty-four RCTs (published in 40 articles^251–254,^ ^256–269,^ ^272–277,^ ^287–302^) reported on harms from bisphosphonates; four were new to this update.^275–277,^ ^302^ A summary of RCT characteristics is in Table 2 with additional narrative description in Appendix E.4. Detailed study characteristics are in Appendix D Table 6, and detailed findings are in Appendix D Table 16.

#### Bisphosphonates: Findings From RCTs

The findings from included trials reporting the harms of bisphosphonates compared with placebo are summarized in this section, including discontinuations due to adverse events, serious adverse events, upper GI adverse events, and other rare harm outcomes (Figure 7). Findings were consistent for each outcome when alternative pooling methods or data from the non-FDA-approved doses were used (Appendix E.4 Table 5).

##### Discontinuations Due to Adverse Events

Twenty-seven RCTs reported discontinuations due to adverse events; however, none were powered for this outcome.^252–254,^ ^256–261,^ ^264,^ ^266–268,^ ^272,^ ^275–277,^ ^288,^ ^291–294,^ ^296–299,^ ^302^ Three RCTs reported only data for the intervention arm and thus could not be included in the pooled estimate.^253,^ ^292,^ ^293^ ^272^ The pooled RR was 1.00 (95% CI, 0.92 to 1.08; 25 RCT comparisons; 18,617 participants; I^2^=0%; Appendix E.4 Figure 7). This corresponds to an ARD of 0 fewer discontinuations for adverse event per 1,000 participants treated (95% CI, from 9 fewer to 9 more). The two largest RCTs contributing to this pooled estimate were the Fracture Intervention Trial (FIT) study (N=4,432) comparing alendronate with placebo^254^ and an international multicenter study comparing risedronate with placebo (N=9,331).^257^ In FIT, discontinuations due to adverse events were 10.0 percent in the active drug group compared with 10.2 percent in the placebo group (RR, 0.98 [95% CI, 0.82 to 1.16]).^254,^ ^289^ In the risedronate trial, discontinuations due to adverse events were 17.7 percent in the active drug group compared with 18.0 percent in the placebo group (RR, 0.98 [95% CI, 0.89 to 1.10]).^257^ One trial reported zero discontinuations due to adverse events in at least one study arm.^272^

##### Serious Adverse Events

Twenty-two RCTs reported serious adverse events; however, none were powered for this outcome.^251,^ ^257,^ ^259–261,^ ^264,^ ^266–268,^ ^272,^ ^275,^ ^276,^ ^287,^ ^288,^ ^291–293,^ ^295–297,^ ^299,^ ^302^ Two RCTs could not be included in the pooled estimate because authors did not report data for the control arms.^292,^ ^293^ The pooled RR was 0.97 (95% CI, 0.91 to 1.04; 21 RCT comparisons; 13,878 participants; I^2^=0%; Appendix E.4 Figure 8). This corresponds to an ARD of 6 fewer serious adverse events per 1,000 participants treated (95% CI, from 18 fewer to 8 more). In the largest study contributing to this pooled estimate, an international multicenter RCT (N=9,331) comparing risedronate with placebo, serious adverse events occurred in 30.4 percent of the risedronate group and 31.0 percent of the placebo group.^257^ Three RCTs reported zero events in both the placebo and active drug study arms.^266,^ ^272,^ ^295^ The absolute incidence reported across this drug class was 0.7 to 25.3 percent across study arms, suggesting large variation in rigor of ascertainment methods across included studies.

##### GI Adverse Events

Twenty-six RCTs (representing 27 comparisons) reported GI adverse events.^252,^ ^256–259,^ ^261,^ ^264,^ ^266–269,^ ^272,^ ^275,^ ^276,^ ^289,^ ^291–300,^ ^302^ None of the RCTs were powered for this outcome, and only one trial reported statistically significant differences in GI adverse events between the placebo and treatment arms.^272^ In this trial, the outcome was described as “gastrointestinal acute phase reactions” reported by patients at 1 week postinfusion, potentially measuring a different outcome from the other RCTs. The pooled RR was 1.02 (95% CI, 0.98 to 1.06; 27 RCT comparisons; 22,280 participants; I^2^=0%; Appendix E.4 Figure 9). This corresponds to an ARD of 5 more GI adverse events per 1,000 participants treated (95% CI, from 5 fewer to 16 more). The two largest RCTs contributing to this pooled estimate were the FIT study (N=4,432)^254^ and the international, multicenter study of risedronate compared with placebo (N=9,331).^257^ In FIT, the incidence of upper GI adverse events was 47.6 percent in the alendronate group and 46.2 percent in the placebo group (calculated RR, 1.03 [95% CI, 0.98 to 1.08]).^254,^ ^289^ In the study of risedronate, the incidence of upper GI adverse events was 21.2 percent in the risedronate group and 21.8 percent in the placebo group (calculated RR, 0.91 [95% CI, 0.88 to 1.07]).^257^

##### Cardiovascular Outcomes

Eight RCTs reported on one or more cardiovascular outcomes.^251,^ ^254,^ ^262,^ ^269,^ ^272,^ ^287,^ ^295,^ ^300^ Six RCTs reported on the incidence of atrial fibrillation.^251,^ ^254,^ ^262,^ ^269,^ ^272,^ ^287^ RR estimates ranged from 0.98 to 1.51; however, none were statistically significant. Furthermore, three of these RCTs reported zero events in both study arms.^262,^ ^272,^ ^287^ Three RCTs reported on incidence of myocardial infarction.^251,^ ^269,^ ^300^ RR estimates ranged from 0.61 to 4.68 and were very imprecise because of small sample sizes and rare events. The estimate for this harm was statistically significant in the study comparing zoledronic acid with placebo (RR 4.68 [95% CI, 1.02 to 21.5]) in men but was not statistically significant in the other two RCTs. One trial reported multiple other cardiac outcomes (stroke, transient ischemic attack, cardiac deaths) all of which were nonsignificant and imprecise.^269^

##### Osteonecrosis of the Jaw

Five RCTs, including two new to this update,^269,^ ^272^ reported no cases of osteonecrosis of the jaw.^251,^ ^262,^ ^287^ Additional information about this rare outcome from studies not eligible for inclusion is addressed as Contextual Question 6 in Appendix F.

##### Atypical Fractures of the Femur

We did not identify any RCTs that reported on the rare outcome of atypical femur fracture. Additional information about this rare outcome from studies not eligible for inclusion is addressed as Contextual Question 6 in Appendix F.3.

#### Bisphosphonates: Evidence From Controlled Cohort Studies

Three fair-quality cohort studies set in Denmark,^305^ Sweden and Denmark,^306^ and South Korea^307^ addressed potential harms of bisphosphonate use. Two studies were limited to new users;^305,^ ^307^ the third study provided sensitivity analyses for a treatment-naïve cohort.^306^ The studies predominantly (86%^306^ and 91%^307^) or solely comprised women.^305^ Two studies did not report the prevalence of fractures among participants at the start of the study;^306,^ ^307^ one study reported differences in prevalence of fractures at baseline (12% for alendronate vs. 4% for nonusers).^305^ One study was limited to zoledronic acid,^306^ a second to alendronate,^305^ and the third included all bisphosphonates (which may have included non-FDA-approved bisphosphonates).^307^ Detailed study characteristics are in Appendix D Table 7 and detailed findings are in Appendix D Table 17. Study quality ratings are in Appendix D Tables 58–65.

##### GI Cancers

One fair-quality controlled cohort study set in Denmark^305^ reported on the incidence of GI cancers, specifically colon cancer^305^ among women newly exposed to alendronate when compared with matched nonuser controls over 5 years of followup. The study reported a lower risk of developing colon cancer in new alendronate users when compared with matched nonusers of alendronate (aHR, 0.69 [95% CI, 0.60 to 0.79]).^305^

##### Cardiovascular Outcomes

One fair-quality controlled cohort study set in Sweden and Denmark^306^ reported on cardiovascular outcomes. A propensity-score matched cohort of treatment-naïve users of zoledronic acid compared with nonusers in Sweden and Denmark reported no statistically significant differences in atrial fibrillation (aHR, 1.18 [95% CI, 0.99 to 1.40]), myocardial infarction (aHR, 0.92 [95% CI, 0.64 to 1.31]), and cardiovascular mortality (aHR, 0.97 [95% CI, 0.81 to 1.15]) but did find a statistically significant increased risk for heart failure (aHR, 1.32 [95% CI, 1.08 to 1.61]). This study did not control for known confounders of heart failure such as BMI, smoking and alcohol exposure, hypertension, and metabolic syndrome. It is possible that the zoledronic acid users may have had a higher inherent risk of heart failure.^306^

##### Atypical Femur Fractures

Two fair-quality controlled cohort studies set in Sweden and Denmark^306^ and South Korea^307^ consistently reported increased risk of atypical femur fractures with bisphosphonate exposure. The propensity-score matched cohort of new users of zoledronic acid compared with nonusers in Sweden and Denmark reported an increased risk of atypical femur fractures (aHR, 2.46 [95% CI, 1.17 to 5.15]). However, this study could not control for known confounders of fracture such as baseline levels of calcium and vitamin D, bone density, BMI, smoking and alcohol exposure, hypertension, and metabolic syndrome and could not rule out that zoledronic acid users may have higher inherent risks of frailty. The South Korean study of new bisphosphonate users reported an increased risk of atypical femur fractures with bisphosphonate use (aHR, 1.53 [95% CI, 1.36 to 1.73]) over a mean of 1 year followup when compared with matched bisphosphonate nonuser control participants.^307^ The study did not adjust for confounders other than age, sex, systemic use of glucocorticoids, and comorbidity and may have included drugs not approved by the FDA for osteoporosis.

#### Denosumab: Overview of the Evidence

We identified six fair-quality RCTs (published in 8 articles^278–280,^ ^284–286,^ ^303,^ ^304^) that assessed the harms of denosumab compared with placebo (Figure 7); two were new to this update.^278,^ ^286^ A summary of RCT characteristics is in Table 2 with additional narrative description in Appendix E.4. Detailed study characteristics are in Appendix D Table 6, and detailed findings are in Appendix D Table 16. Findings were consistent for each outcome when alternative pooling methods or data from the non-FDA-approved doses were used (Appendix E.4 Table 6).

#### Denosumab: Findings

##### Discontinuation Due to Adverse Events

Five RCTs^278,^ ^280,^ ^284–286^ reported discontinuations due to adverse events. However, none of the studies were powered for this outcome.^286^ The pooled RR was 1.16 (95% CI, 0.87 to 1.54; 5 RCTs; 8,826 participants; I^2^=0%; Appendix E.4 Figure 10). This corresponds to an ARD of 3 more discontinuations per 1,000 participants treated (95% CI, from 3 fewer to 11 more). This pooled estimate was mostly influenced by the large FREEDOM study (N=7,762) where the incidence of discontinuations due to adverse events was 2.4 percent in the denosumab arm compared with 2.1 percent in the placebo arm (calculated RR, 1.15 [95% CI, 0.85 to 1.54]).^280,^ ^303^

##### Serious Adverse Events

Six RCTs^278–280,^ ^284–286^ reported serious adverse events; however, none of the studies were powered for this outcome. The pooled RR was 1.04 (95% CI, 0.97 to 1.12; 5 RCTs; 8,934 participants; I^2^=0%; Appendix E.4 Figure 11). This corresponds to an ARD of 9 more serious adverse events per 1,000 participants treated (95% CI, from 7 fewer to 28 more). This pooled estimate was mostly influenced by the large FREEDOM study (N=7,762) where the incidence of serious adverse events was 25.8 percent in the denosumab group and 25.1 percent in the placebo group (calculated RR, 1.03 [95% CI, 0.95 to 1.11]).^280,^ ^303^

##### Upper GI Adverse Events

Four RCTs reported upper GI adverse events; however, none of these studies were powered for this outcome.^279,^ ^284–286^ Events were rare across all study groups, including two RCTs with zero events in the placebo arm.^284,^ ^285^ The pooled RR was 2.18 (95% CI, 0.74 to 6.46; 4 RCTs; 932 participants; I^2^=0%; Appendix E.4 Figure 12). This corresponds to an ARD of 14 more GI adverse events per 1,000 participants treated (95% CI, from 3 fewer to 66 more).

##### Cardiovascular Outcomes

Two RCTs reported cardiovascular outcomes.^280,^ ^284,^ ^303^ In the large FREEDOM study, authors reported no significant difference in cardiovascular events (calculated RR, 1.04 [95% CI, 0.85 to 1.27]).^280,^ ^303^ A second trial reported no difference in “cardiac disorders,” but events were rare and estimates imprecise (calculated RR, 0.45 [95% CI, 0.02 to 10.83]).^284^

##### Osteonecrosis of the Jaw

Three RCTs reported on the rare outcome of osteonecrosis of the jaw.^278,^ ^280,^ ^286^ Zero events were reported in all studies, one of which was the large FREEDOM study.^280,^ ^303^ Additional information about this rare outcome from studies not eligible for inclusion is addressed as Contextual Question 6 in Appendix F.3.

##### Atypical Femur Fracture

Two RCTs, new to this update, reported on the rare outcome of atypical femur fracture.^278,^ ^286^ Zero events occurred in both studies. Additional information about this rare outcome from studies not eligible for inclusion, such as the FREEDOM long-term extension study, is addressed as Contextual Question 6 in Appendix F.3.

##### Rebound Vertebral Fractures

No studies that were included for KQ 5 had study designs sufficient to evaluate the outcome of rebound vertebral fractures after denosumab discontinuation. We describe findings for this outcome from studies not eligible for inclusion in this update as Contextual Question 7 in Appendix F.4.

##### Other Adverse Events

Three RCTs reported additional harm outcomes related to skin disease and infection.^280,^ ^284,^ ^285^ In the FREEDOM RCT, a higher incidence of eczema was observed in the denosumab arm compared with placebo (RR, 1.81 [95% CI, 1.34 to 2.44]), and a higher risk for serious skin infection was also observed but was imprecise (RR, 15.0 [95% CI, 1.98 to 113.2]).^280^ There was no difference in the risk of serious infections (RR, 1.19 [95% CI, 0.95 to 1.49]).^280^ Another RCT also reported a higher incidence of rash (calculated RR, 2.82 [95% CI, 1.04 to 7.64]) and serious infection (calculated RR, 8.1 [95% CI, 1.02 to 63.6]).^285^ A third study reported no difference in serious infection (calculated RR, 3.5 [95% CI, 0.07 to 190.8]).^284^