# Chapter 2 Methods

## Key Questions and Analytic Framework

The Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope and key questions (KQs). Figure 1 shows the analytic framework and KQs that guided the review. Five KQs were developed for this review:

1 Does screening for fracture risk or osteoporosis reduce fractures and fracture-related morbidity and mortality in adults?
2a What is the predictive accuracy of risk assessment tools for identifying adults who are at increased risk for hip fractures or major osteoporotic fractures?
2b What is the predictive accuracy of BMD testing with DXA at central skeletal sites for identifying adults who are at increased risk for hip or major osteoporotic fractures?
2c What is the diagnostic accuracy of risk assessment tools for identifying adults with osteoporosis?
2d What is the evidence to determine screening intervals, and how do these intervals vary by baseline or current individual fracture risk?
3 What are the harms of screening for fracture risk or osteoporosis?
4 What is the effectiveness of pharmacotherapy with selected FDA-approved medications on fracture incidence and fracture-related morbidity and mortality?
5 What are the harms associated with selected FDA-approved medications?

Figure 1 Analytic Framework

Abbreviations: DXA=dual-energy X-ray absorptiometry.

This figure is an analytic framework depicting the key questions (KQs) within the context of the populations, interventions, comparisons, outcomes, time frames, and settings (PICOTS) relative to the effectiveness and harms of screening for osteoporosis to prevent fractures. This figure illustrates the screening pathway for the population of interest, adults in primary care without a diagnosis of osteoporosis and no history of fracture. From the population on the left, an overarching arrow representing KQ 1 leads directly to the end of the pathway, represented by a box showing the outcomes investigated in the review (fractures, fracture-related morbidity and mortality, and all-cause mortality). Another arrow representing KQ 2 goes through the middle of the figure from the populations on the left to screening for fracture risk or osteoporosis (KQ 2) with selected tools. This arrow splits in to two paths for populations with either increased risk for fracture or no increased risk for fracture. Leading away from this arrow is a curved line leading to potential harms of screening (KQ 3). One of the branched pathways ends after the no increased risk box. The other pathway continues after the increased risk box to treatment (KQ 4) and a curved line leads away from this pathway to potential harms of treatment (KQ 5). This indirect pathway also ends at the outcomes box on the right of the figure.

We also addressed the following contextual questions:

1. What is the evidence from modeling studies about the effectiveness of risk screening strategies that use different ages at which to start and stop screening and different screening intervals?
2. How do various fracture risk assessment tools use race and ethnicity in fracture risk calculations?
3. What is the incidence of fractures among persons of different races and ethnicities in the United States in the last 10 to 15 years, and what factors might explain differences in incidence among different races and ethnicities?
4. What are the differences in rates of screening or treatment initiation among persons of different races and ethnicities, and what might explain these differences?
5. What are the implications of using fixed-fracture risk thresholds for decisions regarding stepwise screening or treatment?
6. What is the evidence for rare harms of bisphosphonate treatment (i.e., osteonecrosis of the jaw, atypical femur fractures) from observational studies that use noneligible control groups or are uncontrolled?
7. What is the evidence for rebound fractures after discontinuation of denosumab?

These contextual questions are not shown in the analytic framework because they were not analyzed using the same systematic methods as the KQs. They were intended to provide additional background or contextual information for interpreting the results of the KQ and were addressed through targeted literature searches to identify the most recent and relevant information to the questions at hand.

## Data Sources and Searches

We searched PubMed/MEDLINE, Embase, and the Cochrane Library for English-language articles published through January 9, 2024. We used Medical Subject Headings as search terms and keywords when appropriate to describe relevant populations, tests, interventions, outcomes, and study designs and applied additional limits on the completed search to remove case reports, case series, articles with child in the title, and articles with a type categorized as conference abstract. The complete search strategy for all data sources is detailed in Appendix B.1. We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov and the WHO International Clinical Trials Registry Platform. In addition to database searches, we reviewed reference lists of relevant articles, studies suggested by expert reviewers, and comments received during public commenting periods. Since January 2024, we conducted ongoing surveillance through article alerts and targeted searches of journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on July 31, 2024.

## Study Selection

We developed inclusion and exclusion criteria for populations, interventions, comparators, outcomes, settings, and study designs with input from the USPSTF (Appendix B.2). We included good- or fair-quality, English-language studies focused on adults age 40 years or older conducted in countries categorized as very high on the Human Development Index.^104^ Other criteria were specific to each KQ. For KQ 1 (direct benefits of screening), we included controlled trials of screening vs. no screening or usual care that reported fracture or mortality outcomes among persons not known to have osteoporosis, prior fragility fracture, or medical conditions or medications associated with secondary osteoporosis. Eligible screening strategies comprised risk assessment instruments, DXA measurement of BMD, or both. For KQ 3, we used similar criteria as KQ 1 except that we looked for harms of screening and allowed for controlled cohort studies in addition to trials.

For KQ 2, we included cohort studies or SRs of cohort studies that evaluated the accuracy of risk assessment instruments (KQ 2a) or BMD alone (KQ 2b) for predicting future incident fractures or the diagnostic accuracy of DXA for identifying osteoporosis (KQ 2c). For predictive accuracy, we sought studies reporting calibration or discrimination outcomes and for diagnostic accuracy, we sought studies reporting discrimination outcomes. Calibration measures the extent to which predicted fracture risks are similar to observed risks over time for the population overall and across the spectrum of predicted risks. Discrimination measures the extent to which a risk assessment (KQ 2a) or BMD (KQ 2b) identifies persons who ultimately experience a fracture as higher risk compared with those who do not. For KQ 2c, discrimination measures the extent to which risk assessment instruments identify persons with osteoporosis compared with those without osteoporosis. Discrimination reported with area under the receiver operating characteristics curve (AUC), sensitivity, and specificity were eligible for KQ 2a, 2b, and 2c. For risk assessment instruments, we included only instruments that had been evaluated in at least two independent external cohorts to the development cohort. We allowed risk assessment instruments that had been evaluated in only one external cohort if it was conducted in men because of a more limited pool of evidence for use of such tools in men. We limited primary research studies for KQ 2a and 2b to studies conducted in countries with hip fracture incidence similar to the United States.^105^ We did not include any accuracy data from model development cohorts. For KQ 2a and KQ 2b, we included poor-quality studies because of the limited pool of good- or fair-quality predictive accuracy studies. For KQ 2d, we included studies reporting data that would inform conclusions related to screening intervals.

For KQs 4 and 5 (benefits and harms of treatment), we included RCTs or controlled cohort studies (for harms only) that reported on FDA-approved bisphosphonates or denosumab compared with placebo and that reported fracture, mortality, or harm outcomes. The review was limited to these agents for women because this was not a comprehensive review of all treatment options and bisphosphonates and denosumab are the most frequently prescribed agents. We also considered studies of teriparatide, abaloparatide, or romosozumab for men because of the limited pool of treatment studies among men. We excluded studies where the majority of enrolled participants had secondary osteoporosis or prior fragility fractures.

Two team members independently reviewed titles, abstracts, and full-text articles using study selection criteria to determine inclusion in or exclusion from this update. Disagreements were resolved by discussion or review by a third reviewer. We reassessed studies included in the prior 2018 review^3,^ ^70^ against the updated study selection criteria for this update. We screened all citations using the DistillerSR platform (DistillerSR, Inc.) and managed citations using EndNote Version 9.2 (Clarivate™).

## Data Abstraction and Quality Assessment

One reviewer abstracted relevant information for each included study into a structured form in DistillerSR including design, population, intervention, comparator, outcomes, timing, and setting. A second person reviewed all data abstractions for accuracy. We considered data from the same study population or cohort but reported in separate publications as one study. We contacted study authors to clarify study data when needed.

We assessed the risk of bias for each included study using design-specific risk of bias assessments (RoB 2 for RCTs,^106^ ROBINS-I for nonrandomized studies of interventions,^107^ QUADAS-2 for diagnostic test accuracy,^108^ ROBIS for SRs).^109,^ ^110^ For predictive accuracy of risk assessment instruments, we first evaluated the risk of bias of each instrument in its development cohort(s) using the full PROBAST risk of bias instrument adapted to include health equity signaling items.^111,^ ^112^ We next evaluated the risk of bias of studies assessing these instruments in external validation cohorts using an adapted version of the PROBAST short form.^110^ For all study designs, we translated risk-of-bias ratings from instruments to methodological quality ratings using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B.3).^113^ Two independent investigators assigned quality ratings for each study. Disagreements were resolved by discussion or review by a third reviewer.

## Data Synthesis and Analysis

We synthesized findings for each KQ in tabular and narrative format. To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies following established guidance that includes evaluating the similarities in study population, intervention, dose, and frequency and similarities in timing and specification of outcomes.^114^ For KQs 1, 3, 4, and 5, when at least two similar studies were available, quantitative synthesis was conducted with random-effects models using the inverse-variance weighted method (DerSimonian and Laird) to estimate pooled effects.^115^ We calculated pooled relative risks (RRs) and 95 percent confidence intervals (CIs) for fracture and mortality outcomes; we then re-expressed the pooled RRs as absolute risk differences (ARDs) per 1,000 persons screened or treated.^116^ Statistical significance was assumed when 95 percent CIs of pooled results did not cross the null effect. All testing was two-sided. For all quantitative syntheses, we used the I^2^ statistic to assess statistical heterogeneity.^117,^ ^118^ An I^2^ from 0 to 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, 50 to 90 percent may represent substantial heterogeneity, and 75 percent or greater represents considerable heterogeneity.^117,^ ^118^ For KQ 4 and KQ 5, data were pooled across dosage groups for studies with more than one active intervention arm and we conducted sensitivity analyses for alternative types of vertebral fractures (clinical vs. vertebral), for drug dosages that were not FDA-approved dosages, and for alternative pooling methods to account for rare or zero events in one or both study arms.^113^ We conducted all quantitative analyses using Stata version 17 (StataCorp LLC).

We assessed the overall strength of the body of evidence for each comparison and outcome organized by KQ as high, moderate, low, or insufficient using methods developed for the USPSTF (and the EPC program), based on the quality of studies and limitations, consistency of results between studies, precision of findings, and risk of reporting bias.^113,^ ^119^ We also assessed the applicability of the findings to U.S. primary care populations and settings.

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF website for public comment from August 12, 2021, to September 9, 2021. In response, the USPSTF included additional outcomes, added two contextual questions regarding rare but serious harms, and listed special populations of interest. The USPSTF also made several minor additions and wording changes to improve the clarity and specificity of the research approach.

A draft report was reviewed by four content experts, five representatives of federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments received. In response to these comments, additional sensitivity analyses were conducted for KQ 1 and KQ 4 and new information related to overdiagnosis was added for KQ 3. Several new studies were added to KQ 2, and results were further stratified by men, women, and younger women. Additional sources of heterogeneity were discussed for KQ 2, and additional limitations were noted for all KQs. In addition, the draft report was posted for public comment from June 11, 2024, to July 8, 2024. Based on public comments, we made revisions to improve the clarity of the report, but no new eligible studies were identified.

## USPSTF and AHRQ Involvement

Members of the USPSTF helped develop the scope of work, including the analytic framework and KQs, and review the evidence synthesis. AHRQ staff provided project oversight, conducted reviews of the draft report, and helped facilitate an external review of the evidence synthesis.