# Chapter 1 Introduction

## Scope and Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2018 recommendations for screening for osteoporosis to prevent fractures.^1^ The USPSTF recommended screening for osteoporosis with bone measurement testing to prevent fractures in women age 65 years or older (B recommendation). For postmenopausal women younger than age 65 years, the USPSTF recommended screening with bone measurement testing for those at increased risk of osteoporosis, as determined by a formal clinical risk assessment tool (B recommendation). For men, the evidence was insufficient to assess the balance of benefits and harms (I statement). These recommendations and statements were consistent with the prior recommendation from 2011;^2^ the primary difference was that for postmenopausal women younger than age 65 years, the 2018 recommendation updated the threshold to consider bone mineral density (BMD) testing based on fracture risk assessment. The USPSTF suggested that postmenopausal women younger than age 65 years with at least the 10-year risk of major osteoporotic fracture (MOF) from the Fracture Risk Assessment Tool (FRAX^®^) for a 65-year-old White woman of average weight (73.9 kg) and height (160.3 cm) based on National Health and Nutrition Examination Survey (NHANES) 2011–2014 data (MOF risk of 8.4%) could be used to identify younger women for bone measurement testing.^1,^ ^3^

## Condition Definition

Osteoporosis is a disorder of the skeletal system and is characterized by decreased bone mass, microarchitectural deterioration of bone tissue, and a consequent increase in bone fragility and risk of fractures.^4^ The ability to measure bone density (related to bone mass) using dual-energy X-ray absorptiometry (DXA) in grams/centimeter^2^, also referred to as areal BMD, was available in routine clinical practice by the 1990s. However, differences in DXA machines made by different manufacturers led to widely varying absolute BMD results (in grams/centimeter^2^) for a single individual depending on the machine used. This variation led to the use of relative measures to express BMD results, specifically T-scores, to account for variation across DXA machines. In 1994, the World Health Organization (WHO) operationalized the definition of osteoporosis in postmenopausal White women as bone density at the hip or spine that is 2.5 standard deviations (SDs) or lower (T-score ≤−2.5) than the mean BMD measured at the femoral neck (FN) for a reference population of young healthy White women. WHO chose this threshold because the lifetime risk of osteoporotic fracture in women was at least 30 to 40 percent and a T-score of −2.5 (acknowledged by WHO as somewhat arbitrary) would categorize approximately 30 percent of women as having osteoporosis. At the time this threshold was selected, it was not known whether the 30 percent of women identified based on T-score would be the same women who would eventually have a fracture.^5,^ ^6^ We now know that although there is some overlap in these populations, they are not the same.

Soon after the WHO definition, DXA machine manufacturers reached consensus on using a specific reference population for FN and total hip (TH) BMD measurements that is still used today. This reference population is White women ages 20 to 29 years from NHANES III (1988–1994).^7^ After the implementation of T-scores to report BMD for women, BMD for men was still being reported in reference to a young male population.^8^ However, because males have a higher average BMD than females, the same absolute BMD measurement in grams/centimeter^2^ for a male would result in a lower T-score in reference to a young male population than in reference to a young female population.^8^ Because fracture risk for males and females is similar at the same absolute BMD (in grams/centimeter^2^),^9^ the use of sex-specific reference populations for generating T-scores results in more osteoporosis diagnoses and treatment among males compared with females with the same absolute BMD.^8^ The sex differences in BMD do not appear to be explained by nutrition, level of activity, weight, or lean mass but may be explained by bone size.^10^

The use of country- or race-specific reference populations to calculate T-scores also leads to different T-scores for the same absolute BMD. To ensure that the same absolute BMD result in grams/centimeter^2^ generates the same T-score worldwide, it is necessary for all DXA manufacturers to use the same reference population for all persons (without regard to sex, race, or country of origin). Thus, the International Society for Clinical Densitometry recommended using the Caucasian (non-race-adjusted) young female NHANES III reference standard for calculating FN and TH BMD T-scores for both males and females and for all racial and ethnic groups.^11^ Because lumbar spine (LS) BMD was not included in NHANES III data, DXA machines use their own reference data for reporting T-scores at the LS. These are referred to as “local reference populations” and vary by manufacturer.

Osteoporosis and low bone mass (T-score between −1.0 and −2.5, formerly referred to as osteopenia) are asymptomatic risk factors for fragility fractures (also known as “low-energy” or “low-trauma” fractures), which are fractures sustained from a fall from standing height or lower that would not cause a fracture in most healthy persons.^12^ Although low-trauma hip and vertebral fractures are usually considered to be fragility fractures, low-trauma fractures at other skeletal sites often depend on the fall circumstances, and there is debate as to whether such fractures should be considered fragility fractures. For example, higher physical activity is associated with an increased risk for wrist fracture but lower risk of proximal humerus fractures. Bone density is one of many risk factors for fragility fractures, and persons with a BMD in the osteoporotic range have a higher relative risk of fragility facture compared with those in the low or normal bone mass range. But the majority of fragility fractures actually occur in persons with low or normal bone mass because these categories of BMD include many more people compared with the category of persons with osteoporosis.^13–16^ As a result, some experts have suggested a revision to the operational definition of osteoporosis.^17^ Many consider a personal history of a fragility fracture as pathognomonic for osteoporosis, regardless of T-score. The U.K. National Institute for Health and Care Excellence noted that although osteoporosis is defined by a T-score of −2.5 or below on a DXA scan, the diagnosis may be assumed in women age 75 years or older if the responsible clinician considers a DXA scan to be clinically inappropriate or infeasible.^18^ The National Bone Health Alliance has proposed that in addition to a T-score of less than or equal to −2.5 at the spine or hip, the identification of a hip fracture; vertebral, proximal humerus, pelvis, or some wrist fractures in persons with low bone mass; or fracture risk assessment scores above prespecified thresholds should confer an osteoporosis diagnosis.^19,^ ^20^

## Prevalence and Burden of Disease

An analysis of NHANES data from 2017 to 2018 suggests an age-adjusted prevalence of osteoporosis of 12.6 percent among the noninstitutionalized U.S. population age 50 years or older; the prevalence was higher in women (19.6%) compared with men (4.4%).^21^ Prevalence is higher among persons age 65 years or older (Women 27.1%, Men 5.7%) compared with persons ages 50 to 64 years (Women 13.1%, Men 3.3%).^21^ Prevalence also varied by race and ethnicity: prevalence was 12.9 percent in non-Hispanic White persons, 18.4 percent in non-Hispanic Asian persons, and 14.7 percent in Hispanic persons; these differences were not statistically significant.^22^ The prevalence in non-Hispanic Black persons was 6.8 percent and was significantly different from other racial and ethnic groups.^22^ The prevalence of osteoporosis or low bone mass is 51.5 percent in women and 33.5 percent in men.^21^

The most worrisome concern resulting from osteoporosis is a fragility fracture, which can lead to significant morbidity and mortality.^23^ These fractures are associated with an increase in excess mortality,^24^ risk of subsequent fractures,^25–27^ loss of independence,^28,^ ^29^ reduced ability to perform activities of daily living,^28,^ ^29^ and psychological consequences.^29^ Mortality associated with a hip fracture is highest in the first few months immediately after the fracture.^30,^ ^31^ Although osteoporosis and fragility fractures are more common in women than men,^32^ excess mortality is more common in men.^32–34^ Among Medicare beneficiaries in 2016, 40 percent with a new osteoporotic fracture were hospitalized within a week of fracture, and among those with hip fracture, 90 percent were hospitalized.^35^ One review found that only between 40 and 60 percent of persons experiencing a hip fracture recovered their prefracture level of mobility and ability to perform instrumental activities of daily living, while only 40 to 70 percent gained their level of independence for basic activities of daily living.^28^ The burden associated with hip fractures is more commonly reported than the burden associated with vertebral or other fractures, leading to a concern that the burden from vertebral fractures and other fractures may be underestimated.^23,^ ^36^ However, despite excess mortality associated with fractures, trials of fracture prevention have not clearly demonstrated a reduction in mortality.

Based on Medicare fee-for-service and Medicare Advantage data, the number of beneficiaries who experienced a new osteoporotic fracture was 1.8 million in 2016.^35^ Appendix A Table 1 depicts the age-standardized incidence of hip fractures from a cohort of over 1.8 million Medicare Advantage health plan enrollees between 2007 and 2017.^35^ Age-standardized incidence rates of fragility fractures decreased between 2007 and 2013.^35,^ ^37^ This decline was hypothesized to be because of increasing rates of obesity, increasing use of antiresorptive agents, and birth cohort effects.^38^ However, because of the aging of the population, the absolute incidence is increasing. Further, recent studies have suggested that the decline in age-standardized fracture rates may have plateaued in the last 5 to 7 years.^35,^ ^39,^ ^40^

## Etiology and Natural History

Fragility fractures can be a consequence of osteoporosis. Although those with osteoporosis have the greatest relative risk of fracture, most fractures occur in those with low bone mass (i.e., T-scores between −1.0 and 2.5) or normal bone density (T-score >−1) because they represent a greater share of the population.^13,^ ^41–45^

Osteoporosis may occur either without a known cause (referred to as primary osteoporosis) or secondary to a medical condition or medications (referred to as secondary osteoporosis).^46^ Postmenopausal osteoporosis is considered a type of primary osteoporosis.^46^ Secondary osteoporosis is bone loss associated with certain medical conditions: various endocrine conditions of the pituitary, thyroid, parathyroid, or reproductive organs; eating disorders; disorders of the gastrointestinal (GI) or biliary tract; renal disease; bone marrow disorders; and cancer.^46,^ ^47^ Secondary osteoporosis can also result after organ transplantation and can arise from chronic use of medications with known deleterious effects on bone mass, such as glucocorticoids, immunosuppressants, antiepileptic medications, heparin, gonadotropin-releasing hormone agonists, and some long-acting progesterone agents used as contraceptives (which may be reversible).^46,^ ^47^ The identification and management of secondary osteoporosis is outside of the scope of the USPSTF’s current recommendation.

A biological basis for differences in the age of onset and the prevalence of osteoporosis between males and females exists. We note that most of the research in the area of bone metabolism and fractures uses the terms “men” and “women” to refer to biological sex (male and female); we use the terms used by individual study authors in this report, which is typically “men” and “women.” Women lose bone mass at a younger age, and the rate of loss is faster than for men.^10^ The prevalence of low bone mass in women increases rapidly beginning around age 60 years, and the prevalence of osteoporosis doubles by age 70 years, whereas the prevalence of osteoporosis only doubles by age 80 years for men.^10^ Transmen and transwomen who have not undergone any hormonal treatment associated with transitioning likely have the same risks and prevalence as persons assigned female and male sex at birth, respectively.

Data from the Study of Women’s Health Across the Nation (SWAN),^48^ a multisite longitudinal epidemiologic study in the United States, reported that bone turnover increases about 2 years before the final menstrual period, increases rapidly for the next 4 years with a peak 2 years after the final menstrual period, and subsequently plateaus thereafter. However, the rate of turnover after this plateau is approximately 20 percent higher than premenopausal levels. In SWAN, larger increases in bone turnover were observed for women with body mass index (BMI) less than 25 kg/m^2^, and the smallest increases in turnover were observed in women with BMI greater than 30 kg/m^2^. Furthermore, higher turnover levels were observed among Japanese Americans, and smaller turnover levels were observed among African Americans, even after adjusting for other variables such as BMI.

### Risk Factors

Although bone density is an important risk factor for fragility fractures for both males and females, advancing age is the more critical determinant.^49^ Older adults have much higher fracture rates than younger adults with the same BMD because of concurrent increasing risk from declining bone quality and an increasing tendency to fall.^50^ Appendix A Figure 1 demonstrates the impact of age on estimated fracture risk based on the FRAX calibrated to the U.S. population by race (Caucasian, Black, Hispanic, Asian). As seen in this figure, the risk of fracture is higher at age 70 years compared with age 50 years, holding BMD constant for both males and females of all races and ethnicities. Race-neutral estimated fracture risks from FRAX calibrated to the Canadian and U.K. populations are also provided in this figure for comparison.

Bone density may not be as useful a predictor of fracture risk, particularly in younger persons. An Australian case-control study evaluating the relationship between osteoporosis and fragility fractures found that only 20 percent of women ages 50 to 59 years with incident fracture had osteoporosis. In comparison, 45 percent, 60 percent, and 70 percent of those ages 60 to 69 years, 70 to 79 years, and age 80 years or older with incident fractures had osteoporosis.^45^ Fractures in younger persons that occur at some sites (e.g., wrist) may be associated with higher physical activity levels and greater risk-taking behaviors, so some experts have suggested they should not be considered fragility fractures.

Aside from medical conditions and medications (e.g., corticosteroids) associated with secondary osteoporosis, additional risk factors include menopausal status in women, previous osteoporotic fracture, low body weight (less than 58 kg [127 lbs]), parental history of hip fracture, cigarette smoking, and excess alcohol consumption.^51,^ ^52^ Diabetes treated with insulin (type 1 or type 2) increases the risk of fracture but has a variable relationship with BMD. Type 1 diabetes is associated with a reduction in BMD and an increased risk of fracture. Type 2 diabetes has a variable relationship. Some studies have observed that type 2 diabetes mellitus (DM) is associated with both increased BMD and fracture risk, suggesting BMD may be less useful in predicting fracture risk because bone integrity, not density, may be responsible for fracture in this population.^53^ However, two recent large cohort studies suggest negligible contribution of type 2 DM to overall fracture risk. One study among men in the United Kingdom observed no association between type 2 DM and future fracture,^54^ while another study among adults in Sweden observed a small increase in relative risk of MOF and in hip fracture for persons with diabetes, but negligible contribution of diabetes to overall fracture risk when all other risks were considered.^55^ Further, the association between type 2 DM and fracture risk was absent when competing mortality was considered.

A systematic review (SR) and meta-analysis identified risk factors associated with fragility fractures in men.^56^ The review found statistically significant associations between fractures and increasing age, low BMI, excessive alcohol intake (daily intake or greater than 10 servings per week), current smoking, chronic corticosteroid use, history of prior fractures, history of falls within the past year, hypogonadism, history of cerebrovascular accident, and history of diabetes.

Racial differences in both the prevalence of osteoporosis and incidence of osteoporotic fractures are discussed in detail in Appendix A Contextual Question 3. Studies reported lower fracture incidence in Asian, Hispanic, and Black populations compared with White populations among both men and women.^57–59^ Decreases in BMD are observed with increasing age across all races and ethnicities, but differences in BMD alone are not sufficient to explain racial and ethnic differences in fracture incidence. For example, Asian women have been found to have lower BMD than White women but lower fracture risk.^60–62^ Moreover, racial categories are broad, are socially determined, and vary between countries. It is possible that unaccounted for environmental differences between racial and ethnic groups are responsible for differences in fracture incidence or that racial and ethnic differences in fracture incidence may reflect differences in underlying clinical risks in these populations. U.S. racial categories obscure the tremendous diversity that occurs within racial groups.

## Rationale for Screening/Screening Strategies

The rationale for screening is to identify persons with osteoporosis or at risk of a fragility fracture and provide treatment to increase bone mass or prevent further losses to minimize the occurrence of fragility fractures and related morbidity.

### Bone Measurement Tests

As described earlier, the WHO defines osteoporosis in postmenopausal females and males age 50 years or older as a BMD measurement associated with a T-score of −2.5 or lower obtained through DXA at a central skeletal site (e.g., total hip, FN, or LS). This definition is widely used throughout the world and has remained unchanged for decades. Compared with other imaging modalities, DXA has been correlated to biomechanical bone strength and clinical fracture outcomes and uses low doses of radiation.^63^ Further, centrally measured DXA was the test used for diagnosis of osteoporosis among participants enrolled in nearly all trials of bone-conserving pharmacotherapies.^64^ Evidence suggests that BMD at any skeletal site can predict fracture risk, but fracture risk at a specific site (e.g., hip or spine) is best predicted by BMD measurement at that site.^65^ Further, morbidity of fragility fractures at central sites, particularly the hip, is much higher than morbidity of fragility fractures that occur at other sites.^66–68^ For these reasons, and because centrally measured DXA does not require any followup tests to confirm the diagnosis of osteoporosis, it is the test recommended for assessing BMD and is the one that is used most widely.

Other bone measurement tests are available but are not in widespread use for primary screening.^63^ These include enhancements to traditional DXA scanning such as vertebral fracture assessment or trabecular bone score, quantitative ultrasound, DXA measured at peripheral sites (e.g., wrist), quantitative computed tomography, and radiograph absorptiometry.^69^ However, none of these tests were used to identify participants for randomized, controlled trials (RCTs) of pharmacotherapy for fracture prevention.

### Risk Assessment Tools

BMD alone may not be a sensitive enough screening tool for identifying persons at high fracture risk.^69^ Some experts recommend a screening approach that assesses for increased fracture risk, rather than identifying osteoporosis, because 1) most fragility fractures occur in persons without osteoporosis, 2) measured bone density only reflects one aspect of bone quality, and 3) nonskeletal factors also contribute to fracture risk.^69^ Several risk assessment tools that incorporate age and sex, with or without other risk factors, have been developed to assess the risk for current osteoporosis or to predict the risk for future fragility fracture. Appendix A Table 2 summarizes tools that were evaluated in the prior review for the USPSTF.^3,^ ^70^ These tools were originally developed to either 1) identify osteoporosis or 2) predict fracture risk, but subsequent studies have evaluated the diagnostic or predictive accuracy of many of them with respect to both outcomes. However, some of the risk assessment tools were developed on small cohorts using homogenous populations or have limited published evidence. Three instruments (FRAX,^12,^ ^71^ Fracture Risk Calculator [FRC],^72,^ ^73^ and the Garvan Fracture Risk Calculator^74,^ ^75^) can be used with or without BMD as a risk factor input. The instruments designed to identify osteoporosis generally require fewer risk inputs than instruments designed to predict future fracture. Additionally, several instruments include risk factors (such as personal history of fragility fracture or medical conditions or medications known to be associated with secondary osteoporosis), suggesting that the population for which these tools were developed includes persons beyond a general primary care screening population.

Some risk assessment instruments incorporate race or ethnicity as a risk factor. These include the Simple Calculated Osteoporosis Risk Estimation (SCORE) to identify a person’s current risk for osteoporosis (i.e., T-score <−2.5)^76^ and two fracture risk prediction instruments: FRAX, calibrated for use internationally, and QFracture, developed for use in the United Kingdom.^77^ Additional information about how race and ethnicity are used in these risk assessment tools is in Appendix A Contextual Question 2.

The most studied fracture risk assessment instrument is FRAX; however, its underlying model parameters are not publicly available. It was derived from nine cohorts in Europe, the United States, Japan, and Canada and further validated in an additional 11 cohort studies.^12,^ ^71^ Detailed information about FRAX is in Appendix A Additional Background. As of release version 4.2, 73 different country-specific versions of FRAX are available that have been calibrated using country-specific fracture incidence and mortality data, which is considered a competing risk in the model.^78^ As of 2016, FRAX was incorporated into 120 guidelines worldwide and added into DXA machine software following regulatory approval by the Food and Drug Administration (FDA) and has been incorporated into clinical decision support tools within electronic health record systems.^69^ For the United States, four different versions of FRAX are available that have been calibrated based on racial- and ethnic-specific fracture incidence data, including a version for non-Hispanic Caucasians, a version for non-Hispanic Blacks, a version for Hispanics, and a version for non-Hispanic Asians. It is unclear what version of FRAX clinicians should use for persons who are mixed race, of other races, or immigrants from other countries who are now living in the United States.^79^ In the wake of recent attention to racial bias in clinical algorithms, some have raised questions regarding the validity of race-specific FRAX calculators, which predict lower rates of fracture for people of color compared with White persons of the same age, BMD, and clinical risk factors.^80,^ ^81^ Few countries other than the United States have developed race-specific versions of FRAX, and other countries with similar ethnic diversity as the United States (e.g., United Kingdom, Australia, Canada) use a single version of FRAX with all races and ethnicities.

## Interventions

Reducing fracture risk involves addressing underlying modifiable risks through approaches such as smoking cessation, increased physical activity, avoidance of heavy alcohol use, adequate calcium and vitamin D intake, and fall prevention interventions in older persons at increased risk for falls. However, most relevant to the scope of this update is the use of pharmacologic treatment to increase bone mass or prevent further loss of bone mass.

First-line therapy typically includes drugs within the bisphosphonate class. FDA-approved drugs for prevention or treatment include four bisphosphonates (alendronate, zoledronic acid, risedronate, ibandronate), the RANK-ligand inhibitor denosumab, the sclerostin inhibitor romosozumab, recombinant parathyroid hormone agents (teriparatide, abaloparatide), estrogen (with or without progesterone), selective estrogen receptor modulators (raloxifene, bazedoxifene in combination with estrogen), and calcitonin. Although most second-line agents have demonstrated efficacy at reducing loss of bone mass or decreasing fragility fractures, not all have demonstrated efficacy for specifically reducing hip fractures.^82,^ ^83^ Off-label treatments (i.e., drugs that do not have an FDA-approved indication for the prevention or treatment of osteoporosis) include testosterone, tamoxifen, and other bisphosphonates (i.e., etidronate, pamidronate, tiludronate). Appendix A Table 3 provides detailed information related to bisphosphonate drugs with FDA-approved indications and denosumab for the prevention or treatment of osteoporosis in the United States.

For primary prevention of fractures, pharmacotherapy is generally recommended for T-scores of −2.5 or less (osteoporosis). Further, pharmacotherapy may also be warranted based on shared decision making for persons with T-scores between −1.0 and −2.5 (low bone mass) who are at high risk for fracture as determined based on clinical judgment or increasingly based on standardized risk calculators such as FRAX. For primary fracture prevention in the United States, the Bone Health and Osteoporosis Foundation (formerly known as the National Osteoporosis Foundation [NOF]) recommends treatment for individuals with low bone mass who have a 10-year hip fracture risk of at least 3 percent or a 10-year MOF risk of at least 20 percent based on FRAX.^84^ The hip fracture risk threshold was selected based on a U.S.-specific economic analysis of cost-effectiveness from a societal perspective sponsored by the NOF and that assumed one-step BMD screening, use of generic bisphosphonates, and a willingness-to-pay threshold of $60,000 per quality-adjusted life-year gained.^80,^ ^85^ These treatment thresholds have not been evaluated in trials. The use of absolute fracture risk in addition to BMD increases the number of candidates for pharmacologic therapy in the United States.^86,^ ^87^ Some countries have adopted the U.S. thresholds for intervention, while others use age-dependent thresholds or a combination of fixed and age-dependent thresholds.^88^ Countries may establish different risk thresholds for initiating treatment based on country-specific epidemiology, competing health priorities, costs, and resource availability.^88^ For example, Japan recommends the use of FRAX in persons without a prior fracture with a T-score between −1.8 and −2.7 and recommends treatment for an MOF risk of 15 percent or higher.^89^

## Current Clinical Practice

Screening and primary prevention of osteoporosis in asymptomatic adults without known risks for secondary osteoporosis or prior fragility fracture is within the scope of practice for most primary care providers (PCPs). Guidelines developed by various organizations and specialty societies vary widely and provide recommendations based on age, sex, menopausal status, and other characteristics (Appendix A Table 4). Many guidelines recommend fracture risk assessment, DXA measurement, or both. Variation with respect to population, timing, and frequency also exists. Some guidelines include recommendations for those with prior fractures or at-risk conditions (e.g., long-term glucocorticoid steroid use), which is beyond the scope of the review for the USPSTF.

In 2023, the Canadian Task Force on Preventive Health Care (CTFPHC) issued updated recommendations for screening to prevent primary fragility fractures.^90^ The CTFPHC recommends screening women age 65 years or older with the Canadian FRAX tool to facilitate shared decision making about pharmacotherapy. If pharmacotherapy is a consideration, it then recommends ordering DXA testing to facilitate re-estimation of fracture risk with a BMD input. The CTFPHC recommends against screening in men age 40 years or older and in women younger than age 65 years.

For primary osteoporosis, nearly all guidelines acknowledge that a variety of medications are available and can be effective for treating osteoporosis. Some specifically state that bisphosphonates should be used as first-line therapy. Some also suggest denosumab as initial therapy, particularly for patients who are intolerant of bisphosphonates or because of its proven efficacy for reducing hip fracture.^91^ However, as the field has evolved from focusing solely on the treatment of osteoporosis to identification and treatment of high fracture risk, guidelines diverge about when to treat. Some guidelines focus on BMD exclusively when deciding whether to begin treatment, others on predicted fracture risk assessment, often without a specific rationale.

An SR of osteoporotic fracture risk assessment and treatment guidelines identified 120 guidelines^88^ recommending the use of FRAX-based fracture risks for conducting DXA testing and considering treatment. Of these, 38 did not provide a rationale for how fracture probabilities derived should be used for decision making. Some guidelines recommend DXA testing or treatment using fixed-probability thresholds (k=58, a group that includes the USPSTF 2011 and 2018 recommendations), while others recommend an age-dependent threshold (k=22) or a combination of the two (k=2). Of the guidelines referencing fixed-probability thresholds for treatment, over half (k=39) reference an absolute fracture risk of 20 percent or greater for MOF as the threshold for treatment in those with low bone mass.

### Implementation in Practice

The implementation of screening for osteoporosis in practice is heavily influenced by quality performance measures related to this service. In 2006, the National Committee for Quality Assurance introduced the Healthcare Effectiveness Data and Information Set measure assessing the percentage of women ages 65 to 85 years who report ever having received a bone density test to screen for osteoporosis.^92^ The rate of receipt of bone density tests rose in the ensuing decade.^93^ In 2006, 64.4 percent of women ages 65 to 85 years in a Medicare health maintenance organization plan and 71.3 percent in a Medicare preferred provider organization reported ever having a bone density test. By 2014, these numbers had risen to 74.2 percent and 78.5 percent, respectively. The Centers for Medicare & Medicaid Services (CMS) Measures Inventory now includes “Screening for Osteoporosis for Women Ages 65–85 Years of Age.”^94^ Despite these quality measures, a review of the CMS data between 2006 and 2016 found that performance gaps persist in osteoporosis identification and treatment.^92^ A study using a sample of U.S. Medicare claims-based data evaluated physician-reported reasons for not providing recommended screening or treatment. In this study, 24 percent of claims documented that care was considered but not provided because of contraindications, other reasons, or patient preference.^95^ This suggests that it may be difficult to achieve further improvement on this measure beyond current levels. However, racial differences in screening and treatment exist. Black women are less likely to be screened and treated for osteoporosis than White women.^96,^ ^97^ Additional information about differences in receipt of screening and treatment for osteoporosis by race and ethnicity is addressed in Appendix A Contextual Question 4.

Although some underuse may exist, some studies have also identified overuse of BMD screening. The Choosing Wisely Campaign, which is endorsed by multiple medical societies, lists bone density testing as a test that should be considered carefully before ordering in women younger than age 65 years and in men younger than age 70 years with no risk factors.^98^ The National Physicians Alliance Good Stewardship Working Group defines overuse as DXA screening in women younger than age 65 years or men younger than 70 years with no risk factors.^99^ CMS includes a measure to decrease overuse: “Appropriate Use of DXA Scans in Women Under 65 Years Who Do Not Meet the Risk Factor Profile for Osteoporotic Fracture (eCQM).”^100^ Findings from the National Ambulatory Medical Care Survey indicated that overuse of DXA in primary care accounted for $527 million per year in expenditures.^101^ Further, a study in a large regional healthcare system suggested that about one half of women younger than age 65 years without risk factors received DXA screening over a 7-year period.^96^

Poor treatment adherence among those identified with osteoporosis and offered medication potentially limits the beneficial impact of widespread, routine screening. In one study conducted in the United States, nearly 30 percent of persons who were prescribed bisphosphonates filled the prescription, and only half of those who filled the prescription were still taking medication 1 year later.^102^ In an analysis of a U.S. commercial insurance database from January 2009 to March 2020, alendronate was the most common medication used for osteoporosis, representing just over 60 percent of prescriptions for bone-directed therapies.^103^ Further, denosumab prescriptions increased since 2009 and represented about 20 percent of prescriptions by the end of the study period, outpacing all other medications except alendronate.^103^ Over 92 percent of prescriptions were directed to women and 76 percent were to persons older than the age of 65 years.^103^