# Appendix H Ongoing Studies

Relevant KQ | Title; Trial Registry # | Intervention; Comparator | Primary Outcomes | Estimated Completion Date
KQs 1 and 3 | Models of Primary Osteoporosis Screening in Male Veterans (MOPS); NCT04079868 | Intervention: Osteoporosis screening, education, and followup handled centrally by the bone health team; Control: No practice management support | Screening rates (%), medication discontinuation (days), medication initiation (%), medication implementation (% of days covered with medication), bone mineral density (gram/sq centimeter), harms (%), primary care provider time; outcomes measured at 2 or 5 years | August 2024
KQs 1 and 3 | Effects of FRAX+SARC-F Pre-screening on Preventing Fragility Fracture and Fall in Community-Dwelling Older Adults; NCT04709393 | Intervention: Receiving FRAX+SARC-F questionnaire prescreening results on estimated fracture risk; Control: Not receiving FRAX+SARC-F questionnaire prescreening preliminary results on estimated fracture risk | Proportions of participants diagnosed with osteoporosis in the FRAX+SARC-F prescreening and control groups. Time frame: within 1–6 months | December 2028
KQs 4 and 5 | Preventing Osteoporosis Using Denosumab; NCT02753283 | Intervention: Denosumab, then zoledronic acid; Control: Placebo then zoledronic acid; Both groups also received vitamin D and calcium | Bone density (total hip and spine) | September 2023

Abbreviations: FRAX=Fracture Risk Assessment Tool; KQ=key question; NCT=National Clinical Trial.