# Appendix G Risk of Bias in Development Cohorts of Fracture Risk Assessment Instruments for Key Questions 2a

The tables included in this section offer risk-of-bias assessments for the development studies and cohorts for five of the six instruments included in addressing the KQ on the predictive accuracy of risk assessment instruments (KQ 2a).

- Fracture Risk Calculator (FRC)
- Fracture Risk Assessment Tool (FRAX)
- Fracture Risk Evaluation Model (FREM)
- Garvan Fracture Risk Calculator
- QFracture
- Women’s Health Initiative Fracture Risk Model

Risk of bias was assessed using a modified version of the Prediction model study Risk Of Bias Assessment Tool (PROBAST^111,^ ^112^). This instrument was modified to include additional health equity signaling items. These items as denoted with an “a” after the signaling item in the tables that follow.

The seventh risk assessment instrument included for KQ 2a (Osteoporosis Self-Assessment Tool, OST) was not developed as a fracture risk prediction instrument; therefore, we cannot assess the risk of bias of the development study or cohort for predicting fractures.

Appendix G Table 1 Fracture Risk Calculator (FRC) Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Step 1 and 2 Specification of Review Questions

Item | Response
Intended use of model: | Predict risk of developing an osteoporotic fracture
Participants including selection criteria and setting: | Patients age 40 years or older
Predictors (used in prediction modeling), including types of predictors (e.g., history, clinical examination, biochemical markers, imaging tests), time of measurement, specific measurement issues (e.g., any requirements/prohibitions for specialized equipment): | Low body weight, current smoking, hip fracture in mother or sister, personal fracture history (nonspinal after age 50 years or older), with or without BMD
Outcome to be predicted: | Risk of osteoporotic fracture (with a minimum of 3 years’ observation for studies with no specified prediction interval or a median or mean of 80% of the time in studies with a specified prediction interval)
Type of prediction study | Development and validation
Citations | Ettinger B, Hillier TA, Pressman A, Che M, Hanley DA. Simple computer model for calculating and reporting 5-year osteoporotic fracture risk in postmenopausal women. J Womens Health (Larchmt). 2005 Mar;14(2):159–71. doi: 10.1089/jwh.2005.14.159. PMID: 15775734.15775734

Abbreviations: BMD=bone mineral density; FRC=Fracture Risk Calculator.

Appendix G Table 2 Fracture Risk Calculator (FRC) Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 1 Participants

Item | Response
Describe the sources of data and criteria for participant selection: | The authors used two different sources for data for development. The risk factors and three major osteoporotic nonspinal fractures (hip, wrist, humerus) came from 1996–2000 fracture incidence derived from inpatient and outpatient databases of the Kaiser Permanente Medical Care Program, Northern California Region. Because the membership rate for each age category remained constant during the study, the authors assumed the cohort of members at risk also remained constant per year. It is not stated that these were first fractures. They used these data to calculate the percentage of female members ages 45–75 years treated for each of the fractures for each year. But because of ICD-9 coding deficiencies, vertebral fractures were underdiagnosed and inaccurate. So for vertebral fractures, they relied on data from the Geelong Osteoporosis Study report (https://pubmed.ncbi.nlm.nih.gov/10525717/, which described a cohort study of persons living in Geelong, Australia, for whom fracture outcome was monitored during the 2-year study period (1994–1996). “The Geelong Osteoporosis Study is a population-based study designed to determine complete fracture rate within a defined region sufficiently large and representative of national demographics to establish reliable rates of fracture. The advantage of this population is that all radiologic facilities are provided through two centralized services.” The data were limited to first fractures. The authors of FRC noted that they calculated 5-year vertebral fracture rates for White women but did not explain assumptions made in calculating 5-year rates from 2 years of data from the Geelong data.; The model was then validated in 2 “large prospective observational studies,” Study of Osteoporotic Fractures (SOF) (https://pubmed.ncbi.nlm.nih.gov/7862179/ and https://pubmed.ncbi.nlm.nih.gov/1952469/) and Canadian Multicentre Osteoporosis Study (CaMOS). SOF included 9,516 White women age 65 years or older who had no previous hip fracture from four clinical centers in the United States. The CaMOS source cited in the FRC article is not accessible ( Kreiger N, Tenenhouse A, Joseph L, Mackenzie T, Poliquin S, Brown JP, . The Canadian multicentre osteoporosis study (CaMoS): background, rationale, methods. CJA. 1999;18:376–387 .). But another CAMOS source (https://pubmed.ncbi.nlm.nih.gov/25451323/) seems to indicate that the baseline cohort of 6,314 women and 2,789 men from 1995–1997 of whom 94.9% were White.
Risk of Bias | | Dev | Val
Were appropriate data sources used, e.g., cohort, RCT or nested case-control study data?; Incidence of risk factors came from a routine care database, as did the nonspinal fractures for the development cohort. The spinal fractures for the development cohort came from a prospective cohort designed to address fractures. Both validation cohorts were prospective and designed to address fractures | | PN | NA
Were all inclusions and exclusions of participants appropriate?; No information on exclusions | | NI | NA
Was there sufficient representation of individuals from racial and ethnic groups in model development data?; The nonspinal fracture data from Kaiser Permanente Medical Care program in the Northern California region included 70% non-Hispanic White females, 7.5% African American or Black females, 8% Latino or Hispanic females, and 13.5% Asian females. The vertebral fracture data were designed to include only White women. | | PY for nonspinal fractures, N for spinal fractures | NA
Were racial and ethnic groups classified/categorized in a similar way in the development data and population to whom model is applied? (Validation studies only); The model validation cohorts were predominantly or exclusively White but the model did not include race. | | NA | NA
Item | Response
Risk of bias introduced by selection of participants; (low/high/unclear) | High; The predictors and the nonspinal fracture data came from a routine care database, which is not ideal because data were not collected with standardized research protocol.
Applicability
Describe included participants, setting and dates: | Development cohort for nonspinal fractures from inpatient and outpatient databases of the Kaiser Permanente Medical Care Program so likely representative of wide population of women and include races other than White women. The spinal fracture development cohort and the two validation cohorts were large and prospective and intended to be broadly representative, except that two-thirds did not include men, and all were almost entirely White.
Concern that the included participants and setting do not match the review question; (low/high/unclear) | Unclear; Development and validation cohorts broadly representative of White women but not other women.

Abbreviations: CaMOS=Canadian Multicentre Osteoporosis Study; Dev=development; FRC=Fracture Risk Calculator; ICD-9=International Statistical Classification of Diseases and Related Health Problems, 9^th^ Edition; ICD=International Statistical Classification of Diseases and Related Health Problems; NA=not available; NI=no information; PN=probably no; PY=probably yes; RCT=randomized, controlled trial; SOF=Study of Osteoporotic Fractures; Val=validation.

Appendix G Table 3 Fracture Risk Calculator (FRC) Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 2 Predictors

Item | Response
List and describe predictors included in the final model, e.g., definition and timing of assessment: | Risk factors included; Age; Height; Weight; Current smoker; Prior nonspinal fracture; No. of spinal fractures; Hip fractures in sister; Hip fractures in mother; BMD; It is unclear how the data were collected and what approaches were used to address missing data.; 5-year followup was the primary time point for prediction.
Risk of Bias | | Dev | Val
Were predictors defined and assessed in a similar way for all participants?; Routine care database so consistency of data collection for items such as family history-taking is unknown. Unclear how missing data were handled. | | PN
Were predictor assessments made without knowledge of outcome data? | | PY
Are all predictors available at the time the model is intended to be used? | | PY
Did the model avoid using race and ethnicity as a proxy for a biological or other risk factor that could be measured with more accuracy or fidelity?; Race and ethnicity were not used in the model. | | Y
Was differential missingness of predictor data in racial and ethnic groups considered?; Not applicable, race was not used | | NA
Risk of bias introduced by predictors or their assessment; (low/high/unclear) | High; Because this is a routine care database, unclear whether predictors were defined as assessed in the same way for all participants. The handling of missing data was also unclear.
Applicability
Concern that the definition, assessment, or timing of predictors in the model do not match the review question; (low/high/unclear) | Low; These predictors are relevant to what would be collected in primary care and included in electronic medical records.

Abbreviations: BMD=bone mineral density; Dev=development; NA=not available; PN=probably no; PY=probably yes; Val=validation.

Appendix G Table 4 Fracture Risk Calculator (FRC) Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 3 Outcome

Item | | Response
Describe the outcome, how it was defined and determined, and the time interval between predictor assessment and outcome determination: | | Two primary outcomes: 5-year nonspinal (hip, humerus, and wrist) fracture risk and 5-year spinal fracture risk.; Nonspinal fractures came from the Kaiser database and were used to create a 5-year fracture risk outcome for any of 3 limb fractures; the arithmetic function described the relation between age and 5-year fracture risk of any one of the three limb fractures is RISK = 0.0433 * e^0.0703*AGE.^; For spinal fractures, the authors acknowledged the deficiencies in recording vertebral fractures in their database and stated they used data from a population-based study to calculate the 5-year incidence of clinical spinal fracture in their model. That study collected all radiographic reports of first spinal fractures in Geelong, Australia; during a 2-year period; from these rates, the authors of FRC calculated 5-year rates using data for women ages 45 to 75 years. Based on the information in the appendix, it appears that they used the Geelong data to calculate risk of clinical spinal fracture as a function of age. (RISK= 0.0000000000005*AGE^6.8436^)
Risk of Bias | | | Dev | Val
Was the outcome determined appropriately?; Nonspinal fractures from a routine care database. Outcome determination methods not specified by protocol so open to coding errors, particularly for humerus and wrist. Hip fracture data may be more accurate given the devastating nature of this outcome. Spinal fractures from a prospective cohort designed to measure fractures, using ICD-9 codes and imaging data. | | | PN for nonspinal fractures, PY for spinal fractures | NA
Was a prespecified or standard outcome definition used?; From routine care database using ICD-9 codes (wrist [813.4x, 813.5x, 813.8x, 813.9x], hip [820.x], and humerus [812.x]), so these are not adjudicated or standardized so they will be open to coding errors. Again, hip fracture is probably okay given how devastating this outcome is. | | | PN for nonspinal fractures, PY for spinal fractures | NA
Were predictors excluded from the outcome definition?; Yes | | | Y | NA
Was the outcome defined and determined in a similar way for all participants?; Within each outcome, possibly, but there was not enough information to determine it. Across outcomes, no, because as noted earlier, fracture risk for nonspinal fractures was derived from ICD-9 data for which consistency is unclear. | | | PN | NA
3.4a Was differential followup or ascertainment of the outcome in racial and ethnic groups considered?; Followup not reported, either overall or by race. Could possibly have differential censoring in different populations. | | | N | NA
Was the outcome determined without knowledge of predictor information? | | | Y | NA
Was the time interval between predictor assessment and outcome determination appropriate?; 5-year horizon may be short to address some outcomes. | | | PN | NA
Were proxy outcomes avoided as the predicted outcome, where the meaning of the proxy may differ in racial and ethnic groups (label choice bias)?; Actual fractures were used as the outcome. This study did not create separate risk categories by race. | | | PY | NA
Risk of bias introduced by the outcome or its determination; (low/high/unclear) | High; Outcomes ascertained from routine care database, so these were not adjudicated or standardized so they are open to coding errors. Predictors included in outcome definition. Unknown followup or percentage of individuals dying/getting censored.
Applicability
At what time point was the outcome determined: | | The outcome was determined over 5 years, but the rate of risk was assumed to be same (other than by age) year-on-year.
If a composite outcome was used, describe the relative frequency/distribution of each contributing outcome: | | Unclear for the composite outcome of nonspinal fracture risk.
Concern that the outcome, its definition, timing or determination do not match the review question; (low/high/unclear) | | Low; The outcome of a fracture as indicated on a medical record seems broadly applicable.

Abbreviations: Dev=development; FRC=Fracture Risk Calculator; ICD-9=International Statistical Classification of Diseases and Related Health Problems, 9^th^ Edition; N=no; PN=probably no; PY=probably yes; Val=validation; Y=yes.

Appendix G Table 5 Fracture Risk Calculator (FRC) Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 4 Analysis

Item | Response
Describe numbers of participants, number of candidate predictors, outcome events and events per candidate predictor: | Development cohort: unclear, the Kaiser cohort included “more than 400,000 female members treated for any one of the three nonspinal fractures during the study period (59,628 with prior fracture); 59,772 new osteo fractures; 20,028 hip fractures; 14,528 fracture events, including 3,412 hip fractures.”; For the Geelong cohort, total women ages 45 to 75 years=32,566, number of vertebral fractures=116; Predictors: 8 variables, but they combined height and weight into BMI with a cut point of <21 kg/m^2^ to indicate thinness. Each of the predictors appears to have been weighted by relative risks obtained from various other sources (the authors cited 5 references for each clinical factor). Specifically, the relative risk for thinness for wrist and hip fracture risk was 1.3, current smoker for hip fracture risk was 1.5, mother’s hip fracture for hip fracture risk was 1.3, sister’s hip fracture for hip fracture risk was 1.6, prior spinal fracture for hip fracture risk was 1.5, prior fractures for spinal fracture risk was 3.2 for 1 prior fracture and 8.0 for 2 or more prior fractures, for nonspinal fracture risk was 1.6 for 1 prior fracture and 2.0 for 2 or more, each SD for BMD for spinal fracture was 2.0 and for nonspinal fracture was 1.5.; The relative risk came from the following sources:; Hemenway D, Colditz GA, Willett WC, Stampfer MJ, Speizer FE. Fractures and lifestyle: Effect of cigarette smoking, alcohol intake, and relative weight on the risk of hip and forearm fractures in middle-aged women. Am J Public Health 1988;78:1554.3189632; Cooper C, Wickham C. Cigarette smoking and the risk of age-related fractures. In: Wald NJ, Baron JA, eds. Smoking and hormone-related disorders. Oxford, New York: Oxford University Press, 1990;93.; Forsén L, Bjørndal A, Bjartveit K, . Interaction between current smoking, leanness, and physical inactivity in the prediction of hip fracture. J Bone Miner Res 1994;9:1671.7863817; Fox KM, Cummings SR, Powell-Threets K, Stone K. Family history and risk of osteoporotic fracture. Study of Osteoporotic Fractures Research Group. Osteoporos Int 1998;8:557.10326061; Wasnich RD, Davis JW, Ross PD. Spine fracture risk is predicted by nonspine fractures. Osteoporos Int 1994;4:1.; Note that these were not adjusted for each other so likely there was a lot of overlap in risk between the factors (which probably explains why the model overestimated risk so much in the validation studies). Also note that they did not always have RR for spinal and nonspinal factors separately and applied RRs for hip fractures to the other fractures. Then, because the model compared the risk in women who have the risk factor with the risk in the entire female population of the same age (some with and some without the risk factor), RRs needed to be adjusted for prevalence of the risk factor in the population. Using reported osteoporotic fracture rates in another reference (which is listed in what appears to be an error as the Geelong database, but is likely the next reference in the list that is specific to smoking), they estimated population prevalence of the risk factor (prior fracture) by age. Then, they determined the best-fitting regression equation (defined as R^2^=0.99) and used this equation to estimate population prevalence of prior fracture in women at various ages.; PThinness = ((0.021 * (AGE2)) - (2.6 * AGE) + 92.9)/100; PSmoking = (−0.001 * (AGE2) - 0.1 * AGE + 20.1)/100; PNonspinal fracture = (0.038 * (AGE2) - 3.4 * AGE + 83.5)/100; P1 Spinal fracture = (0.013 * (AGE2) - 0.8 * AGE + 12.3)/100; P_2 Spinal fractures = (0.015 * (AGE2) _ 1.5 * AGE + 39.9)/100; PSister with hip fracture= (0.004 * (AGE2) _ 0.4 * AGE + 9.5)/100; PMother with hip fracture= (−0.005 * (AGE2) + 0.9 * AGE - 31.8)/100
Describe how the model was developed (for example, in regards to modeling technique [e.g., survival or logistic modeling], predictor selection, and risk group definition): | Relative risks from background documents and prevalence estimates from databases were used to adjust the weights of predictors in the model, which then predicted fracture risk (which was itself a function of age). The exact model (combination of factors) was not described. Predictor selection was not described.
Describe whether and how the model was validated, either internally (e.g., bootstrapping, cross-validation, random split sample) or externally (e.g., temporal validation, geographical validation, different setting, different type of participants): | The model was validated externally using two large prospective cohort studies that were designed to study fractures, as noted above.
Describe the performance measures of the model, e.g., (re)calibration, discrimination, (re)classification, net benefit, and whether they were adjusted for optimism: | Calibration plot:; Predicted vs. observed risk for any one of three nonspinal fractures for every 2.5 percentile intervals of predicted risk from <2.5 to 10+ in two cohorts at 5 years in two cohorts (CaMOS and SOF); Predicted vs. observed risk interval for spinal fractures for every 2.5 percentile intervals of predicted risk from <2.5 to 10+ at 5 years in one cohort (CaMOS) and mean of 3.7 years in a second cohort (SOF)
Describe any participants who were excluded from the analysis: | NR
Describe missing data on predictors and outcomes as well as methods used for missing data: | NR
Risk of Bias | | Dev | Val
Were there a reasonable number of participants with the outcome?; Kaiser cohort: 59,772 new osteoporotic fractures; 20,028 hip fractures; 14,528 fracture events, including 3,412 hip fractures; Geelong cohort: 116 vertebral fractures | | Y for nonspinal fractures, N for vertebral | NA
4.1a Were there sufficient outcomes in racial and ethnic groups to assess model performance separately in these groups? (Model validation studies); NA, model performance was not reported separately by race. | | | NA
Were continuous and categorical predictors handled appropriately?; BMI was entered as a categorical variable, others were handled as expected (categorical or continuous). | | PY | NA
Were all enrolled participants included in the analysis? | | NI | NA
Were participants with missing data handled appropriately? | | NI | NA
Was selection of predictors based on univariable analysis avoided?; Regression coefficients (log of HR) from final models were used as weights. The relative risks were unadjusted for other variables. | | N | NA
Were complexities in the data (e.g., censoring, competing risks, sampling of controls) accounted for appropriately?; Not a competing risk model. Given that those with advanced age were in the relevant population, competing risk of death from any cause could be important. The study did specify a shorter prediction interval than 10-year predictors but did not report how many people died and were censored on that basis. | | N | NA
4.6a Was differential life expectancy in racial and ethnic groups accounted for using competing risk methods?; No race/ethnicity differences reported, not a competing risk model. | | NA | NA
Were relevant model performance measures evaluated appropriately?; Only calibration was reported. | | PN | NA
4.7a Were relevant model performance measures evaluated appropriately in racial and ethnic groups? How does model performance (calibration, discrimination) compare in racial and ethnic groups?; Model performance measures not reported separately in different racial and ethnic groups. | | N | NA
Were model overfitting and optimism in model performance accounted for?; No | | N | NA
Do predictors and their assigned weights in the final model correspond to the results from multivariable analysis?; There is no final model and no multivariate analysis | | N | NA
Risk of bias introduced by the analysis; (low/high/unclear) | High; Relative risks unadjusted for other variables. Small number of vertebral fractures, no information on missingness, only calibration was reported

Abbreviations: BMD=bone mineral density; BMI=body mass index; CaMOS=Canadian Multicentre Osteoporosis Study; Dev=development; FRC=Fracture Risk Calculator; HR=hazard ratio; N=no; NA=not available; NR=not reported; PN=probably no; PY=probably yes; RR=relative risk; SD=standard deviation; SOF=Study of Osteoporotic Fractures; Val=validation; Y=yes.

Appendix G Table 6 Fracture Risk Assessment Tool (FRAX) Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Step 1 and 2

Item | Response
Intended use of model: | Predict risk of developing an osteoporotic fracture
Participants including selection criteria and setting: | Patients age 40 years or older
Predictors (used in prediction modeling), including types of predictors (e.g., history, clinical examination, biochemical markers, imaging tests), time of measurement, specific measurement issues (e.g., any requirements/prohibitions for specialized equipment): | Demographic information and clinical and family history with or without BMD
Outcome to be predicted: | Risk of osteoporotic fracture (with a minimum of 3 years’ observation for studies with no specified prediction interval or a median or mean of 80% of the time in studies with a specified prediction interval)
Type of prediction study | Development and validation
Citations | Kanis JA on behalf of the World Health Organization Scientific Group (2007). Assessment of osteoporosis at the primary health care level. Technical Report. World Health Organization Collaborating Centre for Metabolic Bone Diseases, University of Sheffield, U.K. 2007: Printed by the University of Sheffield.; Kanis JA, Johansson H, Oden A, Dawson-Hughes B, Melton LJ 3rd, McCloskey EV. The effects of a FRAX revision for the USA. Osteoporos Int. 2010 Jan;21(1):35–40. doi: 10.1007/s00198-009-1033-8. Epub 2009 Aug 25. PMID: 19705047.19705047; Melton LJ 3rd, Crowson CS, O’Fallon WM. Fracture incidence in Olmsted County, Minnesota: comparison of urban with rural rates and changes in urban rates over time. Osteoporos Int. 1999;9(1):29–37. doi: 10.1007/s001980050113. PMID: 10367027.10367027

Abbreviations: BMD=bone mineral density; FRAX=Fracture Risk Assessment Tool; U.K.=United Kingdom.

Appendix G Table 7 Fracture Risk Assessment Tool (FRAX) Fracture Risk Model Development Cohort Assessment from Prediction From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 1 Participants

Item | Response
Describe the sources of data and criteria for participant selection: | Describe the sources of data and criteria for participant selection:; The 2007 WHO Technical Report describes that candidate risk factor data from 12 “prospectively studied” cohorts were used for model development. In total, these cohorts involved 59,644 participants, 1,141 hip fractures, and 2,218 osteoporotic fractures. Complete information was available from all cohorts for continuous variables of BMI and BMD, but not all cohorts had complete information on all dichotomous risk factors (for example, only 3/12 provided alcohol or arthritis predictor data).; Subsequently, in 2009 there was a publication describing a revision based on updated fracture incidence and mortality rates for the U.S. Those updated sources are described below. However, the methods behind model updating were exceedingly unclear (further discussed described in analysis domain).; Hip fracture (FRAX 3.0, U.S. model): National hospital discharge data for White non-Hispanic women and men in 2006 from the Healthcare Cost and Utilization Project, inpatient sample. Incidence in 1-year age intervals was calculated from U.S. Census projections for 2006. Fracture rates were assumed to be a constant ratio of those in White population for other groups (see Discussion in article for this).; Other osteoporotic fractures (FRAX 3.0, U.S. model): 1989–1991 Olmsted County, MN, data for fracture-specific incidence rates: 2,901 county residents age 35 years or older experienced 3,665 separate fractures during the 3-year period (2,362 experienced a single fracture). Population-based database study (Rochester Epidemiology Project), Mayo Clinic and common medical record system with 2 large, affiliated hospitals. The diagnoses and surgical procedures recorded in records were indexed. The index included the diagnoses made for outpatients seen in office or clinic consultations, emergency room visits, or nursing home care, as well as the diagnoses recorded for hospital inpatients, at autopsy examination or on death certificates. Medical records of the other providers who served the local population, most notably the Olmsted Medical Group, were also indexed. The complete (inpatient and outpatient) medical records were reviewed for all local residents with any diagnosis attributable to rubrics 800 through 829 in the International Classification of Diseases. Of 9,260 potential cases, record review was completed on all but 74 (0.8%) who had not provided an authorization for review of their medical records in accordance with a Minnesota privacy law that took effect in January 1997. All fractures were radiologically confirmed, but original radiographs were not available for review. Searched for fracture diagnoses made by any provider in any setting. Patients attended for complications of fractures prior to study period were excluded (other than this we do not see any discussion of inclusion and exclusion).; Mortality (FRAX 3.0, U.S. model): Age-, sex-, and race-specific death rates for 2004 (CDC Vital Statistics) in 1-year intervals for the White population and 5-year intervals for other groups (see Discussion for interval information). Mortality records were based on information reported on death certificates as completed by funeral directors, attending physicians, medical examiners, and coroners.
Risk of Bias | | Dev | Val
Were appropriate data sources used, e.g., cohort, RCT, or nested case-control study data?; Fracture data were retrospectively collected from routine care databases.; Hip fracture: Nationally representative, all-payer hospital discharge data. Based on the Burge paper cited in the 2009 revision development publication, hip fracture incidence rates were defined using primary ICD-9 codes 820.0x, 820.2x, 820.8x, closed only and excluding trauma-related cases according to E-codes. These outcome data will not be standardized/adjudicated in the same way that a prospective cohort study is doing this (they were also not longitudinally linked so cannot verify first vs. recurrent fracture).; Other osteoporotic fractures: Rochester Epidemiology Project. Population-based database study. The WHO Technical Report described the 12 contributing cohorts as prospective, but in fact these data were retrospectively collected from a routine care database. Unclear which trauma definitions were used for this outcome.; Mortality: National Vital Statistics Report | | PN | NA
Were all inclusions and exclusions of participants appropriate?; Very sparse reporting. We just learn from the Rochester data that patients who attended for complications of fractures prior to study period were excluded. Unlikely that these individuals were pharmacologically treated (e.g., bisphosphonates) given the time period. | | NI | NA
Was there sufficient representation of individuals from racial and ethnic groups in model development data?; Hip fracture incidence data were exclusively from White non-Hispanic populations in HCUP. This is confusing because hip fracture incidence is available by racial and ethnic group in this dataset. Fracture-specific incidence rates (other than hip) were taken from predominately White Olmstead County, MN, 1989–1991 sample. Another publication from the Rochester study reported that 99.1% of Olmstead County is White.; Mortality was race specific. Assumption is that the death hazard function is the only one that has true variation in race; the other outcomes are based on White participants exclusively (hip fracture) or an assumed ratio of events (other fractures).; In the original development paper, the racial and ethnic distribution of participants in the 12 cohorts was not reported. Cohorts were from Europe, Canada, Australian, Scandinavia, the U.S., and Japan. The one U.S. cohort is from Olmstead County, MN, which is 99.1% White. | | N | NA
Were racial and ethnic groups classified/categorized in a similar way in the development data and population to whom model is applied? (Validation studies only); The online tool provides options for “Caucasian,” Black, Hispanic, and Asian.; For the U.S.-based external validations noted in the 2007 WHO Technical Report, Study of Osteoporotic Fractures had 99.7% White participant population. Women’s Health Initiative used classifications of White (87%), Black, Hispanic, American Indian/Alaska Native, Asian/Pacific Islander.; It is unclear how ethnicity was handled or which calculator that American Indian/Alaska Native populations should use. | | PY/NI | NA
Risk of bias introduced by selection of participants; (low/high/unclear) | High; Exceedingly sparse reporting about inclusion and exclusion of participants (and whether inclusion and exclusion were consistent between hip and other fracture sources, which are different). Routine care databases used instead of prospective longitudinal cohorts in model revision.
Applicability
Describe included participants, setting and dates: | 2006 for hip fracture rates; 1989–1991 for other fracture rates—from predominately White Olmstead county, MN; 2004 for mortality: age, sex, and race specific
Concern that the included participants and setting do not match the review question; (low/high/unclear) | High; Data are quite dated. Hip fracture data use estimates from White populations only, despite separate reporting by race and that the WHO Technical Report acknowledged that fracture rates are heterogeneous in different populations and settings. The very restricted geographical sample of Olmstead County, MN, is also concerning in its applicability. The 2009 revision paper stated that FRAX 3.0 is calibrated to the U.S., but the other fractures equation is “calibrated” to Olmstead County, MN.

Abbreviations: BMD=bone mineral density; BMI=body mass index; CDC=Centers for Disease Control and Prevention; Dev=development; FRAX=Fracture Risk Assessment Tool; HCUP=Healthcare Cost and Utilization Project; ICD-9=International Statistical Classification of Diseases and Related Health Problems, 9^th^ Edition; MN=Minnesota; N=no; NI=no information; PN=probably no; PY=probably yes; RCT=randomized, controlled trial; U.S.=United States; Val=validation; WHO=World Health Organization.

Appendix G Table 8 Fracture Risk Assessment Tool (FRAX)Fracture Risk Model Development Cohort Assessment from Prediction From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 2 Predictors

Item | Response
List and describe predictors included in the final model, e.g., definition and timing of assessment: | 4 models:; Probability of hip fracture with BMD; Probability of hip fracture without BMD; Probability of other osteoporotic fracture with BMD; Probability of other osteoporotic fracture without BMD; Predictors: Age (continuous), BMD (continuous), BMI (continuous), parental history of hip fracture, prior fragility fracture, current smoking, oral glucocorticoids, rheumatoid arthritis, >2 units of alcohol/day.; Time horizon for prediction is 10 years, but initial and revision papers did not clearly report the time horizon of the contributing cohorts. Reported as 252,034 patient-years of followup for all 12 cohorts combined.; BMD was entered as a densitometer-specific BMD or as a T-score. The transformation to a T-score was derived from the NHANES III database for White females ages 20 to 29 years.
Risk of Bias | | Dev | Val
Were predictors defined and assessed in a similar way for all participants?; Pg 92 in the WHO Technical Report:; A history of current or past smoking was obtained by self-report. There was inadequate information to assess possible dose-response effects. The assessment of alcohol intake differed between cohorts and was converted into a daily intake expressed as units/day. A unit of alcohol is equivalent to 8 g in the United Kingdom, though varies somewhat in different countries. A family history was collected of any fracture in first-degree relatives. In addition, a family history of hip fracture was noted but was available only in three of the cohorts. Prior fracture history of each individual was documented, though the construct of the question varied, particularly the age from which a fracture had occurred. Use of oral glucocorticoids ever during a person’s lifetime (ever use) was used to characterize steroid exposure because all but three cohorts did not distinguish between ever use and current use. Neither the dose nor the duration of use was analyzed. The presence or absence of rheumatoid arthritis was by self-report. | | N | NA
Were predictor assessments made without knowledge of outcome data?; Fracture ascertainment was by self-report in 6 contributing cohorts and many of the contributing predictors are also by self-report (see item 2.1 above). Those with a prior fracture may be more aware of their risk factor status. | | N | NA
Are all predictors available at the time the model is intended to be used?; Theoretically, yes this could be done. But not all cohorts had complete information on all dichotomous risk factors. For example, history of smoking and alcohol use not available from Rochester. | | Y | NA
Did the model avoid using race and ethnicity as a proxy for a biological or other risk factor that could be measured with more accuracy or fidelity?; The WHO Technical Report noted a dramatic heterogeneity of age-adjusted and sex-adjusted incidence for hip fracture in various regions in the world and noted that in the U.S. a higher hip fracture rate in White individuals compared with Black individuals may be in part based on BMD differences, but that BMD differences do not explain lower rates in Hispanic and Asian populations. Because equations are available with and without BMD as an input, race/ethnicity was included for calibration rather than as a proxy. The report also noted that country-level differences in fracture risk may be largely attributable to differences in life expectancy because fracture risk is exponentially higher at older ages. Life expectancy differences were captured in the age-, sex-, and race-specific mortality data used in competing hazards model. But that mortality data are from 2004. On the other hand, pg 113 also states that “the frequency of falling is less in Black people than among Whites, as is the risk of fracture, which might indicate an important genetic factor related to falls. It was not possible to investigate other important skeletally-related factors such as the size and shape of bone or the microarchitecture of trabecular elements in cancellous bone.” There were some mixed messages about why race and ethnicity were included in the model. | | PY | NA
Was differential missingness of predictor data in racial and ethnic groups considered?; Not addressed. There is a lot of missing predictor data regardless of racial and ethnic group distribution (whole predictors are missing in many cohorts). There is not much missing opportunity for missing data in BIPOC populations because of very little representation. | | NI | NA
Risk of bias introduced by predictors or their assessment; (low/high/unclear) | High; Self-reported data for many predictors; because fracture assessment was also self-report in many cohorts, this is not independent. Those with a previous fracture might be more aware of their risk factors. Dramatic amount of missing predictor data among cohorts. Unknown followup time.
Applicability
Concern that the definition, assessment or timing of predictors in the model do not match the review question; (low/high/unclear) | High; Unknown followup time. BMD was transformed into a T-score using reference data from White women ages 20 to 29 years.

Abbreviations: BIPOC=Black, Indigenous, and People of Color; BMD=bone mineral density; BMI=body mass index; Dev=development; N=no; NHANES=National Health and Nutrition Examination Survey; NI=no information ; PY=probably yes; U.S.=United States; Val=validation; WHO=World Health Organization; Y=yes.

Appendix G Table 9 Fracture Risk Assessment Tool (FRAX) Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 3 Outcome

Item | | Response
Describe the outcome, how it was defined and determined, and the time interval between predictor assessment and outcome determination: | | 10-year probability of hip fracture or major osteoporotic fracture (hip, clinical spine, shoulder, or wrist). These sites are considered osteoporotic on the general definition that fractures from low-energy trauma can be osteoporotic and that a low-energy trauma would not give rise to a fracture in a healthy individual. Apparently, the coding of fracture sites as osteoporotic in the U.S. Is based on expert opinion.; Note that these equations predict both risk of first fracture and subsequent fracture.; Hip fracture (FRAX 3.0, U.S. model): National hospital discharge data for White non-Hispanic women and men in 2006 from the Healthcare Cost and Utilization Project, inpatient sample. Incidence in 1-year age intervals was calculated from U.S. Census projections for 2006. For other racial and ethnic groups, fracture rates were assumed to be a constant ratio of those in White populations (see Discussion in 2009 paper and pg 195 in original development paper).; Other osteoporotic fractures (FRAX 3.0, U.S. model): 1989–1991 Olmsted County, MN, data for fracture-specific incidence rates: 2,901 county residents age 35 or older experienced 3,665 separate fractures. These were used for the revised model with the exception of vertebral fracture. In the case of vertebral fracture, the version 2.0 estimates comprised not only symptomatic (i.e., clinical) vertebral fractures but also included those found incidentally during routine medical care. In the absence of robust empirical data for the incidence of clinically significant vertebral fractures, for the revised model, it has been assumed that the ratio of clinical vertebral fractures to hip fractures in the U.S. was the same as that from Malmo, Sweden, a methodology used for the construction of FRAX. The removal of incidental or nonclinical vertebral fractures in the revision will reduce the estimated 10-year probability of a major fracture.; Mortality (FRAX 3.0, U.S. model): Age-, sex-, and race-specific death rates for 2004 (CDC Vital Statistics) in 1-year intervals for the White population and 5-year intervals in other groups (see Discission for interval information). Mortality records were based on information reported on death certificates as completed by funeral directors, attending physicians, medical examiners, and coroners.
Risk of Bias | | | Dev | Val
Was the outcome determined appropriately?; Clinical vertebral fractures not actually measured; they were just assumed to be a ratio of hip fractures and that ratio was taken from Sweden. Ascertainment of vertebral fracture is problematic because not all vertebral fractures come to clinical attention. Individuals with more access to imaging are going to have a higher ascertainment rate of incidental findings.; For racial and ethnic groups other than White populations, hip fracture rates were not actually measured but were assumed to be a constant ratio of total fractures.; Fractures obtained by self-report in half the cohorts. | | | N | NA
Was a prespecified or standard outcome definition used?; Hip fracture: Based on the Burge paper cited in the 2009 revision development publication, hip fracture incidence rates were defined using primary ICD-9 codes 820.0x, 820.2x, 820.8x, closed only, and excluding trauma-related cases according to E-codes. In the original development paper, a mix of self-reported and verified fractures was used (see 3.4 for more detail).; Other osteoporotic fracture: ICD 800-829; In no dataset were outcomes adjudicated or standardized, so they are open to coding errors. | | | PN | NA
Were predictors excluded from the outcome definition?; However, equations predict either first or subsequent fracture, so event index bias is likely present. This is a problem because the coefficients for recurrent events are likely different than first events. After a first event, individuals may modify risk factors (use of steroids, alcohol, etc.) so the assumption that the weighting of the coefficients will be the same in first event/recurrent event individuals is flawed. This also ignores the natural history of fractures (small bones break first before hip or vertebral involvement). | | | Y | NA
Was the outcome defined and determined in a similar way for all participants?; In the main development paper, there is a mix of self-report and verification of outcomes from databases: Fracture ascertainment was undertaken by self-report in 6 cohorts (Sheffield, EVOS/EPOS, Hiroshima, Kuopio, EPIDOS, OFELY) or verified from hospital or central databases in 8 (Gothenburg, CaMos, DOES, Kuopio, Sheffield, EVOS/EPOS, Rochester, Rotterdam). However, the updated “calibration” is using Rochester and HCUP. | | | N | NA
3.4a Was differential followup or ascertainment of the outcome in racial and ethnic groups considered?; Followup of cohorts not reported, either overall or by group. | | | NI | NA
Was the outcome determined without knowledge of predictor information?; In some studies, fracture ascertainment was self-reported and predictor information was also self-reported. | | | N | NA
Was the time interval between predictor assessment and outcome determination appropriate?; 10-year horizon is reasonable; however, we do not know how long followup was in these cohorts from the primary paper. | | | N | NA
Were proxy outcomes avoided as the predicted outcome, where the meaning of the proxy may differ in racial and ethnic groups (label choice bias)?; Hip fracture is hospitalized hip fracture, which seems reasonable given that most hip fractures are hospitalized.; For other fractures, diagnosis codes are from a wide range of settings (inpatient, outpatient, office or clinic consultations, ER, nursing home care, autopsy exam or death certificates).; Fractures identified incidentally are likely to be differentially ascertained in populations with greater access to imaging. The model revision (3.0) focused on symptomatic vertebral fractures, which is a change from 2.0, which also included incidental findings. | | | PY | NA
Risk of bias introduced by the outcome or its determination; (low/high/unclear) | High; Many outcomes were not actually measured or verified. Predictor and outcome ascertainment not always independent. Followup time and loss to followup unknown. Event index bias was likely present because the model included both first and recurrent fractures; the weighting of coefficients in each situation was likely different.
Applicability
At what time point was the outcome determined: | | Unknown. 10-year prediction model but we do not know mean followup in years from these cohorts.
If a composite outcome was used, describe the relative frequency/distribution of each contributing outcome: | | Separate models for hip fracture and other fractures. Frequency of the Olmstead County other fractures reported in the Melton paper, but it is unclear how that is being used in the model revision. There are various distributions for each type of fracture reported in initial paper.
Concern that the outcome, its definition, timing or determination do not match the review question; (low/high/unclear) | | High; Followup/timing issues. Prediction of first and recurrent fracture in the same model is problematic.

Abbreviations: CaMOS=Canadian Multicentre Osteoporosis Study; CDC=Centers for Disease Control and Prevention; Dev=development; DOES=Dubbo Osteoporosis Epidemiology Study; ER=emergency room; FRAX=Fracture Risk Assessment Tool; HCUP=Healthcare Cost and Utilization Project; ICD=International Statistical Classification of Diseases and Related Health Problems; ICD-9=International Statistical Classification of Diseases and Related Health Problems, 9^th^ Edition; MN=Minnesota; N=no; NI=no information ; OFELY=Os des Femmes de Lyon; PN=probably no; PY=probably yes; U.S.=United States; Val=validation; Y=yes.

Appendix G Table 10 Fracture Risk Assessment Tool (FRAX) Fracture Risk Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 4 Analysis

Item | Response
Describe numbers of participants, number of candidate predictors, outcome events and events per candidate predictor: | 4 models: prediction of hip fracture with and without BMD; prediction of other osteoporotic fractures (excluding hip fracture), with and without BMD; (model without BMD); Age (continuous), BMI (continuous), parental history of hip fracture, prior fragility fracture, current smoking, oral glucocorticoids, rheumatoid arthritis, >2 units of alcohol/day.; +interactions with sex, age, quadratic of each variable (8*3); 24+8=32 (model with BMD); Age (continuous), BMD, BMI (continuous), parental history of hip fracture, prior fragility fracture, current smoking, oral glucocorticoids, rheumatoid arthritis, >2 units of alcohol/day.; +interactions with sex, age, BMD, quadratic of each variable (9*4); 36+9=45; These represent a conservative count of candidate predictors. WHO Technical Report pg 10 also states that contraceptive pills, age at menopause, age at menarche, hysterectomy, diabetes, and consumption of milk (6 additional predictors) were also considered, but it is unclear how far these were tested with interactions, so we omitted from the counts above. The events per variable were already pretty high so it probably makes little difference.; There is also an additional situation with other secondary osteoporosis, where if the field for RA was entered as no but yes for secondary osteoporosis, the same function as used for RA was applied to the situation where BMD is not entered. If BMD was entered, no additional risk was assumed in the presence of secondary osteoporosis since independence of BMD was uncertain.; In addition to using a calculator for the full score, simplified paper risk stratification tables are available.; Fundamentally, it is unclear how race was included in the model. Assuming stratified because it is not listed as a candidate predictor variable. Also, we assumed it is just the death hazard function using actual race-specific data—hip fractures in BIPOC populations were never measured; instead a correction factor was applied to the rate in White populations.
Describe how the model was developed (for example, in regards to modeling technique [e.g., survival or logistic modeling], predictor selection, and risk group definition): | Competing hazards. For each model, fracture and death as continuous hazard functions were computed using a Poisson regression. The effect of the candidate risk factor, age, and sex on the risk of any fracture, any osteoporotic fracture, and hip fracture alone was examined using Poisson regression models in each cohort separately. A Poisson model was chosen since it has greater power than logistic regression and can accommodate all information with variable durations of followup. In addition, time can be accommodated as an interaction term, and for some risk factors, relative risk may decrease with longer durations of observation. For each risk factor studied, covariates included current age and time since followup with and without BMD. Where appropriate, interaction terms were included. Outcome variables comprised any fracture, any osteoporotic fracture, and hip fracture alone. The results of different cohorts (men separate from women) were then merged using weighted coefficients and fixed effects model used.; WHO Technical Report pg 10: Risk factors recommended for use were selected on the basis of their international validity and evidence that the identified risk was likely to be modified by subsequent intervention (modifiable risk). Modifiable risk was validated from clinical trials (BMD, prior fracture, glucocorticoid use, secondary osteoporosis) or partially validated by excluding interactions of risk factors on therapeutic efficacy in large randomized intervention studies (e.g., smoking, family history, BMI). A further step was then to merge these meta-analyses of each risk factor so that account could be taken of the interdependence of the risk factors chosen and, therefore, the risk provided by any combination of risk factors with and without the additional use of BMD.; For each risk factor, all significant interactions (p<0.05) that were identified by meta-analysis were entered in the model (with age, time, sex, and the risk factor) with and without BMD. Interactions that were significant for hip fracture risk were also entered in the model for other osteoporotic fractures and also included in the model for death. Where interactions noted in the “mega-analyses” were no longer significant for hip fracture and other osteoporotic fractures, these were omitted in a stepwise manner by dropping the interaction with the largest p-value. For the death hazard, all significant interactions for fracture risk were included and thereafter omitted if appropriate in a stepwise manner, as described for the fracture hazard.
Describe whether and how the model was validated, either internally (e.g., bootstrapping, cross-validation, random split sample) or externally (e.g., temporal validation, geographical validation, different setting, different type of participants): | No internal validation noted.; Pg 205: evaluated in 11 independent cohorts. Study of Osteoporotic Fracture and WHI from U.S.
Describe the performance measures of the model, e.g., (re)calibration, discrimination, (re)classification, net benefit, and whether they were adjusted for optimism: | No calibration data; this is a major issue. Discrimination reported with AUC. No assessment of optimism.
Describe any participants who were excluded from the analysis: | Unclear.
Describe missing data on predictors and outcomes as well as methods used for missing data: | In original development dataset, many cohorts did not have measurement/data for all risk factors. Apparently, this was handled by setting the coefficient to 0 and calculating score on basis of available risk factors.
Risk of Bias | | Dev | Val
Were there a reasonable number of participants with the outcome?; 59,644 participants; 1,141 hip fractures; 2,218 osteoporotic fractures; Models without BMD had 32 candidate predictors (conservatively):; Hip fracture events per variable: 1,141/32= 35.6; Other fractures events per variable: 2,218/32= 69.3; Models with BMD had 45 candidate predictors (conservatively):; Hip fracture events per variable: 1,141/45= 23.4; Other fractures events per variable: 2,218/45= 49.3; Depending on how interactions were tested in other candidate predictors, the model with BMD may have had too few events per variable, but probably okay. | | PY
4.1a Were there sufficient outcomes in racial and ethnic groups to assess model performance separately in these groups? (Model validation studies); Outcomes per group not reported for validation (2007 WHO Report). Representation from racial and ethnic groups other than White is likely very limited.; The 2007 WHO Report provided AUCs for external validation cohorts, and 2 are from the U.S. that presumably are relevant to the U.S. equations. The Study of Osteoporotic Fractures has 99.7% White participant population. Women’s Health Initiative uses classifications of White (87%), Black (7%), Hispanic (3%), American Indian/Alaska Native (<1%), Asian/Pacific Islander (2%).; Model performance was not reported separately by group. | | NA | NA
Were continuous and categorical predictors handled appropriately?; BMI was entered as a categorical variable; others were handled as expected (categorical or continuous). | | Y | NA
Were all enrolled participants included in the analysis?; Unclear | | NI | NA
Were participants with missing data handled appropriately?; When predictor data were unavailable for a cohort, the coefficient was set to 0. Further detail in the WHO Technical Report, but for example only 3/12 cohorts provided alcohol or arthritis predictor data. | | N | NA
Was selection of predictors based on univariable analysis avoided?; Unclear. pg 93 of WHO Technical Report notes that at the individual cohort level, for any risk factor, covariates included current age and time since followup, with and without BMD, but this is not all of the risk factors, so there could be additional confounding. | | PN | NA
Were complexities in the data (e.g., censoring, competing risks, sampling of controls) accounted for appropriately?; Competing hazards. We do not know about loss to followup, so censoring in the fracture hazard functions is unknown. | | PY | NA
4.6a Was differential life expectancy in racial and ethnic groups accounted for using competing risk methods?; Competing hazards with mortality where mortality was age, sex, and race specific. | | PY | NA
Were relevant model performance measures evaluated appropriately?; No calibration data; this is a major issue. AUC reported. | | N | NA
4.7a Were relevant model performance measures evaluated appropriately in racial and ethnic groups? How does model performance (calibration, discrimination) compare in racial and ethnic groups?; No calibration data.; Discrimination (AUC) reported by cohort but not further by group. | | N | NA
Were model overfitting and optimism in model performance accounted for?; No. No mention of any resampling. | | N/NI | NA
Do predictors and their assigned weights in the final model correspond to the results from multivariable analysis?; Underlying equations/coefficients were not reported. | | NI | NA
Risk of bias introduced by the analysis; (low/high/unclear) | High; Unclear if all participants were used in analysis. When predictor data for a cohort were not available (not measured), the predictor was set to 0. High degree of missing predictor data in various cohorts. Selection of predictors not entirely multivariable. Calibration not assessed. Model optimism and optimism not addressed. Underlying equations not reported. Unclear exactly how race was being used—assuming stratified and that race is mainly affecting death hazard function. The 2 things that the analysis did right were keeping continuous measures continuous and using a competing risk model.

Abbreviations: AUC=area under the curve; BIPOC=Black, Indigenous, and People of Color; BMD=bone mineral density; BMI=body mass index; Dev=development; N=no; NA=not available; NI=no information; PN=probably no; PY=probably yes; RA=rheumatoid arthritis; U.S.=United States; Val=validation; WHI=Women’s Health Initiative; WHO=World Health Organization; Y=yes.

Appendix G Table 11 Fracture Risk Evaluation Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Step 1 and 2

Item | Response
Intended use of model: | Predict risk of developing a major osteoporotic fracture (primary outcome) or a hip fracture (secondary outcome)
Participants including selection criteria and setting: | Total population of Denmark age 45 years and older from 1998 to 2013
Predictors (used in prediction modeling), including types of predictors (e.g., history, clinical examination, biochemical markers, imaging tests), time of measurement, specific measurement issues (e.g., any requirements/prohibitions for specialized equipment): | Major osteoporotic fracture in women: 38 predictive baseline diagnoses from ICD-10 codes; Major osteoporotic fractures in men: 43 predictive baseline diagnoses from ICD-10 codes; Hip fractures in men or women: 28 predictive baseline diagnoses from ICD-10 codes
Outcome to be predicted: | 1 year risk of MOF or hip fracture
Type of prediction study | Development and validation
Citations | https://pubmed.ncbi.nlm.nih.gov/29924428/

Abbreviations: ICD-10=International Statistical Classification of Diseases and Related Health Problems, 10^th^ Edition; MOF=major osteoporotic fracture.

Appendix G Table 12 Fracture Risk Evaluation Model Development Cohort Assessment from Prediction From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 1 Participants

Item | Response
Describe the sources of data and criteria for participant selection: | The study used the Danish Civil Registration System to identify persons living in Denmark age 45 years or older on January 1, 2013, and extracted ICD-10 codes from the National Patient Register for those persons between 1998 and 2013
Risk of Bias | | Dev | Val
Were appropriate data sources used, e.g., cohort, RCT or nested case-control study data? | | Y | Y
Were all inclusions and exclusions of participants appropriate?; No exclusions reported | | Y | Y
Was there sufficient representation of individuals from racial and ethnic groups in model development data?; Race not reported | | NA | NA
Were racial and ethnic groups classified/categorized in a similar way in the development data and population to whom model is applied? (Validation studies only); The model does not include race | | NA | NA
Risk of bias introduced by selection of participants; (low/high/unclear) | Low
Applicability
Describe included participants, setting, and dates: | Development cohorts were likely predominantly White (race NR); applicability unclear to other races
Concern that the included participants and setting do not match the review question; (low/high/unclear) | Unclear

Abbreviations: ICD-10=International Statistical Classification of Diseases and Related Health Problems, 10^th^ Edition; NA=not applicable; Y=yes.

Appendix G Table 13 Fracture Risk Evaluation Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 2 Predictors

Item | Response
List and describe predictors included in the final model, e.g., definition and timing of assessment: | Predictors included age and health conditions listed in ICD-10 codes at level 2; ICD-10 codes coded for administrative information were excluded. This yielded 1,564 codes among women and 1,467 among men. If those codes with prevalence less than 0.1% were excluded (958 in women and 931 in men). Codes associated with the condition with a p-value ≥0.01 were retained in the model, leading to 38 predictive baseline diagnoses in women and 43 in men for major osteoporotic fracture and 32 codes for both women and men for hip fractures. Codes were categorized using the Charlson comorbidity index.; The prediction was for 1-year risk
Risk of Bias | | Dev | Val
Were predictors defined and assessed in a similar way for all participants? | | Y | Y
Were predictor assessments made without knowledge of outcome data? | | PY | PY
Are all predictors available at the time the model is intended to be used? | | Y | Y
Did the model avoid using race and ethnicity as a proxy for a biological or other risk factor that could be measured with more accuracy or fidelity?; Race is not included in the model | | NA | NA
Was differential missingness of predictor data in racial and ethnic groups considered?; Race is not included in the model | | NA | NA
Risk of bias introduced by predictors or their assessment; (low/high/unclear) | Low; Standardized diagnosis codes
Applicability
Concern that the definition, assessment, or timing of predictors in the model do not match the review question; (low/high/unclear) | Low; These predictors are relevant to what would be collected in primary care and included in electronic medical records.

Abbreviations: ICD-10=International Statistical Classification of Diseases and Related Health Problems, 10^th^ Edition; NA=not applicable.

Appendix G Table 14 Fracture Risk Evaluation Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 3 Outcome

Item | | Response
Describe the outcome, how it was defined and determined, and the time interval between predictor assessment and outcome determination: | | MOF defined as at least one code for a hip, clinical vertebral, wrist, or humerus fracture (ICD-10 codes: S120, S121, S122, S220, S221, S320, T08, S422, S423, S720, S721, S722, S525, S526) during 2013; Hip fracture defined as having at least one code (S720, S721, S722) during 2013
Risk of Bias | | | Dev | Val
Was the outcome determined appropriately?; The timing of diagnoses vs. fractures may not be clear in a small subset of persons who may have experienced fractures in late 2012 and diagnosed in 2013 but likely a very small number compared to the whole population.; Some MOF fractures may be open to coding errors, particularly for humerus and wrist. Hip fracture data may be more accurate given the devastating nature of this outcome | | | PN for MOF, PY for hip | PN for MOF, PY for hip
Was a prespecified or standard outcome definition used?; As noted above, MOF fractures may be open to coding errors, particularly for humerus and wrist. Hip fracture data may be more accurate given the devastating nature of this outcome | | | PN for MOF, PY for hip | PN for MOF, PY for hip
Were predictors excluded from the outcome definition?; Yes | | | Y | Y
Was the outcome defined and determined in a similar way for all participants? | | | Y | Y
3.4a Was differential followup or ascertainment of the outcome in racial and ethnic groups considered?; Followup not reported, either overall or by race but because the data come from national registries, censoring from attrition is not a concern | | | NA | NA
Was the outcome determined without knowledge of predictor information? | | | PY | PY
Was the time interval between predictor assessment and outcome determination appropriate?; 1-year horizon is short. | | | PN | PN
Were proxy outcomes avoided as the predicted outcome, where the meaning of the proxy may differ in racial and ethnic groups (label choice bias)?; The study did not create separate risk categories by race. | | | NA | NA
Risk of bias introduced by the outcome or its determination; (low/high/unclear) | Unclear for MOF, low for hip; Outcomes for MOF ascertained from routine care database, so these were not adjudicated or standardized so they are open to coding errors
Applicability
At what time point was the outcome determined: | | The outcome was determined over 1 year
If a composite outcome was used, describe the relative frequency/distribution of each contributing outcome: | | Unclear for the composite outcome of MOF
Concern that the outcome, its definition, timing or determination do not match the review question; (low/high/unclear) | | Low; The outcome of a fracture as indicated on a medical record seems broadly applicable.

Abbreviations: ICD-10=International Statistical Classification of Diseases and Related Health Problems, 10^th^ Edition; MOF=major osteoporotic fracture; N=no; PN=probably no; PY=probably yes; Y=yes.

Appendix G Table 15 Fracture Risk Evaluation Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 4 Analysis

Item | | Response
Describe numbers of participants, number of candidate predictors, outcome events and events per candidate predictor: | | Women; Development cohort N=647,103, MOF fractures: 8,890 (1.37%), hip fractures: 3,008 (0.46%); Validation cohort N=647,103, MOF fractures: 8,804 (1.36%), hip fractures: 3,047 (0.47%); Men; Development cohort N=600,567, MOF fractures: 3,345 (0.56%), hip fractures: 1,417 (0.24%); Validation cohort N=600,566, MOF fractures: 3,371 (0.56%), hip fractures: 1,405 (0.23%); Predictor variables were ICD-10 codes categorized by the Charlson comorbidity index: 38 for women for MOF, 43 for men for MOF, 32 for men and women for hip; All candidate predictors had prevalence of 0.1% of higher.; For women and MOF predictors, the highest prevalence was 8% for fracture of the forearm and dislocation/strains/sprains. For men and MOF predictors, the highest prevalence was for open head wound (10%). For women and hip predictors, the highest prevalence was 8% for fracture of the forearm. For men and hip predictors, the highest prevalence was for open head wound (10%). Detailed prevalence for predictor variables is reported in the development cohort study^477^
Describe how the model was developed (for example in regards to modelling technique (e.g., survival or logistic modelling), predictor selection, and risk group definition): | | All ICD-10 codes other than administrative ones were included, codes with prevalence lower than 0.1% were dropped, and codes with p values of 0.01 or more in logistic regression were retained in iterative analyses (all codes were included and then dropped based on p value).
Describe whether and how the model was validated, either internally (e.g., bootstrapping, cross validation, random split sample) or externally (e.g., temporal validation, geographical validation, different setting, different type of participants): | | The population was stratified by gender and then randomly split into development and validation cohorts
Describe the performance measures of the model, e.g., (re)calibration, discrimination, (re)classification, net benefit, and whether they were adjusted for optimism: | | 1. Produced ROC curve comparing the full model with the model only including age only and calculated area under the curve (AUC); calculated AUC separately for each age group; 2. Compared in a step diagram predicted with observed fracture risk with 95% CIs in 1% risk intervals (with one large interval for risk >5%) for MOFs and 0.3% risk intervals for hip fractures (with one large interval for risk >1.5%). The authors categorized risks above 5% for MOFs and 1.5% for hip fractures together because they judged that these risks are high enough to clearly indicate further diagnosis, and hence not require more detailed distinction.; 3. Evaluated the calibration of the logistic regression by calculating the Brier score.; Random split sample gives some information on overfitting
Describe any participants who were excluded from the analysis: | | None
Describe missing data on predictors and outcomes as well as methods used for missing data: | | None
Risk of Bias | | | Dev | Val
Were there a reasonable number of participants with the outcome?; Yes for women, probably yes for men for hip fractures | | | Y | Y
4.1a Were there sufficient outcomes in racial and ethnic groups to assess model performance separately in these groups? (Model validation studies); NA, model performance is not reported separately by race | | | NA | NA
Were continuous and categorical predictors handled appropriately?; All were categorical | | | Y | Y
Were all enrolled participants included in the analysis?; Yes | | | Y | Y
Were participants with missing data handled appropriately?; No missing participants | | | NA | NA
Was selection of predictors based on univariable analysis avoided?; Yes, all predictors entered into logistic regression and eliminated based on backwards selection | | | Y | NA
Were complexities in the data (e.g., censoring, competing risks, sampling of controls) accounted for appropriately?; Not a competing risk model. Competing risk of death from any cause could be important. The study did specify a short prediction interval (1 year) but did not report how many people died and were censored on that basis. No other censoring or sampling (full population) | | | PY | NA
4.6a Was differential life expectancy in racial and ethnic groups accounted for using competing risk methods?; NA, race was not reported | | | NA | NA
Were relevant model performance measures evaluated appropriately?; Calibration and discrimination reported | | | Y | NA
4.7a Were relevant model performance measures evaluated appropriately in racial and ethnic groups? How does model performance (calibration, discrimination) compare in racial and ethnic groups? | | | NA | NA
Were model overfitting and optimism in model performance accounted for?; Random split sample validation gives us some information on optimism. Performance was better in the validation cohort | | | Y | NA
Do predictors and their assigned weights in the final model correspond to the results from multivariable analysis?; Not specified but coefficients are reported in the supplement, other studies note using the coefficients without modification^162^ | | | PY | NA
Risk of bias introduced by the analysis; (low/high/unclear) | Unclear; censoring/competing risks based on death not reported

Abbreviations: AUC=area under the curve; ICD-10=International Statistical Classification of Diseases and Related Health Problems, 10^th^ Edition; MOF=major osteoporotic fracture; N=no; NA=not available; PN=probably no; PY=probably yes; OC=receiver-operating characteristic; U Y=yes.

Appendix G Table 16 Garvan Fracture Risk Calculator Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Step 1 and 2 Specification of Review Question

Item | Response
Intended use of model: | Predict risk of developing an osteoporotic fracture
Participants including selection criteria and setting: | Patients age 40 years or older
Predictors (used in prediction modeling), including types of predictors (e.g., history, clinical examination, biochemical markers, imaging tests), time of measurement, specific measurement issues (e.g., any requirements/prohibitions for specialized equipment): | Demographic information and clinical and family history with or without BMD
Outcome to be predicted: | Risk of osteoporotic fracture (with a minimum of 3 years’ observation for studies with no specified prediction interval or a median or mean of 80% of the time in studies with a specified prediction interval)
Type of prediction study | Development only
Citations | Nguyen ND, Frost SA, Center JR, Eisman JA, Nguyen TV. Development of a nomogram for individualizing hip fracture risk in men and women. Osteoporos Int. 2007 Aug;18(8):1109–17. doi: 10.1007/s00198-007-0362-8. Epub 2007 Mar 17. PMID: 17370100.17370100; Nguyen ND, Frost SA, Center JR, Eisman JA, Nguyen TV. Development of prognostic nomograms for individualizing 5-year and 10-year fracture risks. Osteoporos Int. 2008 Oct;19(10):1431–44. doi: 10.1007/s00198-008-0588-0. Epub 2008 Mar 7. PMID: 18324342.18324342; Both articles are writeups of the development of the nomogram. The earlier publication (2007) presented results for a nomogram that included age, BMD, prior fractures, and prior falls for hip fractures. The 2008 publication, although published later, appears to address an earlier stage in the development of the nomogram, where the authors were trying to compare nomogram results with BMD vs. body weight and predict any osteoporotic fracture (barring morphometric and some others).

Abbreviations: BMD=bone mineral density.

Appendix G Table 17 Garvan Fracture Risk Calculator Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 1 Participants

Item | Response
Describe the sources of data and criteria for participant selection: | The authors used risk and fracture data from the Dubbo Osteoporosis Epidemiology Study (DOES), a cohort study designed specifically to study osteoporosis. All men and women age 60 years or older living in Dubbo, a city (400 km north west of Sydney, Australia), were invited to participate in an epidemiological study. Risk factors and BMD came from these individuals and T-scores were calculated for the BMD, based on “young normal” BMD was obtained from a sample of 52 Australian men and women ages 20 to 32 years. These values were identical to those in the LUNAR Caucasian database (the study collected BMD using LUNAR machines).
Risk of Bias | | Dev | Val
Were appropriate data sources used, e.g., cohort, RCT or nested case-control study data?; Data source explicitly designed for osteoporosis epidemiology. | | PY | NA
Were all inclusions and exclusions of participants appropriate?; No exclusions; all residents invited to participate. | | NA | NA
Was there sufficient representation of individuals from racial and ethnic groups in model development data?; 98.6% were Caucasian and 1.4% indigenous Aboriginal. | | N | NA
Were racial and ethnic groups classified/categorized in a similar way in the development data and population to whom model is applied? (Validation studies only); The model validation cohorts were predominantly or exclusively White but the model does not include race. | | NA | NA
Risk of bias introduced by selection of participants; (low/high/unclear) | Low; Appropriate data sources, no exclusions
Applicability
Describe included participants, setting and dates: | Development cohort was almost entirely White, applicability unclear to other races.
Concern that the included participants and setting do not match the review question; (low/high/unclear) | Unclear; Development and validation cohorts broadly representative of White women but not other women.

Abbreviations: BMD=bone mineral density; Dev=development; DOES=Dubbo Osteoporosis Epidemiology Study; N=no; NA=not available; PY=probably yes; RCT=randomized, controlled trial; Val=validation.

Appendix G Table 18 Garvan Fracture Risk Calculator Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 2 Predictors

Item | Response
List and describe predictors included in the final model, e.g., definition and timing of assessment: | In the 2007 (hip fracture) article, the risk factors included; Age; BMD; Prior fracture; Prior fall; Quadricep strength was included in an initial model but found to only add 1.5% to the predictive power and was dropped; Information on age, anthropomorphic data, and lifestyle factors were collected at baseline by interview by a nurse using a structured questionnaire (https://asbmr.onlinelibrary.wiley.com/doi/full/10.1359/JBMR.050520). BMD (g/cm^2^) was measured at the lumbar spine and femoral neck by DXA using a LUNAR DPX-L densitometer.; The 2008 article (any fracture (any first osteoporotic fracture)) tested weight instead of BMD and found that having BMD made the nomogram more accurate than having weight (AUC of 0.75 instead of 0.72 for women and 0.74 for men.; 5-year or 10-year followup were the time points for prediction.
Risk of Bias | | Dev | Val
Were predictors defined and assessed in a similar way for all participants?; Routine care database so consistency of data collection for items such as family history-taking is unknown. Unclear how missing data were handled. | | PY
Were predictor assessments made without knowledge of outcome data? | | PY
Are all predictors available at the time the model is intended to be used? | | PY
Did the model avoid using race and ethnicity as a proxy for a biological or other risk factor that could be measured with more accuracy or fidelity?; Race and ethnicity were not used in the model | | Y
Was differential missingness of predictor data in racial and ethnic groups considered?; Not applicable, race was not used | | NA
Risk of bias introduced by predictors or their assessment; (low/high/unclear) | Low; Appears that predictors were collected in the same way.
Applicability
Concern that the definition, assessment or timing of predictors in the model do not match the review question; (low/high/unclear) | Low; These predictors are relevant to what would be collected in primary care.

Abbreviations: AUC=area under the curve; BMD=bone mineral density; Dev=development; DXA=dual-energy x-ray absorptiometry; NA=not available; PY=probably yes; Val=validation; Y=yes.

Appendix G Table 19 Garvan Fracture Risk Calculator Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 3 Outcome

Item | | Response
Describe the outcome, how it was defined and determined, and the time interval between predictor assessment and outcome determination: | | Fractures occurring during the study period were identified for residents of the Dubbo local government area through radiologists’ reports from the two centers providing X-ray services. Fractures due to major trauma, underlying disease, those of digits, skull, or cervical spine, or morphometric vertebral fractures were not included. Hip fractures were the focus on the 2007 article, and first osteoporotic low trauma and nonpathological fractures were considered the primary outcome of the 2008 study. In the 2008 article, 92% of those who had fractures in the DOES agreed to have BMD. Fractures were only included if the report of fracture was definite and, on interview, had occurred with minimal trauma (fall from standing height or less). Fractures more than 3 months before study entry were not considered in the analysis. Fractures were classified as hip, vertebrae (symptomatic), wrist, metacarpal, humerus, scapula, clavicle, distal femur, proximal tibia, patella, pelvis, and sternum.
Risk of Bias | | | Dev | Val
Was the outcome determined appropriately?; The timing of eligible fractures is unclear, it appears that some fractures may have taken place up to 3 months before study entry and measurement of BMD, from the description of eligible fractures. Fractures came from radiologists’ reports | | | PN
Was a prespecified or standard outcome definition used? | | | PY for clinical fractures, NA for morphometric and other fractures (digits, skull, cervical spine)
Were predictors excluded from the outcome definition? | | | Y
Was the outcome defined and determined in a similar way for all participants? | | | PY
3.4a Was differential followup or ascertainment of the outcome in racial and ethnic groups considered?; Followup not reported, either overall or by race. Could possibly have differential censoring in different populations, but the vast majority of the population was White. | | | N
Was the outcome determined without knowledge of predictor information? | | | Y
Was the time interval between predictor assessment and outcome determination appropriate?; Median duration of followup was 13 years | | | Y
Were proxy outcomes avoided as the predicted outcome, where the meaning of the proxy may differ in racial and ethnic groups (label choice bias)? | | | Y
Risk of bias introduced by the outcome or its determination; (low/high/unclear) | Low; In the 2007 study, 8% of sample with fractures did not have BMD measurements, but the Ns are not clearly described. From a total of 1,581 men and 2,095 women age ≥60 years, data were analyzed from 1,358 women and 858 men who had been followed up between 1989 and 2004, which means only 60% of the overall sample was retained.
Applicability
At what time point was the outcome determined: | | Median 13-year followup
If a composite outcome was used, describe the relative frequency/distribution of each contributing outcome: | | Not applicable.
Concern that the outcome, its definition, timing or determination do not match the review question; (low/high/unclear) | | Unclear; The outcome of a fracture by radiologist report seems broadly applicable, but the exclusion of morphometric and other fractures may reduce the applicability of the instrument to all fractures

Abbreviations: BMD=bone mineral density; Dev=development; DOES=Dubbo Osteoporosis Epidemiology Study; N=no; NA=not available; PN=probably no; PY=probably yes; Val=validation; Y=yes.

Appendix G Table 20 Garvan Fracture Risk Calculator Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 4 Analysis

Item | | Response
Describe numbers of participants, number of candidate predictors, outcome events and events per candidate predictor: | | 1,581 men and 2,095 women age ≥60 years in Dubbo. Of these, 1,028 women and 740 men (48%) were included in the 2007 analysis and 1,358 women (of these 96 women and 31 men sustained at least one hip fracture) and 858 men (60%) in the 2008 analysis (of these 426 women and 149 men sustained at least one fracture).; For hip fracture, N events per candidate predictor is not reported, but HRs for women are: for 5+ years of age, HR: 1.95 (95% CI, 1.70 to 2.22); each prior fracture HR: 2.89 (95% CI, 1.85 to 4.50); falls in the past 12 months, each fall HR: 1.42 (95% CI, 0.93 to 2.16); FNBMD for −0.12 g/cm^2^ HR: 2.62 (95% CI, 2.21 to 3.11). For men, for 5+ years of age, HR: 2.31 (95% CI, 1.76 to 3.03); each prior fracture HR: 4.23 (95% CI, 2.96 to 6.04); falls in the past 12 months, each fall HR: 1.40 (95% CI, 1.20 to 1.62); FNBMD for −0.12 g/cm^2^ HR: 2.61 (95% CI, 1.95 to 3.50).; For any fracture, for women, events per candidate predictor were not reported, but HRs for women were: for 5+ years of age, HR: 1.43 (95% CI, 1.34 to 1.53); each prior fracture HR: 2.06 (95% CI, 1.87 to 2.26); falls in the past 12 months, each fall HR: 1.23 (95% CI, 1.10 to 1.38); FNBMD for −0.12 g/cm^2^ HR: 1.68 (95% CI, 1.55 to 1.82). For men, for 5+ years of age, HR: 1.67 (95% CI, 1.48 to 1.88); each prior fracture HR: 2.92 (95% CI, 2.43 to 3.52); falls in the past 12 months, each fall HR: 1.38 (95% CI, 1.13 to 1.69); FNBMD for −0.12 g/cm^2^ HR: 1.62 (95% CI, 1.43 to 1.83).
Describe how the model was developed (for example, in regards to modeling technique [e.g., survival or logistic modeling], predictor selection, and risk group definition): | | For both hip and any fractures, Bayesian model average helped identify the most parsimonious models. 1,000 subsamples, each with 150 subjects, of the entire sample were repeatedly resampled (with replacement) and analyzed. For hip fracture, the most parsimonious one included age, femoral neck BMD, prior fracture, previous fall, and quadriceps strength, but the last one was dropped because it only added 1.5% to the predictive power.
Describe whether and how the model was validated, either internally (e.g., bootstrapping, cross-validation, random split sample) or externally (e.g., temporal validation, geographical validation, different setting, different type of participants): | | The model was not validated externally. The nomograms were internally validated by the bootstrap method.
Describe the performance measures of the model, e.g., (re)calibration, discrimination, (re)classification, net benefit, and whether they were adjusted for optimism: | | For hip fracture, the study report maximum calibration error (2% for women, 7% for men), and c-index of 0.85 (unclear if overall or for men or women). No visual depiction of calibration.; For any fracture, max calibration error (less than 1%) and a graph of predicted to observed probabilities were shown. Although the c-index is mentioned in methods, it is not reported in the results.
Describe any participants who were excluded from the analysis: | | NR
Describe missing data on predictors and outcomes as well as methods used for missing data: | | NR, see above, 48% to 60% retained and missing data not described clearly.
Risk of Bias | | | Dev | Val
Were there a reasonable number of participants with the outcome?; PN for hip fractures, unclear for any fractures | | | PN | NA
4.1a Were there sufficient outcomes in racial and ethnic groups to assess model performance separately in these groups? (Model validation studies); NA, model performance is not reported separately by race | | | NA | NA
Were continuous and categorical predictors handled appropriately?; BMI was entered as a categorical variable, others were handled as expected (categorical or continuous) | | | PY | NA
Were all enrolled participants included in the analysis? | | | N
Were participants with missing data handled appropriately? | | | NI | NA
Was selection of predictors based on univariable analysis avoided?; Regression coefficients (log of HR) from final models were used as weights. The relative risks were unadjusted for other variables. | | | PY | NA
Were complexities in the data (e.g., censoring, competing risks, sampling of controls) accounted for appropriately?; Not a competing risk model. Unclear how other complexities were addressed. | | | NI | NA
4.6a Was differential life expectancy in racial and ethnic groups accounted for using competing risk methods?; No race/ethnicity differences reported, not a competing risk model | | | NA | NA
Were relevant model performance measures evaluated appropriately?; Both calibration and validation measures not reported for both models | | | PN | NA
4.7a Were relevant model performance measures evaluated appropriately in racial and ethnic groups? How does model performance (calibration, discrimination) compare in racial and ethnic groups?; Model performance measures not reported separately in different racial and ethnic groups, but overwhelming majority was White. | | | N | NA
Were model overfitting and optimism in model performance accounted for?; Yes | | | Y | NA
Do predictors and their assigned weights in the final model correspond to the results from multivariable analysis?; Difficult to map weights from final model to multivariate analysis for the hip fracture model, not possible in the any fracture model because individual coefficients not reported | | | PY | NA
Risk of bias introduced by the analysis; (low/high/unclear) | High; Large missingness, no explanation of effects, some but not all performance measures

Abbreviations: BMD=bone mineral density; BMI=body mass index; CI=confidence interval; Dev=development; FNBMD=femoral neck bone mineral density; HR=hazard ratio; N=no; NA= not available; NI= no information; NR=not reported; PN=probably no; PY=probably yes; Val=validation; Y=yes.

Appendix G Table 21 QFracture Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Steps 1 and 2 Specification of Review Question

Item | Response
Intended use of model: | Predict risk of developing an osteoporotic fracture
Participants including selection criteria and setting: | Patients age 40 years or older
Predictors (used in prediction modeling), including types of predictors (e.g., history, clinical examination, biochemical markers, imaging tests), time of measurement, specific measurement issues (e.g., any requirements/prohibitions for specialized equipment): | Demographic information and clinical and family history with or without BMD
Outcome to be predicted: | Risk of osteoporotic fracture (with a minimum of 3 years observation for studies with no specified prediction interval or a median or mean of 80% of the time in studies with a specified prediction interval)
Type of prediction study | Development and validation
Citations | Hippisley-Cox J, Coupland C. Derivation and validation of updated QFracture algorithm to predict risk of osteoporotic fracture in primary care in the United Kingdom: prospective open cohort study. BMJ. 2012 May 22;344:e3427. doi: 10.1136/bmj.e3427. PMID: 22619194.22619194

Abbreviations: BMD=bone mineral density.

Appendix G Table 22 QFracture Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 1 Participants

Item | Response
Describe the sources of data and criteria for participant selection: | QResearch database. U.K. nationally representative primary care electronic database. All QResearch practices that have been using EMIS computer system for 1 year were included. Random split sample validation of two thirds of practices in derivation set and one third in validation set.; Patients ages 30 to 100 years at study entry date and registered with eligible practices at some time between 1 January 1993 and 1 October 2011. Patients needed to have 1 year of complete data in the medical record. Patients with a previous recorded fracture were eligible for inclusion in the cohort.
Risk of Bias | | Dev | Val
Were appropriate data sources used, e.g., cohort, RCT or nested case-control study data?; Routine care database. Authors described this as a “prospective open cohort study,” but these data were not being collected with a defined research protocol. | | N | NA
Were all inclusions and exclusions of participants appropriate?; No exclusions based on missing values. Imputation for missing values for alcohol, smoking, and BMI.; Includes those with prior fracture (approximately 2% of population). | | Y | NA
Was there sufficient representation of individuals from racial and ethnic groups in model development data?; Based on Table 1, it appears that self-assigned ethnic origin was only recorded in ~45% of derivation and validation cohorts. and those with ethnic origin not reported are combined with White participants in later analysis. Missing information about race or ethnicity (or anything else) was associated with fewer contacts with the healthcare system. This study required only a minimum of 1 year of data in the medical record.; If White participants have higher fracture risk (as suggested in Table 3), this may result in overstated risk in those with nonrecorded ethnicity, unless they are also White. However, the reference category includes White and nonrecorded ethnicity, so the true estimate of increased fracture risk in Whites in this dataset is unknown. 2011 Census data show that 87% of the United Kingdom is White, yet ~95% are categorized as White or not recorded in Table 1.; The percentage of participants from other ethnic groups is small, but given the extremely large size of the database, there are probably sufficient absolute numbers. | | PY | NA
Were racial and ethnic groups classified/categorized in a similar way in the development data and population to whom model is applied? (Validation studies only); White or not recorded, Indian, Pakistani, Bangladeshi, Other Asian, Caribbean, Black African, Chinese, Other. Two thirds of QResearch practices assigned to derivation dataset and one third to validation dataset so underlying population classifications are the same. | | NA | Y
Risk of bias introduced by selection of participants; (low/high/unclear) | High; Routine care database is not ideal as data are not collected with standardized research protocol. Further, self-assigned race and ethnicity data are not available from ~55% of population.
Applicability
Describe included participants, setting and dates: | Primary care practices in the United Kingdom. The website refers to this version of the tool as QFracture-2016, so another update occurred after this main publication and March 2019 is listed as the last update date on the website. It is likely they are not adding new variables, but coefficients are probably getting updated—somewhat unclear.
Concern that the included participants and setting do not match the review question; (low/high/unclear) | Low; Recent and nationally representative population of primary care patients in the United Kingdom. This Q product does not include post-code specific deprivation score, making it more transportable to the United States.

Abbreviations: BMI=body mass index; Dev=development; N=no; PY=probably yes; RCT=randomized, controlled trial; U.K.=United Kingdom; Val=validation; Y=yes.

Appendix G Table 23 QFracture Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 2 Predictors

Item | Response
List and describe predictors included in the final model, e.g., definition and timing of assessment: | This is the list of candidate risk factors; followed by notes of whether it was retained or combined in final model.; 2009 risk factors: (24); - Age at study entry (in single years); - Body mass index (continuous); - Smoking status (non-smoker, ex-smoker, light smoker (<10 cigarettes/day), moderate smoker (10-19 cigarettes/day), heavy smoker (≥20 cigarettes/day); - Parental history of osteoporosis or hip fracture in a first-degree relative (binary variable; yes/no); - Cardiovascular disease (binary variable; yes/no); - Alcohol intake (none, trivial (<1 unit/day), light (1-2 units/day), medium (3-6 units/day), heavy (7-9 units/day), very heavy (>9 units/day); - Rheumatoid arthritis (binary variable; yes/no)—combined with SLE in final model; - Type 2 diabetes (binary variable; yes/no); - Asthma (binary variable; yes/no)—combined with COPD in final model; - History of falls (binary variable; yes/no); - Chronic liver disease (binary variable; yes/no); - Gastrointestinal conditions likely to result in malabsorption (that is, Crohn’s disease, ulcerative colitis, celiac disease, steatorrhoea, blind loop syndrome at baseline) (binary variable; yes/no); - Other endocrine conditions (thyrotoxicosis, primary or secondary hyperparathyroidism, Cushing’s syndrome) at baseline (binary variable; yes/no); - At least two prescriptions for systemic corticosteroids in the six months preceding baseline (binary variable; yes/no); - At least two prescriptions for tricyclic antidepressants in the six months preceding baseline (binary variable; yes/no); - At least two prescriptions for hormone replacement therapy (in women) in the six months preceding baseline (binary variable; yes/no)—estrogen-only HRT in final model; - Menopausal symptoms in women (binary variable; yes/no)—considered but not included in final model; New risk factors examined: (20); - Self-assigned ethnic origin (White or not recorded, Indian, Pakistani, Bangladeshi, other Asian, Black African, Black Caribbean, Chinese, other including multiethnic); - Previous fracture (hip, vertebral, proximal humerus, or distal radius fracture) (binary variable; yes/no); - Use of other antidepressants apart from tricyclic antidepressants (at least two prescriptions in previous six months) (binary variable; yes/no)—combined with tricyclic antidepressants in final model; - Chronic obstructive pulmonary disease (binary variable; yes/no)—combined with asthma in final model; - Epilepsy (binary variable; yes/no)—combined with anticonvulsants in final model; - At least two prescriptions of anticonvulsants in the 6 months preceding baseline (binary variable; yes/no); - Dementia (binary variable; yes/no); - Parkinson’s disease (binary variable; yes/no); - Any cancer (binary variable; yes/no); - Systemic lupus erythematosus (binary variable; yes/no)—combined with RA in final model; - Chronic renal disease (binary variable; yes/no); - Type 1 diabetes (binary variable; yes/no); - Care or nursing home residence (binary variable; yes/no)—included in equations for men only; All values of these variables were restricted to those recorded in the person’s electronic healthcare record before baseline, except for body mass index, alcohol intake, and smoking status. Values recorded closest to study entry date and recorded before the diagnosis of osteoporotic fracture were used (or for patients who did not develop a fracture, before censoring). Assumed that if there was no recorded value of a diagnosis, prescription, or family history, then the patient did not have that exposure.; 10-year followup was the primary time point for prediction, but risk equations were also derived for each year from 1 to 15 years so users could select time period for evaluation.
Risk of Bias | | Dev | Val
Were predictors defined and assessed in a similar way for all participants?; Routine care database, so consistency of data collection for items such as family history-taking is unknown. If there was no recorded value of a diagnosis, prescription, or family history, then the patient was categorized as not having that exposure. | | PN | NA
Were predictor assessments made without knowledge of outcome data? | | Y | NA
Are all predictors available at the time the model is intended to be used? | | Y | NA
Did the model avoid using race and ethnicity as a proxy for a biological or other risk factor that could be measured with more accuracy or fidelity?; It appears that ethnic origin was included for calibration. Table 3 reports adjusted HRs for fractures by ethnic origin where all groups had a statistically significant lower incidence compared with the reference category of White or not recorded. No other rationale for inclusion of race or ethnicity is provided. It is interesting that while race and ethnicity were probably included for calibration, calibration was not reported separately by group. | | PY | NA
Was differential missingness of predictor data in racial and ethnic groups considered?; Missingness of data is not reported by race and ethnicity. However, multiple imputation was used for missing values for alcohol, smoking, and BMI. | | PY | NA
Risk of bias introduced by predictors or their assessment; (low/high/unclear) | High; Because this is a routine care database, we cannot guarantee that predictors were defined as assessed in the same way for all participants. The handling of missing data through multiple imputation is a strength of the approach.
Applicability
Concern that the definition, assessment or timing of predictors in the model do not match the review question; (low/high/unclear) | Low; These predictors are relevant to what would be collected in primary care and included in electronic medical records.

Abbreviations: BMI=body mass index; COPD=chronic obstructive pulmonary disease; Dev=development; HR=hazard ratio; HRT= hormone replacement therapy; PN=probably no; PY=probably yes; RA=rheumatoid arthritis; SLE=systemic lupus erythematosus; Val=validation; Y=yes.

Appendix G Table 24 QFracture Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 3 Outcome

Item | | Response
Describe the outcome, how it was defined and determined, and the time interval between predictor assessment and outcome determination: | | Two primary outcomes: osteoporotic fracture defined as a diagnosis of a hip, vertebral, proximal humerus, or distal radius fracture during followup and diagnosis of hip fracture, where these fractures were recorded either on the general practice record or the linked death record.
Risk of Bias | | | Dev | Val
Was the outcome determined appropriately?; From a routine care database. Outcome determination methods not specified by protocol so open to coding errors. However, the recording of hip fracture is probably fine given how devastating this outcome is it is likely to have been recorded. Mortality and hospital data were true record linkages but otherwise, it is incumbent on the GP to record other incidents in the medical record. | | | PY for hip; N for osteo | NA
Was a prespecified or standard outcome definition used?; From routine care database, so these are not adjudicated or standardized so they will be open to coding errors. Again, hip fracture is probably okay given how devastating this outcome is. | | | PY for hip; N for osteo | NA
Were predictors excluded from the outcome definition?; However, equations are predicting either first or subsequent fracture so event index bias is likely present. This is a problem because the coefficients for recurrent events are likely different than first events. After a first event, individuals may modify risk factors (use of steroids, alcohol, etc.) so the assumption that the weighting of the coefficients will be the same in first event/recurrent event individuals is flawed. This also ignores the natural history of fractures (small bones break first before hip or vertebral involvement). | | | Y | NA
Was the outcome defined and determined in a similar way for all participants?; Predictors and outcome taken from same routine care database for everyone; however, we do not know the consistency of imaging or other diagnostics used across the population. | | | NI | NA
3.4a Was differential followup or ascertainment of the outcome in racial and ethnic groups considered?; Followup not reported, either overall or by group. Considering the context of national healthcare system we assumed followup overall is good, but we do not know % dying, which could generate differential censoring in different populations. | | | NI | NA
Was the outcome determined without knowledge of predictor information? | | | Y | NA
Was the time interval between predictor assessment and outcome determination appropriate?; 10-year horizon is reasonable. Developers also created different models for different horizons of followup. | | | Y | NA
Were proxy outcomes avoided as the predicted outcome, where the meaning of the proxy may differ in racial and ethnic groups (label choice bias)?; It is unclear whether incidental findings were included. Incidental findings were likely higher in populations with more access to imaging. For other fractures, diagnosis codes were from a wide range of settings (inpatient, outpatient, office or clinic consultations, ER, nursing home care, autopsy exam or death certificates). Fractures identified incidentally were likely to be differentially ascertained in populations with greater access to imaging. The model revision (3.0) focused on symptomatic vertebral fractures, which is a change from 2.0, which included incidental findings. | | | NI | NA
Risk of bias introduced by the outcome or its determination; (low/high/unclear) | High; Outcomes ascertained from routine care database, so these are not adjudicated or standardized so they will be open to coding errors. Unknown followup or percentage of individuals dying/getting censored.
Applicability
At what time point was the outcome determined: | | 10 years is the primary time horizon, but equations were also developed for other horizons and these are available on the website.
If a composite outcome was used, describe the relative frequency/distribution of each contributing outcome: | | NR
Concern that the outcome, its definition, timing or determination do not match the review question.; (low/high/unclear) | | Low; The outcome of a fracture as indicated on a medical record seems broadly applicable.

Abbreviations: Dev=development; ER=emergency room; GP=general practitioner; N=no; NI=no information ; NR=not reported; PY=probably yes Val=validation; Y=yes.

Appendix G Table 25 QFracture Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 4 Analysis

Item | | Response
Describe numbers of participants, number of candidate predictors, outcome events and events per candidate predictor: | | 4 equations: men and women separately and osteoporotic and hip fracture separately; Derivation: 3,142,673 (59,628 with prior fracture); 59,772 new osteo fractures; 20,028 hip fractures; Validation: 1,583,373 (27,907 with prior fracture); 28,685 new osteo fractures; 9,610 hip fractures; Candidate predictors: 44 from predictors section plus 3 fractional polynomial terms for each model (below)=47; Above RFs plus fractional polynomial terms for age and BMI; - Osteo fracture: (age/10)2; (age/10)3; BMI/10)-1; - Hip fracture: (age/10)2; (age/10)3; (BMI/10)-2; Events per candidate predictor:; 59,772 new osteo fractures/47=1,272; 20,028 hip fractures/47=426
Describe how the model was developed (for example, in regards to modeling technique [e.g., survival or logistic modeling], predictor selection, and risk group definition): | | Cox proportional hazards model: Separate for osteoporotic fracture and hip fracture and separate for men and women. Robust variance estimates used to allow for clustering of patients with general practices. Graphical methods used to check assumption of proportional hazards. Fractional polynomials used to model nonlinear risk associations with continuous variables (age and BMI).; Predictors from the previous QFracture were carried forward for evaluation (except for Townsend deprivation score, which is not further explained), and risk factors recommended in 2012 NICE report were evaluated for inclusion. They retained the predictor if it was significant (threshold not reported that we can see). For example, care home residency was retained in the equation for men only because it was only statistically significant in this population.; Clinically similar variables were tested to determine if they could be appropriately combined. They ran a model with separate terms for each variable; if two similar variables were both significant (hazard ratio <0.8 or >1.20, and p<0.01), they were compared with a direct significance test. If this comparison was not significant (at P <0.01) and if the hazard ratios were within 0.2 of each other, the variables were combined into a new variable (for example, either rheumatoid arthritis or systemic lupus erythematosus).
Describe whether and how the model was validated, either internally (e.g., bootstrapping, cross-validation, random split sample) or externally (e.g., temporal validation, geographical validation, different setting, different type of participants): | | Random split sample validation (420 in derivation, 207 in validation). This can tell us about reproducibility of coefficients but does not tell us anything about transportability—for that it would have been preferred to split the sample by geography or time.
Describe the performance measures of the model, e.g., (re)calibration, discrimination, (re)classification, net benefit, and whether they were adjusted for optimism: | | Calibration plot: predicted vs. observed risk at 10 years for every tenth of predicted risk (Figure 2); Overall performance measure: R2; Discrimination: D statistic, AUC; Reclassification in patients reclassified from high to low risk (low to high) compared to 2009 algorithm; Sensitivity for the top 10% of risk predicting a new fracture; Internal split sample validation gives us some information about optimism.
Describe any participants who were excluded from the analysis: | | None
Describe missing data on predictors and outcomes as well as methods used for missing data: | | Loss to followup unknown—given that this is part of the national health system, it is of less concern. We do not know, however, how many people died, which would give us more information about percentage censored. ~25% with missing BMI data, ~12% with missing smoking data, ~55% with missing self-assigned race or ethnicity, ~28% with no alcohol data
Risk of Bias | | | Dev | Val
Were there a reasonable number of participants with the outcome?; 59,772 new osteo fractures/47=1,272; 20,028 hip fractures/47=426 | | | Y | NA
4.1a Were there sufficient outcomes in racial and ethnic groups to assess model performance separately in these groups? (Model validation studies); At least 100 participants with the outcome is recommended.; The numbers do not appear adequate for all categories except White or not recorded or Indian (these include Pakistani, Bangladeshi, Other Asian, Caribbean, Black African, Chinese, and other ethnic group). | | | PN | NA
Were continuous and categorical predictors handled appropriately?; Age and BMI were entered continuously.; Smoking status and alcohol were categorized.; (Giving partial credit) | | | PY | NA
Were all enrolled participants included in the analysis? | | | Y | NA
Were participants with missing data handled appropriately?; Multiple imputation | | | Y | NA
Was selection of predictors based on univariable analysis avoided?; Regression coefficients (log of HR) from final models were used as weights. | | | Y | NA
Were complexities in the data (e.g., censoring, competing risks, sampling of controls) accounted for appropriately?; Not a competing risk model. Given that those with advanced age are in the relevant population, competing risk of death from any cause could be important. However, there is the option to specify a shorter prediction interval, which would reduce this issue. We do not know how many people died and were censored on that basis. | | | N | NA
4.6a Was differential life expectancy in racial and ethnic groups accounted for using competing risk methods?; As above | | | N | NA
Were relevant model performance measures evaluated appropriately? | | | Y | NA
4.7a Were relevant model performance measures evaluated appropriately in racial and ethnic groups? How does model performance (calibration, discrimination) compare in racial and ethnic groups?; Model performance measures not reported separately in different racial and ethnic groups. | | | N | NA
Were model overfitting and optimism in model performance accounted for?; Random split sample validation gives us some information on optimism. More ideal would have been a geographic or temporal split. More efficient would have been bootstrapping or other form of resampling. | | | Y | NA
Do predictors and their assigned weights in the final model correspond to the results from multivariable analysis? | | | Y | NA
Risk of bias introduced by the analysis; (low/high/unclear) | High; Primary issue is that a competing risk model was not used, which could be more appropriate because of risk of death in older age groups. We do not know the extent of the issue because we do not know the % who died during followup. Model overfitting and optimism were not accounted for; however, this dataset is huge with high events per variable so not downgrading on that. Performance in different racial and ethnic groups cannot be evaluated because performance was not reported by group, and the number of outcome events was limited in many groups. Both calibration and discrimination were reported, which is a strength.

Abbreviations: AUC=area under the curve; BMI =body mass index; Dev=development; HR=hazard ratio; N=no; NICE=National Institute for Health and Care Excellence; PN=probably no; PY=probably yes; RF=risk factor; Val=validation; Y=yes.

Appendix G Table 26 Women’s Health Initiative Fracture Risk Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Step 1 and 2 Specification of Review Question

Item | Response
Intended use of model: | Predict risk of developing an osteoporotic fracture
Participants including selection criteria and setting: | Patients age 40 years or older
Predictors (used in prediction modeling), including types of predictors (e.g., history, clinical examination, biochemical markers, imaging tests), time of measurement, specific measurement issues (e.g., any requirements/prohibitions for specialized equipment): | Demographic information and clinical and family history with or without BMD
Outcome to be predicted: | Risk of osteoporotic fracture (with a minimum of 3 years observation for studies with no specified prediction interval or a median or mean of 80% of the time in studies with a specified prediction interval)
Type of prediction study | Development and validation
Citations | Robbins J, Aragaki AK, Kooperberg C, Watts N, Wactawski-Wende J, Jackson RD, LeBoff MS, Lewis CE, Chen Z, Stefanick ML, Cauley J. Factors associated with 5-year risk of hip fracture in postmenopausal women. JAMA. 2007 Nov 28;298(20):2389–98. doi: 10.1001/jama.298.20.2389. PMID: 18042916.18042916

Abbreviations: BMD=bone mineral density.

Appendix G Table 27 Women’s Health Initiative Fracture Risk Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 1 Participants

Item | Response
Describe the sources of data and criteria for participant selection: | The authors developed the algorithm using the population of postmenopausal women ages 50 to 79 years from 40 clinical centers participating in the observational study component of the Women’s Health Initiative (93,676), then validated it using the sample of women enrolled in clinical trials (68,132). Participants in the clinical trial tended to be younger (mean, 62.7 years), taller (161.1 cm [63.42 in]), heavier (76.1 kg [169.1 lb]), less likely to be White (81.5% were White), with a lower proportion of the clinical trial reporting fair to poor health (8.3%), history of fracture after age 55 years (13.1%), either parent breaking a hip (11.8%), and corticosteroid use (0.1%) than in the observational studies. They were also more likely to be physically inactive (19.2%), currently smoking (7.9%), and taking treatment for diabetes (4.8%). The women in the clinical trial had volunteered to participate, were taking trial-required medications, and were following diet plans. The authors tested the addition of BMD to the model by testing ROC curves for the algorithm, DXA, or both in a subset of women with BMD measurements (10,750).
Risk of Bias | | Dev | Val
Were appropriate data sources used, e.g., cohort, RCT or nested case-control study data?; Trial data were more restrictive in inclusion and participations were randomized to treatments that may have affected the outcome. | | PY | NA
Were all inclusions and exclusions of participants appropriate?; No exclusions; all residents invited to participate. Exclusions not described in the manuscript, but per Wikipedia, “included medical conditions that would be predictive of a survival of less than three years, possessing characteristics or conditions that may diminish study adherence (e.g., substance abuse, mental illness, or cognitive impairment), or concurrent enrollment in another randomized controlled clinical trial.” | | NA | NA
Was there sufficient representation of individuals from racial and ethnic groups in model development data?; In the observational study, 94% were White, 2.4% were Black, 1.0% were Hispanic, and the rest were a combination of American Indian, Asian/Pacific Islander, and unknown. Race/ethnicity for the trial and the subset with BMD not provided. | | N | NA
Were racial and ethnic groups classified/categorized in a similar way in the development data and population to whom model is applied? (Validation studies only); The model validation cohort’s race/ethnicity data were not reported. | | Unclear | NA
Risk of bias introduced by selection of participants; (low/high/unclear) | Unclear; Appropriate data sources, no exclusions, but validation cohort race/ethnicity NR.
Applicability
Describe included participants, setting and dates: | Development cohort were predominantly White, applicability unclear to other races.
Concern that the included participants and setting do not match the review question; (low/high/unclear) | Unclear; Development and validation cohorts broadly representative of White women but probably not other women.

Abbreviations: BMD=bone mineral density; Dev=development; DXA=dual-energy x-ray absorptiometry; N=no; NA=not available; NR=not reported; PY=probably yes; RCT=randomized, controlled trial; ROC=receiver operator characteristic; Val=validation.

Appendix G Table 28 Women’s Health Initiative Fracture Risk Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 2 Predictors

Item | Response
List and describe predictors included in the final model, e.g., definition and timing of assessment: | Age per each year: 1/2 point per year >50; Self-reported health; Fair or poor vs. excellent: 3 points; Good vs. excellent: 1 point; Very good vs. excellent: 0 point; Height per each inch:1/2 point per inch >64; Weight per each pound: 1 point per 25 lb <200; Fracture on or after age 55 y; Not applicable vs. no: 0 point; Yes vs. no: 2 points; Race/ethnicity: White= 3 point; Physical activity, metabolic equivalent tasks (METs): 1 point; Smoking status; Current vs. never: 3 points; Parent broke hip, yes vs. no: 1 point; Corticosteroid use, yes vs. no: 3 points; Use of hypoglycemic agent, yes vs. no: 2 points; 5-year followup was the time point for prediction.
Risk of Bias | | Dev | Val
Were predictors defined and assessed in a similar way for all participants?; Routine care database so consistency of data collection for items such as family history-taking is unknown. Unclear how missing data were handled. | | PY | NA
Were predictor assessments made without knowledge of outcome data? | | PY | NA
Are all predictors available at the time the model is intended to be used? | | PY | NA
Did the model avoid using race and ethnicity as a proxy for a biological or other risk factor that could be measured with more accuracy or fidelity?; Race and ethnicity were not used in the model | | N | NA
Was differential missingness of predictor data in racial and ethnic groups considered?; Not applicable, race was not used | | N | NA
Risk of bias introduced by predictors or their assessment; (low/high/unclear) | Low; Appears that predictors were collected in the same way.
Applicability
Concern that the definition, assessment or timing of predictors in the model do not match the review question; (low/high/unclear) | Low; These predictors are probably more intensive than routine collection in primary care (e.g., metabolic equivalents) but are feasible.

Abbreviations: Dev=development; N=no; NA=not applicable; PY=probably yes; Val=validation.

Appendix G Table 29 Women’s Health Initiative Fracture Risk Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 3 Outcome

Item | | Response
Describe the outcome, how it was defined and determined, and the time interval between predictor assessment and outcome determination: | | Incidence of hip fracture was collected using a standardized medical update questionnaire completed by all participants. These were collected every 6 months for those in the clinical trial and annually for those in the observational study until the study closed between October 2004 and March 2005. Hip fractures were self-reported and then confirmed both locally and centrally by review of medical records including x-ray and surgical reports.; It appears that non-self-reported fractures were not being counted but likely with hip fractures; this may not have been a big number because it is such a big event.
Risk of Bias | | | Dev | Val
Was the outcome determined appropriately?; Self-report confirmed by medical reports (X-ray and surgery). | | | PY | NA
Was a prespecified or standard outcome definition used? | | | PY | NA
Were predictors excluded from the outcome definition? | | | Y | NA
Was the outcome defined and determined in a similar way for all participants? | | | PY | NA
3.4a Was differential followup or ascertainment of the outcome in racial and ethnic groups considered?; All of the participants, including those who agreed to being followed up after dropping out of the interventions, are used in this analysis. Participants with missing data in their predictor variables, and 5.5% (n=5,161) of the participants who did not have a hip fracture within 5 years or did not have 5 years of followup were excluded from the logistic regression model. Unclear how many had missing data. The participants who were excluded from the logistic regression model tended to be minorities (28% vs. 16%). | | | N | NA
Was the outcome determined without knowledge of predictor information? | | | Y | NA
Was the time interval between predictor assessment and outcome determination appropriate?; For the observational study, women were followed for a mean (SD) of 7.6 (1.7) years (median, 7.9 years; interquartile range, 6.9–8.9 years); The mean (SD) followup time for women in the clinical trial was 8.0 (1.7) years; (median, 8.0 years; interquartile range, 7.4–9.0 years). | | | PN | NA
Were proxy outcomes avoided as the predicted outcome, where the meaning of the proxy may differ in racial and ethnic groups (label choice bias)?; White race used as proxy | | | N | NA
Risk of bias introduced by the outcome or its determination; (low/high/unclear) | High; Reasonable duration (although not 10 years), standardized outcome collection, but N excluded for missing predictors unclear. Potential differential attrition by race, and race is part of the model.
Applicability
At what time point was the outcome determined: | | Mean of 8 years
If a composite outcome was used, describe the relative frequency/distribution of each contributing outcome: | | Not applicable
Concern that the outcome, its definition, timing, or determination do not match the review question; (low/high/unclear) | | Low; Broadly applicable population

Abbreviations: Dev=development; N=no; NA=not applicable; PN=probably no; PY=probably yes; SD=standard deviation; Val=validation; Y=yes.

Appendix G Table 30 Women’s Health Initiative Fracture Risk Model Development Cohort Assessment From Prediction Model Study Risk-of-Bias Assessment Tool—Domain 4 Analysis

Item | | Response
Describe numbers of participants, number of candidate predictors, outcome events and events per candidate predictor: | | Developed using the observational study component of the Women’s Health Initiative (93,676 women, 1,132 hip fractures, 0.16%), then validated it using the sample of women enrolled in clinical trials (68,132 women, 791 hip fractures, 0.14%); Candidate predictors (11 listed below): Number of hip fractures; Age per each year: 1/2 point per year >50: 50–59: 102; 60–69: 359; 70–79: 671; Self-reported health: NR; Height per each inch: NR; Weight per each pound: NR; Fracture on or after age 55 y: 313; Race/ethnicity: White: 1,064; Physical activity, metabolic equivalent tasks (METs): 0: 181; <5: 241; 5–12: 292; ≥12: 395; Smoking status; Current: 565; Parent broke hip, yes: 240; Corticosteroid use, yes: 41; Use of hypoglycemic agent, yes vs. no: NR
Describe how the model was developed (for example, in regards to modeling technique [e.g., survival or logistic modeling], predictor selection, and risk group definition): | | Potential risk factors were identified from the literature and fit 1 at a time in a Cox proportional hazards model, adjusting for age and race/ethnicity. Variables that achieved a modest level of statistical significance (p<0.25), based on the score test were included in the pool of variables used to select a final prediction model. Tenfold cross-validation was used to determine the optimal number of predictors; the training data were divided into 10 parts. Nine-tenths of the data were used to select the best model with k predictors by fitting a hazard regression model, which uses stepwise addition and deletion and considers interactions and nonparametric (spline) terms. For each model, they then evaluated the prediction log-likelihood on the remaining one-tenth of the data that were not used to select the model. For each k, they added the predicted log likelihoods to obtain a prediction score. The value of k that minimized the cross-validated prediction score was taken to be the optimal number of predictors. A hazard regression model with K* predictors was then selected from the entire WHI observational study data. The probability of a hip fracture within 5 years was then calculated using a multivariate logistic regression model fit on the WHI observational study dataset, using the K* variables from the earlier exercise
Describe whether and how the model was validated, either internally (e.g., bootstrapping, cross-validation, random split sample) or externally (e.g., temporal validation, geographical validation, different setting, different type of participants): | | Receiver operator characteristic (ROC) curves and the corresponding area under the curve (AUC) in the clinical trial data were used to evaluate how the prediction model preformed on the test data. The 95% confidence intervals (CIs) were obtained by bootstrapping
Describe the performance measures of the model, e.g., (re)calibration, discrimination, (re)classification, net benefit, and whether they were adjusted for optimism: | | The Hosmer-Lemeshow statistic was used to ascertain lack of fit (calibration) of this model.
Describe any participants who were excluded from the analysis: | | Participants with missing data in their predictor variables, and 5.5% (n=5,161) of the participants who did not have a hip fracture within 5 years or did not have 5 years of followup were excluded from the logistic regression model.
Describe missing data on predictors and outcomes as well as methods used for missing data: | | See above, not described clearly for predictors vs. outcomes.
Risk of Bias | | | Dev | Val
Were there a reasonable number of participants with the outcome?; PN for hip fractures | | | PN | NA
4.1a Were there sufficient outcomes in racial and ethnic groups to assess model performance separately in these groups? (Model validation studies); Race included in the model, but majority of the population was White, and attrition was skewed to minority participants | | | PN | NA
Were continuous and categorical predictors handled appropriately?; BMI was entered as a categorical variable, others were handled as expected (categorical or continuous) | | | PY | NA
Were all enrolled participants included in the analysis?; Some dropout as described above | | | N | NA
Were participants with missing data handled appropriately?; No adjustment | | | N | NA
Was selection of predictors based on univariable analysis avoided? | | | PY | NA
Were complexities in the data (e.g., censoring, competing risks, sampling of controls) accounted for appropriately?; Not a competing risk model. Unclear how other complexities were addressed. | | | NI | NA
4.6a Was differential life expectancy in racial and ethnic groups accounted for using competing risk methods?; No | | | N | NA
Were relevant model performance measures evaluated appropriately?; Only Hosmer-Lemeshow reported over for development cohort. For the validation cohort, a table comparing observed and predicted fractures against threshold values (T-score above and below −2.5, WHI algorithm score above and below 21 points) | | | N | NA
4.7a Were relevant model performance measures evaluated appropriately in racial and ethnic groups? How does model performance (calibration, discrimination) compare in racial and ethnic groups?; Model performance measures not reported separately in different racial and ethnic groups. | | | N | NA
Were model overfitting and optimism in model performance accounted for?; Yes | | | Y | NA
Do predictors and their assigned weights in the final model correspond to the results from multivariable analysis?; Unclear | | | PY | NA
Item | Response
Risk of bias introduced by the analysis; (low/high/unclear) | High; Differential racial missingness not addressed, performance measures not fully reported other than Hosmer-Lemeshow for calibration

Abbreviations: AUC=area under the curve; BMI =body mass index; CI=confidence interval; Dev=development; MET=metabolic equivalents; n=number; N=no; NA= not available; NI=no information; NR=not reported; PN=probably no; PY=probably yes; ROC=receiver operator characteristic; WHI=Women’s Health Initiative; Val=validation; Y=yes.