# Appendix F Contextual Questions 1, 5, 6, and 7

## F.1 Contextual Question 1

What is the evidence from modeling studies about the effectiveness of risk screening strategies that use different ages at which to start and stop screening and different screening intervals?

Contextual evidence comes from a small number of publications that have attempted to identify appropriate screening intervals based on the time in which it takes individuals to transition to osteoporosis or a certain fracture risk threshold. This range varied across studies.

A publication using healthy postmenopausal women age 65 years or older from the Study of Osteoporotic Fractures evaluated the time for 10 percent of women to develop osteoporosis across the various BMD categories;^317^ it found that baseline T-score is the most important determinant of BMD testing intervals, with results suggesting that the times for 10 percent of women to develop osteoporosis are as follows: 16.8 years (95% CI, 11.5 to 24.6) for women with normal BMD (T-score, −1.00 or higher), 17.3 years (95% CI, 13.9 to 21.5) for women with mild osteopenia (T-score, −1.01 to −1.49), 4.7 years (95% CI, 4.2 to 5.2) for women with moderate osteopenia (T-score, −1.50 to −1.99), and 1.1 years (95% CI, 1.0 to 1.3) for women with advanced osteopenia (T-score, −2.00 to −2.49).^317^ Within a given T-score range, the estimated time for 10 percent of women to transition from osteopenia to osteoporosis was longer for women with younger age and for those taking estrogen at baseline. For women with moderate osteopenia at baseline, the estimated BMD testing interval was 5.6 years (95% CI, 4.9 to 6.4) for women age 67 years compared with 3.2 years (95% CI, 2.6 to 3.9) for women age 85 years. Also for women with moderate osteopenia, the estimated BMD testing interval for past or never-users of estrogen was shorter, 4.3 years (95% CI, 3.9 to 4.8), than for women with current estrogen use, 6.9 years (95% CI, 5.7 to 8.4).^317^

Using an absolute risk-based prognostic model with a sample of nonosteoporotic women and men older than age 60 years from the Dubbo Osteoporosis Epidemiology study, authors found that current age and BMD T-score could be used to estimate the optimal time to repeat BMD testing for both men and women.^451^ For example, the time for women age 60 years with a normal BMD to reach a 10 percent risk of sustaining a fracture or developing osteoporosis was 8.9 years (90% CI, 6.7 to 10.6); it was 2.7 years (90% CI, 2.3 to 3.1) for women age 80 years.

A third study provided contextual evidence for identifying the time to transition to fracture (rather than osteoporosis) in younger postmenopausal women ages 50 to 64 years.^452^ In a study of women from the Women’s Health Initiative with a baseline BMD, investigators estimated the time for 1 percent of women to sustain a hip or clinical vertebral fracture and for 3 percent of women to sustain a MOF.^452^ Women were followed for up to 11 years after the initial BMD. Similar to findings of studies estimating time to transition to osteoporosis, the study found that age and baseline T-score were associated with the estimated time for 1 percent of women to transition to fracture. For women without osteoporosis at baseline (T-score >−2.50), the estimated times for 1 percent of women to transition to hip or clinical vertebral fracture were 12.8 years (95% CI, 8 to 20.4) for ages 50 to 54 years, 11.7 years (95% CI, 6.9 to 20) for ages 55 to 59 years, and 7.6 years (95% CI, 4.8 to 12.1) for ages 60 to 64 years. For all women with osteoporosis at baseline (T-score ≤−2.50), the time interval for 1 percent of women ages 50 to 64 years to transition to hip or clinical vertebral fracture was 3.0 years (95% CI, 1.3 to 7.1). There were similar findings for MOF.

## F.2 Contextual Question 5

What are the implications of using fixed-fracture risk thresholds for decisions regarding stepwise screening or treatment?

The predictive and diagnostic accuracy of risk assessment instruments are described in detail in KQs 2a and 2c of this update evidence report. The most reported accuracy outcome was AUC, which represents the average value of sensitivity and specificity over all possible values. However, for risk assessments to be usable in clinical practice to inform shared decision making about who to screen with DXA or who to treat with pharmacotherapy, risk thresholds must be established. Although many studies included for KQ 2a and KQ 2c reported AUC, fewer studies reported the sensitivity or specificity of specific risk thresholds. In considering the role of risk assessments in clinical practice, an understanding of the origin of commonly cited thresholds and advantages and disadvantages of fixed or variable risk thresholds is warranted. Nearly all articles that discussed intervention thresholds focused on FRAX because it is the most ubiquitous and widely studied risk assessment tool. Thus, this CQ will focus exclusively on the impact of using fixed-fracture risk thresholds with FRAX and challenges related to a mechanistic application of thresholds versus their use as part of shared decision making.

### Origins of FRAX Fixed Threshold for Intervention

For primary fracture prevention in the United States, the Bone Health and Osteoporosis Foundation (formerly known as the National Osteoporosis Foundation [NOF]) recommends treatment for individuals with osteoporosis, prior fragility fracture, or in persons with low bone mass (i.e., formerly called osteopenia) who have a 10-year hip fracture risk of at least 3 percent or a 10-year MOF risk of at least 20 percent based on FRAX.^84^ The hip fracture risk threshold was selected based on a U.S.-specific economic analysis of cost-effectiveness from a societal perspective sponsored by the NOF and that assumed one-step BMD screening, use of generic bisphosphonates, a relative risk reduction of 35 percent for all fracture types, and a willingness-to-pay threshold of $60,000 per quality-adjusted life-year gained.^80,^ ^85^ The MOF threshold was derived from the hip fracture threshold through a complex transformation.^88^ These thresholds (3% hip, 20% MOF) are pervasively cited in the literature and have formed the basis of intervention thresholds used in many countries other than the United States but have never been evaluated in trials. Some countries have used a similar methodology to derive their own country-specific intervention thresholds for considering treatment. Such studies have factored in reimbursement considerations, access to DXA, local health economic assessments, and willingness to pay for osteoporosis-related care.^88^ Thus, intervention thresholds that are often recommended for use in clinical practice are based on a variety of factors beyond clinical benefit or harms, including economic considerations.

The prevalence of estimated FRAX risks above the 3 percent hip/20 percent MOF risks based on 2013–2014 U.S. NHANES data are summarized in Table F.2-1.^453^ Across all adults age 50 years or older, 81 percent will have estimated fracture risks below these thresholds for both fracture types, 8 percent will have an estimated risk above both the hip fracture and MOF thresholds, 11 percent will have an estimated hip risk above the threshold alone, and less than 1 percent will have an estimated MOF risk above the threshold alone.^453^ If these prevalences are applied to the entire U.S. population based on 2020 Census data, the absolute number of persons with estimated fracture risk at or above these thresholds can be estimated (Table F.2-1). If a lower risk threshold is used, more people would be above the threshold, and even small changes have the potential to affect a large absolute number of persons.^454^ Similarly, the use of a higher threshold (such as what might result from an increase in the price of medications or willingness-to-pay assumption) would result in fewer persons above the threshold.

As the use of fracture risk assessments has become more common, experts continue to emphasize that decisions about treatment should not be based solely on fracture risk and that clinical judgment and shared decision making should continue to play a key role in decision making.^20,^ ^80^ An overlay mechanistic application of thresholds can lead to clinically illogical scenarios, for example, offering treatment to someone just above the threshold but not to someone with the same clinical risks who might fall just below the threshold because they are a few years younger. Further, the sensitivity of the currently established thresholds to the price of medication may be of concern for implementing fixed thresholds for individual clinical decision making. Although much has been published on establishing treatment thresholds, relatively less has been published concerning thresholds for screening with DXA.

Table F.2-1 Prevalence of High Fracture Risk Among Adults Age 50 or Older Based on NHANES Data (NHANES, 2013–2014)^453^ Extrapolated to the Size of the U.S. Population Based on 2020 Census Data^455^

Characteristics | Proportion With 10-Year Hip Fracture Risk 3% or Higher | Number of Persons | Proportion With 10-Year MOF Risk 20% or Higher | Number of Persons
All persons | 22.6%^*^ | 26,088,315 | 9.6%^*^ | 11,081,762
Men | 16.6%^*^ | 8,948,369 | 2.3%^*^ | 1,239,834
Women | 27.4%^*^ | 16,858,997 | 15.5%^*^ | 9,537,024
Ages 50 to 59 | 6.7% | 2,864,685 | 2.9% | 1,239,938
Ages 60 to 69 | 11.3% | 4,250,776 | 6.4% | 2,407,519
Ages 70 to 79 | 38.6% | 8,630,918 | 16.1% | 3,599,943
Age 80 or older | 71.6% | 9,094,026 | 27.4% | 3,480,116
Non-Hispanic White | 25.5%^*^ | 20,970,366 | 11.6%^*^ | 9,539,461
Non-Hispanic Black | 4.8%^*^ | 589,696 | Unstable estimate | NA
Hispanic | 10.7%^*^ | 1,530,225 | 1.8%^*^ | 257,421
Non-Hispanic Asian | 16.0%^*^ | 991,740 | Unstable estimate | NA

* Age-adjusted estimate.

Note: We calculated the number of persons by multiplying the number of persons in the age/sex/race category by the proportion with a 10-year FRAX fracture risk equal to or more than the 3% (hip) or 20% (MOF) risk. The number of persons represent the ceiling of potential persons who would be candidates for screening or treatment as some will not be eligible for various clinical or other reasons.

Abbreviations: MOF=major osteoporotic fracture; NA=not available; NHANES=National Health and Nutrition Examination Survey; U.S.=United States.

### Types of Intervention Thresholds

The intervention threshold described in the previous section is considered a fixed threshold because it is applied to men and women irrespective of age. Fixed thresholds are the easiest to implement in clinical practice. However, if one considers that persons with prior fragility fracture should be treated (regardless of BMD), then a fixed threshold creates a problem for younger persons (i.e., women younger than age 65 years and men younger than age 70 years), who will seldom have a risk above established thresholds even with a prior fracture. Yet, lowering established thresholds means a sizable proportion of the population would suddenly become eligible, and nearly all persons at older ages would be eligible. Further, because hip fracture incidence in the United States is lower in most non-White racial and ethnic groups, predicted fracture risk estimates for persons in non-White racial and ethnic groups will always be lower than risk estimates for White persons of the same age, sex, weight, BMD, and clinical risks used in the FRAX model.^80^ Figure F.2-1 illustrates the predicted FRAX 10-year hip fracture risk (without BMD input) for women with BMI of 25 kg/m^2^ without any clinical risk factors for women across ages 50 to 90 years. Estimates at the oldest ages decline because of competing mortality. The pattern is similar for men except that the steep increase in predicted fracture starts a decade later in men compared with women. White women cross the hip fracture risk intervention threshold of 3 percent just after age 70 years, while Black women do not cross for 6 to 7 years later. A systematic review published in 2016 reported 82 guidelines recommending the use of FRAX; 58 recommended fixed thresholds and 24 recommended age-dependent thresholds.^88^ In almost all cases, these guidelines were recommending thresholds for treatment intervention, and the role of these thresholds for informing decisions about DXA testing varied across guidelines.

Age-specific thresholds vary the threshold for intervention by age. The most common way this is done is by setting the intervention threshold at the risk equivalent of a person of the same age with a prior fracture. The rationale for this approach is that if a person at a certain age with prior fracture is eligible for treatment, then a person without fracture but at the same risk (presumably because of other risk factors) should also be eligible for treatment. Under this model, the intervention thresholds are generally lower at younger ages and increase with age, but then plateau or even decrease to account for competing mortality at the oldest of ages.^88^ This allows for younger persons at elevated relative risk to be identified without having to lower the threshold for all ages, which would result in most older persons being above the threshold. Age-dependent thresholds are more complicated to implement in practice but may be better at efficiently identifying the persons at highest risk.^88^ Age-dependent thresholds also have the advantage of not being dependent on cost-effectiveness findings, which become outdated as costs of drugs or willingness-to-pay thresholds change.^20^ However, some have suggested that the use of a threshold equivalent to someone with a prior fracture sets the risk threshold too high, and empiric evaluations of this approach suggests it misses many persons who end up having fractures who may have benefited from treatment.^456^ Further, in one application of age-dependent thresholds in the United Kingdom, analyses suggested the creation of a disparity in access to treatment for some women age 70 years or older without prior fracture, as these women had higher estimated fracture risks than women of same age with a prior fracture, yet were not getting offered treatment.^454,^ ^457^ As a result, hybrid thresholds were implemented that included age-dependent thresholds through age 70 years and then applied fixed thresholds after age 70 years.^88^

Figure F.2-1 Ten-Year Hip Fracture Risk According to the Fracture Risk Assessment Tool (FRAX) for Women Ages 50 to 90 Years

Note: Fracture risk based on woman with BMI of 25.0 (height 64 in, weight 141 lb) and no other clinical risks. The horizontal dashed line at 3% percent 10-year hip fracture risk represents a common threshold for treatment intervention promoted in the United States.

Abbreviations: BMD=bone mineral density; BMI=body mass index; FRAX= Fracture Risk Assessment Tool; U.S.=United States.

This figure depicts the predicted FRAX 10-year hip fracture risk (without bone mineral density [BMD] input) for women ages 50 to 90 years with body mass index (BMI) equal to 25 and without any clinical risk factors. The x-axis shows age in 5-year increments and the y-axis shows the 10-year hip fracture risk in percentages ranging from 0 to 10 percent in 1 percent increments. The graph compares U.S. Caucasian (square), U.S. Hispanic (star), U.S. Black (triangle), and U.S Asian (circle) populations. For all populations, the risk increases from ages 50 through 85 years before declining between ages 85 through 90 years. The U.S. Caucasian population consistently trends the highest, peaking between 9 percent and 10 percent at age 85 years and the U.S. Black population trends the lowest, peaking slightly above 4 percent at age 85 years; the U.S. Hispanic and U.S. Asian populations trend between the U.S. Caucasian and U.S. Black populations, peaking at slightly less than 6 percent at age 85 years. The graph also depicts a horizontal line that crosses the y-axis at the 3 percent mark, which represents the most common threshold for treatment intervention in use in the United States. White women cross this threshold just after age 70 years and Hispanic and Asian women cross the threshold about 5 years after, while Black women do not cross the threshold for 6 to 7 years later.

The U.K. National Osteoporosis Guideline Group recommends a hybrid-threshold and direct treatment (without BMD testing) for those above the threshold considered high risk and reassurance and no BMD testing for those below the threshold considered low risk.^457,^ ^458^ In this approach, BMD measurement is reserved for those considered at intermediate risk based on initial fracture risk assessment. The fracture risk is then recomputed with BMD, and the patient is reclassified as high risk or low risk. At least one study has demonstrated that the use of a fixed threshold in the oldest age groups reduced the need for BMD in older age groups compared with an age-dependent threshold.^457^ Opponents of an approach that recommends direct treatment for high fracture risk cited the lack of trial evidence in persons without BMD testing.^20^ Proponents argued that because many (if not the majority of) fragility fractures occur in community-dwelling people with T-scores greater than −2.5, requiring a BMD assessment in the osteoporosis range for treatment is not useful.^20^ Post hoc analyses of some treatment trials demonstrated no treatment heterogeneity based on baseline BMD level, and larger fracture reductions in persons at higher baseline FRAX risk compared with lower baseline risk seemed to support this position.^454^ Proponents also suggested this approach may be most useful in low-resource settings where DXA resources are limited.^454^

## F.3 Contextual Question 6

What is the evidence for rare harms of bisphosphonate treatment (i.e., osteonecrosis of the jaw, atypical femur fractures) from observational studies that use noneligible control groups or are uncontrolled?

### Summary

In addition to studies eligible for inclusion in the SR portion of this update (KQ 5: Harms of Treatment), we sought recent seminal reviews and reports supplemented with new observational studies with large sample sizes (≥1,000) to address this CQ. The studies we identified for this CQ consistently suggest increased risk of atypical femur fractures (AFF) or osteonecrosis of the jaw (ONJ) with bisphosphonate (BP) use and increases in risk with longer duration of therapy, though risk estimates vary widely given differences in comparator arms, definitions and method of outcome ascertainment, and followup duration. In addition, estimates related to long-term use may be subject to confounding by indication as longer-term users may also have lower initial BMD or elevated fracture risk factors. However, the absolute risk of these outcomes is rare.^459^ Risk for these harms typically declined with cessation of BP treatment. Few studies included for this CQ reported on BPs other than alendronate. Studies frequently also considered BPs as a class in analyses. Studies typically included primarily postmenopausal women.

### Detailed Findings

### Atypical Femur Fracture

Definition. The American Society for Bone Mineral Research revised its definition of AFF in 2013 to include fractures located along the femoral diaphysis from just distal to the lesser trochanter to just proximal to the supracondylar flare, with four of five major features present. Major features include:

- Fracture associated with minimal or no trauma
- Fracture line originating at lateral cortex with substantially transverse orientation
- Complete fractures extend through both cortices, incomplete involve only lateral cortex
- Noncomminuted or minimally comminuted fractures
- Localized periosteal or endosteal thickening of the lateral cortex at fracture site.^459^

The definition also outlines minor features (increased cortical thickness of the femoral diaphysis, prodromal groin or thigh pain, bilateral incomplete or complete femoral diaphysis fractures, delayed fracture healing) that are not required to be present but have been associated with AFF.

### Evidence From Systematic Reviews and Seminal Reports

Bisphosphonates. ASBMR reports noted variable risk ratios (RRs) for AFF but consistently low absolute risk (3.2 to 50 cases/100,000 person-years [Appendix F.3 Table 1]).^459,^ ^460^ Risk increased with prolonged BP use (>3 years) and declined with discontinuation. While the optimal duration of use is not clear and likely varies based on patient risk factors, ASBMR suggests that for up to 5 years of BP use among 100,000 users, 175 hip fractures, 1,470 vertebral fractures, and 945 wrist fractures would be averted (2,590 total) and 16 AFFs would occur, for a total of 162 fractures of the spine, hip, or forearm prevented per AFF caused.^460^ It should be noted that AFF also occurs in individuals who did not receive antiresorptive therapies.^460^

Three SRs^461–463^ reported consistently increased risk of AFF with BP use, though the magnitude of risk varied by agent and study design (Appendix F.3 Table 1). Absolute numbers of AFF cases, when reported, varied from 0 to 412 in populations ranging from 2,000 to over 2 million. One review of SRs reported an adjusted odds ratio (OR) for AFF of 1.99 to 2.08 in studies of BP users vs. control or no exposure and RR estimates ranging from 1.52 to 11.12 depending on the type of studies (RCTs, observational studies) included and the duration of use (variably defined as >1 year to >6 years).^461^ Strength of evidence reported for these findings in this SR ranged from very low to moderate. Overlap among the studies included in these SRs was not described, and the authors reported variable methodologic quality (median 7.5 rating on 11-point AMSTAR scale).^461^

A second SR examined fracture risk with long-term use of BPs in postmenopausal women with at least 12 months of exposure and similarly reported higher AF risk in women taking alendronate vs. placebo.^462^ Observational studies included in this SR reported increased risk of AFF with longer treatment duration. In one Kaiser Permanente cohort, the incidence rate of AFF after 2 years of BP exposure was 2 per 100,000 person-years and 78 per 100,000 person-years after 8 years.

A third SR assessed long-term (>3 years) use of BPs and reported wide-ranging risk estimates for AFF depending on study design: in an RCT and observational studies of alendronate vs. placebo or no treatment, HRs for AFF (with or without radiologic confirmation) ranged from 1.03 to 2.90, while in observational studies of BPs vs. no BPs, ORs ranged from 9.46 to 116.^463^ Overall, this SR reported increased AFF risk with BP use with low strength of evidence.

Appendix F.3 Table 1 Reviews and Seminal Reports Addressing Atypical Femoral Fracture and Bisphosphonate Use

Author, Year; (Search Dates) | Focus | Agents Included | Included Studies Addressing AFF (N Cases/N Participants) | AFF Outcomes
ASBMR Reports
Shane et al 2013^459^; (NA) | Epidemiology and definition of AFF | BPs as a class | 12 observational studies with radiographic adjudication (458/NR) | Proportion ST/FS fractures with AFF features ranged from 1% to 48%; Number of AFF in each study ranged from 6 to 142, proportion occurring in BP users ranged from 12% to 97%; aORs for AFF in BP users ranged from 2.1 to 69.1; Absolute risk for AFF ranged from 3.2 to 50 cases/100,000 patient-years. For up to 5 years of use among 100,000 BP users, 2,590 fractures would be averted and 16 AFF would occur (162 fractures averted per 1 AFF caused).
Adler et al 2016^460^; (NR) | Safety of long-term BP use | BPs as a class | NA | AFF risk increases with duration of BP exposure; in one study aIR increased from 1.8/100,000 per year with 2 years exposure to 113/100,000 per year with 8 to 9.9 years of exposure
Reviews
Lu et al 2020^461^; (NR-Dec. 2018) | Review of SRs and meta-analyses of RCTs or observational studies reporting rare harms associated with long-term (>1 year) BP use | Alendronate, ibandronate, etidronate, zoledronic acid, or risedronate | 3 SRs addressing alendronate or BPs as a drug class (NR) | Pooled risk measures (95% CI) for AFF in included SRs; Lee 2015 (BP vs. control or no exposure, N=658,497, 1 RCT+9 obs studies); aOR=1.99 (1.28 to 3.10); GRADE: Very low; Lee 2015 (BP vs. control or no exposure, N=643,174, 9 obs studies); aOR=2.08 (1.29 to 3.35); GRADE: Low; Lydia 2013 (BP vs. control, N pts=NR, 11 obs studies); RR=1.70 (1.22 to 2.37); GRADE: Very low; Lydia 2013 (BP vs. control, N=686,929, 6 obs studies); RR=1.52 (1.08 to 2.15); GRADE: Moderate; Lydia 2013 (BP vs. control, N=NR, 5 case-control studies); RR=11.12 (2.68 to 46.18); GRADE: Low; Lu 2013 (BP vs. no exposure, N=686,929, 6 obs studies); RR=1.55 (0.94 to 2.16); GRADE: Very Low; Lu 2013 (BP vs. no exposure >5 years’ use, N=247,211, 3 obs studies); RR=1.54 (1.16 to 1.92); GRADE: Moderate
Dennison et al 2019^462^; (NR) | Fracture risk with long-term use of BP in postmenopausal women with ≥1 year of treatment exposure | Alendronate, zoledronic acid, risedronate | 1 secondary analysis of FIT and FLEX and Horizon RCTs^*^ (2/14,195) | Overall IR=2.3 per 10,000 patient-years; HRs ranged from 1.03 to 1.33 in 1 RCT and extension of alendronate vs. placebo; HR of 1.50 (0.25 to 9.00) in RCT of zoledronic acid vs. placebo
Dennison et al 2019^462^; (NR) | Fracture risk with long-term use of BP in postmenopausal women with ≥1 year of treatment exposure | Alendronate, zoledronic acid, risedronate | 4 obs studies (NR) | Swedish registry study, 59 AFF: OR for AFF, BP vs. no BP ranged from=0.28 to 33.3 depending on duration of use and time since last use (decline in risk post-discontinuation); Swedish registry study, 172 AFF: aRR for AFF in female BP users=55 and 54 in males. RR after ≥4 years’ use=126 (95% CI, 55 to 288), AR=11 AFF per 10,000 person-years (95% CI, 7 to 14); declines in risk after discontinuation; Southern California OP cohort: HR for AFF in women stopping BP vs. continuing=0.56 (95% CI, 0.38 to 0.82); IR in current users=46 per 100,000 patient-years; Kaiser Permanente cohort: Unadjusted IR after 2 years BP exposure=2 per 100,000 person-years, after 8 years=78 per 100,000 person-years
Dennison et al 2019^462^; (NR) | Fracture risk with long-term use of BP in postmenopausal women with ≥1 year of treatment exposure | Alendronate, zoledronic acid, risedronate | 1 SR (23 studies) | IR ranged from 3.0 to 9.8 per 100,000 patient-years
Fink et al 2019^463^; (Jan. 1995-Oct. 2018) | SR of RCTs or obs studies of long-term (>3 years) use of OP drug treatment vs. control in men or women age ≥50 | Alendronate, zoledronic acid, any BP | 1 secondary analysis of FIT AND FLEX and Horizon RCTs^*^, 2 obs studies of alendronate vs. no treatment (316/227,353) | RCT analysis, HR for ST or FS fracture with alendronate=1.03 (95% CI, 0.06 to 16.46), ARR=0 (95% CI, −0.09 to 0.09); SOE: Insufficient; Obs studies—HR for ST or FS ranged from 1.37 to 2.90, ARRs 0.09 to 0.20; SOE: Low
Fink et al 2019^463^; (Jan. 1995-Oct. 2018) | SR of RCTs or obs studies of long-term (>3 years) use of OP drug treatment vs. control in men or women age ≥50 | Alendronate, zoledronic acid, any BP | 3 obs studies, BP vs. no BP (412/~2,808,032) | OR for AFF or ST/FS without X-ray confirmation ranged from 9.46 to 116; SOE: Low
Fink et al 2019^463^; (Jan. 1995-Oct. 2018) | SR of RCTs or obs studies of long-term (>3 years) use of OP drug treatment vs. control in men or women age ≥50 | Alendronate, zoledronic acid, any BP | 2 obs studies, current BP use vs. past BP use (368/2,027) | Higher risk with current use, OR ranged from 1.59 to 5.17; SOE: Low
Fink et al 2019^463^; (Jan. 1995-Oct. 2018) | SR of RCTs or obs studies of long-term (>3 years) use of OP drug treatment vs. control in men or women age ≥50 | Alendronate, zoledronic acid, any BP | 1 RCT^†^, zoledronic acid vs. placebo (0/2,000) | 0 AFF, SOE: Not rated

* One FIT publication (Cummings et al, 1998^254^) included to address KQs.

† RCT included to address KQ—Reid et al, 2018.^269^

Abbreviations: AFF=atypical femoral fracture; aIR=adjusted incidence rate; aOR=adjusted odds ratio; AR=absolute risk; aRR=adjusted risk ratio; ARR=absolute risk reduction; ASBMR=American Society for Bone and Mineral Research; BP=bisphosphonates; CI=confidence interval; FIT=Fracture Intervention Trial; FLEX=Fracture Intervention Trial Long-term Extension; GRADE=Grading of Recommendations, Assessment, Development, and Evaluation; HR=hazard ratio; IR=incidence rate; KQ=key question; N=number; NA=not applicable; NR=not reported; obs=observational; OP=osteoporosis; OR=odds ratio; RCT=randomized, controlled trial; RR=risk ratio; SOE=strength of the evidence; SR=systematic review; ST/FS=subtrochanteric and femoral shaft; vs.=versus.

### Evidence From Observational and Long-Term Extension Studies

Bisphosphonates. Recent observational studies from the Republic of Korea (k=1) and the United States (k=2) included primarily postmenopausal women and reported cases of AFF ranging from 46 to 113 in populations ranging from 6,000 to more than 94,000 individuals receiving BPs (Appendix F.3 Table 2).^464–466^ Two studies included radiographic evaluation of fractures using blinded or dual assessment and used 2013 ASBMR criteria for AFF. Duration of BP use ranged from less than 1 year to 10 years.

The study conducted in the Republic of Korea reported that the incidence of AFF increased with duration of use from 31.2 per 100,000 person-years for short-term users to 67.1 per 100,000 person-years in long-term users (p<0.001).^464^ The two studies conducted in the United States reported a similarly increased incidence of AF with duration of use.^465,^ ^466^ In these two studies reporting on an overlapping cohort of more than 80,000 Kaiser Permanente health plan users, for postmenopausal women incidence increased from 9 per 100,000 person-years with between 2 and 4 years of BP exposure to 112 per 100,000 person-years with 8 or more years of BP exposure in one of the studies.^465^ In the second study from the United States, the adjusted cumulative AFF incidence in short-term (<3 years) BP users was 27 per 100,000 patient-years compared with 363 per 100,000 person-years in long-term (≥3 years) users.^466^

Denosumab. Few AFF were reported with denosumab use in studies reviewed for this CQ. In the multinational FREEDOM RCT and long-term extension (up to 7 years of denosumab after the 3-year RCT), 2 AFF occurred (0.8 per 10,000 participant-years): one in a participant receiving 7 years of denosumab and one in a crossover participant who had received denosumab for 3 years.^467^

Appendix F.3 Table 2 Recent Observational Studies Addressing Atypical Femoral Fracture and Bisphosphonate Use

Author, Year; Country; Study Design | Population and Number of AFF Cases | Assessment Method (AFF Criteria) | AFF Outcomes
Won et al 2020^464^; Republic of Korea; Controlled cohort study | 36,529 women age 50 years or older initiating oral or IV BP between 2003 and 2011 (Korean National Health Insurance database); 61 AFF in long-term users (≥1 year, n=14,689) and 36 AFF in short-term users (<1 year, n=21,840) | ICD fracture codes and codes for fracture repair surgical procedures | Unadjusted IR in long-term users=67.1 per 100,000 person-years (95% CI, 50.3 to 83.9) and 31.2 per 100,000 person-years (95% CI, 21.0 to 41.4) in short-term users (p<0.001); aHR 2.34 (95% CI, 1.54 to 3.57) for long-term vs. short-term use; NNH=400 (1 AFF per 400 women with long-term treatment)
*Lo et al 2020^466^; U.S.; Controlled cohort study | 87,820 women between ages 45 and 84 years starting oral BP between 2002–2014 from a large health system; mean age=68.6 (SD 9.1); 46 AFF in 86,204 short-term (<3 years) users and 82,239 long-term (≥3 years) users; 32 of these AFF occurred after 3 years of use | Identification of fractures using ICD codes, blinded radiologic review (ASBMR 2013 criteria) | Cumulative AFF incidence remained stable in short-term users and increased in long-term users; At 10 years, adjusted cumulative AFF incidence in short-term group=27 per 100,000 person-years (95% CI, 8 to 46) vs. 363 per 100,000 person-years (95% CI, 132 to 593) in long-term users; Adjusted 10-year absolute risk difference=336 per 100,000 person-years (95% CI, 110 to 570)
*Lo et al 2019^465^; U.S.; Cohort study; Note: Population overlaps with Lo 2020 | 94,542 women between ages 45 and 89 years initiating oral BP between 2002–2014 from a large health system; mean age=69.9 (SD 10); 113 AFF (107 occurring during BP exposure or <12 months after cessation); median BP exposure=2.2 years (0.5 to 5.0) | Identification of fractures using ICD codes, blinded radiologic review (ASBMR 2013 criteria) | 22 AFF cases occurred with exposure <4 years vs. 85 cases with ≥4 years’ exposure; 6 cases occurred 1 to 3.5 years after cessation; Age-adjusted incidence at 2 to <4 years exposure=9 per 100,000 person-years, incidence at ≥8 years exposure=112 per 100,000 person-years; Majority of AFF occurred in Asian women (62.8%) and non-Hispanic Whites (26.6%)
Bone et al 2017^467^; FREEDOM; RCT + open-label extension | 2,343 women receiving denosumab in RCT and extension study and 2,207 women receiving placebo in RCT and denosumab in extension, mean age overall at enrollment=72.3 (SD 5.2); 2 AFF | Radiologic review (ASBMR 2010 or 2013 criteria, depending on study year) | 1 AFF occurred in participant receiving denosumab in RCT and extension after 7 years of treatment, 1 in a crossover participant after 3 years of denosumab (exposure-adjusted incidence=0.8 AFF per 10,000 participant-years); No AFF reported in years 5–7 of extension study in either group

* Lo et al (2020) and Lo et al (2019) included an overlapping population of women from the Kaiser Permanente Northern California System.

Abbreviations: AFF=atypical femoral fracture; aHR=adjusted hazard ratio; ASBMR=American Society for Bone and Mineral Research; BP=bisphosphonates; CI=confidence interval; ICD=International Statistical Classification of Diseases and Related Health Problems; IR=incidence rate; IV=intravenous; n=number; NNH=number needed to harm; RCT=randomized, controlled trial; SD=standard deviation; vs.=versus.

### Osteonecrosis of the Jaw

Definition. ONJ nomenclature has changed over time to reflect the agents with which ONJ has been associated (e.g., BPs, denosumab, tyrosine kinase inhibitors), which may complicate understanding of risk and incidence. In 2014, the American Association of Oral and Maxillofacial Surgeons (AAOMS) revised characteristics used to define medication-related ONJ^468^:

- Current or previous treatment with antiresorptive or antiangiogenic agents, and
- Exposed bone or bone in the maxillofacial region for longer than 8 weeks, and
- No history of radiation therapy to or obvious metastatic disease of the jaws.

ONJ pathogenesis is likely related to multiple factors including infection, immune system dysfunction, tooth extraction, smoking, poor oral hygiene, and use of antiresorptive or antiangiogenic medications.^460,^ ^468,^ ^469^

### Evidence From Systematic Reviews and Seminal Reports

Bisphosphonates. An ASBMR report noted that the incidence of ONJ is rare: approximately 1 case per 10,000 to 100,000 person-years, with a largely self-limiting clinical course in patients with osteoporosis treated with BPs (Appendix F.3 Table 3).^460^ Three SRs addressed the association between ONJ and BP use.^461,^ ^463,^ ^469^ One SR conducted for the European Calcified Tissue Society noted incidence estimates in individuals using BPs ranging from 0.01 percent to 0.06 percent, with higher incidence among persons in Asian countries.^469^ A review of SRs reported increased risk of ONJ with BPs vs. control in observational studies (ORs ranging from 2.57 to 3.29, low strength of evidence).^461^ Another SR similarly reported increased risk for ONJ (with and without radiographic review) with alendronate vs. no treatment or raloxifene (HRs from 0.86 to 7.42); the review authors recalculated the reported HR estimate of 0.86 because incidence rates suggested a higher risk of ONJ. The recalculated estimate was 1.20 (95% CI, 0.59 to 2.56).^463^

Denosumab. One SR noted incidence of ONJ with denosumab use; the review cited the FREEDOM RCT and extension study which is discussed in the next section.^469^ This review also cited a postmarketing study that reported 47 adjudicated cases of ONJ in 1,960,405 patient-years of denosumab exposure; all patients had risk factors for ONJ development.^469^

Appendix F.3 Table 3 Recent Reviews and Seminal Reports Addressing Osteonecrosis of the Jaw and Bisphosphonate or Denosumab Use

Author, Year; (Search Dates) | Focus | Agents | Included Studies; (N Cases/N Participants) | ONJ Outcomes
ASBMR Reports
Adler et al 2016^460^; (NR) | Safety of long-term BP use | BPs as a class | NA | Incidence rates range from 1 per 10,000 to 1 per 100,000 person-years; Report noted a trend for increased ONJ risk with increased duration of BP use
Reviews
Lu et al 2020^461^; (NR-Dec. 2018) | Overview of SRs including meta-analyses of RCTs or observational studies reporting rare BP harms | Alendronate, ibandronate, etidronate, zoledronic acid, or risedronate | 8 SRs addressing alendronate or BPs in general (NR) | Lee 2014 (BP vs. control, N=NR, 9 obs studies) OR=2.57 (95% CI, 1.37 to 4.84); GRADE: Low; Lee 2014 (oral BP vs. control, N=NR, 5 obs studies) OR=3.29 (95% CI, 1.39 to 7.77); GRADE: Low
Fink et al 2019^463^; (Jan. 1995-Oct. 2018) | SR of RCTs or obs studies of long-term (>3 years) use of OP drug treatment vs. control in men or women age ≥50 | Alendronate, zoledronic acid, any BP | 2 obs studies of alendronate vs. no treatment (28/220,894) | ONJ without X-ray or pathology review, HR=3.15 (95% CI, 1.44 to 6.87); SOE: Low
Fink et al 2019^463^; (Jan. 1995-Oct. 2018) | SR of RCTs or obs studies of long-term (>3 years) use of OP drug treatment vs. control in men or women age ≥50 | Alendronate, zoledronic acid, any BP | 1 obs study of alendronate vs. raloxifene (40/8,354) | ONJ with X-ray/pathology review, HR=7.42 (95% CI, 1.02 to 54.09); SOE: Low
Fink et al 2019^463^; (Jan. 1995-Oct. 2018) | SR of RCTs or obs studies of long-term (>3 years) use of OP drug treatment vs. control in men or women age ≥50 | Alendronate, zoledronic acid, any BP | 1 obs study of alendronate vs. raloxifene or calcitonin (46/43,645) | ONJ without X-ray, pathology review, HR=0.86 (95% CI, 0.44 to 1.69); authors recalculated as 1.20 (95% CI, 0.59 to 2.56); SOE: Insufficient
Fink et al 2019^463^; (Jan. 1995-Oct. 2018) | SR of RCTs or obs studies of long-term (>3 years) use of OP drug treatment vs. control in men or women age ≥50 | Alendronate, zoledronic acid, any BP | 1 RCT of zoledronate vs. placebo (0/2,000) | SOE: Not rated
Anastasilakis et al 2022^469^; (NR) | ECTS “detailed review” of ONJ incidence and characteristics | BPs, denosumab | NR | Variable definitions of medication-related ONJ complicate incidence estimates; higher incidence with IV BPs, potentially because IV agents more often used in cancer patients, and greater incidence ONJ in patients with cancer vs. OP; Incidence in persons taking BPs ranged from 0.01% to 0.06%, with higher incidence in persons from Asian countries; Data from FREEDOM RCT^467^ and extension study suggested an incidence rate of 5.2 per 10,000 person-years (based on 13 cases of ONJ observed).; 47 cases of ONJ in 1,960,405 patient-years of denosumab exposure in postmarketing surveillance study; all patients had risk factors for ONJ such as invasive dental procedures, cancer

Abbreviations: ASBMR=American Society for Bone and Mineral Research; BP=bisphosphonates; CI=confidence interval; ECTS=European Calcified Tissue Society; GRADE=Grading of Recommendations, Assessment, Development, and Evaluation; HR=hazard ratio; IV=intravenous; N=number; NA=not applicable; NR=not reported; obs=observational; ONJ=osteonecrosis of the jaw; OP=osteoporosis; OR=odds ratio; RCT=randomized, controlled trial; SOE=strength of the evidence; SR=systematic review; vs.=versus.

### Evidence from Observational and Long-Term Extension Studies

Bisphosphonates or Denosumab. As noted in Appendix F.3 Table 4, 13 cases of ONJ occurred in the FREEDOM RCT and open-label extension: seven in participants who received denosumab in the RCT and extension and six in participants who received placebo in the RCT and crossed over to denosumab (5.2 cases per 10,000 participant-years).^467^ Other recent observational studies also addressed the association between ONJ and use of BPs or denosumab or denosumab alone. One study conducted in Switzerland reported a rate of ONJ cases of 4.5 per 10,000 BP users and 28.3 per 10,000 denosumab users, all of whom had been previously treated with BPs.^470^ A 3-year Japanese postmarketing study reported 15 ONJ cases in 3,534 patients; six of these met AAOMS criteria for an incidence rate of 76.2 per 100,000 person-years.^471^

Appendix F.3 Table 4 Recent Observational Studies Addressing Osteonecrosis of the Jaw and Bisphosphonate or Denosumab Use

Author, Year; Country; Study Design | Population; ONJ Cases | Assessment Criteria | Key Findings
Bone et al 2017^467^; Multinational; RCT + open-label extension (FREEDOM) | 2,343 women receiving denosumab in RCT and extension study and 2,207 women receiving placebo in RCT and denosumab in extension, mean age overall at enrollment=72.3 (SD 5.2); 13 cases of ONJ | Adjudication using AAOMS definition | 7 cases of ONJ occurred in participants who received denosumab in the RCT and extension; 6 in placebo crossover participants; Exposure-adjusted incidence rate=5.2 per 10,000 person-years; 11 cases resolved (2 lost to followup), 4 while on denosumab treatment
Everts-Graber 2022^470^; Switzerland; Case series/Registry | 3,068 patients with ≥1 DXA scan and receiving BPs or denosumab between 2015–2019 seen at 1 outpatient center and included in Swiss Society of Rheumatology OP registry; median age=69 years (range=63 to 76 years); 17 cases identified: 12 in denosumab users (9 pretreated with BPs, mean 6.7 years’ exposure) and 5 in oral or IV BP users (0 had prior denosumab) | Blinded assessment using AAOMS definition of ONJ | Incidence=28.3 per 10,000 person-years in denosumab users and 4.5 per 10,000 in BP users; 9/17 patients with ONJ had risk factors including smoking, cancer, and aromatase inhibitor or steroid use; 9 of 12 patients with ONJ receiving denosumab had received prior BPs (mean BP treatment duration=6.7 years); HR for ONJ with denosumab vs. BP use: 3.49, 95% CI, 1.16 to 10.5, p=0.026; Time to ONJ healing ranged from 2 months to 3.5 years
Tanaka et al 2021^471^; Japan; Postmarketing analysis | 3,534 patients receiving denosumab over 3 years; 1,643 discontinued over the followup period; mean age=75.7 years (SD 9.3); 15 cases of ONJ, 6 met AAOMS criteria | Diagnosis of osteomyelitis and/or ONJ using AAOMS definition | Based on adjudicated cases, IR=76.19 per 100,000 person-years (95% CI, 62.28 to 93.20); ONJ recovered or improved in 12 of 15 patients (3 others lost to followup); 13% of patients has secondary or drug-induced OP; ONJ developed earlier in those receiving BPs prior to denosumab than those not receiving prior BPs (timing not reported)

Abbreviations: AAOMS=American Association of Oral and Maxillofacial Surgeons; BP=bisphosphonates; CI=confidence interval; DXA=dual-energy X-ray absorptiometry; HR=hazard ratio; IR=incidence rate; IV=intravenous; ONJ=osteonecrosis of the jaw; OP=osteoporosis; RCT=randomized, controlled trial; SD=standard deviation; vs.=versus.

## F.4 Contextual Question 7

What is the evidence for rebound fractures after discontinuation of denosumab?

### Summary

We identified recent (within the last 5 years) reviews and observational studies to address this CQ. We also included data from the seminal FREEDOM RCT extension analysis. Overall, studies included relatively few participants, and some included mixed populations of persons receiving denosumab for osteoporosis or for cancer-related bone problems. No consensus definition for “rebound fracture” currently exists. Study followup periods varied and typically did not exceed 24 months post-treatment cessation, while what authors classified as rebound fractures occurred from roughly 2 months’ to 16 months’ post-cessation. Analyses primarily from FREEDOM suggest that the risk of multiple vertebral fractures is increased relatively soon after treatment discontinuation and may be higher in persons with prior fractures.

In studies in which participants had a delay in denosumab dosing, higher fracture risk was similarly estimated to occur with a delay of as little as 4 months. A limitation across studies reporting on rebound fractures is that they were not designed to evaluate causality or estimate potential net benefits to denosumab over the long run, despite the occurrence of rebound fractures after treatment discontinuation.

### Detailed Findings

Definition. Bone loss may rebound to levels experienced pretreatment when patients discontinue denosumab.^472^ Rebound fractures, typically vertebral fractures, have been described as fractures that occur shortly after cessation of denosumab therapy; however, the timing of fracture occurrence is variable and no consensus definition exists. In the FREEDOM trial of denosumab, fracture assessment occurred in patients who received two to five doses of denosumab or placebo and continued study participation for at least 7 months after the study ended for a maximum of 24 months followup (mean 0.8 years/patient).^473,^ ^474^ Followup periods post-treatment cessation in other studies have generally not exceeded 20 months.

### Association Between Rebound Fractures and Denosumab Discontinuation

The FREEDOM RCT and extension study^473,^ ^474^ assessed the incidence and risk factors for rebound fractures after denosumab use (Appendix F.4 Table 1). In a post hoc analysis including participants in both the RCT and extension study and analyzing vertebral fractures specifically, more denosumab discontinuers had multiple vertebral fractures vs. placebo discontinuers (60.7% vs. 38.7%) with rates of 4.2 per 100 in denosumab discontinuers and 3.2 per 100 in placebo discontinuers.^474^

Across two observational studies reporting time to fracture, months to fracture ranged from 1.8 to 16 after the last denosumab dose;^440,^ ^441^ in a third cross-sectional study, fractures occurred a median 12 months (mean 13 months) after the last injection^442^ (Appendix F.4 Table 1). One dose-ranging study reported 17 fractures in eight participants: four women had multiple vertebral fractures, three had single vertebral fractures, and one had a radius fracture.^475^ Additionally, in two studies, both including persons with cancer and persons with osteoporosis, more than 50 percent of patients had multiple vertebral fractures post-discontinuation.^476,^ ^477^

In the FREEDOM RCT and extension study, risk factors for rebound fracture included prevalent vertebral fractures, greater gains and losses in hip BMD on therapy and after therapy, and longer duration off therapy. In this study, prior fracture was the strongest predictor of post-treatment fracture (OR 3.9 [95% CI, 2.1 to 7.2]).^474^ In addition, the association between duration of denosumab therapy and rebound fracture was not clear. In one observational study, the number of injections was not significantly associated with rebound facture,^477^ while in another, women taking denosumab for 2 or more years had more fractures than those taking denosumab for less than 2 years.^476^ Both of these studies, however, included participants with cancer and osteoporosis.

### Association Between Rebound Fractures and Delays in Denosumab Dosing

Recent studies have also evaluated the association between rebound fractures and delay in denosumab treatment (Appendix F.4 Table 2).^478,^ ^479^ A typical dosing schedule is every 6 months. Several studies evaluated delays ranging from 1 month to 4 months.^478^ In one study, higher vertebral (but not other fractures) fracture rates were estimated with a delay in denosumab therapy of more than 16 weeks vs. treatment within 4 weeks of the last denosumab dose,^478^ and fracture incidence rates were significantly increased in patients with a delay of at least 3 months vs. persistent users in a second study.^479^

Appendix F.4 Table 1 Recent Observational and Other Studies Addressing Denosumab and Rebound Fractures

Author, Year; Country; Study Design | Population (Mean Age) | Denosumab Use and Discontinuation | Key Findings
Trials/Trial; Extensions
Brown et al (FREEDOM) 2013^473^; Multinational; RCT; Cummings et al (FREEDOM+ Extension) 2018^474^; Multinational; Post hoc, long-term extension study | FREEDOM RCT: 797 trial participants discontinuing denosumab (n=327) or placebo (n=470) after 2 to 5 doses; mean age 73 (SD 5); FREEDOM + 7-year extension: 1,471 participants discontinuing placebo (n=470) or denosumab (n=1,001) after ≥2 doses (age NR) | FREEDOM: Mean followup from last dose of denosumab or placebo + 7 mo)=0.8 years (median=0.5 year); FREEDOM + extension: median 0.2 years (IQR: 0.1 to 0.7) | FREEDOM RCT: 51 vertebral fractures post-treatment in placebo arm and 26 in denosumab; In 470 FREEDOM placebo-treated subjects discontinuing placebo and followed for a total of 378 subject-years and 327 denosumab-treated subjects discontinuing treatment and followed for 267 subject-years, overall fracture rate per 100 subject-years=13.5 for placebo and 9.7 for denosumab (HR 0.82 [95% CI, 0.49 to 1.38]); No difference in time to fracture between placebo and denosumab groups in FREEDOM trial; FREEDOM + 7-year extension: 31 vertebral fractures (12 multiple vertebral fractures) in placebo discontinuers and 56 vertebral fractures (34 multiple vertebral fractures) in denosumab discontinuers; 14 placebo discontinuers and 23 denosumab discontinuers had ≥1 nonvertebral fracture; In post hoc analysis of 1,471 FREEDOM + extension patients, more denosumab users had multiple vertebral fractures post-discontinuation vs. placebo: 60.7% vs. 38.7%; Off-treatment exposure-adjusted rate of any new vertebral fractures per 100 subject-years in placebo arm was 8.5 vs. 7.1 in denosumab; rate for multiple vertebral fractures was 3.2 per 100 subject-years in placebo discontinuers vs. 4.2 per 100 in denosumab discontinuers; Rate of nonvertebral fractures was 3.8 per 100 (95% CI, 1.8 to 5.8) in placebo discontinuers and in denosumab discontinuers=2.8 per 100 subject-years (95% CI, 1.7 to 4.0); Prior fracture was strongest predictor of post-treatment fractures (OR=3.9); odds of multiple vertebral fracture were 1.6 times higher with each additional year of off-treatment followup
Observational Studies
McClung et al 2017^475^; U.S. (13 centers); Case series; McClung et al 2017^475^; U.S. (13 centers); Case series | 82 women who had received denosumab in a 4-year phase 2 denosumab dose-ranging trial or 4-year extension study and ceased denosumab treatment (68.9) | 52 women had received denosumab for 8 months prior to discontinuation (i.e., were in the denosumab arm in the dose-ranging parent trial and extension study); 12 had discontinued denosumab after 2–4 months and restarted for the extension study; 8 had discontinued alendronate and started denosumab in the extension study; 10 had taken placebo and started denosumab in the extension; 12 months’ followup post-discontinuation | 8 participants had at least 1 post-treatment fracture, 17 total fractures. 4 women had multiple vertebral fractures, 3 had single vertebral fractures, 1 had radius fracture; Among the 8 of 82 participants with an osteoporotic fracture in the 12-month post-denosumab followup period, 2/8 had history of prior fracture; all had fracture risk factors; Time to fracture after stopping denosumab: Rebound fractures occurred from 1.8 to 13.1 months after last dose of denosumab; Age at fracture ranged from 62 to 79. No participants were receiving OP treatment after stopping denosumab before fracture occurred; Study also reported data from 2 women who did not participate in the 12-month followup but had participated in the dose-ranging trial: 1 had multiple vertebral fractures, and 1 had single fracture. Time to fracture after stopping denosumab: Fractures occurred 1 or 3.5 months post-discontinuation in participants 61 and 74 years old; Spine radiographs not obtained in the dose-ranging trial; thus, it was not clear if post-treatment fractures were acute or chronic
Burckhardt et al 2021^477^; Switzerland; Cross sectional (Survey of 39 clinicians from hospitals across country conducted in 2019) | 797 women with OP or nonmetastatic breast cancer receiving denosumab (65.3 years); 134 women had breast cancer (fracture incidence not reported separately for OP and cancer patients) | Mean injections=5.9 (range 2 to 20); Mean treatment duration=35 months (range 5 to 120); Mean followup post-discontinuation=27.5 months (SD 15.5) | 215 post-treatment vertebral fractures in 82 women (mean 2.6 fractures; 69.5% with multiple fractures) and 16 post-treatment nonvertebral fractures (N women NR); Time to fracture after stopping denosumab: First fracture occurred mean 13 months/median 12 months after last injection; 75% occurred between 6 and 15 months after last injection; Number of denosumab injections not significantly associated with rebound fracture occurrence; BP use pre-denosumab or post-denosumab associated with lower risk of vertebral fracture and multiple vertebral fractures (HR for BP use pre-denosumab=0.24, for use after denosumab=0.042, for use before and after denosumab=0.048); greater protective effect with post-discontinuation use of BPs; BP use post-denosumab discontinuation associated with lower incidence of nonvertebral fractures (0.08)
Anastasilakis et al 2017^476^; Greece; Review and case series | Total N considered in review NR; N of women considered eligible for case series NR | Time on denosumab ranged from 1 to 5 years, mean 2.9 years; Duration followup NR | 13 women with post-discontinuation fractures identified in literature search; 11 women experiencing fractures in authors’ centers; Total of 112 fractures in 24 women after stopping denosumab (median 5.0 fractures, range 1 to 9); Time to fracture after stopping denosumab: All fractures occurred 8 to 16 months after last denosumab injection; 92% of patients had multiple vertebral fractures; Women with ≥2 years denosumab duration had more fractures vs. those with ≤2 years (mean (SEM) fractures=5.2 (1.4) vs. 3.2 (0.7), p=0.055); 5 of 24 patients were receiving aromatase inhibitors for cancer, 1 was receiving glucocorticoids

Abbreviations: BP=bisphosphonates; CI=confidence interval; FREEDOM=Fracture REduction Evaluation of Denosumab in Osteoporosis Every 6 Months; HR=hazard ratio; IQR=interquartile ratio; n/N=number; NR=not reported; OP=osteoporosis; OR=odds ratio; RCT=randomized, controlled trial; SD=standard deviation; SEM=standard error of the mean; vs.=versus.

Appendix F.4 Table 2 Observational Studies Assessing Fracture After Delays in Denosumab Treatment

Author, Year; Country; Study Design | Population (Mean Age) | Denosumab Use and Discontinuation | Key Findings
Lyu et al, 2020^478^; U.K.; Cohort study | 2,594 patients initiating denosumab for OP; mean age 75.8 (SD 9.5) | 6,144 injections, Treatment delay defined as within 4 weeks of prior injection, 4–16 weeks delay, >16 weeks delay | Fracture risk within 4 weeks of prior denosumab injection: composite fracture 27.3 per 1,000 persons; MOF 14.7 per 1,000 persons; vertebral fracture 2.2 per 1,000 persons; Fracture risk with delay of 4 to 16 weeks to next denosumab injection: composite fracture 32.2 per 1,000 persons; MOF 18.1 per 1,000 persons; vertebral 3.6 per 1,000 persons; Fracture risk with >16 weeks delay in denosumab injection: composite fracture 42.4 per 1,000 persons; MOF 27.2 per 1,000 persons; vertebral 10.1 per 1,000 persons; aHR for fracture between dosing within 4 weeks and delay of 4–16 weeks or >16 weeks were elevated but not significant except for vertebral fractures; aHR for vertebral fracture with delay of >16 weeks vs. within 4 weeks 3.91 (95% CI, 1.62 to 9.45)
Tripto-Shkolnik et al, 2020^479^; Israel; Cohort study | 1,500 patients discontinuing denosumab treatment; mean age 72.4 (SD 9.6) at first denosumab purchase | Patients were included if they had at least 2 denosumab purchases; treatment discontinuation defined as refill gap of ≥3 months; Post-discontinuation fractures defined as occurring within 1 year of discontinuation | 54 of 1,500 patients had any MOF post-denosumab discontinuation (21 with any vertebral, 12 with multiple vertebral, 13 with hip, 22 with non-hip, nonvertebral fractures); incidence rate for any fracture 5.1 per 100 person-years (95% CI, 3.94 to 6.62); Fracture incidence rate per 100 person-years in discontinuers with prior vertebral fracture 6.81 (95% CI, 4.0 to 11.3); Higher rates of MOF, vertebral fractures, multiple vertebral fractures, hip fractures in discontinuers vs. persistent users: IRRs ranging from 2.23 to 14.63, all p≤0.005; Unadjusted HR for fracture within 1 year in discontinuers vs. persistent users was 2.5 (95% CI, 1.3 to 4.7, p=0.003) in patients with 2 denosumab purchases and 3.18 (95% CI, 1.6 to 6.5, p<0.001) in patient with 3 purchases; HRs not significant in those with 4 or 5 purchases

Abbreviations: aHR=adjusted hazard ratio; CI=confidence interval; HR=hazard ratio; IRR=incidence rate ratio; MOF=major osteoporotic fracture; OP=osteoporosis; SD=standard deviation; U.K.=United Kingdom; vs.=versus.