# Appendix E Additional Results

## E.1 Detailed Findings for Key Question 1

Detailed study characteristics are reported in Appendix D Table 1, and detailed findings are reported in Appendix D Table 8.

### The ROSE Trial

The ROSE RCT randomly selected women ages 65 to 80 years living in southern Denmark to receive an invitation to participate in a two-step screening process (n=34,229).^126–128^ Before recruitment, these women were randomized to either screening (n=17,072) with FRAX followed by DXA and vertebral fracture assessment (VFA) if 10-year FRAX MOF risk was greater than or equal to 15 percent or to a control group that continued to receive usual care as directed by their primary care provider (PCP), with no routine screening offered by the study (n=17,157).^126^ Because study participants were identified through the Danish Civil Registration system, study authors applied no clinical exclusion criteria. Results of the DXA test in the screening group were sent to the participant and her general practitioner, which included recommendations based on national guidelines, while control group participants received no further followup. Screening guidelines at the time included a recommendation for measuring BMD if one or more clinical risk factors were present.^445^ Treatment guidelines at the time of the study called for the initiation of treatment for 1) a fragility fracture of the hip or spine, or 2) T-score less than −2.5 with one clinical risk factor, or 3) T-score between −1.0 and −2.5 if on glucocorticoid therapy, or 4) if T-score less than 4.0 with no clinical risk factors.^445^ Of participants randomized who returned the initial questionnaire with no missing data (N=20,905), the mean (SD) 10-year FRAX risk was 23.2 (11.0) percent for MOF and 10.0 (9.1) percent for hip. Further, 12.3 percent reported a history of a fragility fracture and 9.5 percent reported already being treated for osteoporosis. Of the women who completed a DXA scan in the screening group (N=5,064), the mean T-score was −1.2 (SD 1.0) at the TH and was −1.3 (SD 1.4) at the LS. Further, 3.7 percent had prevalent vertebral fractures.

We assessed the ROSE study as fair quality. Because the study was pragmatic in nature, the intervention was not blinded to participants. No missing data were reported because the analysis was intent-to-treat based on all participants randomized, although 45.6 percent of participants did not receive screening with FRAX (1,132 already on treatment, 2,894 returned questionnaire blank, 104 returned questionnaire with data missing to calculate FRAX, and the rest did not return the questionnaire). Significant differences were found between responders and nonresponders. In the intervention group, 12 percent (2,047/17,072 randomized) were high risk but did not receive a DXA (830 were not interested in a DXA and 1,217 dropped out; or 29% of those with high-risk FRAX scores [2,047/7,056]). Only 7 percent (1,236/17,072 randomized) had a positive DXA for osteoporosis after a FRAX risk above the study threshold, and only 6 percent (986/17,072, or 80% [986/1,236] of those with an indication) received treatment. The authors stated that 23 percent of the screening group received medication after the index date (mailing of questionnaire), which we assumed is the 986 participants started on medication and the 1,132 women who were already receiving medication on the baseline questionnaire along with an unknown number of women who were randomized to screening but who did not return the questionnaire but who may have been prescribed medication by their PCPs through the course of usual care outside of this study.

Similarly, in the control group, 45.6 percent (7,831/17,157 randomized) did not participate (1,168 were already on treatment, 3,143 returned a blank questionnaire, 111 returned a questionnaire with missing data to calculate FRAX, and the rest did not return the questionnaire). Additionally, there was contamination in the control group such that 25 percent of the control group received a DXA at some point after the study index date, possibly from increased awareness after completing the baseline questionnaire. The overall difference in the use of osteoporotic medications after the study index date was 5 percent (23% in the intervention vs. 18% in the control group), although it is unclear who was included in the denominators the authors used to report these percentages. The authors did not specify whether these data included those on treatment from the index date (mailing of the questionnaire). Outcome ascertainment was through the national health registry, and persons retrieving data from these health registries were not formally blinded to group allocation.^126,^ ^127^

At a median followup of 5.0 years, the incidence of MOF for the intent-to-treat analysis (which was the primary study endpoint) was not significantly different in the invitation-to-screening group (9.9%) compared with the control group (10.0%) with an adjusted subhazard ratio (aSHR) of 0.986 (95% CI, 0.922 to 1.055).^126^ The subhazard ratios (SHRs) for hip fracture and all osteoporotic fractures (excluding fingers, toes, skull, and face), both as unadjusted and aSHRs between groups, were also not significantly different. Mortality outcomes were not reported but used as competing outcomes in their SHRs and noted to be virtually complete because the national health registries were used.

Given the potential challenges with the study design (e.g., participants were randomized before giving consent), the authors prespecified a per-protocol analysis to examine fracture outcomes between the screening and control groups with completed FRAX calculations and not in current osteoporotic treatment. The per-protocol incidence of MOF was 725/9,279 (7.8%) in the completed FRAX screening group compared with 786/9,326 (8.4%) in the completed FRAX control group with an aSHR of 0.914 (95% CI, 0.827, 1.011). The per-protocol incidence of hip fracture was 169/9,279 (1.8%) in the completed FRAX screening group compared with 202/9,326 (2.2%) in the control group with an aSHR of 0.82 (95% CI, 0.670 to 1.007), p=0.059.^126^ The per-protocol incidence of all fractures was 996 (10.7%) in the completed FRAX screening group compared with 1,025 (11.0%) in the control group with an aSHR of 0.968 (95% CI, 0.887 to 1.056).^126^

In a second, post hoc, per-protocol analysis comparing persons with high-risk FRAX who were DXA scanned with high-risk controls, the aSHR for hip fracture was 0.741 (95% CI, 0.578 to 0.950). However, this per-protocol analysis should be interpreted with caution because the women in the DXA-scanned group showed significant differences in baseline characteristics compared with the high-risk controls (e.g., they were younger, had higher rates of previous fractures, and were less likely to smoke), although some of these differences were of uncertain clinical significance. In another analysis with the second per-protocol population, authors excluded hip fractures from the MOF outcome and the MOF results became nonsignificant, suggesting that most of the differences observed for MOF were being driven by differences in hip fractures.

### The SCOOP Trial

The SCOOP RCT randomly selected women ages 70 to 85 years from 100 general practices in England and randomized them to either screening (n=6,233) with a FRAX assessment and invitation to DXA if risk was greater than or equal to an age-based threshold or to routine care as directed by the participant’s PCP (n=6,250).^120^ Participants were excluded if they were on treatment for osteoporosis (other than calcium and vitamin D) or had known comorbidity or another factor that might make participation inappropriate (e.g., advanced cancer or recent bereavement).^121^ Of participants randomized who returned the initial questionnaire with no missing data (N=12,483), the mean (SD) 10-year FRAX risk was 19.3 (8.9) percent for MOF and 8.5 (7.4) percent for hip, and 23 percent had a history of a broken bone since age 50 years. Among those who completed DXA (2,817/6,233 randomized), the mean T-score was −2.6 at the FN. Although the two randomized groups were similar in baseline demographic characteristics, those who participated in the study had higher education, higher socioeconomic status, and more frequent history of previous fractures or parental hip fracture than nonparticipants.^120^

We assessed the SCOOP study as fair quality. Because the study was pragmatic in nature, the intervention was not blinded to participants. There was minimal missing data because the analysis was conducted on an intent-to-treat basis. Of the 49 percent of women in the screening group deemed initially high risk based on FRAX hip fracture risk, 4 percent (247/6,233 randomized) were high risk and did not have a DXA (157 declined, 81 were unable to have hip BMD measured, and 9 died); 45 percent (2,817/6,233 randomized) were high risk and had a DXA. In the screening group, 14 percent (898/6,233 randomized) had a high-risk FRAX after recalculation with the FN BMD. In the screening group, over the course of the study, 24 percent (1,486/6,233 randomized) received at least one prescription for treatment, with 15 percent (953/6,233 randomized) having at least one prescription for treatment in the first 12 months. Of the high-risk screening group (703/898), 78 percent had at least one prescription in the first 6 months.^123^ In the control group, over the course of the study, 16 percent (982/6,250 randomized) received at least one prescription for treatment, suggesting evidence of contamination.^120^ Outcome ascertainment was verified with medical records, and assessors were blinded to study group assignment.^121^

At 5 years followup, the incidence of fractures excluding hands, feet, nose, skull, and cervical vertebrae and without regard to trauma (the study’s primary endpoint) for the intent-to-treat analysis was not significantly different in the invitation-to-screening group (12.9%) compared with the control group (13.6%) with an adjusted hazard ratio (aHR) of 0.94 (95% CI, 0.85 to 1.03).^126^Authors reported several prespecified secondary endpoints. The aHR for any clinical fracture (not excluding any site) was not significant, but the incidence of hip fracture was significantly lower in the screening group (2.6%) compared with the control group (3.5%; aHR: 0.72, 0.59 to 0.89).^446^ All-cause mortality was not significantly different between groups.

In a post hoc analysis evaluating the association between baseline 10-year FRAX hip risk without BMD risk and fracture incidence, there were no significant differences between the screening group and the control group at the 10th, 25th, and 50th percentile of 10-year FRAX hip risk (2.6%, 3.8%, and 6.3%, respectively) for any clinical fracture (with or without selected sites excluded).^122^ There were also no significant differences in any clinical fractures (with or without selected sites excluded) at the 75th and 90th percentiles of 10-year FRAX hip risk (10.5% and 16.8%, respectively), but there were significant differences for hip fracture incidence and when considering FRAX risk as a continuous measure, a significant interaction was observed for the association between FRAX score and hip fracture but not for any clinical fracture (with or without selected sites excluded.^122^

### The SOS Trial

The SOS RCT randomly assigned women ages 65 to 90 years from general practice registries in the Netherlands who had one or more clinical risk factors for osteoporosis and completed baseline information (N=11,032).^124,^ ^125^ Participants were excluded if they were on treatment for osteoporosis currently or in the preceding 5 years or took prednisone. Participants assigned to the screening group (n=5,575) received a multicomponent screening intervention (FRAX [without BMD], DXA, VFA, falls risk assessment, and blood chemistries to exclude secondary osteoporosis), while those assigned to the control group (n=5,457) received routine care as directed by their PCP. The mean (SD) 10-year FRAX risk of participants was approximately 24 percent (10) for MOF and 11 percent (10) for hip, and 43 percent reported a fracture after age 50 years.

We assessed the SOS study as fair quality. Because the study was pragmatic in nature, the intervention was not blinded to participants. There were little missing data because authors used an intention-to-treat analysis. Twenty-four percent of participants invited to screening (1,347/5,575 randomized) did not participate.^124^ Twenty-five percent randomized to screening (1,417/5,575 randomized) had an indication for treatment, but 31 percent of those did not start treatment.^124^ In the screening group, 21 percent (1,154/5,575 randomized) received treatment over the course of the study, with 18 percent (982/5,575 randomized) reporting starting treatment and 12 percent (657/5,575 randomized) reporting still being on treatment at 36 months.^124^ In the control group, 6 percent (316/5,457 randomized) received a DXA/VFA over the course of the study; 2 percent (112/5,457 randomized) received DXA/VFA within 3 months of randomization. About 5 percent (291/5,457 randomized) of the control group received treatment over the course of the study—3 percent (167/5,457 randomized) by 18 months.^124^ Outcome ascertainment was blinded, and fractures were confirmed with medical records.^125^

Over a mean followup of 3.7 years, no statistically significant differences were found on the primary outcome of time to first incident fracture of any type. In total, 626 (11.3%) persons in the intervention group had a fracture vs. 632 (11.7%) in the control group (aHR, 0.97 [95% CI 0.87 to 1.08]).^124^ Additionally, no statistically significant differences were found on any secondary fracture measures or mortality.^124^Authors also reported no significant interaction effects with age, history of prior fracture, or recency of prior fracture for the outcome of “all fractures.” However, there was a significant interaction with recency of prior fracture (within 2 years of baseline) for MOF and hip fracture, although these analyses were post hoc.^124^

Appendix E.1 Figure 1 Randomized, Controlled Trials of Screening vs. Usual Care: Fracture Outcomes (KQ 1)—Sensitivity Analysis Using the ROSE Intention-to-Treat Sample

* SCOOP reported an outcome entitled “osteoporotic fractures,” which were defined as clinical fractures excluding hand, foot, skull, and cervical vertebrae. It is not entirely clear how this definition differs from the definition of MOF used by the other two studies (hip, clinical vertebral, distal forearm, and humerus); as such, we have included SCOOP “osteoporosis” outcome in the estimate for both “osteoporotic fractures” and for “MOF.”

Abbreviations: ARD=absolute risk difference; CI=confidence interval; DL=DerSimonian & Laird estimator for pooling estimates; FRAX=Fracture Risk Assessment Tool; F/U=followup;Fx=fracture; KQ=key question; MOF=major osteoporotic fracture; N/n=number; ROSE=Risk-stratified Osteoporosis Strategy Evaluation; RR=risk ratio; SCOOP=Screening in the Community to Reduce Fractures in Older Women; SOS=Stichting Artsen Laboratorium enTrombosedienst (SALT) Osteoporosis Study; vs.=versus.

This figure depicts forest plots of five outcomes assessed in randomized controlled trials of screening versus usual care. The plots represent sensitivity analyses using the Risk-stratified Osteoporosis Strategy Evaluation (ROSE) randomized controlled trial intention-to-treat sample for three of the five outcomes analyzed (osteoporotic fractures, major osteoporotic fractures, and hip fractures). The pooled risk ratio for the outcome of “all fractures” in the Screening in the Community to Reduce Fractures in Older Women (SCOOP) and Stichting Artsen Laboratorium en Trombosedienst (SALT) Osteoporosis Study (SOS) trials was 0.96 with a 95 percent confidence interval between 0.90 and 1.02 with an I-squared statistic of 0 percent. The pooled risk ratio for the outcome of “osteoporotic fractures” in the SCOOP, SOS, and ROSE trials was 0.98 with a 95 percent confidence interval between 0.93 and 1.03 and the I-squared statistic was 18.9%. The pooled risk ratio for the outcome “major osteoporotic fractures” in the SCOOP, SOS, and ROSE trials was 0.97 with a 95 percent confidence interval between 0.92 and 1.02 and an I-squared statistic of 0 percent. The pooled risk ratio of hip fractures in the SCOOP, SOS, and ROSE trials was 0.90 with a 95 percent confidence interval between 0.75 and 1.07 and an I-squared statistic of 67.1 percent. The pooled risk ratio for the outcome of “mortality” in the SCOOP and SOS trials was 1.04 with a 95 percent confidence interval between 0.95 and 1.13 and an I-squared statistic of 0 percent.

## E.2 Detailed Calibration Outcomes (Key Question 2b)

Appendix E.2 Table 1 Calibration Outcomes From 12 Unique Cohorts Reported for the Accuracy of Bone Mineral Density to Predict Fracture (KQ 2b)

Sex and Fracture Type | Gradient of Risk HR (95% CI) per SD decrease in FN BMD | Observed/Expected Ratio^*^ | Calibration Plots | Hosmer-Lemeshow Goodness of Fit^†^
Men
MOF | NR | NR | NR | p=0.1672^146^
Hip | 2.30 (1.89 to 2.82)^15^ | NR | NR | p=0.2655^146^
Major nonvertebral | 2.31 (1.79 to 3.00)^182^ | NR | NR | NR
Nonvertebral | 1.37 (1.25 to 1.49)^15^ | NR | NR | NR
Women
MOF | 1.68 (1.58 to 1.78)^183^; 1.97 (1.91 to 2.03)^160^; 1.78 (1.43 to 2.2)^190^; 1.94 (1.81 to 2.08)^172^ | NR | Dose-response observed in a plot by quartile of predicted risk; no other statistics reported^150^
Hip | 2.60 (2.23 to 3.03)^183^; 2.99 (2.84 to 3.15)^160^; 2.47 (NR)^185^; 1.97 (1.76 to 2.21)^15^; 3.82 (3.17 to 4.61)^172^; 2.0 (1.9 to 2.1)^192^; 3.22 (2.47 to 4.20)^194^ | Across all quintiles of risk: 0.83 (95% CI, 0.65 to 1.04)^185^ | Dose-response observed in a plot by quartile of predicted risk; no other statistics reported^150^ | p=0.015^185^
Fragility | 2.11 (1.62 to 2.73)^186^ | NR | NR | NR
Hip or MOF | 1.70 (1.35 to 2.14)^189^ | NR | NR | NR
Nonvertebral | 1.42 (1.35 to 1.50)^15^; 1.5 (1.4 to 1.5)^192^ | NR | NR | NR
Mixed Population
MOF | 1.56 (1.42 to 1.71)^154^; 1.58 (1.50 to 1.66)^157^ | NR | NR | NR
Hip | 1.96 (1.62 to 2.37)^154^; 2.19 (1.97 to 2.43)^157^ | NR | NR | NR

* Ratios close to 1 indicate good agreement between observed and predicted.

† P values <0.05 indicate poor fit.

Abbreviations: BMD=bone mineral density; CI=confidence interval; FN=femoral neck; HR=hazard ratio; KQ=key question; MOF=major osteoporotic fracture; NR=not reported; SD=standard deviation.

## E.3 Detailed Results for Diagnostic Accuracy (KQ 2c)

### Age, Body Size, No Estrogen

#### Study Characteristics

Five fair-quality studies (total N=4,203 participants) reported on the accuracy of Age, Body Size, No Estrogen (ABONE);^206,^ ^207,^ ^233,^ ^242,^ ^245^ three studies were new to this update.^233,^ ^242,^ ^245^ Three studies were conducted in Asian countries,^207,^ ^233,^ ^245^ one was conducted in Greece,^242^ and one was conducted in Canada.^206^ One study included men;^233^ the rest were conducted exclusively among women. The mean age across studies ranged from 62 to 68 years. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 ranged from 4.0 percent to 24.4 percent across four of the included studies; the prevalence was not reported in one study.^242^

#### Findings

The reported AUC across cohorts ranged from 0.62 to 0.78 using a reference BMD measurement at the FN, LS, or both. The exception to this range was one cohort^245^ that was an outlier with respect to values reported for four different risk assessment tools, suggesting something unique about the underlying study population or study approach.

The most common score threshold reported was a score greater than or equal to 2, which was reported by four cohorts.^206,^ ^207,^ ^233,^ ^245^ Other included studies reported using a score threshold of greater than 1.5^242^ or greater than or equal to 3.^207^ The sensitivities ranged from 66 percent to 100 percent, and the specificities ranged from 16.7 percent to 60 percent, excluding the outlier study.^245^

One study reported findings separately for men vs. women.^233^ The AUC was 0.78 (95% CI, 0.64 to 0.93) in men and 0.70 (95% CI, 0.61 to 0.77) in women. The sensitivity was the same among men and women (100%); the specificity was 28 percent among men and 10 percent among women.^233^

### Age, Menopause, Menarche, BMI

#### Study Characteristics

Two fair-quality studies (total N=1,520 participants) reported on the accuracy of Age, Menopause, Menarche, BMI (AMMEB);^199,^ ^225^ neither was new to this update. Both studies were conducted in Italy, and both were exclusively conducted among postmenopausal women. The mean age of participants in one study^199^ was 65 years and in the other study^225^ ranged from 57 (normal BMD), 60 (osteopenia), to 62 years (osteoporosis) depending on BMD status. The prevalence of osteoporosis as measured by DXA BMD T-scores less than −2.5 at the FN or LS were 33.7 percent in the study^199^ enrolling postmenopausal women from general practices (race/ethnicity NR) and 47.4 percent in the study^225^ enrolling Caucasian women referred to a university bone metabolic unit for DXA, of which 13 percent were noted to have secondary osteoporosis.

#### Findings

The reported AUCs were 0.63^199^ and 0.71,^225^ both using reference BMD measurements at the FN or LS. Neither study reported sensitivity or specificity.

### Fracture Risk Assessment Tool

#### Study Characteristics

Fifteen fair-quality studies reporting on 12 unique cohorts^141,^ ^143,^ ^195,^ ^196,^ ^200,^ ^220,^ ^232–239,^ ^241^ (total N=37,756 participants) reported on the accuracy of FRAX. Ten articles were new to this update.^141,^ ^143,^ ^233–239,^ ^241^ One study was conducted in Canada,^200^ one study was conducted in Taiwan,^233^ and two studies were conducted in Australia.^196,^ ^239^ The rest of the studies were conducted in the United States. Of studies in the United States, most had a high percentage of White participants, with all but two reporting greater than 85 percent White participants.

Four studies included both men and women, with three including 44 to 65 percent male participants;^196,^ ^233,^ ^239^ another study^241^ included only 13 percent male participants. Four studies included exclusively men.^232,^ ^235,^ ^237,^ ^238^ The other studies included exclusively women.^141,^ ^195,^ ^200,^ ^220,^ ^234,^ ^236^ The mean age across studies ranged from 57 years to 80 years. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 ranged from 4.5 percent to 25.9 percent. One study had an outlying prevalence of osteoporosis of 51.1 percent; this study had a small sample size (N=45) from a rural area in the United States, included those at increased risk for osteoporosis (e.g., on chronic steroids), and did not report what site or T-score reference range was used to define osteoporosis.^241^

#### Findings

All but three studies^141,^ ^195,^ ^238,^ ^241^ reported AUCs based on FRAX MOF risk, FRAX hip fracture risk, or both. We included only FRAX risk estimates calculated without the use of BMD because BMD is the reference test for this KQ. Over all studies reporting AUCs, the AUCs ranged from 0.55 to 0.86 using a reference BMD measurement at the FN only or at the lowest site from among the TH, LS, or FN. One study^239^ also considered BMD measured at the forearm in addition to the three usual sites. Two studies^236,^ ^241^ did not report the site for the reference BMD measurement used. When limited to AUCs based on FRAX MOF risk only, AUCs ranged from 0.55 to 0.79.^143,^ ^195,^ ^196,^ ^200,^ ^220,^ ^232–237,^ ^239^ When limited to AUCs based on FRAX hip fracture only, AUCs ranged from 0.70 to 0.86.^196,^ ^233,^ ^239^ In the one study that reported AUCs based on either MOF or hip fracture risk, the AUC was 0.65 (95% CI, 0.59 to 0.71) when calculated based on patient characteristics derived from electronic health record data and was 0.72 (95% CI, 0.67 to 0.78) when based on data collected directly from participants.^237^ Four studies conducted exclusively in men or that included results separately for men reported AUCs, and these results ranged from 0.62 to 0.86.^232,^ ^233,^ ^235,^ ^237^

All but two studies^200,^ ^239^ reported sensitivity and specificity or provided data for us to calculate these estimates. For determining sensitivity and specificity, the thresholds authors used varied by type of fracture risk (MOF vs. hip vs. both) and numeric value used. Some studies reported on multiple thresholds using the same data.

Authors used an MOF risk greater than or equal to 9.3 percent (the threshold suggested for use by the USPSTF’s 2011 recommendation) in six studies.^195,^ ^220,^ ^232,^ ^234–236^ The sensitivity for this threshold among the four studies conducted exclusively in women ranged from 24 to 37 percent and the specificity ranged from 73 to 86 percent.^195,^ ^220,^ ^234,^ ^236^ Within the two studies conducted exclusively in men, the sensitivity was 39 percent^232^ and 59 percent,^235^ and the specificity was 89 percent^232^ and 59 percent.^235^ An MOF risk greater than or equal to 8.4 percent (suggested by the 2018 USPSTF recommendation) was used in one study conducted exclusively in women and was reported for a variety of age ranges.^141^ The sensitivity was 5.2 percent for women ages 50 to 54 years, 16.9 percent for women ages 55 to 59 years, and 48.5 percent for women ages 60 to 64 years. The specificity ranged from 95.8 percent for the youngest age group to 63.4 percent for the oldest age group.^141^

An MOF risk greater than or equal to 20 percent (a commonly used threshold for initiating treatment) was reported in one study.^233^ The sensitivity for this threshold was 0 percent for men and 17 percent for women, and the specificity for this threshold was 99 percent for men and 96 percent for women.

Accuracy was also reported for MOF risk thresholds between 6.5 and 10 percent in three studies.^196,^ ^235,^ ^238^ Sensitivity ranged from 53 percent to 90 percent, and specificity ranged from 32 percent to 65 percent in these studies.

Two studies used a hip fracture risk threshold of 3 percent or greater (a commonly used threshold for initiating treatment).^196,^ ^233^ The sensitivity for this threshold ranged from 80 percent to 92 percent, and the specificity ranged from 37 percent to 71 percent.

Three studies defined a positive screening test based on having either a hip fracture risk greater than 3 percent or having an MOF risk greater than 20 percent (both commonly used thresholds for initiating treatment).^237,^ ^238,^ ^241^ In the studies conducted exclusively in men, sensitivity was 27 percent^238^ and 69 percent,^237^ and the specificity was 88 percent^238^ and 54 percent.^237^ In the study conducted predominantly in women (87%), the sensitivity was 100 percent, and the specificity was 91 percent.^241^

One study conducted exclusively in men also evaluated other approaches based on either MOF or hip fracture risk (Appendix D Table 14).^238^

### Garvan Fracture Risk Calculator: Hip and MOF Risk

#### Study Characteristics

Two fair-quality studies (total N=1,084 participants) reported the accuracy of the Garvan Fracture Risk Calculator;^233,^ ^239^ both studies were new to this update. One study was conducted in Taiwan,^233^ and the other was conducted in Australia.^239^ Both studies included men and women: 55.8 percent of participants across both studies were women. The mean age in one study^233^ was 67.4 years, and the mean age in the other study^239^ was 78 years. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 was 17.5 percent in one study^233^ and was 24.5 percent in the other study, which had the higher mean age.^239^

#### Findings

The reported AUCs for the Garvan Fracture risk ranged from 0.72 to 0.80 for hip fracture and 0.71 to 0.75 for any osteoporotic fracture or MOF using a reference BMD measurement at the FN in one study^233^ or the lowest BMD at the FN, TH, LS, or forearm in the other study.^239^

For determining sensitivity and specificity, one study reported score thresholds of greater than or equal to 3 percent for hip fracture risk and greater than or equal to 20 percent for any MOF.^233^ The other study used an empirically derived, age-stratified risk threshold for both hip and MOF risk.^239^ The sensitivities ranged from 20 percent to 72 percent, and the specificities ranged from 73 percent to 96 percent across these risk thresholds.

One study reported findings separately for men vs. women for both hip fracture risk and MOF risk.^233^ The AUC for hip fracture risk was 0.72 (95% CI, 0.44 to 1.0) in men and 0.80 (95% CI, 0.73 to 0.88) in women. The AUC for MOF risk was 0.72 (95% CI, 0.46 to 0.98) in men and 0.75 (95% CI, 0.66 to 0.85) in women. The sensitivity for hip fracture risk was 60 percent among men and 28 percent among women; the specificity was 79 percent among men and 95 percent among women. The sensitivity for MOF risk was 20 percent among men and 55 percent among women; the specificity was 96 percent among men and 73 percent among women.

### Male Osteoporosis Risk Estimation Score

#### Study Characteristics

Two fair-quality studies and 1 good-quality study (total N= 4,788 participants) reported on the accuracy of the Male Osteoporosis Risk Estimation Score (MORES)^197,^ ^202,^ ^232^; none of the studies were new to this update. All three studies were conducted in the United States, and all studies were conducted exclusively among predominantly White men (76% to 81% of participants). The mean age for the subjects varied from 63 to 70 years. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 ranged from 4.3 percent^197^ and 4.5 percent^232^ in two studies, but was 10 percent in one study.^202^ The study with the highest prevalence used the BMD reference values from White men ages 20 to 29 years to generate T-scores from, compared to the use of values from NHANES III for young, non-Hispanic women in the other two studies.

#### Findings

The reported AUCs ranged from 0.66 to 0.87 using reference BMD measurements at the FN, TH, or LS.^197,^ ^202,^ ^232^ One study also evaluated efficacy when reference BMD was any site (thoracic vertebra, LS, arms, ribs, pelvis, legs), and the reported AUC was 0.73.^202^

For determining sensitivity and specificity, all studies reported results based on a score threshold of greater than or equal to 6. The sensitivities ranged from 58 to 96 percent, and the specificities ranged from 61 to 70 percent.

One study^202^ reported on the sensitivity and specificity of identifying osteoporosis at the LS stratified by age bands of 5 years starting at age 50 years through age 89 years. Sensitivity was highest in the age group of 80 to 84 years (8%) and lowest in the age group of 50 to 54 years (29%).^202^ Specificity was highest in the age group of 50 to 54 years (90%) and lowest in the age group of 85 to 89 years (23%).^202^ This study also reported on the sensitivity and specificity for identifying osteoporosis at the LS stratified by race/ethnicity. Sensitivity was lowest in White participants (51% [95% CI, 38% to 64%]) and highest in participants of other (i.e., not African American or Mexican American) ethnicity (90% [95% CI, 66% to 98%]). Specificity was lowest in participants of other ethnicities (50% [95% CI, 40% to 60%]) and highest in White patients (67% [95% CI, 65% to 70%]).^202^

### Male Osteoporosis Screening Tool

#### Study Characteristics

One fair-quality study (total N=4,658 participants) reported on the accuracy of the Male Osteoporosis Screening Tool (MOST);^218^ it was not new to this update. This study was conducted among men in the United States and Hong Kong from the MrOs cohort study. The mean age of enrolled participants was not reported, but only men age 65 years or older were enrolled in the MrOs cohort study. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 at the FN or at the LS was 5.0 percent among U.S. participants.^218^

#### Findings

Data were analyzed separately for participants in the United States and Hong Kong. BMD reference measurements were reported for both FN alone and for the lowest T-score from either the FN or LS or TH.^218^ The reported AUCs for U.S. participants were 0.799 (FN or LS or TH) and 0.807 (FN only) and for Hong Kong participants were 0.831 (FN or LS or TH) and 0.876 (FN only).^218^

For determining sensitivity and specificity, the data for participants from the United States were reported based on a score threshold of less than or equal to 26. The sensitivity was 89 percent, and the specificity was 50 percent based on lowest site BMD. The data for participants from Hong Kong were reported based on a score threshold of less than or equal to 21. The sensitivity was 87 percent, and the specificity was 59 percent based on lowest site BMD.

### Male Simple Calculated Osteoporosis Risk Estimation

#### Study Characteristics

One fair-quality study (total n=197 participants) reported on the accuracy of the Male Simple Calculated Osteoporosis Risk Estimation (MSCORE);^216^ it was not new to this update. This study was conducted exclusively in the United States; all participants were men age 40 years or older (94% Caucasian) enrolled from Veterans Affairs general medical or specialty clinic sites. The mean age for participants was 68 years. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 at the FN was 11.2 percent. This study also reported on a separate cohort of 134 African American men (mean age, 61 years) comprising a convenience sample recruited separately from the original development and validation cohorts.

#### Findings

The reported AUC for MSCORE was 0.84 (95% CI, 0.74 to 0.95) using a reference BMD measurement at the FN. For determining sensitivity and specificity, the study reported score thresholds of greater than or equal to 9. The sensitivity was 88 percent, and the specificity was 57 percent. In the separate African American convenience sample, the sensitivity was 93 and 100 percent depending on whether a Caucasian or African American BMD reference range was used to calculate the T-score, respectively. Similarly, the specificity was 73 or 79 percent.

### National Osteoporosis Foundation Risk Score

#### Study Characteristics

Four fair-quality studies (total N=4,087 participants) reported on the accuracy of the National Osteoporosis Foundation (NOF) risk score.^199,^ ^206,^ ^225,^ ^226^ No new studies were included in this update. Two studies were conducted in Italy,^199,^ ^225^ one was conducted in Canada,^206^ and one was conducted in the United States.^226^ Participants from the studies in Canada and the United States were recruited from the general population,^206,^ ^226^ while the participants in the Italian studies were from either general practice clinics^199^ or referred to an osteoporosis clinic from general practice clinics or gynecologists.^225^ All studies included only postmenopausal women. The mean age across studies ranged from 60.5 to 69 years. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 at the FN only or at the FN or LS ranged from 10 percent to 47 percent across studies.

#### Findings

The reported AUCs across studies ranged from 0.60 to 0.70 using a reference BMD measurement at the FN only or measurement at the FN and LS. All studies used a threshold score of 1 or more. Only two studies reported sensitivity and specificity.^206,^ ^226^ The sensitivities were 96 percent and 100 percent, and the specificities were 10 percent and 18 percent in those studies.^206,^ ^226^

One study reported findings separately for different age groups.^226^ The group ages 45 to 64 years had an AUC of 0.69; sensitivity was 100 percent and specificity was 19 percent. The group age 65 years or older had an AUC of 0.60; sensitivity was 100 percent and specificity was 0 percent.

### Osteoporosis Risk Assessment Instrument

#### Study Characteristics

Twenty-two publications^199,^ ^203,^ ^206–210,^ ^214,^ ^217,^ ^223–228,^ ^230,^ ^231,^ ^233,^ ^234,^ ^236,^ ^242,^ ^245^ covering 21 unique cohorts (total N=24,427 participants) reported on the accuracy of the Osteoporosis Risk Assessment Instrument (ORAI) for 28 comparisons. We rated all analyses as fair quality. Five new studies were included in this update.^233,^ ^234,^ ^236,^ ^242,^ ^245^ Six studies were conducted in the United States,^224,^ ^226,^ ^230,^ ^231,^ ^234,^ ^236^ five in Commonwealth countries,^206,^ ^208,^ ^217,^ ^223,^ ^227^ seven in Europe,^199,^ ^203,^ ^208–210,^ ^214,^ ^217,^ ^225,^ ^228,^ ^242^ and three studies in Asia.^207,^ ^233,^ ^245^ Twelve studies included only perimenopausal or postmenopausal women;^199,^ ^203,^ ^207,^ ^208,^ ^214,^ ^224–226,^ ^228,^ ^236,^ ^242,^ ^245^ the one study that included both men and women was 66 percent women.^233^ Five studies included participants referred for BMD testing or to an osteoporosis-related clinic.^208,^ ^210,^ ^214,^ ^217,^ ^242^ Three studies recruited participants from the general population,^206,^ ^226,^ ^233^ and one study recruited participants from both primary care and specialty clinics.^203^ The mean age across studies ranged from 50.5 to 70.5 years. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 (at one or at least one site if multiple sites measures) had a wide range from 4.6 percent to 47.4 percent, although half were between 10 percent and 30 percent,^203,^ ^206–208,^ ^214,^ ^223,^ ^224,^ ^230,^ ^231,^ ^233,^ ^234,^ ^245^ and one study did not report osteoporosis prevalence.^242^

#### Findings

Twenty publications covering 19 unique cohorts reported AUC for women.^199,^ ^203,^ ^206–210,^ ^214,^ ^217,^ ^223–226,^ ^228,^ ^230,^ ^233,^ ^234,^ ^236,^ ^242,^ ^245^ These AUCs ranged from 0.32 to 0.84 excluding one extreme outlier.^245^ In this study, only 15 percent of its 150 participants with osteoporosis reported an AUC of 0.047 and 0.129.^245^ In another study of 525 participants, half of whom had osteoporosis, authors reported an AUC of 0.32.^225^ The AUCs in the rest of the studies ranged from 0.60 to 0.84.^227,^ ^231^

For determining sensitivity and specificity, studies used a variety of thresholds ranging from greater than or equal to 8 up to greater than 15. Two studies examined a range of thresholds: greater than 9, 16, and 20^207^ and greater than 8 and 13,^209^ respectively. Twelve studies used a threshold greater than or equal to 9.^203,^ ^206,^ ^207,^ ^214,^ ^224,^ ^226,^ ^230,^ ^231,^ ^234,^ ^236,^ ^245^ Five studies used a threshold greater than or equal to 8.^199,^ ^209,^ ^210,^ ^223,^ ^225^ One study did not report a threshold nor did it report sensitivity or specificity.^217^ Two other studies did not report sensitivity or specificity either.^225,^ ^447^ The sensitivities ranged from 52 percent to 100 percent for studies restricted to those using a threshold of 8 or 9^199,^ ^203,^ ^206,^ ^207,^ ^209,^ ^210,^ ^214,^ ^223–226,^ ^230,^ ^231,^ ^234,^ ^236,^ ^245^ and from 43 percent to 89 percent for the remainder of thresholds.^207–209,^ ^217,^ ^227,^ ^228,^ ^242^ The specificities ranged from 5 percent to 100 percent (restricted to studies using thresholds of 8 or 9) and from 44.7 percent to 86 percent (for the remainder).

Five studies reported results in women younger than age 65 years; however, these studies did not use the same score threshold, which may partially explain the variation in results for sensitivity and specificity.^209,^ ^226,^ ^228,^ ^234,^ ^236^ The AUCs ranged from 0.60 to 0.84, the sensitivities ranged from 44 percent to 99 percent, and the specificities ranged from 36 percent to 77 percent.^209,^ ^226,^ ^228,^ ^234,^ ^236^

The one study that included men reported an AUC of 0.87 for men and, using a score threshold of greater than or equal to 9, reported a sensitivity of 100 percent and a specificity of 19 percent.^233^

### Osteoporosis Index of Risk

#### Study Characteristics

Seven fair-quality studies (total N=7,173 participants) reported on the accuracy of the Osteoporosis Index of Risk (OSIRIS).^203,^ ^208,^ ^210,^ ^214,^ ^217,^ ^233,^ ^242^ Two new studies were included in this update.^233,^ ^242^ Six studies were conducted in Europe; two in the United Kingdom,^199,^ ^225^ two in Spain,^203,^ ^214^ one in Belgium,^210^ and one in Greece;^242^ one study was conducted in Taiwan.^448^ All studies except one included only postmenopausal women; the one study that included both men and women was 66 percent women.^233^ Five studies included participants referred for BMD testing or to an osteoporosis-related clinic.^208,^ ^210,^ ^214,^ ^217,^ ^242^ One study recruited participants from the population,^233^ and one study recruited participants from both primary care and specialty clinics.^203^ The mean age across studies ranged from 54 to 67 years. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 (at one or at least one site if multiple sites measured) ranged from 18 percent to 34 percent across six of the seven included studies; one study did not report osteoporosis prevalence.^242^

#### Findings

The reported AUCs for women across studies ranged from 0.63 to 0.83. For determining sensitivity and specificity, most studies used a threshold of around 1; three studies used a threshold of less than or equal to 1,^210,^ ^214,^ ^233^ one study used a threshold of less than 1,^210^ and one study reported using a threshold of less than 0.5 and less than 1.5.^242^ As outliers, one study used a threshold of less than 0,^208^ and one used a threshold of less than or equal to −3.^203^ One study did not report a threshold nor did it report sensitivity or specificity.^217^ The sensitivities ranged from 58 percent to 100 percent (both restricted to studies using thresholds around 1 and unrestricted), and the specificities ranged from 6 percent to 69 percent (restricted to studies using thresholds around 1).^210,^ ^214,^ ^233,^ ^242^ This level of variation may be due to the underlying population or sites of reference BMD measurement.

The one study that included men reported an AUC of 0.94 for men and, using a score threshold of less than or equal to 1, reported a sensitivity of 100 percent and a specificity of 29 percent.^233^

### Osteoporosis Self-Assessment Tool

#### Study Characteristics

Thirty studies reported on the accuracy of Osteoporosis Self-Assessment Tool (OST).^159,^ ^195,^ ^196,^ ^198–201,^ ^203,^ ^205,^ ^208–210,^ ^214,^ ^216–219,^ ^221,^ ^223,^ ^225,^ ^228,^ ^230,^ ^231,^ ^234–237,^ ^240,^ ^242,^ ^243^ One study was good quality;^205^ the rest were fair quality. Seven studies were new to this update.^234–237,^ ^240,^ ^242,^ ^243^ Eleven studies were conducted in the United States,^195,^ ^198,^ ^216,^ ^219,^ ^221,^ ^230,^ ^231,^ ^234–237^ and the rest were conducted in Canada, Australia, or various European or Asian countries. Nine studies were conducted exclusively in men,^198,^ ^201,^ ^216,^ ^218,^ ^219,^ ^221,^ ^235,^ ^237,^ ^240^ one study was conducted in men and women and reported results by sex,^243^ one study was conducted in men and women but did not report results separately,^196^ and the 19 remaining studies were conducted exclusively in women.^159,^ ^195,^ ^199,^ ^200,^ ^203,^ ^205,^ ^208–210,^ ^214,^ ^217,^ ^223,^ ^225,^ ^228,^ ^230,^ ^231,^ ^234,^ ^236,^ ^242^ The mean age across studies ranged from 51 years to 80 years; however, more than two-thirds had a mean age of 60 years or older. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 ranged from 4.6 percent to 47.4 percent; the prevalence was not reported in one study.^242^ The reference standard used to determine the presence of osteoporosis varied across studies: some used a single measurement at only one anatomical site, typically the FN or LS, while others used the lowest T-score from either the FN or LS or the FN, LS, or TH.

#### Findings

Across the 29 studies reporting AUCs, estimates ranged from 0.32 to 0.89. Nineteen (63%) studies reported an AUC of 0.70 or higher.^159,^ ^195,^ ^196,^ ^200,^ ^203,^ ^205,^ ^208–210,^ ^216,^ ^218,^ ^219,^ ^221,^ ^223,^ ^230,^ ^236,^ ^237,^ ^240,^ ^243^

All but four studies reported sensitivity and specificity.^199,^ ^200,^ ^217,^ ^225^ Of those studies reporting sensitivity and specificity, authors used different score thresholds, and some studies reported accuracy results for more than one threshold. The most common threshold used was a score less than 2, reported by 14 studies.^195,^ ^201,^ ^205,^ ^210,^ ^214,^ ^216,^ ^219,^ ^221,^ ^223,^ ^228,^ ^234–236,^ ^243^ Less than 2 is the threshold specified in the first use of the tool in a U.S. population and was selected based on it resulting in an approximately 90 percent sensitivity.^231^ This is the same approach used by the original developers of the tool to establish a score threshold; however, the score threshold corresponding to a 90 percent sensitivity among the development cohorts that were in Asian populations was a score less than −1.^449^

Across the entire evidence base that used varied score thresholds, sensitivities ranged from 29 percent to 95 percent, and specificities ranged from 25 percent to 92 percent. At a threshold of less than 2, the sensitivities ranged from 53 percent to 95 percent, and the specificities ranged from 36 percent to 74 percent. When limited to the 11 studies reporting in women, the sensitivities ranged from 53 percent to 95 percent, and the specificities ranged from 37 percent to 72 percent. Seven studies reported findings among women younger than age 65 years.^159,^ ^195,^ ^200,^ ^209,^ ^228,^ ^234,^ ^236^ The AUCs ranged from 0.63 to 0.77. Sensitivities ranged from 47 percent to 89 percent, and specificities ranged from 45 percent to 81 percent; however, studies used different thresholds which likely contributed the variability in estimates across studies.

Other reported thresholds included less than (or equal to) 1 (6 studies^159,^ ^209,^ ^221,^ ^231,^ ^235,^ ^237^), less than (or equal to) −1 (5 studies^203,^ ^208,^ ^209,^ ^230,^ ^235^), less than (or equal to) 0 (4 studies^196,^ ^198,^ ^235,^ ^450^), less than 3 (4 studies^216,^ ^221,^ ^235,^ ^242^), less than −2 (1 study^218^), less than 6 (1 study^198^), and less than −1.86 (1 study^240^). The use of thresholds other than less than 2 or less than −1 appears to be authors’ attempts to assess the influence of different cutoff scores on accuracy or to maximize the accuracy of the tool in the specific population under study. These data demonstrate as much variation among studies using the same score threshold as there is variation across studies that used different score thresholds. This variation is likely explained by differences in the site of BMD measurement used to determine osteoporosis, differences in reference values used for determining T-scores, and differences in the characteristics of the study populations (e.g., population-based cohorts vs. referral populations).

In the studies conducted exclusively in men or reporting separately for men, the AUCs ranged from 0.63 to 0.89, and, across the various score threshold used, sensitivities ranged from 40 percent to 93 percent, and specificities ranged from 25 percent to 85 percent.^198,^ ^201,^ ^216,^ ^218,^ ^219,^ ^221,^ ^235,^ ^237,^ ^240,^ ^243^ When limited to the studies using a score threshold of less than 2, the sensitivities ranged from 62 percent to 89 percent, and the specificities ranged from 36 percent to 74 percent.^201,^ ^216,^ ^218,^ ^219,^ ^221,^ ^235,^ ^243^

### Osteoporosis Self-assessment Tool for Asians

#### Study Characteristics

Eleven fair-quality studies (total N=8,304 participants) reported on the accuracy of the Osteoporosis Self-assessment Tool for Asians (OSTA).^201,^ ^204,^ ^207,^ ^212,^ ^213,^ ^215,^ ^227,^ ^229,^ ^233,^ ^244,^ ^245^ Three new studies were included in this update.^233,^ ^244,^ ^245^ Nine studies were conducted in Asia; four in South Korea;^204,^ ^215,^ ^229,^ ^244^ two in Hong Kong;^212,^ ^213^ and one each in Singapore,^210^ Taiwan,^233^ and Malaysia.^245^ One study was conducted in Australia (98.6% participants were White),^227^ and one study was conducted among a population-based sample in Portugal (race and ethnicity not reported).^201^ Six studies were conducted exclusively among women,^204,^ ^207,^ ^213,^ ^215,^ ^227,^ ^245^ four studies were conducted exclusively among men,^201,^ ^212,^ ^229,^ ^244^ and one study included both men (34%) and women (66%).^233^ Most studies recruited participants from the local community^201,^ ^207,^ ^212,^ ^213,^ ^227,^ ^233^ or from nationally representative samples.^204,^ ^229,^ ^244^ One study recruited participants from a primary care clinic,^245^ and one study recruited participants from a menopause clinic.^215^ The mean age across studies in women ranged from 59 to 71 years. The mean age across studies in men ranged from 58 to 67 years. The prevalence of osteoporosis in women as measured by DXA BMD T-score less than −2.5 at one or more sites ranged from 11 percent to 42 percent, and the prevalence in men ranged from 6 percent to 18 percent.

#### Findings

The reported AUCs for women across studies ranged from 0.62 to 0.87 using a reference BMD measurement at either the FN, LS, or both, except for one study that was an extreme outlier with respect to values reported for this tool (along with five other risk assessment tools), suggesting something unique about the underlying study population or study approach; results for this study are not reported further in the text.^245^ One study, conducted in Australia, did not report an AUC.^227^

The reported AUCs for men across five studies ranged from 0.62 to 0.94.^201,^ ^212,^ ^229,^ ^233,^ ^244^ The AUC in the one study conducted in Portuguese men^201^ did not vary from the AUCs reported by the other studies that were all conducted in Asian countries.

The thresholds used for the OSTA varied widely, ranging from less than 0 to −1 and −2 in women and ranging from less than 2, to 0.5, 0, and −1, in men, with the threshold of less than or equal to −1 most used among both women and men. At this threshold, the sensitivities ranged from 41 percent to 100 percent, and the specificities ranged from 27 percent to 67 percent in women.^204,^ ^207,^ ^213,^ ^215,^ ^227,^ ^233^ For the three included studies in men that used the threshold of less than or equal to −1, the sensitivities ranged from 71 percent to 100 percent, and the specificities ranged from 58 percent to 68 percent.^212,^ ^229,^ ^233^

### Simple Calculated Osteoporosis Risk Estimation

#### Study Characteristics

Twenty publications reporting on 18 unique cohorts (N=24,461 participants) reported on the accuracy of the Simple Calculated Osteoporosis Risk Estimation (SCORE).^195,^ ^203,^ ^206–211,^ ^217,^ ^222,^ ^224,^ ^226,^ ^228,^ ^230,^ ^231,^ ^233,^ ^234,^ ^236,^ ^242,^ ^245^ We rated all analyses as fair quality. Five of the studies were new to this update.^233,^ ^234,^ ^236,^ ^242,^ ^245^ One study was conducted in Canada,^206^ six studies were conducted in European countries,^203,^ ^208–211,^ ^217,^ ^228,^ ^242^ and three studies were conducted in Asian countries.^207,^ ^233,^ ^245^ The rest of the studies were conducted in the United States. A third of participants (n=186) in one study were men;^233^ the rest of the studies were conducted exclusively among women. The mean age across studies ranged from 51 years to 69 years. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 ranged from 4.6 percent to 34.2 percent. This wide variation could be explained by differences in age in the enrolled populations; the study with the lowest prevalence^228^ had the lowest mean age, and the study with the highest prevalence^226^ had the highest mean age. Studies also varied by whether they reported prevalence based on lowest T-score at any site or based on one site.

#### Findings

All but one study^231^ reported AUCs. The AUCs ranged from 0.58 to 0.91 (except for one outlier study that reported 0.072 and 0.161) using a reference BMD measurement at the FN, TH, LS, or lowest T-score from any of the three sites. Two studies^236,^ ^242^ did not report the site for the reference BMD measurement used. When limited to women only, the AUCs ranged from 0.58 to 0.87.

For determining sensitivity and specificity, the most common threshold reported was a score greater than or equal to 6 and was used by 11 studies.^203,^ ^206,^ ^211,^ ^224,^ ^226,^ ^228,^ ^230,^ ^233,^ ^234,^ ^236,^ ^245^ The sensitivities for this threshold ranged from 54 to 100 percent, and the specificities ranged from 15 to 72 percent (except for outliers in two studies, which reported 8%^245^ and 93%^230^); however, about half of the studies reported specificities less than 50 percent. Five studies reported a score threshold of greater than or equal to 7.^195,^ ^209,^ ^210,^ ^222,^ ^231^ The sensitivities for this threshold ranged from 74 to 94 percent, and the specificities ranged from 24 to 71 percent. Five studies reported results for score thresholds of between 8 and 20.75 (Appendix D Table 14).^207–209,^ ^211,^ ^242^

At a score threshold of greater than 6 or 7, sensitivities ranged from 54 to 100 percent, and specificities ranged from 24 to 72 percent (except for one outlier that reported 93%^230^).

Six studies reported findings among women younger than age 65 years.^195,^ ^209,^ ^226,^ ^228,^ ^234,^ ^236^ In this age group, AUCs ranged from 0.58 to 0.87, sensitivities ranged from 62 percent to 100 percent, and specificities ranged from 25 percent to 71 percent; however, the same score threshold was not used by all studies.

One study, conducted in Taiwan, included 34 percent men and reported results separately for men and women.^233^ For men, the AUC was 0.91 with a sensitivity of 100 percent and specificity of 45 percent at a score threshold of 6 or greater in reference to BMD measured at the FN. The AUC for women was 0.80, with a sensitivity of 100 percent and a specificity of 15 percent.

### Study of Osteoporotic Fractures Research Group Study Utilizing Risk Factors

#### Study Characteristics

Three fair-quality studies (total N=1,720 participants) reported on the accuracy of Study of Osteoporotic Fractures Research Group Study Utilizing Risk Factors (SOFSURF);^208,^ ^227,^ ^231^ none of the studies were new to this update. One study was conducted in the United Kingdom,^208^ one was conducted in Australia,^227^ and one was conducted in the United States.^231^ All three studies were conducted exclusively among women. The mean age across studies ranged from 60 to 71 years. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 ranged from 13.8 percent to 41.5 percent. In addition to difference in mean age of the study populations, we note that these studies each used a different normative reference database to transform raw BMD values into T-scores, which may also explain differences in the prevalence of osteoporosis among these studies.

#### Findings

Only one study (N=208) reported an AUC, which was 0.72 (95% CI, 0.67 to 0.78), using the lowest BMD measurement at the LS or TH as the reference standard.^208^

All three studies used different score thresholds for determining sensitivity and specificity; one study used a score threshold of greater than or equal to 1,^208^ another used a score threshold of greater than 1.7,^227^ and another study used a score threshold of greater than or equal to 0.^231^ The sensitivities ranged from 72 percent to 92 percent, and the specificities ranged from 36 percent to 67 percent.

### Veterans Affairs Fracture Absolute Risk Assessment Tool

#### Study Characteristics

One fair-quality study (total N=463 participants) reported on the accuracy of the Veterans Affairs Fracture Absolute Risk Assessment tool (VA-FARA);^237^ this study was new to this update. This study was conducted in the United States, and all participants were men (94% Caucasian). The mean age of enrolled participants was 80 years. The prevalence of osteoporosis as measured by DXA BMD T-score less than −2.5 at either the FN, TH, or LS was 24 percent. Only men older than age 70 years assigned to the bone health team at the study site were enrolled, potentially explaining the high incidence of osteoporosis among participants.

#### Findings

The reported AUC was 0.640 (95% CI, 0.58 to 0.70) using a reference BMD measurement for the lowest T-score at the FN, LS, or TH. For determining sensitivity and specificity, the study reported score thresholds of greater than 20 percent risk for major fracture or 3 percent for hip fracture. The sensitivity was 64 percent, and the specificity was 58 percent.

## E.4 Detailed Results: Benefits and Harms of Treatment (Key Questions 4 and 5)

### KQ 4 Detailed Study Characteristics: Bisphosphonates

#### Alendronate

We identified eight fair- to good-quality RCTs (total N=9,052) that compared alendronate with placebo and reported fracture outcomes; none reported mortality outcomes.^252–254,^ ^256,^ ^259,^ ^267,^ ^268,^ ^277^ The largest study, which was conducted in the United States, was the Fracture Intervention Trial (FIT; N=4,432).^254^ The remaining seven trials had sample sizes ranging from 144 to 1,908 and consisted of four international multicenter studies^252,^ ^256,^ ^259^ and three U.S. studies.^253,^ ^268,^ ^277^ All studies were conducted in postmenopausal women. All studies reported the race and ethnicity of the study population, the majority of whom were White. Three studies included participants with prior fracture at baseline, making up 48.5 percent of participants in one study,^267^ 21 percent of participants in the second study,^256^ and 34 to 42 percent in the third study. No participants had fractures in three studies.^252–254^ Two studies did not specify the proportion of participants with fractures at baseline.^259,^ ^268^ The duration of intervention ranged from 1 to 3 years. Three trials compared daily (10 mg) or weekly (70 mg) alendronate with placebo,^252,^ ^259,^ ^267^ whereas the others compared a range of 1 mg to 40 mg of daily alendronate with placebo.^253,^ ^254,^ ^256,^ ^268,^ ^277^ In the four dose-ranging studies, the groups that received daily doses above 10 mg were switched to a lower dose or placebo during the study period.

#### Zoledronic Acid

We identified three fair-quality^260,^ ^262,^ ^272^ and two good-quality RCTs^251,^ ^269^ (total N=3,780) examining fracture outcomes for patients receiving zoledronic acid compared with placebo and two that reported mortality.^251,^ ^269^ Two studies were new to this update.^269,^ ^272^ The studies included sample sizes ranging from 50 to 2,000. Four of the trials were conducted in postmenopausal women,^260,^ ^262,^ ^269,^ ^272^ and one included only men ages 50 to 85 years.^251^ Three studies reported the race and ethnicity of participants, the majority of whom were White or European,^251,^ ^260,^ ^269^ and two studies did not report race or ethnicity.^262,^ ^272^ Four of the studies reported the proportion of participants with prior fractures at baseline ranging from 14 percent to 42 percent of the total study population,^251,^ ^262,^ ^269,^ ^272^ and one reported no participants with prior fractures.^260^ The intervention duration ranged from 1 to 6 years. Three studies^251,^ ^262,^ ^269^ compared 5-mg dosages of zoledronic acid intravenous (IV) with placebo, and two studies^260,^ ^272^ included dosages ranging from 0.25-mg to 5-mg IV. Two studies administered zoledronic acid as a single dosage,^262,^ ^272^ one study administered dosages at 12-month intervals,^251^ and one study administered dosages at 18-month intervals.^269^ Lastly, one study administered dosages at intervals ranging from 3 months to 1 year with shorter intervals being used for lower dosages and longer intervals for higher dosages.^260^

#### Risedronate

We identified four fair-quality RCTs (total N=10,161) examining fracture outcomes for patients receiving risedronate vs. placebo.^257,^ ^258,^ ^261,^ ^267^ None of these studies reported mortality data. The studies included sample sizes ranging from 111 to 9,331, with the largest being an international multicenter study.^257^ All studies were conducted in postmenopausal women, nearly all of whom were White. Two studies reported the prevalence of prior fractures at baseline as 41 percent^257^ and 48.5 percent,^267^ one study reported no participants with fractures at baseline,^258^ and one study did not report about this characteristic.^261^ The intervention duration ranged from 3 months to 2 years. All studies compared 5 mg of daily risedronate with placebo. Some studies also compared 2.5 mg daily risedronate^257^ and a cyclic regimen of 5 mg daily for the first 2 weeks of the month followed by placebo for the rest of the month with placebo.^258^

#### Ibandronate

We identified four fair-quality RCTs (total N=564) that examined fracture or mortality outcomes for patients receiving ibandronate vs. placebo, none of which reported fracture outcomes.^264–266,^ ^275^ The studies included postmenopausal women with sample sizes ranging from 144 to 240. All participants in one study were White women,^264^ and the other three studies did not report the race or ethnicity of participants. Two studies had no participants with prior fractures,^264,^ ^275^ and two did not report a history of prior fractures. The intervention duration ranged from 3 months to 2 years. One study compared 150 mg of monthly ibandronate to placebo^275^ and one study compared a range of daily doses of ibandronate from 0.25 mg to 5.0 mg with placebo.^264^ One study compared 0.25 mg daily ibandronate and an intermittent cyclic dose of 20 mg daily for the first 24 days of every 3 months followed by 9 weeks without an active drug with placebo.^265^ Another study compared monthly doses of ibandronate ranging from 50 to 150 mg with placebo, including one arm that received 50-mg ibandronate for the first month and 100 mg for the next 2 months.^266^

### Sensitivity Analyses KQ 4 Bisphosphonates

Appendix E.4 Table 1 Results From Sensitivity Analyses for KQ 4 Evaluating Various Dosages of Bisphosphonates and Methods for Pooling Data With Rare Events

Outcome | RR; FDA Doses | Peto OR; FDA Doses | RR; All Doses | Peto OR; All Doses
| Measure of effect (95% CI, I^2^ value)
Vertebral fractures | 0.51 (0.39 to 0.66, I^2^=0%) | 0.50 (0.39 to 0.64, I^2^=0%) | 0.50 (0.38 to 0.66, I^2^=0%) | 0.50 (0.38 to 0.65, I^2^=0%)
Nonvertebral fractures | 0.81 (0.74 to 0.88, I^2^=0%) | 0.78 (0.71 to 0.86, I^2^=0%) | 0.81 (0.75 to 0.88, I^2^=0%) | 0.79 (0.72 to 0.87, I^2^=0%)
Hip fractures | 0.67 (0.45 to 1.00, I^2^=0%) | 0.66 (0.44 to 0.99, I^2^=0%) | 0.67 (0.45 to 1.00, I^2^=0%) | 0.66 (0.44 to 0.99, I^2^=0%)
Mortality | 0.72 (0.49 to 1.05, I^2^=0%) | 0.70 (0.47 to 1.04, I^2^=0%) | 0.71 (0.48 to 1.03, I^2^=0%) | 0.70 (0.47 to 1.03, I^2^=0%)

Abbreviations: CI=confidence interval; FDA=U.S. Food and Drug Administration; KQ=key question; OR=odds ratio; RR=relative risk.

Appendix E.4 Table 2 Results From Sensitivity Analyses for KQ 4 Evaluating Different Types of Vertebral Fractures

Vertebral Fracture Type | RR; Measure of Effect (95% CI, I^2^ value) | Peto OR; Measure of Effect (95% CI, I^2^ value)
All Vertebral Fractures | 0.51 (0.39 to 0.66, I^2^=0%) | 0.50 (0.38 to 0.66, I^2^=0%)
Clinical Vertebral Fractures | 0.44 (0.24 to 0.79, I^2^=0%) | N/A^*^
Radiographic Vertebral Fractures | 0.51 (0.39 to 0.66, I^2^=0%) | 0.50 (0.39 to 0.65, I^2^=0%)

* Only 1 study reported more than 0 clinical vertebral fractures in at least one study arm, therefore meta-analysis was not possible.

Abbreviations: CI=confidence interval; KQ=key question; OR=odds ratio; RR=relative risk.

### KQ 4 Detailed Study Characteristics: Denosumab

We identified six fair-quality RCTs (total N=9,108) evaluating denosumab compared with placebo.^278–280,^ ^284–286^ Two studies were new to this update.^278,^ ^286^ The largest study was the phase 3 international, multicenter Fracture Reduction Evaluation of Denosumab in Osteoporosis Every 6 Months (FREEDOM) trial (N=7,808).^280–282,^ ^303^ The other four trials had sample sizes ranging from 135 to 365. One study was an international multicenter study^278^ and the rest were conducted in the United States,^284^ the United States and Canada,^285^ Japan,^279^or Korea.^286^ Two studies reported the race and ethnicity of the study population, a majority of whom were White (86.2%, 94.2%)^278,^ ^284^ and another was conducted exclusively among Japanese individuals.^279^ Most were conducted in postmenopausal women (mean age range, 59 to 72 years) with low bone mass or osteoporosis (mean T-score ranging from −3.0 to −1.6 at LS, TH, or FN). One study was conducted exclusively in men ages 30 to 85 years with low bone mass or osteoporosis (mean T-score ranging from −2.0 to −1.3 at the LS, TH, FN, or trochanter.^278^ Two trials excluded women with any previous fractures.^284,^ ^285^ The other three trials in women had between 23 percent and 50 percent of participants with a prior fracture.^279,^ ^280,^ ^286^ The trial conducted in men had 39.3 percent of participants with any prior fracture.^278^ Five trials evaluated subcutaneous denosumab (60 mg every 6 months against placebo and measured outcomes at 1 to 3 years followup),^278–280,^ ^284,^ ^285^ while one trial compared a single 60-mg intravenous dose of denosumab with placebo at 6 months followup.^286^

### Sensitivity Analyses KQ 4 Denosumab

Appendix E.4 Table 3 Results From Sensitivity Analyses for KQ 4 Evaluating Various Dosages of Denosumab and Methods for Pooling Data With Rare Events

Outcome | RR; FDA Doses | Peto OR; FDA Doses | RR; All Doses | Peto OR; All Doses
| Measure of effect (95% CI, I^2^ value)
Vertebral fractures | | | 0.33 (0.26 to 0.41, I^2^=0%) | 0.34 (0.28 to 0.42, I^2^=0%)
Nonvertebral fractures
Hip fractures | 0.61 (0.38 to 0.99, I^2^=0%) | 0.61 (0.38 to 0.98, I^2^=0%)
Mortality | | | 0.79 (0.58 to 1.07, I^2^=0%) | 0.79 (0.58 to 1.08, I^2^=0%)

Abbreviations: CI=confidence interval; FDA=U.S. Food and Drug Administration; KQ=key question; OR=odds ratio; RR=relative risk.

Appendix E.4 Table 4 Results From Sensitivity Analyses for KQ 4 Evaluating Effect of Denosumab on Different Types of Vertebral Fractures

Vertebral Fracture Type | RR; Measure of Effect (95% CI, I^2^ value) | Peto OR; Measure of Effect (95% CI, I^2^ value)
All vertebral fractures | 0.33 (0.26 to 0.41, I^2^=0%) | 0.34 (0.28 to 0.42, I^2^=0%)
Clinical vertebral fractures | 0.31 (0.21 to 0.47, I^2^=0%) | 0.35 (0.24 to 0.49, I^2^=0%)
Radiographic vertebral fractures^*^ | 0.33 (0.01 to 8.12, I^2^=0%) | 0.37 (0.02 to 5.89, I^2^=0%)

* Only one study included in this stratum.

Abbreviations: CI=confidence interval; KQ=key question; OR=odds ratio; RR=relative risk.

### KQ 5 Detailed Study Characteristics: Bisphosphonates

#### Alendronate

We identified 16 RCTs (total N=11,941) reporting on harms. Three were good quality;^254,^ ^298,^ ^300^ the rest were fair quality. Twelve RCTs were conducted exclusively in postmenopausal women,^252–254,^ ^256,^ ^259,^ ^267,^ ^268,^ ^276,^ ^294,^ ^296,^ ^297,^ ^300,^ ^302^ and two RCTs were conducted in combined populations of women and men (however, women made up over 90% of the study population in these two RCTs).^298,^ ^299^ Four RCTs included participants with prior fracture at baseline,^256,^ ^267,^ ^277,^ ^296^ and the proportion with a prior fracture ranged from 6.8 percent to 48.5 percent. Four RCTs excluded participants with prior fractures,^252–254,^ ^300^ and eight did not specify the proportion enrolled with prior fractures.^259,^ ^268,^ ^276,^ ^294,^ ^297–299,^ ^302^ Fourteen RCTs reported the race or ethnicity of participants and one was conducted among exclusively African American women.^276^ The other studies reporting race or ethnicity were conducted among mostly White participants.^252–254,^ ^256,^ ^259,^ ^267,^ ^268,^ ^277,^ ^294,^ ^296–299^ Two RCTs did not specify the race or ethnicity of participants.^300,^ ^302^

The largest trial was the Fracture Intervention Trial (FIT, N=4,432).^254^ The other trials had sample sizes ranging from 144 to 1,908, seven of which were international multicenter RCTs.^252,^ ^256,^ ^259,^ ^267,^ ^294,^ ^298,^ ^302^ Eight RCTs, including FIT, were conducted in the United States,^253,^ ^254,^ ^268,^ ^276,^ ^277,^ ^297,^ ^299,^ ^300^ and one was conducted in Canada and Colombia.^296^ All RCTs compared daily or weekly oral alendronate with placebo for durations ranging from 3 months to 3 years. Six RCTs administered doses of 10 mg daily,^252,^ ^259,^ ^276,^ ^294,^ ^296,^ ^300^ four RCTs administered 70 mg weekly,^267,^ ^297–299^ and six administered doses ranging from 1 mg to 40 mg daily.^253,^ ^254,^ ^256,^ ^268,^ ^277,^ ^302^ In the dose-ranging RCTs, the groups that received daily doses above 10 mg were switched to a lower dose or placebo during the study period.^254,^ ^256,^ ^268^

#### Zoledronic Acid

We identified six RCTs (total N=4,361) reporting on harms,^251,^ ^260,^ ^262,^ ^269,^ ^272,^ ^287^ two of which were new to this update.^269,^ ^272^ Two RCTs were good quality,^251,^ ^269^ and the rest were fair quality. Study sample sizes ranged from 50 to 2,000. Five of these RCTs were conducted in postmenopausal women,^260,^ ^262,^ ^269,^ ^272,^ ^287^ and one was conducted in men ages 50 to 85 years.^251^ Four of the RCTs reported the prevalence of prior fractures at baseline, ranging from 14 percent to 42 percent of the total study population,^251,^ ^262,^ ^269,^ ^272^and two excluded participants with prior fractures.^260,^ ^269^ Three RCTs reported the race and ethnicity of participants, a majority of whom were White or European,^251,^ ^260,^ ^269^ and three RCTs did not report this information.^262,^ ^272,^ ^287^ The duration of the RCTs ranged from 1 to 6 years. Five RCTs compared doses of 5-mg zoledronic acid IV with placebo as either a single dose^262,^ ^272,^ ^287^ or with a repeat dose every 1^251,^ ^272^ to 1.5 years.^269^ One trial administered doses between 0.25 mg and 4 mg at intervals ranging from 3 months to 1 year with shorter intervals being used for lower doses and longer intervals for higher doses.^260^

#### Risedronate

We identified five fair-quality RCTs (total N=10,372) reporting on harms.^257,^ ^258,^ ^261,^ ^267,^ ^295^ The RCTs included sample sizes ranging from 111 to 9,331, with the largest being an international multicenter study.^257^ All RCTs were conducted in postmenopausal women. Four RCTs included nearly all White participants,^257,^ ^258,^ ^261,^ ^267^ and one RCT was conducted in Japanese women.^295^ The duration of the RCTs ranged from 3 months to 2 years. All RCTs compared 5 mg of daily risedronate with placebo. Some RCTs also compared placebo with 1 mg of daily risedronate,^295^ 2.5 mg of daily risedronate,^257,^ ^295^ or a cyclic regimen of 5 mg daily for the first 2 weeks of the month followed by placebo for the rest of the month.^258^

#### Ibandronate

We identified eight fair-quality RCTs (N=2,281) reporting on harms.^264–266,^ ^275,^ ^288,^ ^291–293^ The RCTs included sample sizes ranging from 126 to 653, all of whom were postmenopausal women. One trial in Denmark included all White participants,^264^ and the other trials took place at various sites across North America and Europe but did not report specific race and ethnicity of their participants. The duration of the trials ranged from 3 months to 2 years. Two trials compared 150-mg oral ibandronate monthly with placebo.^275,^ ^288^ Four trials compared oral doses ranging from 0.25 to 5 mg daily,^264^ 0.5 to 2.5 mg daily,^291^ 5 to 20 mg weekly,^292^ or 50 to 150 mg monthly with placebo.^266^ Two trials compared placebo with cyclic oral regimens including 50 mg for 1 month followed by 100 mg for 2 months^266^ and 20 mg daily for the first 24 days of every 3 months followed by 9 weeks without active treatment.^265^ One trial compared IV doses of ibandronate ranging from 0.25 to 2 mg every 3 months paired with 1,000 mg daily calcium with placebo.^293^

### K5 Sensitivity Analyses: Bisphosphonates

Appendix E.4 Table 5 Results From Sensitivity Analyses for KQ 5 Evaluating Various Dosages of Bisphosphonates and Methods for Pooling Data With Rare Events

Outcome | RR; FDA Doses | Peto OR; FDA Doses | RR; All Doses | Peto OR; All Doses
| Measure of effect (95% CI, I^2^ value)
Discontinuations due to AEs | 1.00 (0.92 to 1.08); I^2^=0% | 1.00 (0.91 to 1.10); I^2^=0% | 0.99 (0.92 to 1.07); I^2^=0% | 1.00 (0.91 to 1.09); I^2^=0%
Serious AEs | 0.97 (0.91 to 1.04); I^2^=0% | 0.96 (0.88 to 1.05); I^2^=0% | 0.97 (0.91 to 1.03); I^2^=0% | 0.96 (0.88 to1.04); I^2^=0%
Upper GI AEs | 1.02 (0.98 to 1.06); I^2^=0% | NA | 1.01 (0.97 to 1.05); I^2^=0% | NA

Abbreviations: AE=adverse event; CI=confidence interval; FDA=U.S. Food and Drug Administration; GI=gastrointestinal; KQ=key question; OR=odds ratio; RR=relative risk.

### KQ 5 Detailed Study Characteristics: Denosumab

The studies included for KQ 5 were the same as the studies included for KQ 4. Please refer to the earlier section for a detailed description.

### K5 Sensitivity Analyses: Denosumab

Appendix E.4 Table 6 Results From Sensitivity Analyses for KQ 5 Evaluating Various Dosages of Denosumab and Methods for Pooling Data With Rare Events

Outcome | RR; FDA Doses | Peto OR; FDA Doses | RR; All Doses | Peto OR; All Doses
| Measure of effect (95% CI, I^2^ value)
Discontinuations due to AEs | 1.16 (0.87 to 1.54); I^2^=0% | 1.16 (0.85 to 1.56); I^2^=0%
Serious AEs | 1.04 (0.97 to 1.12); I^2^=0% | | 1.04 (0.97 to 1.12); I^2^=0%
Upper GI AEs | 2.18 (0.74 to 6.16); I^2^=0% | 2.42 (0.84 to 7.00); I^2^=0% | 2.13 (0.85 to 5.34), I^2^=0% | 2.52 (0.96 to 6.66); I^2^=0%

Abbreviations: AE=adverse event; CI=confidence interval; FDA=U.S. Food and Drug Administration; GI=gastrointestinal; KQ=key question; OR=odds ratio; RR=relative risk.

Appendix E.4 Figure 1 Key Question 4 Bisphosphonates vs. Placebo Vertebral Fractures

* Varied dose regimen of 5 mg/d for 2 years then 10 mg/d from 1 year for those without existing vertebral fractures and for 2 to 2.6 years for those with vertebral fractures.

^†^ Varied dose regimen of 5 or 10 mg/d for 3 years or 20 mg/d for 2 years followed by 5 mg/d for 1 year.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; DL=DerSimonian & Laird estimator for pooling estimates; FIT=Fracture Intervention Trial; vs.=versus; y=year.

This figure depicts a forest plot of vertebral fractures assessed in nine randomized controlled trials of bisphosphonates compared to placebo. Five trials compared alendronate to placebo and the pooled subgroup risk ratio was 0.56 (95 percent confidence interval [CI], 0.40 to 0.79). Two trials compared risedronate to placebo and the pooled subgroup risk ratio was 1.99 (95 percent CI, 0.16 to 24.89). Three trials compared zoledronic acid with placebo and the pooled subgroup risk ratio was 0.43 (95 percent CI, 0.29 to 0.64). The pooled risk ratio across all 10 trials was 0.51 with a 95 percent confidence interval between 0.39 and 0.66 and an I-squared statistic of 0 percent. This corresponds to an absolute risk difference of 18 fewer per 1,000 persons with a 95 percent confidence interval between 23 fewer to 13 fewer. Data for the individual studies depicted in Figure 1 are detailed in Appendix D Tables 6 and 16.

Appendix E.4 Figure 2 Key Question 4 Bisphosphonates vs. Placebo Nonvertebral Fractures

* Varied dose regimen of 5 mg/d for 2 years then 10 mg/d from 1 year for those without existing vertebral fractures and for 2 to 2.6 years for those with vertebral fractures.

^†^ Varied dose regimen of 5 or 10 mg/d for 3 years or 20 mg/d for 2 years followed by 5 mg/d for 1 year.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; DL=DerSimonian & Laird estimator for pooling estimates; FIT=Fracture Intervention Trial; FOSIT=Fosamax International Trial; vs.=versus; y=year.

This figure depicts a forest plot of nonvertebral fractures assessed in 12 randomized controlled trials of bisphosphonates compared to placebo. Six trials compared alendronate to placebo and the pooled subgroup risk ratio was 0.83 with a 95 percent confidence interval between 0.72 and 0.95. Three trials compared risedronate to placebo and the pooled subgroup risk ratio was 0.83 with a 95 percent confidence interval between 0.74 and 0.94. Four trials compared zoledronic acid to placebo and the pooled subgroup risk ratio was 0.68 with a 95 percent confidence interval between 0.54 and 0.86. The pooled risk ratio across all 13 trials was 0.81 with a 95 percent confidence interval between 0.74 and 0.88 and I-squared statistic of 0 percent. This corresponds to an absolute risk difference of 28 fewer per 1,000 persons with a 95 percent confidence interval between 38 fewer to 18 fewer. Data for the individual studies depicted in Figure 2 are detailed in Appendix D Tables 6 and 16.

Appendix E.4 Figure 3 Key Question 4 Bisphosphonates vs. Placebo Hip Fractures

* Varied dose regimen of 5 mg/d for 2 years then 10 mg/d from 1 year for those without existing vertebral fractures and for 2 to 2.6 years for those with vertebral fractures.

^†^ Varied dose regimen of 5 or 10 mg/d for 3 years or 20 mg/d for 2 years followed by 5 mg/d for 1 year.

^‡^ Data included for this analysis are a subgroup without vertebral fracture at baseline. The overall risk ratio when including the entire study population is 0.72 (95% CI, 0.58 to 0.91); Peto odds ratio is 0.71 (95% CI, 0.56 to 0.90).

Abbreviations: ARD=absolute risk difference; CI=confidence interval; DL=DerSimonian & Laird estimator for pooling estimates; FIT=Fracture Intervention Trial; FOSIT=Fosamax International Trial; vs.=versus; y=year.

This figure depicts a forest plot of hip fractures assessed in six randomized controlled trials of bisphosphonates compared to placebo. Three trials compared alendronate to placebo and the pooled subgroup risk ratio was 0.72 with a 95 percent confidence interval between 0.42 and 1.26. Two trials compared risedronate to placebo and the pooled subgroup risk ratio was 0.59 with a 95 percent confidence interval between 0.28 and 1.25. One trial compared zoledronic acid to placebo and the subgroup risk ratio was 0.67 with a 95 percent confidence interval between 0.27 and 1.62. The pooled risk ratio across all six trials was 0.67 with a 95 percent confidence interval between 0.45 and 1.00. and I-squared statistic of 0 percent. This corresponds to an absolute risk difference of 3 fewer per 1,000 with a 95 percent confidence interval between 5 fewer to 0 fewer. Data for individual studies depicted in Figure 3 are detailed in Appendix D Tables 6 and 16.

Appendix E.4 Figure 4 Key Question 4 Bisphosphonates vs. Placebo Mortality

* 20 mg/2 d for the first 24 days out of every 3 months, followed by a 9-week period without active drug.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; DL=DerSimonian & Laird estimator for pooling estimates; m=month; MOPS=Monthly Oral Pilot Study; vs.=versus; y=year.

This figure depicts a forest plot of mortality assessed in six randomized controlled trials of bisphosphonates compared to placebo. Four trials compared ibandronate to placebo and the pooled subgroup risk ratio was 0.60 with a 95 percent confidence interval between 0.11 and 3.26. Two trials compared zoledronic acid to placebo and the pooled subgroup risk ratio was 0.72 with a 95 percent confidence interval between 0.49 to 1.07. The pooled risk ratio across all six trials was 0.71 with a 95 percent confidence interval between 0.49 and 1.05 and an I-squared statistic of 0 percent. This corresponds to an absolute risk difference of 10 fewer per 1,000 with a 95 percent confidence interval between 17 fewer to 2 more. Data for individual studies depicted in Figure 4 are detailed in Appendix D Tables 6 and 16.

Appendix E.4 Figure 5 Key Question 4 Denosumab vs. Placebo Fractures

Note: RRs listed here may differ slightly from the RRs reported by study authors because of differences in statistical packages used. Vertebral fractures reported were radiographic in FREEDOM.

* RR reported by study authors was 0.60 (95% CI, 0.37 to 0.97).

^†^ Peto odds ratio estimate, 1.00 (95% CI, 0.38 to 0.98).

^‡^ Peto odds ratio estimate, 1.00 (95% CI, 0.01 to 87.49).

^§^ Peto odds ratio estimate, 0.37 (95% CI, 0.02 to 5.89).

^ǁ^ Peto odds ratio estimate, 0.14 (95% CI, 0.00 to 6.62).

^¶^ Peto odds ratio estimate, 2.99 (95% CI, 0.57 to 15.65)

^#^ Varied dose regimen of 6, 14, or 30 mg/3 mo or 14, 60, 100, or 210 mg/6 mo

Abbreviations: ARD=absolute risk difference; CI=confidence interval; FREEDOM=Fracture Reduction Evaluation of Denosumab in Osteoporosis Every 6 Months; m=month; RR=relative risk; vs.=versus; y=year.

This figure depicts a forest plot of hip, vertebral, nonvertebral, and osteoporotic fractures assessed in five randomized controlled trials of denosumab compared to placebo. Two trials assessed hip fractures and the pooled risk ratio was 0.61 with a 95 percent confidence interval between 0.38 and 0.99. This corresponds to an absolute risk difference of 4 fewer per 1,000 with a 95 percent confidence interval between 7 fewer to 0 fewer. Four trials assessed vertebral fractures and the pooled risk ratio was 0.33 with a 95 percent confidence interval between 0.26 to 0.41. This corresponds to an absolute risk difference of 44 fewer per 1,000 with a 95 percent confidence interval between 49 fewer to 39 fewer. Three studies assessed nonvertebral fractures and the pooled risk ratio was 0.80 with a 95 percent confidence interval between 0.68 and 0.94. This corresponds to an absolute risk difference of 14 fewer per 1,000 with a 95 percent confidence interval between 23 fewer to 4 fewer. One study assessed osteoporotic fractures and the risk ratio was 14.76 with a 95 percent confidence interval between 0.06 and 3,616.67. Data for individual studies depicted in Figure 5 are detailed in Appendix D Tables 6 and 16.

Appendix E.4 Figure 6 Key Question 4 Denosumab vs. Placebo Mortality

* Varied dose regimen of 6, 14, or 30 mg every 3 months or 14, 60, 100, or 210 mg every 6 months.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; DL=DerSimonian & Laird estimator for pooling estimates; FREEDOM=Fracture Reduction Evaluation of Denosumab in Osteoporosis Every 6 Months; m=month; vs.=versus; y=year.

This figure depicts a forest plot of mortality in five randomized controlled trials of denosumab compared to placebo. The pooled risk ratio across all five trials was 0.79 with a 95 percent confidence interval between 0.58 and 1.07. This corresponds to an absolute risk difference of 4 fewer per 1,000 with a 95 percent confidence interval between 9 fewer to 1 more. Data for individual studies depicted in Figure 6 are detailed in Appendix D Tables 6 and 16.

Appendix E.4 Figure 7 Key Question 5 Bisphosphonates vs. Placebo Discontinuation due to Adverse Events

* Varied dose regimen of 5 mg/d for 2 years then 10 mg/d for 1 year for those without existing vertebral fractures and for 2 to 2.6 years for those with vertebral fractures.

^†^ Varied dose regimen of 5 or 10 mg/d for 3 years or 20 mg/d for 2 years followed by 5 mg/d for 1 year.

^‡^ This study included three study arms: alendronate, risedronate, and placebo. The same placebo group was used in each comparison to the active drug.

^§^ Varied dose regimen of 0.25, 0.5, or 1 mg every 3 months; 2 mg every 6 months; or 4 mg every year.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; d=day; DL=DerSimonian & Laird estimator for pooling estimates; FIT=Fracture Intervention Trial; FOSIT= Fosamax International Trial; m=month; MOPS=Monthly Oral Pilot Study; vs.=versus; y=year.

This figure depicts a forest plot of discontinuations due to adverse events in 22 randomized controlled trials of bisphosphonates compared to placebo. Fourteen studies compared alendronate to placebo and the pooled subgroup risk ratio was 1.01 with a 95 percent confidence interval between 0.89 and 1.15. Five trials compared ibandronate to placebo and the pooled subgroup risk ratio was 1.15 with a 95 percent confidence interval between 0.61 to 2.20. Four trials compared risedronate to placebo and the pooled subgroup risk ratio was 0.98 with a 95 percent confidence interval between 0.88 and 1.09. Two trials compared zoledronic acid to placebo and the pooled subgroup risk ratio was 2.14 with a 95 percent confidence interval between 0.36 to 12.83. The pooled risk ratio across all 24 studies was 1.00 with a 95 percent confidence interval between 0.92 to 1.08. This corresponds to an absolute risk difference of 0 fewer per 1,000 with a 95 percent confidence interval between 9 fewer to 9 more. Data for individual studies depicted in Figure 7 are detailed in Appendix D Tables 6 and 16.

Appendix E.4 Figure 8 Key Question 5 Bisphosphonates vs. Placebo Serious Adverse Events

* This study included three study arms: alendronate, risedronate, and placebo. The same placebo group was used in each comparison to the active drug.

^†^ Varied dose regimen of 0.25, 0.5, or 1 mg every 3 months; 2 mg every 6 months; 4 mg every year.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; d=day; DL=DerSimonian & Laird estimator for pooling estimates; FOSIT=Fosamax International Trial; m=month; MOPS=Monthly Oral Pilot Study; vs.=versus; y=year.

This figure depicts a forest plot of serious adverse events in 21 randomized controlled trials of bisphosphonates compared to placebo. Eight studies compared alendronate to placebo and the pooled subgroup risk ratio was 0.90 with a 95 percent confidence interval between 0.73 and 1.12. Five trials compared ibandronate to placebo and the pooled subgroup risk ratio was 1.02 with a 95 percent confidence interval between 0.60 and 1.73. Four trials compared risedronate to placebo and the pooled subgroup risk ratio was 0.98 with 95 percent confidence interval between 0.91 and 1.05. Four trials compared zoledronic acid to placebo and the pooled subgroup risk ratio was 1.00 with a 95 percent confidence interval between 0.83 and 1.20. The pooled risk ratio across all 21 studies was 0.97 with a 95 percent confidence interval between 0.91 to 1.04 and an I-squared statistic of 0 percent. This corresponds to an absolute risk difference of 6 fewer per 1,000 with a 95 percent confidence interval between 18 fewer to 8 more. Data for individual studies depicted in Figure 8 are detailed in Appendix D Tables 6 and 16.

Appendix E.4 Figure 9 Key Question 5 Bisphosphonates vs. Placebo Gastrointestinal Adverse Events

* Varied dose regimen of 5 mg/d for 2 years then 10 mg/d for 1 year for those without existing vertebral fractures and for 2 to 2.6 years for those with vertebral fractures.

^†^ Varied dose regimen of 5 or 10 mg/d for 3 y or 20 mg/d for 2 y followed by 5 mg/d for 1 year.

^‡^ This study included three study arms: alendronate, risedronate, and placebo. The same placebo group was used in each comparison to the active drug.

^§^ Varied dose regimen of 0.25 mg, 0.5mg, 1.0 mg, or 2.0 mg every 3 months.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; d=day; DL=DerSimonian & Laird estimator for pooling estimates; FIT=Fracture Intervention Trial; FOSIT=Fosamax International Trial; MOPS=Monthly Oral Pilot Study; vs.=versus; w=week; y=year.

This figure depicts a forest plot of upper gastrointestinal adverse events in 27 randomized controlled trials of bisphosphonates compared to placebo. Fourteen studies compared alendronate to placebo and the pooled subgroup risk ratio was 1.03 with a 95 percent confidence interval between 0.96 to 1.08. Six studies compared ibandronate to placebo and the pooled subgroup risk ratio was 1.32 with a 95 percent confidence interval between 0.99 to 1.76. Five studies compared risedronate to placebo and the pooled subgroup risk ratio was 0.97 with a 95 percent confidence interval between 0.84 and 1.11. Two studies compared zoledronic acid to placebo and the pooled subgroup risk ratio was 1.28 with a 95 percent confidence interval between 0.37 and 4.37. The pooled risk ratio across all 27 studies was 1.02 with a 95 percent confidence interval between 0.98 and 1.06 and an I-squared statistic of 0 percent. This corresponds to an absolute risk difference of 6 more per 1,000 with a 95 percent confidence interval between 5 fewer to 16 more. Data for individual studies depicted in Figure 9 are detailed in Appendix D Tables 6 and 16.

Appendix E.4 Figure 10 Key Question 5 Denosumab vs. Placebo Discontinuation due to Adverse Events

* Varied dose regimen of 6, 14, or 30 mg every 3 months or 14, 60, 100, or 210 mg every 6 months.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; DL=DerSimonian & Laird estimator for pooling estimates; m=month; vs.=versus; y=year.

This figure depicts a forest plot of discontinuations due to adverse events in five randomized controlled trials of denosumab compared to placebo. The pooled risk ratio across all five studies was 1.16 with a 95 percent confidence interval between 0.87 and 1.54 with an I-squared statistic of 0 percent. This corresponds to an absolute risk difference of 3 more per 1,000 with a 95 percent confidence interval between 3 fewer to 11 more. Data for individual studies depicted in Figure 10 are detailed in Appendix D Tables 6 and 16.

Appendix E.4 Figure 11 Key Question 5: Denosumab vs. Placebo Serious Adverse Events

* Varied dose regimen of 6, 14, or 30 mg every 3 months or 14, 60, 100, or 210 mg every 6 months.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; DL=DerSimonian & Laird estimator for pooling estimates; m=month; vs.=versus; y=year.

This figure depicts a forest plot of serious adverse events in six randomized controlled trials of denosumab compared to placebo. The pooled risk ratio across all six studies was 1.03 with a 95 percent confidence interval between 0.97 and 1.08 and an I-squared statistic of 0 percent. This corresponds to an absolute risk difference of 9 more per 1,000 with a 95 percent confidence interval between 7 fewer and 28 more. Data for individual studies depicted in Figure 11 are detailed in Appendix D Tables 6 and 16.

Appendix E.4 Figure 12 Key Question 5: Denosumab vs. Placebo Gastrointestinal Adverse Events

* Varied dose regimen of 6, 14, or 30 mg every 3 months or 14, 60, 100, or 210 mg every 6 months.

^†^ GI AEs include constipation (Tx 5/69, Ctl 2/66) and Gastritis (Tx 3/69, Ctl 1/66).

Abbreviations: AE=adverse event; ARD=absolute risk difference; CI=confidence interval; Ctl=control; DL=DerSimonian & Laird estimator for pooling estimates; GI=gastrointestinal; m=month; Tx=treatment; vs.=versus; y=year.

This figure depicts a forest plot of upper gastrointestinal adverse events in four randomized controlled trials of denosumab compared to placebo. The pooled risk ratio across all four studies was 2.18 with a 95 percent confidence interval between 0.74 and 6.46 and an I-squared statistic of 0 percent. This corresponds to an absolute risk difference of 14 more per 1,000 with a 95 percent confidence interval of 3 fewer to 66 more. Data for individual studies depicted in Figure 12 are detailed in Appendix D Tables 6 and 16.