# Appendix D Evidence Tables

Appendix D Table 1 Characteristics of Included Studies for Direct Benefits and Harms of Screening (Key Questions 1 and 3)

Appendix D Table 2 Characteristics of Included Primary Research Studies for Predictive Accuracy of Risk Assessment Instruments (Key Question 2a)

Appendix D Table 3 Characteristics of Included Studies for Predictive Accuracy of Bone Mineral Density Alone for Fracture (Key Question 2b)

Appendix D Table 4 Characteristics of Included Studies for Diagnostic Accuracy of Risk Assessment Instruments (Key Question 2c)

Appendix D Table 5 Characteristics of Included Studies for Evidence on Repeat Screening (Key Question 2d)

Appendix D Table 6 Characteristics of Included Randomized, Controlled Trials for Benefits and Harms of Treatment (Key Questions 4 and 5)

Appendix D Table 7 Study Characteristics of Included Cohort Studies for Harms of Treatment (Key Question 5)

Appendix D Table 8 Outcomes from Included Trials for Direct Benefits and Harms of Screening (Key Questions 1 and 3)

Appendix D Table 9 Included Systematic Reviews for Direct Benefits and Harms of Screening (Key Question 1 and 3)

Appendix D Table 10 Discrimination Outcomes for Predictive Accuracy of Risk Assessment Instruments (Key Question 2a)

Appendix D Table 11 Calibration Outcomes for Predictive Accuracy of Risk Assessment Instruments (Key Question 2a)

Appendix D Table 12 Discrimination Outcomes from Included Systematic Reviews for Predictive Accuracy of Risk Assessment Instruments for Fracture (Key Question 2a)

Appendix D Table 13 Outcomes from Included Studies for Predictive Accuracy of Bone Mineral Density Alone for Fracture (Key Question 2b)

Appendix D Table 14 Outcomes From Included Studies for Diagnostic Accuracy (Key Question 2c)

Appendix D Table 15 Outcomes From Included Studies for Key Question 2d

Appendix D Table 16 Outcomes from Included Studies for Benefits and Harms of Treatment (Key Questions 4 and 5)

Appendix D Table 17 Outcomes from Included Cohort Studies for Harms of Treatment (Key Question 5)

Appendix D Table 18 Risk of Bias for Included Trials in Key Questions 1 and 3 (Domain 1 Randomization and Allocation Concealment)

Appendix D Table 19 Risk of Bias for Included Trials in Key Questions 1 and 3 (Domain 2 Missing Data)

Appendix D Table 20 Risk of Bias for Included Trials in Key Questions 1 and 3 (Domain 3 Departures from Intended Interventions)

Appendix D Table 21 Risk of Bias for Included Trials in Key Questions 1 and 3 (Domain 4 Outcome Measurement)

Appendix D Table 22 Risk of Bias for Included Trials in Key Questions 1 and 3 (Domain 5 Selective Outcome Reporting and Overall ROB)

Appendix D Table 23 Risk of Bias for Systematic Reviews Included for Key Question 1 (Domain 1 Study Eligibility)

Appendix D Table 24 Risk of Bias for Systematic Reviews Included for Key Question 1 (Domain 2 Identification and Selection of Studies)

Appendix D Table 25 Risk of Bias for Systematic Reviews Included for Key Question 1 (Domain 3 Data Collection and Study Appraisal)

Appendix D Table 26 Risk of Bias for Systematic Reviews Included for Key Question 1 (Domain 4 Synthesis and Findings)

Appendix D Table 27 Risk of Bias for Systematic Reviews Included for Key Question 1 (Overall Risk of Bias)

Appendix D Table 28 Risk of Bias for Included Studies for Key Question 2a (Domain 1 Participants)

Appendix D Table 29 Risk of Bias for Included Studies for Key Question 2a (Domain 2 Predictors)

Appendix D Table 30 Risk of Bias for Included Studies for Key Question 2a (Domain 3 Outcomes)

Appendix D Table 31 Risk of Bias for Included Studies for Key Question 2a (Domain 4 Analysis)

Appendix D Table 32 Risk of Bias for Included Studies for Key Question 2a (Overall)

Appendix D Table 33 Risk of Bias for Systematic Reviews Included for Key Question 2a (Domain 1 Study Eligibility)

Appendix D Table 34 Risk of Bias for Systematic Reviews Included for Key Question 2a (Domain 2 Identification and Selection of Studies)

Appendix D Table 35 Risk of Bias for Systematic Reviews Included for Key Question 2a (Domain 3 Data Collection and Study Appraisal)

Appendix D Table 36 Risk of Bias for Systematic Reviews Included for Key Question 2a (Domain 4 Synthesis and Findings)

Appendix D Table 37 Risk of Bias for Systematic Reviews Included for Key Question 2a (Overall Risk of Bias)

Appendix D Table 38 Risk of Bias of Included Studies for Key Question 2b (Domain 1 Participants)

Appendix D Table 39 Risk of Bias of Included Studies for Key Question 2b (Domain 2 Predictors)

Appendix D Table 40 Risk of Bias of Included Studies for Key Question 2b (Domain 3 Outcomes)

Appendix D Table 41 Risk of Bias of Included Studies for Key Question 2b (Domain 4 Analysis)

Appendix D Table 42 Risk of Bias of Included Studies for Key Question 2b (Overall)

Appendix D Table 43 Risk of Bias of Included Studies for Key Question 2c (Domain 1 Patient Selection)

Appendix D Table 44 Risk of Bias of Included Studies for Key Question 2c (Domain 2 Index Test)

Appendix D Table 45 Risk of Bias of Included Studies for Key Question 2c (Domain 3 Reference Standard)

Appendix D Table 46 Risk of Bias of Included Studies for Key Question 2c (Domain 4 Flow and Timing)

Appendix D Table 47 Risk of Bias of Included Studies for Key Question 2c (Overall Study Quality)

Appendix D Table 48 Risk of Bias for Studies for Key Question 2d (Domain 1 Participants)

Appendix D Table 49 Risk of Bias for Included Studies for Key Question 2d (Domain 2 Predictors)

Appendix D Table 50 Risk of Bias for Studies for Key Question 2d (Domain 3 Outcome)

Appendix D Table 51 Risk of Bias for Studies for Key Question 2d (Domain 4 Analysis)

Appendix D Table 52 Risk of Bias for Studies for Key Question 2d (Domain 5 Overall ROB)

Appendix D Table 53 Risk of Bias of Included Trials for Key Questions 4 and 5 (Domain 1 Randomization and Allocation Concealment)

Appendix D Table 54 Risk of Bias of Included Trials for Key Questions 4 and 5 (Domain 2 Missing Outcome Data)

Appendix D Table 55 Risk of Bias of Included Trials for Key Questions 4 and 5 (Domain 3 Departures from Intended Interventions)

Appendix D Table 56 Risk of Bias of Included Trials for Key Questions 4 and 5 (Domain 4 Outcome Measurement)

Appendix D Table 57 Risk of Bias of Included Trials for Key Questions 4 and 5 (Domain 5 Selective Outcome Reporting and Overall Risk of Bias)

Appendix D Table 58 Risk of Bias of Included Cohort Studies for Key Question 5 (Domain 1 Bias Due to Confounding)—Part 1

Appendix D Table 59 Risk of Bias of Included Cohort Studies for Key Question 5 (Domain 1 Bias Due to Confounding)—Part 2

Appendix D Table 60 Risk of Bias of Included Cohort Studies for Key Question 5 (Domain 2 Bias in Selection of Participants into the Study)

Appendix D Table 61 Risk of Bias of Included Cohort Studies for Key Question 5 (Domain 3 Bias in Classification of Intervention)

Appendix D Table 62 Risk of Bias of Included Cohort Studies for Key Question 5 (Domain 4 Bias Due to Deviations From Intended Intervention)

Appendix D Table 63 Risk of Bias of Included Cohort Studies for Key Question 5 (Domain 5 Bias Due to Missing Data)

Appendix D Table 64 Risk of Bias of Included Cohort Studies for Key Question 5 (Domain 6 Bias in Measurement of Outcomes)

Appendix D Table 65 Risk of Bias of Included Cohort Studies for Key Question 5 (Domain 7 Bias in the Selection of the Reported Result and Overall Risk of Bias)