# Appendix C Excluded Studies

List of Exclusion Codes:

- X1 Not published in English or ineligible publication type
- X2 Ineligible population
- X3 Ineligible study design or timing
- X4 Ineligible geographic setting (except non very high HDI)
- X5 Ineligible or no intervention
- X6 Ineligible or no comparator
- X7 Ineligible or no outcome
- X8 Not in very high HDI country
- X9 Study superseded by new evidence or duplicate or covered by included SR
- X10 Poor quality

1 What evidence for bisphosphonate drug holidays? Drug Ther Bull. 2020 Jun;58(6):88. doi: 10.1136/dtb.2020.000017. PMID: 32188686. Exclusion Code: X5.32188686
2 Abrahamsen B, Pazianas M, Eiken P, . Esophageal and gastric cancer incidence and mortality in alendronate users. J Bone Miner Res. 2012 Mar;27(3):679–86. doi: 10.1002/jbmr.1481. PMID: 22113985. Exclusion Code: X10.22113985
3 Adachi JD, Bone HG, Daizadeh NS, . Influence of subject discontinuation on long-term nonvertebral fracture rate in the denosumab FREEDOM Extension study. BMC Musculoskelet Disord. 2017 Apr 27;18(1):174. doi: 10.1186/s12891-017-1520-6. PMID: 28449657. Exclusion Code: X6.28449657
4 Adami G, Arioli G, Bianchi G, . Radiofrequency echographic multi spectrometry for the prediction of incident fragility fractures: a 5-year follow-up study. Bone. 2020 May;134:115297. doi: 10.1016/j.bone.2020.115297. PMID: 32092480. Exclusion Code: X5.32092480
5 Agarwal A, Baleanu F, Moreau M, . External validation of FRISBEE 5-year fracture prediction models: a registry-based cohort study. Arch Osteoporos. 2022 Dec 23;18(1):13. doi: 10.1007/s11657-022-01205-7. PMID: 36564674. Exclusion Code: X3.36564674
6 Agarwal A, Leslie WD, Nguyen TV, . Performance of the Garvan Fracture Risk Calculator in individuals with diabetes: a registry-based cohort study. Calcif Tissue Int. 2022 Jun;110(6):658–65. doi: 10.1007/s00223-021-00941-1. PMID: 34994831. Exclusion Code: X9.34994831
7 Ahadzadeh Ardebili A, Fu T, Dunnewold N, . Bisphosphonates preserve bone mineral density and suppress bone turnover markers in early menopausal women: a systematic review and meta-analysis of randomized trials. JBMR Plus. 2023 Jun;7(6):e10748. doi: 10.1002/jbm4.10748. PMID: 37283657. Exclusion Code: X2.37283657
8 Ahmed LA, Nguyen ND, Bjornerem A, . External validation of the Garvan nomograms for predicting absolute fracture risk: the Tromso study. PLoS One. 2014;9(9):e107695. doi: 10.1371/journal.pone.0107695. PMID: 25255221. Exclusion Code: X4.25255221
9 Ahmed LA, Schirmer H, Fonnebo V, . Validation of the Cummings’ risk score; how well does it identify women with high risk of hip fracture: the Tromso Study. Eur J Epidemiol. 2006;21(11):815–22. doi: 10.1007/s10654-006-9072-3. PMID: 17119878. Exclusion Code: X7.17119878
10 Aktas I, Nazikoglu C, Kepez A, . Effect of intravenous zoledronic acid infusion on electrocardiographic parameters in patients with osteoporosis. Osteoporos Int. 2016 Dec;27(12):3543–7. doi: 10.1007/s00198-016-3684-6. PMID: 27344642. Exclusion Code: X7.27344642
11 Akyea RK, McKeever TM, Gibson J, . Predicting fracture risk in patients with chronic obstructive pulmonary disease: a UK-based population-based cohort study. BMJ Open. 2019 Apr 3;9(4):e024951. doi: 10.1136/bmjopen-2018-024951. PMID: 30948576. Exclusion Code: X2.30948576
12 Albert SG, Wood E. Meta-analysis of clinical fracture risk reduction of anti-osteoporosis drugs: direct and indirect comparisons and meta-regressions. Endocr Pract. 2021 Jul 9doi: 10.1016/j.eprac.2021.06.015. PMID: 34252583. Exclusion Code: X3.34252583
13 Albertsson D, Mellstrom D, Petersson C, . Hip and fragility fracture prediction by 4-item clinical risk score and mobile heel BMD: a women cohort study. BMC Musculoskelet Disord. 2010 Mar 24;11:55. doi: 10.1186/1471-2474-11-55. PMID: 20334634. Exclusion Code: X7.20334634
14 Albertsson DM, Mellstrom D, Petersson C, Eggertsen R. Validation of a 4-item score predicting hip fracture and mortality risk among elderly women. Ann Fam Med. 2007 Jan–Feb;5(1):48–56. doi: 10.1370/afm.602. PMID: 17261864. Exclusion Code: X7.17261864
15 Alibasic E, Ljuca F, Brkic S, . Secondary prevention of osteoporosis through assessment of individual and multiple risk factors. Mater Sociomed. 2020 Mar;32(1):10–4. doi: 10.5455/msm.2020.32.10-14. PMID: 32410886. Exclusion Code: X7.32410886
16 Alshahrani F, Alsulaiman YA, Almashari YM, . Use of the Osteoporosis Self-Assessment Tool as a screening tool for osteoporosis in Saudi postmenopausal women. Cureus. 2023 Apr;15(4):e37755. doi: 10.7759/cureus.37755. PMID: 37213999. Exclusion Code: X7.37213999
17 Amith N, Augustine S, Raj SPS, . Evaluation of effectiveness of MORES to identify men at risk of osteoporosis. European Journal of Molecular and Clinical Medicine. 2022;9(7):5772–9. Exclusion Code: X8.
18 Anagnostis P, Paschou SA, Gkekas NN, . Efficacy of anti-osteoporotic medications in patients with type 1 and 2 diabetes mellitus: a systematic review. Endocrine. 2018 Jun;60(3):373–83. doi: 10.1007/s12020-018-1548-x. PMID: 29411304. Exclusion Code: X2.29411304
19 Anastasilakis AD, Papapoulos SE, Polyzos SA, . Zoledronate for the prevention of bone loss in women discontinuing denosumab treatment. a prospective 2-year clinical trial. J Bone Miner Res. 2019 Dec;34(12):2220–8. doi: 10.1002/jbmr.3853. PMID: 31433518. Exclusion Code: X6.31433518
20 Ang SB, Xia JY, Cheng SJ, . A pilot screening study for low bone mass in Singaporean women using years since menopause and BMI. Climacteric. 2021 Apr 30:1–7. doi: 10.1080/13697137.2021.1908989. PMID: 33928868. Exclusion Code: X6.33459067
21 Asghar ZB, Godoy Caballero A, Pathirannehelage S, . Saving bones without risking brain-bisphosphonates and risk of stroke: matched case-control study. Osteoporos Int. 2019 Sep;30(9):1845–54. doi: 10.1007/s00198-019-05045-z. PMID: 31214750. Exclusion Code: X3.31214750
22 Ashok Kumar D, Anburajan M, Snekhalatha U. Evaluation of low bone mass and prediction of fracture risk using metacarpal radiogrammetry method: a comparative study with DXA and X-ray phantom. Int J Rheum Dis. 2018 Jul;21(7):1350–71. doi: 10.1111/1756-185x.13326. PMID: 29968333. Exclusion Code: X8.29968333
23 Asirvatham AR, Balachandran K, Kannan S, . FRAX first - Pragmatic approach in resource poor settings. Indian J Endocrinol Metab. 2018 Nov–Dec;22(6):757–9. doi: 10.4103/ijem.IJEM_412_18. PMID: 30766813. Exclusion Code: X7.30766813
24 Azagra R, Roca G, Encabo G, . FRAX(R) tool, the WHO algorithm to predict osteoporotic fractures: the first analysis of its discriminative and predictive ability in the Spanish FRIDEX cohort. BMC Musculoskelet Disord. 2012;13:204. doi: 10.1186/1471-2474-13-204. PMID: 23088223. Exclusion Code: X9.23088223
25 Baek KH, Chung YS, Koh JM, . Romosozumab in postmenopausal Korean women with osteoporosis: a randomized, double-blind, placebo-controlled efficacy and safety study. Endocrinol Metab (Seoul). 2021 Feb;36(1):60–9. doi: 10.3803/EnM.2020.848. PMID: 33677928. Exclusion Code: X5.33677928
26 Bager CL, Bay F, Christiansen C, Karsdal M. Low bone turnover levels predict increased risk of cancer. Bone. 2019 Oct;127:75–81. doi: 10.1016/j.bone.2019.05.032. PMID: 31150870. Exclusion Code: X7.31150870
27 Bala Y, Chapurlat R, Cheung AM, . Risedronate slows or partly reverses cortical and trabecular microarchitectural deterioration in postmenopausal women. J Bone Miner Res. 2014 Feb;29(2):380–8. doi: 10.1002/jbmr.2101 [doi]. PMID: 24115129. Exclusion Code: X10.24115129
28 Bansal B, Mithal A, Chopra SR, . Judicious use of DXA-BMD in assessing fracture risk by using clinical risk factors in the Indian population. Arch Osteoporos. 2018 Oct 29;13(1):115. doi: 10.1007/s11657-018-0536-3. PMID: 30374781. Exclusion Code: X3.30374781
29 Barrett-Connor E, Cauley JA, Kulkarni PM, . Risk-benefit profile for raloxifene: 4-year data From the Multiple Outcomes of Raloxifene Evaluation (MORE) randomized trial. J Bone Miner Res. 2004 Aug;19(8):1270–5. doi: 10.1359/JBMR.040406 [doi]. PMID: 15231013. Exclusion Code: X5.15231013
30 Barrett-Connor E, Grady D, Sashegyi A, . Raloxifene and cardiovascular events in osteoporotic postmenopausal women: four-year results from the MORE (Multiple Outcomes of Raloxifene Evaluation) randomized trial. JAMA. 2002 Feb 20;287(7):847–57. doi: 10.1001/jama.287.7.847 [pii]. PMID: 11851576. Exclusion Code: X5.11851576
31 Barrionuevo P, Kapoor E, Asi N, . Efficacy of pharmacological therapies for the prevention of fractures in postmenopausal women: a network meta-analysis. J Clin Endocrinol Metab. 2019 May 1;104(5):1623–30. doi: 10.1210/jc.2019-00192. PMID: 30907957. Exclusion Code: X3.30907957
32 Bartosch P, Malmgren L. Can frailty in conjunction with FRAX identify additional women at risk of fracture - a longitudinal cohort study of community dwelling older women. BMC Geriatr. 2022 Dec 9;22(1):951. doi: 10.1186/s12877-022-03639-7. PMID: 36494774. Exclusion Code: X4.36494774
33 Bastounis A, Langley T, Davis S, . Assessing the Effectiveness of Bisphosphonates for the Prevention of Fragility Fractures: An Updated Systematic Review and Network Meta-Analyses. JBMR Plus. 2022 May;6(5):e10620. doi: 10.1002/jbm4.10620. PMID: 35509636. Exclusion Code: X3.35509636
34 Bauer DC, Black DM, Bouxsein ML, . Treatment-related changes in bone turnover and fracture risk reduction in clinical trials of anti-resorptive drugs: a meta-regression. J Bone Miner Res. 2018 Apr;33(4):634–42. doi: 10.1002/jbmr.3355. PMID: 29318649. Exclusion Code: X3.29318649
35 Bauer DC, Ewing SK, Cauley JA, . Quantitative ultrasound predicts hip and non-spine fracture in men: the MrOS study. Osteoporos Int. 2007 Jun;18(6):771–7. doi: 10.1007/s00198-006-0317-5 [doi]. PMID: 17273893. Exclusion Code: X5.17273893
36 Beattie JR, Cummins NM, Caraher C, . Raman spectroscopic analysis of fingernail clippings can help differentiate between postmenopausal women who have and have not suffered a fracture. Clin Med Insights: Arthritis Musculoskelet Disord. 2016;9:109–16. doi: 10.4137/cmamd.S38493. PMID: 27429561. Exclusion Code: X5.27429561
37 Beaudart C, Demonceau C, Sabico S, . Efficacy of osteoporosis pharmacological treatments in men: a systematic review and meta-analysis. Aging Clin Exp Res. 2023 Sep;35(9):1789–806. doi: 10.1007/s40520-023-02478-9. PMID: 37400668. Exclusion Code: X3.37400668
38 Beaudoin C, Jean S, Moore L, . Number, location, and time since prior fracture as predictors of future fracture in the elderly from the general population. J Bone Miner Res. 2018 Nov;33(11):1956–66. doi: 10.1002/jbmr.3526. PMID: 29924429. Exclusion Code: X3.29924429
39 Behanova M, Reichardt B, Stamm TA, . Treatment effects of bisphosphonates and denosumab on survival and refracture from real-world data of hip-fractured patients. Calcif Tissue Int. 2019 Dec;105(6):630–41. doi: 10.1007/s00223-019-00611-3. PMID: 31531720. Exclusion Code: X2.31531720
40 Bell KJ, Hayen A, Glasziou P, . Potential usefulness of BMD and bone turnover monitoring of zoledronic acid therapy among women with osteoporosis: secondary analysis of randomized controlled trial data. J Bone Miner Res. 2016 Sep;31(9):1767–73. doi: 10.1002/jbmr.2847. PMID: 27027655. Exclusion Code: X7.27027655
41 Berry ME. Preventing and treating osteoporosis. Radiol Technol. 2019 Jan;90(3):286–93. PMID: 30635461. Exclusion Code: X1.30635461
42 Berry SD, Kiel DP, Colón-Emeric C. Hip fractures in older adults in 2019. JAMA. 2019 Jun 11;321(22):2231–2. doi: 10.1001/jama.2019.5453. PMID: 31074763. Exclusion Code: X1.31074763
43 Bhandari M, Jin L, See K, . Does teriparatide improve femoral neck fracture healing: results from a randomized placebo-controlled trial. Clin Orthop Relat Res. 2016 May;474(5):1234–44. doi: 10.1007/s11999-015-4669-z. PMID: 26932738. Exclusion Code: X2.26932738
44 Bhat KA, Kakaji M, Awasthi A, . Utility of osteoporosis self-assessment tool as a screening tool for predicting osteoporosis in Indian men. J Clin Densitom. 2017 Apr–Jun;20(2):160–3. doi: 10.1016/j.jocd.2016.04.005. PMID: 27210803. Exclusion Code: X8.27210803
45 Bilek LD, Waltman NL, Lappe JM, . Protocol for a randomized controlled trial to compare bone-loading exercises with risedronate for preventing bone loss in osteopenic postmenopausal women. BMC Womens Health. 2016 Aug 30;16(1):59. doi: 10.1186/s12905-016-0339-x. PMID: 27576310. Exclusion Code: X7.27576310
46 Bilezikian JP, Lin CJF, Brown JP, . Long-term denosumab treatment restores cortical bone loss and reduces fracture risk at the forearm and humerus: analyses from the FREEDOM Extension cross-over group. Osteoporos Int. 2019 Sep;30(9):1855–64. doi: 10.1007/s00198-019-05020-8. PMID: 31201481. Exclusion Code: X6.31201481
47 Binkley N, Silverman SL, Simonelli C, . Monthly ibandronate suppresses serum CTX-I within 3 days and maintains a monthly fluctuating pattern of suppression. Osteoporos Int. 2009 Sep;20(9):1595–601. doi: 10.1007/s00198-008-0827-4. PMID: 19145396. Exclusion Code: X10.19145396
48 Biver E, Durosier-Izart C, Chevalley T, . Evaluation of radius microstructure and areal bone mineral density improves fracture prediction in postmenopausal women. J Bone Miner Res. 2018 Feb;33(2):328–37. doi: 10.1002/jbmr.3299. PMID: 28960489. Exclusion Code: X3.28960489
49 Black DM, Bauer DC, Vittinghoff E, . Treatment-related changes in bone mineral density as a surrogate biomarker for fracture risk reduction: meta-regression analyses of individual patient data from multiple randomised controlled trials. Lancet Diabetes Endocrinol. 2020 Aug;8(8):672–82. doi: 10.1016/s2213-8587(20)30159-5. PMID: 32707115. Exclusion Code: X3.32707115
50 Black DM, Condra K, Adams AL, Eastell R. Bisphosphonates and the risk of atypical femur fractures. Bone. 2022 Mar;156:116297. doi: 10.1016/j.bone.2021.116297. PMID: 34920168. Exclusion Code: X1.34920168
51 Black DM, Geiger EJ, Eastell R, . Atypical femur fracture risk versus fragility fracture prevention with bisphosphonates. N Engl J Med. 2020 Aug 20;383(8):743–53. doi: 10.1056/NEJMoa1916525. PMID: 32813950. Exclusion Code: X10.32813950
52 Black DM, Schwartz AV, Ensrud KE, . Effects of continuing or stopping alendronate after 5 years of treatment: the Fracture Intervention Trial Long-term Extension (FLEX): a randomized trial. JAMA. 2006 Dec 27;296(24):2927–38. doi: 10.1001/jama.296.24.2927. PMID: 17190893. Exclusion Code: X2.17190893
53 Bliuc D, Tran T, van Geel T, . Reduced bone loss is associated with reduced mortality risk in subjects exposed to nitrogen bisphosphonates: a mediation analysis. J Bone Miner Res. 2019 Nov;34(11):2001–11. doi: 10.1002/jbmr.3816. PMID: 31402509. Exclusion Code: X7.31402509
54 Bliuc D, Tran T, van Geel T, . Mortality risk reduction differs according to bisphosphonate class: a 15-year observational study. Osteoporos Int. 2019 Apr;30(4):817–28. doi: 10.1007/s00198-018-4806-0. PMID: 30607457. Exclusion Code: X3.30607457
55 Bolton JM, Morin SN, Majumdar SR, . Association of mental disorders and related medication use with risk for major osteoporotic fractures. JAMA Psychiatry. 2017 Jun 1;74(6):641–8. doi: 10.1001/jamapsychiatry.2017.0449. PMID: 28423154. Exclusion Code: X7.28423154
56 Bonaccorsi G, Fila E, Cervellati C, . Assessment of fracture risk in a population of postmenopausal Italian women: a comparison of two different tools. Calcif Tissue Int. 2015 Jul;97(1):50–7. doi: 10.1007/s00223-015-0009-2. PMID: 25939647. Exclusion Code: X4.25939647
57 Bone HG, Greenspan SL, McKeever C, . Alendronate and estrogen effects in postmenopausal women with low bone mineral density. Alendronate/Estrogen Study Group. J Clin Endocrinol Metab. 2000 Feb;85(2):720–6. doi: 10.1210/jcem.85.2.6393. PMID: 10690882. Exclusion Code: X5.10690882
58 Bone HG, Wagman RB, Brandi ML, . 10 years of denosumab treatment in postmenopausal women with osteoporosis: results from the phase 3 randomised FREEDOM trial and open-label extension. Lancet Diabetes Endocrinol. 2017 Jul;5(7):513–23. doi: 10.1016/s2213-8587(17)30138-9. PMID: 28546097. Exclusion Code: X6.28546097
59 Bovijn J, Krebs K, Chen CY, . Evaluating the cardiovascular safety of sclerostin inhibition using evidence from meta-analysis of clinical trials and human genetics. Sci Transl Med. 2020 Jun 24;12(549)doi: 10.1126/scitranslmed.aay6570. PMID: 32581134. Exclusion Code: X3.32581134
60 Bregigeon S, Galinier A, Zaegel-Faucher O, . Frailty in HIV infected people: a new risk factor for bone mineral density loss. AIDS. 2017 Jul 17;31(11):1573–7. doi: 10.1097/qad.0000000000001507. PMID: 28426535. Exclusion Code: X2.28426535
61 Briot K, Paternotte S, Kolta S, . FRAX®: prediction of major osteoporotic fractures in women from the general population: the OPUS study. PLoS One. 2013;8(12):e83436. doi: 10.1371/journal.pone.0083436. PMID: 24386199. Exclusion Code: X9.24386199
62 Brozek W, Reichardt B, Zwerina J, . Antiresorptive therapy and risk of mortality and refracture in osteoporosis-related hip fracture: a nationwide study. Osteoporos Int. 2016 Jan;27(1):387–96. doi: 10.1007/s00198-015-3415-4. PMID: 26576544. Exclusion Code: X2.26576544
63 Buehring B, Hansen KE, Lewis BL, . Dysmobility syndrome independently increases fracture risk in the osteoporotic fractures in men (MrOS) prospective cohort study. J Bone Miner Res. 2018 Sep;33(9):1622–9. doi: 10.1002/jbmr.3455. PMID: 29701911. Exclusion Code: X9.29701911
64 Byun JH, Jang S, Lee S, . The efficacy of bisphosphonates for prevention of osteoporotic fracture: an update meta-analysis. J Bone Metab. 2017 Feb;24(1):37–49. doi: 10.11005/jbm.2017.24.1.37. PMID: 28326300. Exclusion Code: X3.28326300
65 Cai G, Keen HI, Host LV, . Once-yearly zoledronic acid and change in abdominal aortic calcification over 3 years in postmenopausal women with osteoporosis: results from the HORIZON Pivotal Fracture Trial. Osteoporos Int. 2020 Sep;31(9):1741–7. doi: 10.1007/s00198-020-05430-z. PMID: 32361951. Exclusion Code: X7.32361951
66 Caillet P, Klemm S, Ducher M, . Hip fracture in the elderly: a re-analysis of the EPIDOS study with causal Bayesian networks. PLoS One. 2015;10(3):e0120125. doi: 10.1371/journal.pone.0120125. PMID: 25822373. Exclusion Code: X7.25822373
67 Cappelle SI, Ramon I, Dekelver C, . Distribution of clinical risk factors for fracture in a Brussels cohort of postmenopausal women: The FRISBEE study and comparison with other major cohort studies. Maturitas. 2017 Dec;106:1–7. doi: 10.1016/j.maturitas.2017.08.010. PMID: 29150162. Exclusion Code: X7.29150162
68 Cardwell CR, Abnet CC, Cantwell MM, Murray LJ. Exposure to oral bisphosphonates and risk of esophageal cancer. JAMA. 2010 Aug 11;304(6):657–63. doi: 10.1001/jama.2010.1098. PMID: 20699457. Exclusion Code: X10.20699457
69 Carvajal A, Martín Arias LH, Sáinz M, . Carpal tunnel syndrome associated with oral bisphosphonates. a population-based cohort study. PLoS One. 2016;11(1):e0146772. doi: 10.1371/journal.pone.0146772. PMID: 26765346. Exclusion Code: X7.26765346
70 Cass AR, Shepherd AJ, Asirot R, . Comparison of the Male Osteoporosis Risk Estimation Score (MORES) with FRAX in identifying men at risk for osteoporosis. Ann Fam Med. 2016 Jul;14(4):365–9. doi: 10.1370/afm.1945. PMID: 27401426. Exclusion Code: X9.27401426
71 Cauley JA, Norton L, Lippman ME, . Continued breast cancer risk reduction in postmenopausal women treated with raloxifene: 4-year results from the MORE trial. Multiple outcomes of raloxifene evaluation. Breast Cancer Res Treat. 2001 Jan;65(2):125–34. doi: 10.1023/a:1006478317173. PMID: 11261828. Exclusion Code: X5.11261828
72 Cha Y, Kim JT, Kim JW, . Effect of artificial intelligence or machine learning on prediction of hip fracture risk: systematic review. J Bone Metab. 2023 Aug;30(3):245–52. doi: 10.11005/jbm.2023.30.3.245. PMID: 37718902. Exclusion Code: X5.37718902
73 Chalitsios CV, Shaw DE, McKeever TM. Risk of subtrochanteric and femoral shaft fractures due to bisphosphonate therapy in asthma: a population-based nested case-control study. Osteoporos Int. 2022 Apr;33(4):931–5. doi: 10.1007/s00198-021-06197-7. PMID: 34635953. Exclusion Code: X3.34635953
74 Chambers JD, Winn A, Zhong Y, . Potential role of network meta-analysis in value-based insurance design. Am J Manag Care. 2014 Aug;20(8):641–8. PMID: 25295678. Exclusion Code: X3.25295678
75 Champakanath A, Keshawarz A, Pyle L, . Fracture risk assessment (FRAX) without BMD and risk of major osteoporotic fractures in adults with type 1 diabetes. Bone. 2021 Feb;143:115614. doi: 10.1016/j.bone.2020.115614. PMID: 32853853. Exclusion Code: X7.32853853
76 Chan MY, Nguyen ND, Center JR, . Absolute fracture-risk prediction by a combination of calcaneal quantitative ultrasound and bone mineral density. Calcif Tissue Int. 2012 Feb;90(2):128–36. doi: 10.1007/s00223-011-9556-3 [doi]. PMID: 22179560. Exclusion Code: X5.22179560
77 Chandran M. Fracture risk assessment in clinical practice: why do it? what to do it with?. J Clin Densitom. 2017 Jul–Sep;20(3):274–9. doi: 10.1016/j.jocd.2017.06.010. PMID: 28711299. Exclusion Code: X1.28711299
78 Chandran M, Chin YA, Choo KS, . Comparison of the osteoporosis self-assessment tool for Asians and the fracture risk assessment tool - FRAX to identify densitometric defined osteoporosis: a discriminatory value analysis in a multi-ethnic female population in Southeast Asia. Osteoporos Sarcopenia. 2020 Jun;6(2):53–8. doi: 10.1016/j.afos.2020.04.001. PMID: 32715094. Exclusion Code: X6.32715094
79 Chanplakorn P, Lertudomphonwanit T, Daraphongsataporn N, . Development of prediction model for osteoporotic vertebral compression fracture screening without using clinical risk factors, compared with FRAX and other previous models. Arch Osteoporos. 2021 Jun 3;16(1):84. doi: 10.1007/s11657-021-00957-y. PMID: 34085107. Exclusion Code: X8.34085107
80 Chao AS, Chen FP, Lin YC, . Application of the World Health Organization Fracture Risk Assessment Tool to predict need for dual-energy X-ray absorptiometry scanning in postmenopausal women. Taiwan J Obstet Gynecol. 2015 Dec;54(6):722–5. doi: 10.1016/j.tjog.2015.10.005. PMID: 26700992. Exclusion Code: X10.26700992
81 Chavassieux P, Portero-Muzy N, Roux JP, . Reduction of cortical bone turnover and erosion depth after 2 and 3 years of denosumab: iliac bone histomorphometry in the FREEDOM Trial. J Bone Miner Res. 2019 Apr;34(4):626–31. doi: 10.1002/jbmr.3631. PMID: 30601581. Exclusion Code: X7.30601581
82 Chen L, Liu XP, Zhou B, . Relationship between change in bone mineral density of lumbar spine and risk of new vertebral and nonvertebral fractures: a meta-analysis. Orthop Surg. 2022 Feb;14(2):199–206. doi: 10.1111/os.13184. PMID: 34985187. Exclusion Code: X3.34985187
83 Chen L, Wang G, Zheng F, . Efficacy of bisphosphonates against osteoporosis in adult men: a meta-analysis of randomized controlled trials. Osteoporos Int. 2015 Sep;26(9):2355–63. doi: 10.1007/s00198-015-3148-4. PMID: 25944731. Exclusion Code: X3.25944731
84 Chen W, Simpson JM, March LM, . Comorbidities only account for a small proportion of excess mortality after fracture: a record linkage study of individual fracture types. J Bone Miner Res. 2018 May;33(5):795–802. doi: 10.1002/jbmr.3374. PMID: 29314242. Exclusion Code: X3.29314242
85 Chen Y, Liu R, Hettinghouse A, . Clinical application of teriparatide in fracture prevention: a systematic review. JBJS Rev. 2019 Jan;7(1):e10. doi: 10.2106/jbjs.Rvw.18.00052. PMID: 30694878. Exclusion Code: X3.30694878
86 Cherian KE, Kapoor N, Shetty S, . Evaluation of different screening tools for predicting femoral neck osteoporosis in rural south Indian postmenopausal women. J Clin Densitom. 2018 Jan–Mar;21(1):119–24. doi: 10.1016/j.jocd.2017.08.002. PMID: 28958825. Exclusion Code: X8.28958825
87 Chiang CH, Huang CC, Chan WL, . Oral alendronate use and risk of cancer in postmenopausal women with osteoporosis: a nationwide study. J Bone Miner Res. 2012 Sep;27(9):1951–8. doi: 10.1002/jbmr.1645. PMID: 22532232. Exclusion Code: X10.22532232
88 Chiu WY, Yang WS, Chien JY, . The influence of alendronate and tooth extraction on the incidence of osteonecrosis of the jaw among osteoporotic subjects. PLoS One. 2018;13(4):e0196419. doi: 10.1371/journal.pone.0196419. PMID: 29694412. Exclusion Code: X6.29694412
89 Choi D, Choi S, Chang J, Park SM. Exposure to oral bisphosphonates and risk of gastrointestinal cancer. Osteoporos Int. 2020 Apr;31(4):775–82. doi: 10.1007/s00198-020-05327-x. PMID: 32034451. Exclusion Code: X10.32034451
90 Chotiyarnwong P, McCloskey E, Eastell R, . A pooled analysis of fall incidence from placebo-controlled trials of denosumab. J Bone Miner Res. 2020 Jun;35(6):1014–21. doi: 10.1002/jbmr.3972. PMID: 31999376. Exclusion Code: X3.31999376
91 Cipriani C, Castro C, Curione M, . Acute effect of zoledronic acid on the risk of cardiac dysrhythmias. Intern Emerg Med. 2015 Mar;10(2):151–6. doi: 10.1007/s11739-014-1125-0. PMID: 25190623. Exclusion Code: X7.25190623
92 Cipriani C, Pepe J, Bertoldo F, . The epidemiology of osteoporosis in Italian postmenopausal women according to the National Bone Health Alliance (NBHA) diagnostic criteria: a multicenter cohort study. J Endocrinol Invest. 2018 Apr;41(4):431–8. doi: 10.1007/s40618-017-0761-4. PMID: 28956296. Exclusion Code: X7.28956296
93 Cohen A, Shiau S, Nair N, . Effect of teriparatide on bone remodeling and density in premenopausal idiopathic osteoporosis: a phase II trial. J Clin Endocrinol Metab. 2020 Oct 1;105(10)doi: 10.1210/clinem/dgaa489. PMID: 32876328. Exclusion Code: X2.32876328
94 Condurache CI, Chiu S, Chotiyarnwong P, . Screening for high hip fracture risk does not impact on falls risk: a post hoc analysis from the SCOOP study. Osteoporos Int. 2020 Mar;31(3):457–64. doi: 10.1007/s00198-019-05270-6. PMID: 31960099. Exclusion Code: X7.31960099
95 Cortet B, Modi A, Tang J, . Association between gastrointestinal events and osteoporosis treatment initiation in women diagnosed with osteoporosis in France: a retrospective analysis. BMC Musculoskelet Disord. 2016 Apr 30;17:195. doi: 10.1186/s12891-016-1041-8. PMID: 27139225. Exclusion Code: X6.27139225
96 Cosman F, Crittenden DB, Adachi JD, . Romosozumab treatment in postmenopausal women with osteoporosis. N Engl J Med. 2016 Oct 20;375(16):1532–43. doi: 10.1056/NEJMoa1607948. PMID: 27641143. Exclusion Code: X5.27641143
97 Cosman F, Crittenden DB, Ferrari S, . FRAME study: the foundation effect of building bone with 1 year of romosozumab leads to continued lower fracture risk after transition to denosumab. J Bone Miner Res. 2018 Jul;33(7):1219–26. doi: 10.1002/jbmr.3427. PMID: 29573473. Exclusion Code: X3.29573473
98 Cosman F, Hattersley G, Hu MY, . Effects of abaloparatide-SC on fractures and bone mineral density in subgroups of postmenopausal women with osteoporosis and varying baseline risk factors. J Bone Miner Res. 2017 Jan;32(1):17–23. doi: 10.1002/jbmr.2991. PMID: 27612281. Exclusion Code: X2.27612281
99 Cosman F, Miller PD, Williams GC, . Eighteen months of treatment with subcutaneous abaloparatide followed by 6 months of treatment with alendronate in postmenopausal women with osteoporosis: results of the ACTIVExtend Trial. Mayo Clin Proc. 2017 Feb;92(2):200–10. doi: 10.1016/j.mayocp.2016.10.009. PMID: 28160873. Exclusion Code: X6.28160873
100 Cosman F, Peterson LR, Towler DA, . Cardiovascular safety of abaloparatide in postmenopausal women with osteoporosis: analysis from the ACTIVE phase 3 trial. J Clin Endocrinol Metab. 2020 Nov 1;105(11):3384–95. doi: 10.1210/clinem/dgaa450. PMID: 32658264. Exclusion Code: X5.32658264
101 Crandall CJ. Risk assessment tools for osteoporosis screening in postmenopausal women: a systematic review. Curr Osteoporos Rep. 2015 Oct;13(5):287–301. doi: 10.1007/s11914-015-0282-z. PMID: 26233285. Exclusion Code: X10.26233285
102 Cronholm F, Rosengren BE, Nilsson J, . The fracture predictive ability of a musculoskeletal composite score in old men - data from the MrOs Sweden study. BMC Geriatr. 2019 Mar 22;19(1):90. doi: 10.1186/s12877-019-1106-2. PMID: 30902044. Exclusion Code: X3.30902044
103 Cummings SR, Ferrari S, Eastell R, . Vertebral fractures after discontinuation of denosumab: a post hoc analysis of the randomized placebo-controlled FREEDOM trial and its extension. J Bone Miner Res. 2018 Feb;33(2):190–8. doi: 10.1002/jbmr.3337. PMID: 29105841. Exclusion Code: X3.29105841
104 Cummins NM, Poku EK, Towler MR, . Clinical risk factors for osteoporosis in Ireland and the UK: a comparison of FRAX and QFractureScores. Calcif Tissue Int. 2011 Aug;89(2):172–7. doi: 10.1007/s00223-011-9504-2 [doi]. PMID: 21647704. Exclusion Code: X9.21647704
105 Curhan SG, Stankovic K, Halpin C, . Osteoporosis, bisphosphonate use, and risk of moderate or worse hearing loss in women. J Am Geriatr Soc. 2021 May 24doi: 10.1111/jgs.17275. PMID: 34028002. Exclusion Code: X7.34028002
106 Curtis EM, Harvey NC, D’Angelo S, . Bone mineral content and areal density, but not bone area, predict an incident fracture risk: a comparative study in a UK prospective cohort. Arch Osteoporos. 2016 Dec;11(1):39. doi: 10.1007/s11657-016-0293-0. PMID: 27915448. Exclusion Code: X4.27915448
107 Czerwiński E, Borowy P, Kumorek A, . Fracture risk prediction in outpatients from Krakow region using FRAX tool versus fracture risk in 11-year follow-up. Ortop Traumatol Rehabil. 2013 Nov–Dec;15(6):617–28. doi: 10.5604/15093492.1091517. PMID: 24662908. Exclusion Code: X4.24662908
108 Czerwinski E, Cardona J, Plebanski R, . The efficacy and safety of abaloparatide-SC in men with osteoporosis: a randomized clinical trial. J Bone Miner Res. 2022;37(12):2435–42. doi: 10.1002/jbmr.4719. PMID: CN-02470664. Exclusion Code: X9.36190391
109 Czerwinski E, Cardona J, Plebanski R, . The Efficacy and Safety of Abaloparatide-SC in Men With Osteoporosis: A Randomized Clinical Trial. J Bone Miner Res. 2022 Oct 3doi: 10.1002/jbmr.4719. PMID: 36190391. Exclusion Code: X2.36190391
110 Dagan N, Elnekave E, Barda N, . Automated opportunistic osteoporotic fracture risk assessment using computed tomography scans to aid in FRAX underutilization. Nat Med. 2020 Jan;26(1):77–82. doi: 10.1038/s41591-019-0720-z. PMID: 31932801. Exclusion Code: X9.31932801
111 Das P, Goenka S, Sharma RK. Effect of subcutaneous administration of denosumab in postmenopausal osteoporosis. European journal of molecular and clinical medicine. 2022;9(3):2529–36. PMID: CN-02396006. Exclusion Code: X8.
112 Davis S, Martyn-St James M, Sanderson J, . A systematic review and economic evaluation of bisphosphonates for the prevention of fragility fractures. Health Technol Assess. 2016 Oct;20(78):1–406. doi: 10.3310/hta20780. PMID: 27801641. Exclusion Code: X3.27801641
113 Davis SR, Tan A, Bell RJ. Targeted assessment of fracture risk in women at midlife. Osteoporos Int. 2015 Jun;26(6):1705–12. doi: 10.1007/s00198-015-3046-9. PMID: 25630574. Exclusion Code: X3.25630574
114 de Abreu LLF, Holloway-Kew KL, Sajjad MA, . FRAX (Australia) scores in women with impaired fasting glucose and diabetes. Bone Rep. 2019 Dec;11:100223. doi: 10.1016/j.bonr.2019.100223. PMID: 31463338. Exclusion Code: X7.31463338
115 de Vries BCS, Hegeman JH, Nijmeijer W, . Comparing three machine learning approaches to design a risk assessment tool for future fractures: predicting a subsequent major osteoporotic fracture in fracture patients with osteopenia and osteoporosis. Osteoporos Int. 2021 Mar;32(3):437–49. doi: 10.1007/s00198-020-05735-z. PMID: 33415373. Exclusion Code: X2.33415373
116 Deal CL, Mitlak BH, Wang Y, . Response rates for hip, femoral neck, and lumbar spine bone mineral density in patients treated with abaloparatide followed by alendronate: results from phase 3 ACTIVExtend. Bone Rep. 2019 Dec;11:100230. doi: 10.1016/j.bonr.2019.100230. PMID: 31799340. Exclusion Code: X6.31799340
117 Delmas PD, Ensrud KE, Adachi JD, . Efficacy of raloxifene on vertebral fracture risk reduction in postmenopausal women with osteoporosis: four-year results from a randomized clinical trial. J Clin Endocrinol Metab. 2002 Aug;87(8):3609–17. doi: 10.1210/jcem.87.8.8750. PMID: 12161484. Exclusion Code: X5.12161484
118 Dempster DW, Brown JP, Fahrleitner-Pammer A, . Effects of long-term denosumab on bone histomorphometry and mineralization in women with postmenopausal osteoporosis. J Clin Endocrinol Metab. 2018 Jul 1;103(7):2498–509. doi: 10.1210/jc.2017-02669. PMID: 29672714. Exclusion Code: X7.29672714
119 Dhiman P, Andersen S, Vestergaard P, . Does bone mineral density improve the predictive accuracy of fracture risk assessment? A prospective cohort study in Northern Denmark. BMJ Open. 2018 Apr 12;8(4):e018898. doi: 10.1136/bmjopen-2017-018898. PMID: 29654006. Exclusion Code: X3.29654006
120 DiGiulio M, Loveless T, Heider G, . Bisphosphonate drug holidays: one size does not fit all. Nurse Pract. 2020 Mar;45(3):50–5. doi: 10.1097/01.NPR.0000605524.34681.e7. PMID: 32068658. Exclusion Code: X1.32068658
121 Dömötör ZR, Vörhendi N, Hanák L, . Oral treatment with bisphosphonates of osteoporosis does not increase the risk of severe gastrointestinal side effects: a meta-analysis of randomized controlled trials. Front Endocrinol (Lausanne). 2020;11:573976. doi: 10.3389/fendo.2020.573976. PMID: 33240217. Exclusion Code: X3.33240217
122 Donaldson MG, Palermo L, Schousboe JT, . FRAX and risk of vertebral fractures: the fracture intervention trial. J Bone Miner Res. 2009 Nov;24(11):1793–9. doi: 10.1359/jbmr.090511 [doi]. PMID: 19419318. Exclusion Code: X9.19419318
123 Drieling RL, LaCroix AZ, Beresford SA, . Long-term oral bisphosphonate use in relation to fracture risk in postmenopausal women with breast cancer: findings from the Women’s Health Initiative. Menopause. 2016 Nov;23(11):1168–75. doi: 10.1097/gme.0000000000000696. PMID: 27433859. Exclusion Code: X6.27433859
124 Duerksen DR, Lix LM, Johansson H, . Fracture risk assessment in celiac disease: a registry-based cohort study. Osteoporos Int. 2021 Jan;32(1):93–9. doi: 10.1007/s00198-020-05579-7. PMID: 32748311. Exclusion Code: X3.32748311
125 Dundar U, Kavuncu V, Ciftci IH, . The effect of risedronate treatment on serum cytokines in postmenopausal osteoporosis: a 6-month randomized and controlled study. J Bone Miner Metab. 2009;27(4):464–70. doi: 10.1007/s00774-009-0055-9. PMID: 19301089. Exclusion Code: X10.19301089
126 Eastell R, Mitlak BH, Wang Y, . Bone turnover markers to explain changes in lumbar spine BMD with abaloparatide and teriparatide: results from ACTIVE. Osteoporos Int. 2019 Mar;30(3):667–73. doi: 10.1007/s00198-018-04819-1. PMID: 30635696. Exclusion Code: X7.30635696
127 Eiken PA, Prieto-Alhambra D, Eastell R, Abrahamsen B. Surgically treated osteonecrosis and osteomyelitis of the jaw and oral cavity in patients highly adherent to alendronate treatment: a nationwide user-only cohort study including over 60,000 alendronate users. Osteoporos Int. 2017 Oct;28(10):2921–8. doi: 10.1007/s00198-017-4132-y. PMID: 28664276. Exclusion Code: X3.28664276
128 Ensrud KE, Taylor BC, Peters KW, . Implications of expanding indications for drug treatment to prevent fracture in older men in United States: cross sectional and longitudinal analysis of prospective cohort study. BMJ. 2014 Jul 3;349:g4120. doi: 10.1136/bmj.g4120. PMID: 24994809. Exclusion Code: X7.24994809
129 Erjiang E, Wang T, Yang L, . Machine learning can improve clinical detection of low BMD: the DXA-HIP Study. J Clin Densitom. 2021 Oct–Dec;24(4):527–37. doi: 10.1016/j.jocd.2020.10.004. PMID: 33187864. Exclusion Code: X9.33187864
130 Ettinger B, Black DM, Mitlak BH, . Reduction of vertebral fracture risk in postmenopausal women with osteoporosis treated with raloxifene: results from a 3-year randomized clinical trial. Multiple Outcomes of Raloxifene Evaluation (MORE) Investigators. JAMA. 1999 Aug 18;282(7):637–45. doi: 10.1001/jama.282.7.637. PMID: 10517716. Exclusion Code: X5.10517716
131 Ettinger B, Hillier TA, Pressman A, . Simple computer model for calculating and reporting 5-year osteoporotic fracture risk in postmenopausal women. J Womens Health (Larchmt). 2005 Mar;14(2):159–71. doi: 10.1089/jwh.2005.14.159 [doi]. PMID: 15775734. Exclusion Code: X9.15775734
132 Everts-Graber J, Reichenbach S, Gahl B, . Risk factors for vertebral fractures and bone loss after denosumab discontinuation: a real-world observational study. Bone. 2021 Mar;144:115830. doi: 10.1016/j.bone.2020.115830. PMID: 33359006. Exclusion Code: X6.33359006
133 Fadda V, Maratea D, Trippoli S, Messori A. Gastrointestinal and renal side effects of bisphosphonates: differentiating between no proof of difference and proof of no difference. J Endocrinol Invest. 2015 Feb;38(2):189–92. doi: 10.1007/s40618-014-0211-5. PMID: 25412945. Exclusion Code: X3.25412945
134 Fan Q, Wang J. The efficacy and safety of bisphosphonates for osteoporosis in women older than 65 years: a meta-analysis. Curr Pharm Des. 2020;26(32):4022–30. doi: 10.2174/1381612826666200423092602. PMID: 32324507. Exclusion Code: X3.32324507
135 Fan Z, Li X, Zhang X, . Comparison of OSTA, FRAX and BMI for predicting postmenopausal osteoporosis in a Han population in Beijing: a cross sectional study. Clin Interv Aging. 2020;15:1171–80. doi: 10.2147/cia.S257166. PMID: 32764904. Exclusion Code: X8.32764904
136 Ferrari S, Adachi JD, Lippuner K, . Further reductions in nonvertebral fracture rate with long-term denosumab treatment in the FREEDOM open-label extension and influence of hip bone mineral density after 3 years. Osteoporos Int. 2015 Dec;26(12):2763–71. doi: 10.1007/s00198-015-3179-x. PMID: 26068295. Exclusion Code: X6.26068295
137 Ferrari S, Butler PW, Kendler DL, . Further nonvertebral fracture reduction beyond 3 years for up to 10 years of denosumab treatment. J Clin Endocrinol Metab. 2019 Aug 1;104(8):3450–61. doi: 10.1210/jc.2019-00271. PMID: 31125092. Exclusion Code: X6.31125092
138 Ferrari S, Eastell R, Napoli N, . Denosumab in postmenopausal women with osteoporosis and diabetes: subgroup analysis of FREEDOM and FREEDOM extension. Bone. 2020 May;134:115268. doi: 10.1016/j.bone.2020.115268. PMID: 32058020. Exclusion Code: X2.32058020
139 Ferrari S, Lewiecki EM, Butler PW, . Favorable skeletal benefit/risk of long-term denosumab therapy: a virtual-twin analysis of fractures prevented relative to skeletal safety events observed. Bone. 2020 May;134:115287. doi: 10.1016/j.bone.2020.115287. PMID: 32092479. Exclusion Code: X6.32092479
140 Ferrari S, Libanati C, Lin CJF, . Relationship between bone mineral density T-Score and nonvertebral fracture risk over 10 years of denosumab treatment. J Bone Miner Res. 2019 Jun;34(6):1033–40. doi: 10.1002/jbmr.3722. PMID: 30919997. Exclusion Code: X6.30919997
141 Fink HA, Butler ME, Claussen AM, . Performance of fracture risk assessment tools by race and ethnicity: a systematic review for the ASBMR Task Force on Clinical Algorithms for Fracture Risk. J Bone Miner Res. 2023 Dec;38(12):1731–41. doi: 10.1002/jbmr.4895. PMID: 37597237. Exclusion Code: X10.37597237
142 Fogelman I, Ribot C, Smith R, . Risedronate reverses bone loss in postmenopausal women with low bone mass: results from a multinational, double-blind, placebo-controlled trial. BMD-MN Study Group. J Clin Endocrinol Metab. 2000 May;85(5):1895–900. doi: 10.1210/jcem.85.5.6603. PMID: 10843171. Exclusion Code: X10.10843171
143 Forti P, Rietti E, Pisacane N, . A comparison of frailty indexes for prediction of adverse health outcomes in an elderly cohort. Arch Gerontol Geriatr. 2012 Jan–Feb;54(1):16–20. doi: 10.1016/j.archger.2011.01.007. PMID: 21339007. Exclusion Code: X4.21339007
144 Francesco L, Elisa B, Raffaella M, . Assessing risk of osteoporotic fractures in primary care: development and validation of the FRA-HS algorithm. Calcif Tissue Int. 2017 Jun;100(6):537–49. doi: 10.1007/s00223-016-0230-7. PMID: 28160026. Exclusion Code: X3.28160026
145 Friis-Holmberg T, Rubin KH, Brixen K, . Fracture risk prediction using phalangeal bone mineral density or FRAX((R))?-a Danish cohort study on men and women. J Clin Densitom. 2014 Jan–Mar;17(1):7–15. doi: 10.1016/j.jocd.2013.03.014. PMID: 23623379. Exclusion Code: X9.23623379
146 Fuggle NR, Cooper C, Harvey NC, . Assessment of cardiovascular safety of anti-osteoporosis drugs. Drugs. 2020 Oct;80(15):1537–52. doi: 10.1007/s40265-020-01364-2. PMID: 32725307. Exclusion Code: X3.32725307
147 Fujimaki H, Tomioka M, Kanoshima Y, . Accuracy of the Fracture Risk Assessment Tool for judging pharmacotherapy initiation for primary osteoporosis. J Bone Miner Metab. 2022 Sep;40(5):860–8. doi: 10.1007/s00774-022-01356-0. PMID: 35945295. Exclusion Code: X6.35945295
148 Gartlehner G, Patel S, Viswanathan M, . Hormone therapy for the primary prevention of chronic conditions in postmenopausal women: an evidence review for the U.S. Preventive Services Task Force [Internet] (Prepared by the RTI International-University of North Carolina Evidence-based Practice Center under Contract No. HHSA-290-2012-00015-I.) U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews, Evidence Synthesis, No. 155. Report No.: 15-05227-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; December 2017. Exclusion Code: X5.
149 Gazoni FM, Civile VT, Atallah Á N, . Intravenous zoledronate for postmenopausal women with osteopenia and osteoporosis: a systematic review and metanalysis. Sao Paulo Med J. 2023;141(6):e2022480. doi: 10.1590/1516-3180.2022.0480.R1.27032023. PMID: 37255065. Exclusion Code: X3.37255065
150 Genant HK, Engelke K, Bolognese MA, . Effects of romosozumab compared with teriparatide on bone density and mass at the spine and hip in postmenopausal women with low bone mass. J Bone Miner Res. 2017 Jan;32(1):181–7. doi: 10.1002/jbmr.2932. PMID: 27487526. Exclusion Code: X7.27487526
151 Geusens P, Oates M, Miyauchi A, . The effect of 1 year of romosozumab on the incidence of clinical vertebral fractures in postmenopausal women with osteoporosis: results from the FRAME Study. JBMR Plus. 2019 Oct;3(10):e10211. doi: 10.1002/jbm4.10211. PMID: 31687647. Exclusion Code: X5.31687647
152 Ghannam S, Blaney H, Gelfond J, Bruder JM. The use of FRAX in identifying women less than 65 years needing bone mineral density testing. J Clin Densitom. 2021 Jan–Mar;24(1):36–43. doi: 10.1016/j.jocd.2020.05.002. PMID: 32792202. Exclusion Code: X2.32792202
153 Girman CJ, Chandler JM, Zimmerman SI, . Prediction of fracture in nursing home residents. J Am Geriatr Soc. 2002 Aug;50(8):1341–7. doi: 10.1046/j.1532-5415.2002.50354.x. PMID: 12164989. Exclusion Code: X2.12164989
154 Gnudi S, Sitta E. Clinical risk factor evaluation to defer postmenopausal women from bone mineral density measurement: an Italian study. J Clin Densitom. 2005 Summer;8(2):199–205. doi: 10.1385/jcd:8:2:199. PMID: 15908708. Exclusion Code: X5.15908708
155 Gough Courtney M, Roberts J, Godde K. Development of a diverse osteoporosis screening tool for older US adults from the health and retirement study. Heliyon. 2024 Jan 15;10(1):e23806. doi: 10.1016/j.heliyon.2023.e23806. PMID: 38192805. Exclusion Code: X5.38192805
156 Graeff C, Campbell GM, Peña J, . Administration of romosozumab improves vertebral trabecular and cortical bone as assessed with quantitative computed tomography and finite element analysis. Bone. 2015 Dec;81:364–9. doi: 10.1016/j.bone.2015.07.036. PMID: 26232375. Exclusion Code: X7.26232375
157 Greenspan SL, Bone HG, Ettinger MP, . Effect of recombinant human parathyroid hormone (1-84) on vertebral fracture and bone mineral density in postmenopausal women with osteoporosis: a randomized trial. Ann Intern Med. 2007 Mar 6;146(5):326–39. doi: 10.7326/0003-4819-146-5-200703060-00005. PMID: 17339618. Exclusion Code: X5.17339618
158 Greenspan SL, Fitzpatrick LA, Mitlak B, . Abaloparatide followed by alendronate in women ≥80 years with osteoporosis: post hoc analysis of ACTIVExtend. Menopause. 2020 Oct;27(10):1137–42. doi: 10.1097/gme.0000000000001593. PMID: 32665529. Exclusion Code: X6.32665529
159 Gregson CL, Armstrong DJ, Bowden J, . UK clinical guideline for the prevention and treatment of osteoporosis. Arch Osteoporos. 2022 Apr 5;17(1):58. doi: 10.1007/s11657-022-01061-5. PMID: 35378630. Exclusion Code: X1.35378630
160 Grey A, Horne A, Gamble G, . Ten years of very infrequent zoledronate therapy in older women: an open-label extension of a randomized trial. J Clin Endocrinol Metab. 2020 Apr 1;105(4)doi: 10.1210/clinem/dgaa062. PMID: 32016386. Exclusion Code: X6.32016386
161 Habib ZA. Bisphosphonates in the treatment of osteoporosis: a review of skeletal safety concerns. Expert Rev Endocrinol Metab. 2017 Jan;12(1):59–71. doi: 10.1080/17446651.2017.1256199. PMID: 30058876. Exclusion Code: X1.30058876
162 Hagino H, Soen S, Sugimoto T, . Changes in quality of life in patients with postmenopausal osteoporosis receiving weekly bisphosphonate treatment: a 2-year multicenter study in Japan. J Bone Miner Metab. 2019 Mar;37(2):273–81. doi: 10.1007/s00774-018-0914-3. PMID: 29523963. Exclusion Code: X6.29523963
163 Harvey NC, Kanis JA, Odén A, . FRAX and the effect of teriparatide on vertebral and non-vertebral fracture. Osteoporos Int. 2015 Nov;26(11):2677–84. doi: 10.1007/s00198-015-3173-3. PMID: 26092063. Exclusion Code: X5.26092063
164 Harvey NC, Kanis JA, Odén A, . Efficacy of weekly teriparatide does not vary by baseline fracture probability calculated using FRAX. Osteoporos Int. 2015 Sep;26(9):2347–53. doi: 10.1007/s00198-015-3129-7. PMID: 26092062. Exclusion Code: X2.26092062
165 Harvey NC, Odén A, Orwoll E, . Falls Falls predict fractures independently of FRAX probability: a meta-analysis of the Osteoporotic Fractures in Men (MrOS) Study. J Bone Miner Res. 2018 Mar;33(3):510–6. doi: 10.1002/jbmr.3331. PMID: 29220072. Exclusion Code: X3.29220072
166 Hassanabadi N, Berger C, Papaioannou A, . Variation in bone mineral density and fractures over 20 years among Canadians: a comparison of the Canadian Multicenter Osteoporosis Study and the Canadian Longitudinal Study on Aging. Osteoporos Int. 2023 Feb;34(2):357–67. doi: 10.1007/s00198-022-06623-4. PMID: 36449036. Exclusion Code: X7.36449036
167 Henry MJ, Pasco JA, Merriman EN, . Fracture risk score and absolute risk of fracture. Radiology. 2011 May;259(2):495–501. doi: 10.1148/radiol.10101406. PMID: 21292868. Exclusion Code: X9.21292868
168 Henry MJ, Pasco JA, Sanders KM, . Fracture risk (FRISK) score: Geelong Osteoporosis Study. Radiology. 2006 Oct;241(1):190–6. doi: 10.1148/radiol.2411051290. PMID: 16928979. Exclusion Code: X9.16928979
169 Herd RJ, Balena R, Blake GM, . The prevention of early postmenopausal bone loss by cyclical etidronate therapy: a 2-year, double-blind, placebo-controlled study. Am J Med. 1997 Aug;103(2):92–9. doi: 10.1016/s0002-9343(97)00019-3. PMID: 9274891. Exclusion Code: X5.9274891
170 Hillier TA, Cauley JA, Rizzo JH, . WHO absolute fracture risk models (FRAX): do clinical risk factors improve fracture prediction in older women without osteoporosis? J Bone Miner Res. 2011 Aug;26(8):1774–82. doi: 10.1002/jbmr.372. PMID: 21351144. Exclusion Code: X7.21351144
171 Ho-Le TP, Center JR, Eisman JA, . Prediction of hip fracture in post-menopausal women using artificial neural network approach. Annu Int Conf IEEE Eng Med Biol Soc. 2017 Jul;2017:4207–10. doi: 10.1109/embc.2017.8037784. PMID: 29060825. Exclusion Code: X5.29060825
172 Ho-Pham LT, Doan MC, Van LH, Nguyen TV. Development of a model for identification of individuals with high risk of osteoporosis. Arch Osteoporos. 2020 Jul 22;15(1):111. doi: 10.1007/s11657-020-00788-3. PMID: 32699999. Exclusion Code: X3.32699999
173 Hoff M, Meyer HE, Skurtveit S, . Validation of FRAX and the impact of self-reported falls among elderly in a general population: the HUNT study, Norway. Osteoporos Int. 2017 Oct;28(10):2935–44. doi: 10.1007/s00198-017-4134-9. PMID: 28668994. Exclusion Code: X4.28668994
174 Hoff M, Skovlund E, Meyer HE, . Does treatment with bisphosphonates protect against fractures in real life? The HUNT study, Norway. Osteoporos Int. 2021 Jul;32(7):1395–404. doi: 10.1007/s00198-021-05845-2. PMID: 33479844. Exclusion Code: X3.33479844
175 Høiberg MP, Rubin KH, Hermann AP, . Diagnostic devices for osteoporosis in the general population: a systematic review. Bone. 2016 Nov;92:58–69. doi: 10.1016/j.bone.2016.08.011. PMID: 27542659. Exclusion Code: X5.27542659
176 Holloway KL, Mohebbi M, Betson AG, . Prediction of major osteoporotic and hip fractures in Australian men using FRAX scores adjusted with trabecular bone score. Osteoporos Int. 2018 Jan;29(1):101–8. doi: 10.1007/s00198-017-4226-6. PMID: 28940052. Exclusion Code: X9.28940052
177 Holloway-Kew KL, Zhang Y, Betson AG, . How well do the FRAX (Australia) and Garvan calculators predict incident fractures? Data from the Geelong osteoporosis study. Osteoporos Int. 2019 Oct;30(10):2129–39. doi: 10.1007/s00198-019-05088-2. PMID: 31317250. Exclusion Code: X9.31317250
178 Hsu CY, Wu CH, Yu SF, . Novel algorithm generating strategy to identify high fracture risk population using a hybrid intervention threshold. J Bone Miner Metab. 2020 Mar;38(2):213–21. doi: 10.1007/s00774-019-01046-4. PMID: 31583541. Exclusion Code: X7.31583541
179 Huang G, Coviello A, LaValley MP, . Surgical menopause and frailty risk in community-dwelling older women: study of osteoporotic fractures. J Am Geriatr Soc. 2018 Nov;66(11):2172–7. doi: 10.1111/jgs.15505. PMID: 30251302. Exclusion Code: X5.30251302
180 Huang JY, Song WZ, Huang M. Effectiveness of osteoporosis self-assessment tool for Asians in screening for osteoporosis in healthy males over 40 years old in China. J Clin Densitom. 2017 Apr–Jun;20(2):153–9. doi: 10.1016/j.jocd.2017.01.003. PMID: 28153410. Exclusion Code: X8.28153410
181 Huang ML, Hsieh TJ, Lin SS, Huang WC. Associations between trabecular bone score and bone mineral density in Taiwanese older adult men. Journal of Men’s Health. 2023;19(1):15–22. doi: 10.22514/jomh.2023.005. Exclusion Code: X5.
182 Huang X, Chen B, Thabane L, . Fragility of results from randomized controlled trials supporting the guidelines for the treatment of osteoporosis: a retrospective analysis. Osteoporos Int. 2021 Sep;32(9):1713–23. doi: 10.1007/s00198-021-05865-y. PMID: 33595680. Exclusion Code: X3.33595680
183 Hundrup YA, Jacobsen RK, Andreasen AH, . Validation of a 5-year risk score of hip fracture in postmenopausal women. The Danish nurse cohort study. Osteoporos Int. 2010 Dec;21(12):2135–42. doi: 10.1007/s00198-010-1176-7 [doi]. PMID: 20157806. Exclusion Code: X4.20157806
184 Hung WC, Lin YL, Cheng TT, . Establish and validate the reliability of predictive models in bone mineral density by deep learning as examination tool for women. Osteoporos Int. 2023 Sep 20doi: 10.1007/s00198-023-06913-5. PMID: 37728768. Exclusion Code: X4.37728768
185 Iconaru L, Charles A, Baleanu F, . Selection for treatment of patients at high risk of fracture by the short versus long term prediction models - data from the Belgian FRISBEE cohort. Osteoporos Int. 2023 Jun;34(6):1119–25. doi: 10.1007/s00198-023-06737-3. PMID: 37022466. Exclusion Code: X2.37022466
186 Iconaru L, Moreau M, Kinnard V, . Does the prediction accuracy of osteoporotic fractures by BMD and clinical risk factors vary with fracture site? JBMR Plus. 2019 Dec;3(12):e10238. doi: 10.1002/jbm4.10238. PMID: 31844826. Exclusion Code: X3.31844826
187 Iki M, Fujita Y, Tamaki J, . Trabecular bone score may improve FRAX(R) prediction accuracy for major osteoporotic fractures in elderly Japanese men: the Fujiwara-kyo Osteoporosis Risk in Men (FORMEN) Cohort Study. Osteoporos Int. 2015 Jun;26(6):1841–8. doi: 10.1007/s00198-015-3092-3. PMID: 25752623. Exclusion Code: X9.25752623
188 Iki M, Fujita Y, Tamaki J, . Trabecular bone score may improve FRAX® prediction accuracy for major osteoporotic fractures in elderly Japanese men: the Fujiwara-kyo Osteoporosis Risk in Men (FORMEN) Cohort Study. Osteoporos Int. 2015 Jun;26(6):1841–8. doi: 10.1007/s00198-015-3092-3. PMID: 25752623. Exclusion Code: X3.25752623
189 Iki M, Tamaki J, Kadowaki E, . Trabecular bone score (TBS) predicts vertebral fractures in Japanese women over 10 years independently of bone density and prevalent vertebral deformity: the Japanese Population-Based Osteoporosis (JPOS) cohort study. J Bone Miner Res. 2014 Feb;29(2):399–407. doi: 10.1002/jbmr.2048 [doi]. PMID: 23873699. Exclusion Code: X5.23873699
190 İlgezdi ZD, Aktaş İ, Doğan Metin F, . Acute effect of zoledronic acid infusion on atrial fibrillation development in patients with osteoporosis. Anatol J Cardiol. 2015 Apr;15(4):320–4. doi: 10.5152/akd.2014.5333. PMID: 25413229. Exclusion Code: X6.25413229
191 Imai T, Hosoi T, Hagino H, . Antiresorptive drugs and the risk of femoral shaft fracture in men and women with osteoporosis: a cohort study using the national database of health insurance claims of Japan. J Epidemiol. 2023 Dec 5;33(12):633–9. doi: 10.2188/jea.JE20220099. PMID: 36567127. Exclusion Code: X6.36567127
192 Indhavivadhana S, Rattanachaiyanont M, Angsuwathana S, . Validation of osteoporosis risk assessment tools in middle-aged Thai women. Climacteric. 2016 Dec;19(6):588–93. doi: 10.1080/13697137.2016.1231176. PMID: 27667093. Exclusion Code: X6.27667093
193 Inoue D, Muraoka R, Okazaki R, . Efficacy and safety of risedronate in osteoporosis subjects with comorbid diabetes, hypertension, and/or dyslipidemia: a post hoc analysis of phase III trials conducted in Japan. Calcif Tissue Int. 2016 Feb;98(2):114–22. doi: 10.1007/s00223-015-0071-9. PMID: 26466937. Exclusion Code: X6.26466937
194 Iqbal SM, Qamar I, Zhi C, . Role of bisphosphonate therapy in patients with osteopenia: a systemic review. Cureus. 2019 Feb 27;11(2):e4146. doi: 10.7759/cureus.4146. PMID: 31058029. Exclusion Code: X3.31058029
195 Ishibashi H, Crittenden DB, Miyauchi A, . Romosozumab increases bone mineral density in postmenopausal Japanese women with osteoporosis: a phase 2 study. Bone. 2017 Oct;103:209–15. doi: 10.1016/j.bone.2017.07.005. PMID: 28687496. Exclusion Code: X5.28687496
196 Izano MA, Lo JC, Adams AL, . Bisphosphonate treatment beyond 5 years and hip fracture risk in older women. JAMA Netw Open. 2020 Dec 1;3(12):e2025190. doi: 10.1001/jamanetworkopen.2020.25190. PMID: 33284336. Exclusion Code: X6.33284336
197 Jain RK, Weiner MG, Zhao H, Vokes T. Comorbid conditions and GFR predict nonvertebral fractures in patients with diabetes in an ethnic-specific manner. J Clin Endocrinol Metab. 2020 Jun 1;105(6)doi: 10.1210/clinem/dgaa141. PMID: 32193529. Exclusion Code: X5.32193529
198 Jang SP, Yeo I, So SY, . Atypical femoral shaft fractures in female bisphosphonate users were associated with an increased anterolateral femoral bow and a thicker lateral cortex: a case-control study. Biomed Res Int. 2017;2017:5932496. doi: 10.1155/2017/5932496. PMID: 28459066. Exclusion Code: X3.28459066
199 Japan Registry for Clinical Trials.. Phase III clinical study of MN-10-T AI for patients with osteoporosis at higher fracture risk. 2016. Exclusion Code: X1.
200 Japan Registry for Clinical Trials. ITM-058 phase 3 study. 2017. Exclusion Code: X1.
201 Jiang X, Good LE, Spinka R, Schnatz PF. Osteoporosis screening in postmenopausal women aged 50-64 years: BMI alone compared with current screening tools. Maturitas. 2016 Jan;83:59–64. doi: 10.1016/j.maturitas.2015.09.009. PMID: 26471931. Exclusion Code: X9.26471931
202 Johnson T, Fox E, Hassanbein S. Implementing an electronic medical record osteoporosis self-assessment tool score which identifies patients at risk for osteoporosis promotes osteoporosis evaluation. Geriatric Orthopaedic Surgery and Rehabilitation. 2021;12:21514593211002157. doi: 10.1177/21514593211002157. PMID: 35186418. Exclusion Code: X6.35186418
203 Jonasson GB, Sundh V, Hakeberg M, . Evaluation of clinical and radiographic indices as predictors of osteoporotic fractures: a 10-year longitudinal study. Oral Surg Oral Med Oral Pathol Oral Radiol. 2018 May;125(5):487–94. doi: 10.1016/j.oooo.2017.11.009. PMID: 29273194. Exclusion Code: X4.29273194
204 Japan Registry for Clinical Trials. TRINITY study. 2020. Exclusion Code: X1.
205 Jung SM, Han S, Kwon HY. Dose-intensity of bisphosphonates and the risk of osteonecrosis of the jaw in osteoporosis patients. Front Pharmacol. 2018;9(JUL):796. doi: 10.3389/fphar.2018.00796. PMID: 30079024. Exclusion Code: X6.30079024
206 Kalvesten J, Lui LY, Brismar T, Cummings S. Digital X-ray radiogrammetry in the study of osteoporotic fractures: comparison to dual energy x-ray absorptiometry and FRAX. Bone. 2016 May;86:30–5. doi: 10.1016/j.bone.2016.02.011. PMID: CN-01137905. Exclusion Code: X5.26921822
207 Kälvesten J, Lui LY, Brismar T, Cummings S. Digital X-ray radiogrammetry in the study of osteoporotic fractures: comparison to dual energy x-ray absorptiometry and FRAX. Bone. 2016 May;86:30–5. doi: 10.1016/j.bone.2016.02.011. PMID: 26921822. Exclusion Code: X9.26921822
208 Kanazawa I, Notsu M, Miyake H, . Assessment using serum insulin-like growth factor-I and bone mineral density is useful for detecting prevalent vertebral fractures in patients with type 2 diabetes mellitus. Osteoporos Int. 2018 Nov;29(11):2527–35. doi: 10.1007/s00198-018-4638-y. PMID: 30030585. Exclusion Code: X5.30030585
209 Kanis JA, Harvey NC, Lorentzon M, . Combining fracture outcomes in phase 3 trials of osteoporosis: an analysis of the effects of denosumab in postmenopausal women. Osteoporos Int. 2021 Jan;32(1):165–71. doi: 10.1007/s00198-020-05699-0. PMID: 33156354. Exclusion Code: X3.33156354
210 Kanis JA, Johansson H, Harvey NC, . Adjusting conventional FRAX estimates of fracture probability according to the recency of sentinel fractures. Osteoporos Int. 2020 Oct;31(10):1817–28. doi: 10.1007/s00198-020-05517-7. PMID: 32613411. Exclusion Code: X7.32613411
211 Kanis JA, Johnell O, Oden A, . FRAX and the assessment of fracture probability in men and women from the UK. Osteoporos Int. 2008 Apr;19(4):385–97. doi: 10.1007/s00198-007-0543-5. PMID: 18292978. Exclusion Code: X3.18292978
212 Kanis JA, Oden A, Johnell O, . The use of clinical risk factors enhances the performance of BMD in the prediction of hip and osteoporotic fractures in men and women. Osteoporos Int. 2007 Aug;18(8):1033–46. doi: 10.1007/s00198-007-0343-y. PMID: 17323110. Exclusion Code: X3.17323110
213 Karimi Fard M, Aminorroaya A, Kachuei A, . Alendronate improves fasting plasma glucose and insulin sensitivity, and decreases insulin resistance in prediabetic osteopenic postmenopausal women: a randomized triple-blind clinical trial. Journal of Diabetes Investigation. 2019 May;10(3):731–7. doi: 10.1111/jdi.12944. PMID: CN-01991102. Exclusion Code: X8.30267620
214 Karlsson L, Mesterton J, Tepie MF, . Exploring methods for comparing the real-world effectiveness of treatments for osteoporosis: adjusted direct comparisons versus using patients as their own control. Arch Osteoporos. 2017 Sep 21;12(1):81. doi: 10.1007/s11657-017-0375-7. PMID: 28936581. Exclusion Code: X7.28936581
215 Kasai H, Mori Y, Ose A, . Prediction of fracture risk from early-stage bone markers in patients with osteoporosis treated with once-yearly administered zoledronic acid. J Clin Pharmacol. 2021 May;61(5):606–13. doi: 10.1002/jcph.1774. PMID: 33135182. Exclusion Code: X2.33135182
216 Keaveny TM, Crittenden DB, Bolognese MA, . Greater gains in spine and hip strength for romosozumab compared with teriparatide in postmenopausal women with low bone mass. J Bone Miner Res. 2017 Sep;32(9):1956–62. doi: 10.1002/jbmr.3176. PMID: 28543940. Exclusion Code: X7.28543940
217 Keech CA, Sashegyi A, Barrett-Connor E. Year-by-year analysis of cardiovascular events in the Multiple Outcomes of Raloxifene Evaluation (MORE) trial. Curr Med Res Opin. 2005 Jan;21(1):135–40. doi: 10.1185/030079904x18045. PMID: 15881485. Exclusion Code: X5.15881485
218 Kellier-Steele N, Casso D, Anderson A, . Assessing the incidence of osteosarcoma among teriparatide-treated patients using linkage of commercial pharmacy and state cancer registry data, contributing to the removal of boxed warning and other labeling changes. Bone. 2022 Jul;160:116394. doi: 10.1016/j.bone.2022.116394. PMID: 35318162. Exclusion Code: X5.35318162
219 Kendler DL, Bone HG, Massari F, . Bone mineral density gains with a second 12-month course of romosozumab therapy following placebo or denosumab. Osteoporos Int. 2019 Dec;30(12):2437–48. doi: 10.1007/s00198-019-05146-9. PMID: 31628490. Exclusion Code: X6.31628490
220 Kendler DL, Chines A, Brandi ML, . The risk of subsequent osteoporotic fractures is decreased in subjects experiencing fracture while on denosumab: results from the FREEDOM and FREEDOM Extension studies. Osteoporos Int. 2019 Jan;30(1):71–8. doi: 10.1007/s00198-018-4687-2. PMID: 30244369. Exclusion Code: X3.30244369
221 Keshtkar A, Tabatabaie O, Matin N, . Clinical performance of seven prescreening tools for osteoporosis in Iranian postmenopausal women. Rheumatol Int. 2015 Dec;35(12):1995–2004. doi: 10.1007/s00296-015-3286-1. PMID: 25980683. Exclusion Code: X8.25980683
222 Khanizadeh F, Rahmani A, Asadollahi K, Ahmadi MRH. Combination therapy of curcumin and alendronate modulates bone turnover markers and enhances bone mineral density in postmenopausal women with osteoporosis. Arch Endocrinol Metab. 2018 Aug;62(4):438–45. doi: 10.20945/2359-3997000000060. PMID: 30304108. Exclusion Code: X7.30304108
223 Kharroubi A, Saba E, Ghannam I, Darwish H. Evaluation of the validity of osteoporosis and fracture risk assessment tools (IOF one minute test, SCORE, and FRAX) in postmenopausal Palestinian women. Arch Osteoporos. 2017 Dec;12(1):6. doi: 10.1007/s11657-016-0298-8. PMID: 28013446. Exclusion Code: X8.28013446
224 Kim H, Kim JH, Kim MJ, . Low predictive value of FRAX adjusted by trabecular bone score for osteoporotic fractures in Korean women: a community-based cohort study. Endocrinol Metab (Seoul). 2020 Jun;35(2):359–66. doi: 10.3803/EnM.2020.35.2.359. PMID: 32615720. Exclusion Code: X3.32615720
225 Kim HY, Jang EJ, Park B, . Development of a Korean Fracture Risk Score (KFRS) for predicting osteoporotic fracture risk: analysis of data from the Korean National Health Insurance Service. PLoS One. 2016;11(7):e0158918. doi: 10.1371/journal.pone.0158918. PMID: 27399597. Exclusion Code: X3.27399597
226 Kim S, Bang HH, Yoo H, . Difference in bone mineral density change at the lateral femoral cortices according to administration of different bisphosphonate agents. J Bone Metab. 2016 May;23(2):85–93. doi: 10.11005/jbm.2016.23.2.85. PMID: 27294080. Exclusion Code: X7.27294080
227 Kim SH, Lee YK, Kim TY, . Incidence of and risk for osteonecrosis of the jaw in Korean osteoporosis patients treated with bisphosphonates: a nationwide cohort-study. Bone. 2021 Feb;143:115650. doi: 10.1016/j.bone.2020.115650. PMID: 32956854. Exclusion Code: X10.32956854
228 Kim Y, Tian Y, Yang J, . Comparative safety and effectiveness of alendronate versus raloxifene in women with osteoporosis. Sci Rep. 2020 Jul 6;10(1):11115. doi: 10.1038/s41598-020-68037-8. PMID: 32632237. Exclusion Code: X6.32632237
229 Kirilova E, Kirilov N, Bischoff F. Predictive ability of the osteoporosis self-assessment tool for assessing the risk of osteoporosis. Revmatologiia (Bulgaria). 2019;27(3):3–9. Exclusion Code: X10.
230 Kittithaworn A, Toro-Tobon D, Sfeir JG. Cardiovascular benefits and risks associated with calcium, vitamin D, and antiresorptive therapy in the management of skeletal fragility. Womens Health (Lond). 2023 Jan–Dec;19:17455057231170059. doi: 10.1177/17455057231170059. PMID: 37129172. Exclusion Code: X5.37129172
231 Kline GA, Lix LM, Morin SN, Leslie WD. Fracture risk in Asian-Canadian women is significantly over-estimated by the Canadian Association of Radiologists-Osteoporosis Canada risk prediction tool: retrospective cohort study. Arch Osteoporos. 2022 Oct 6;17(1):133. doi: 10.1007/s11657-022-01173-y. PMID: 36201065. Exclusion Code: X5.36201065
232 Klop C, de Vries F, Bijlsma JW, . Predicting the 10-year risk of hip and major osteoporotic fracture in rheumatoid arthritis and in the general population: an independent validation and update of UK FRAX without bone mineral density. Ann Rheum Dis. 2016 Dec;75(12):2095–100. doi: 10.1136/annrheumdis-2015-208958. PMID: 26984006. Exclusion Code: X4.26984006
233 Koh JH, Myong JP, Yoo J, . Predisposing factors associated with atypical femur fracture among postmenopausal Korean women receiving bisphosphonate therapy: 8 years’ experience in a single center. Osteoporos Int. 2017 Nov;28(11):3251–9. doi: 10.1007/s00198-017-4169-y. PMID: 28748389. Exclusion Code: X3.28748389
234 Kong L, Zuo K, Ma L. Clinical effect of zoledronic acid in the treatment of senile osteoporosis. Pak J Med Sci. 2020 Nov–Dec;36(7):1703–7. doi: 10.12669/pjms.36.7.1964. PMID: 33235601. Exclusion Code: X2.33235601
235 Kong SH, Kim S, Kim Y, . Development and validation of common data model-based fracture prediction model using machine learning algorithm. Osteoporos Int. 2023 Aug;34(8):1437–51. doi: 10.1007/s00198-023-06787-7. PMID: 37195320. Exclusion Code: X5.37195320
236 Kranenburg G, Bartstra JW, Weijmans M, . Bisphosphonates for cardiovascular risk reduction: a systematic review and meta-analysis. Atherosclerosis. 2016 Sep;252:106–15. doi: 10.1016/j.atherosclerosis.2016.06.039. PMID: 27513349. Exclusion Code: X3.27513349
237 Kruse C, Eiken P, Vestergaard P. Machine learning principles can improve hip fracture prediction. Calcif Tissue Int. 2017 Apr;100(4):348–60. doi: 10.1007/s00223-017-0238-7. PMID: 28197643. Exclusion Code: X5.28197643
238 Kucukler FK, Simsek Y, Turk A, . Osteoporosis and silent vertebral fractures in nursing home resident elderly men in Turkey. J Clin Densitom. 2017 Apr–Jun;20(2):188–95. doi: 10.1016/j.jocd.2015.05.064. PMID: 26071170. Exclusion Code: X2.26071170
239 Kužma M, Hans D, Koller T, . Less strict intervention thresholds for the FRAX and TBS-adjusted FRAX predict clinical fractures in osteopenic postmenopausal women with no prior fractures. J Bone Miner Metab. 2018 Sep;36(5):580–8. doi: 10.1007/s00774-017-0864-1. PMID: 28884422. Exclusion Code: X3.28884422
240 Kvist AV, Faruque J, Vallejo-Yagüe E, . Cardiovascular safety profile of romosozumab: a pharmacovigilance analysis of the US Food and Drug Administration Adverse Event Reporting System (FAERS). Journal of Clinical Medicine. 2021 Apr 13;10(8)doi: 10.3390/jcm10081660. PMID: 33924496. Exclusion Code: X6.33924496
241 Lam MT, Sing CW, Li GHY, . Development and validation of a risk score to predict the first hip fracture in the oldest old: a retrospective cohort study. J Gerontol A Biol Sci Med Sci. 2020 Apr 17;75(5):980–6. doi: 10.1093/gerona/glz178. PMID: 31353417. Exclusion Code: X4.31353417
242 Langdahl BL, Hofbauer LC, Forfar JC. Cardiovascular safety and sclerostin inhibition. J Clin Endocrinol Metab. 2021 Jun 16;106(7):1845–53. doi: 10.1210/clinem/dgab193. PMID: 33755157. Exclusion Code: X3.33755157
243 Langdahl BL, Ljunggren Ö, Benhamou CL, . Fracture rate, quality of life and back pain in patients with osteoporosis treated with teriparatide: 24-month results from the Extended Forsteo Observational Study (ExFOS). Calcif Tissue Int. 2016 Sep;99(3):259–71. doi: 10.1007/s00223-016-0143-5. PMID: 27137783. Exclusion Code: X6.27137783
244 Langdahl BL, Silverman S, Fujiwara S, . Real-world effectiveness of teriparatide on fracture reduction in patients with osteoporosis and comorbidities or risk factors for fractures: Integrated analysis of 4 prospective observational studies. Bone. 2018 Nov;116:58–66. doi: 10.1016/j.bone.2018.07.013. PMID: 30021126. Exclusion Code: X3.30021126
245 Langdahl BL, Teglbjaerg CS, Ho PR, . A 24-month study evaluating the efficacy and safety of denosumab for the treatment of men with low bone mineral density: results from the ADAMO trial. J Clin Endocrinol Metab. 2015 Apr;100(4):1335–42. doi: 10.1210/jc.2014-4079 [doi]. PMID: 25607608. Exclusion Code: X3.25607608
246 Lauppe R, Åkesson KE, Ljunggren Ö, . Differing impact of clinical factors on the risk of fracture in younger and older women in the general population and an osteoporosis clinic population. Arch Osteoporos. 2019 Apr 8;14(1):45. doi: 10.1007/s11657-019-0592-3. PMID: 30963310. Exclusion Code: X7.30963310
247 Laura I, Felicia B, Alexia C, . Which treatment to prevent an imminent fracture? Bone Rep. 2021 Dec;15:101105. doi: 10.1016/j.bonr.2021.101105. PMID: 34386562. Exclusion Code: X3.34386562
248 Leder BZ, Mitlak B, Hu MY, . Effect of abaloparatide vs alendronate on fracture risk reduction in postmenopausal women with osteoporosis. J Clin Endocrinol Metab. 2020 Mar 1;105(3):938–43. doi: 10.1210/clinem/dgz162. PMID: 31674644. Exclusion Code: X6.31674644
249 Leder BZ, Zapalowski C, Hu MY, . Fracture and bone mineral density response by baseline risk in patients treated with abaloparatide followed by alendronate: results from the phase 3 ACTIVExtend trial. J Bone Miner Res. 2019 Dec;34(12):2213–9. doi: 10.1002/jbmr.3848. PMID: 31411768. Exclusion Code: X6.31411768
250 Lee HJ, Hwang SY, Kim SC, . Relationship between metabolic syndrome and bone fracture risk in mid-aged Korean women using FRAX scoring system. Metab Syndr Relat Disord. 2020 May;18(4):219–24. doi: 10.1089/met.2019.0060. PMID: 32077792. Exclusion Code: X3.32077792
251 Lee WY, Sun LM, Lin MC, . A higher dosage of oral alendronate will increase the subsequent cancer risk of osteoporosis patients in Taiwan: a population-based cohort study. PLoS One. 2012;7(12):e53032. doi: 10.1371/journal.pone.0053032. PMID: 23300854. Exclusion Code: X10.23300854
252 Leeyaphan J, Rojjananukulpong K, Intarasompun P, Peerakul Y. Development and Validation of a New Clinical Diagnostic Screening Model for Osteoporosis in Postmenopausal Women. J Bone Metab. 2023 May;30(2):179–88. doi: 10.11005/jbm.2023.30.2.179. PMID: 37449350. Exclusion Code: X8.37449350
253 Lello S, Sorge R, Surico N. Osteoporosis’s Menopausal Epidemiological Risk Observation (O.M.E.R.O.) study. Gynecol Endocrinol. 2015;31(12):992–8. doi: 10.3109/09513590.2015.1063605. PMID: 26172928. Exclusion Code: X1.26172928
254 Leslie WD, Brennan-Olsen SL, Morin SN, Lix LM. Fracture prediction from repeat BMD measurements in clinical practice. Osteoporos Int. 2016 Jan;27(1):203–10. doi: 10.1007/s00198-015-3259-y. PMID: 26243362. Exclusion Code: X7.26243362
255 Leslie WD, Lix LM. Absolute fracture risk assessment using lumbar spine and femoral neck bone density measurements: derivation and validation of a hybrid system. J Bone Miner Res. 2011 Mar;26(3):460–7. doi: 10.1002/jbmr.248 [doi]. PMID: 20839285. Exclusion Code: X7.20839285
256 Leslie WD, Lix LM, Johansson H, . Spine-hip discordance and fracture risk assessment: a physician-friendly FRAX enhancement. Osteoporos Int. 2011 Mar;22(3):839–47. doi: 10.1007/s00198-010-1461-5 [doi]. PMID: 20959961. Exclusion Code: X7.20959961
257 Leslie WD, Lix LM, Johansson H, . A comparative study of using non-hip bone density inputs with FRAX(R). Osteoporos Int. 2012 Mar;23(3):853–60. doi: 10.1007/s00198-011-1814-8. PMID: 22008881. Exclusion Code: X9.22008881
258 Leslie WD, Lix LM, Majumdar SR, . Total hip bone area affects fracture prediction with FRAX® in Canadian white women. J Clin Endocrinol Metab. 2017 Nov 1;102(11):4242–9. doi: 10.1210/jc.2017-01327. PMID: 29092086. Exclusion Code: X7.29092086
259 Leslie WD, Luo Y, Yang S, . Fracture risk indices from DXA-based finite element analysis predict incident fractures independently from FRAX: the Manitoba BMD registry. J Clin Densitom. 2019 Jul–Sep;22(3):338–45. doi: 10.1016/j.jocd.2019.02.001. PMID: 30852033. Exclusion Code: X9.30852033
260 Leslie WD, Morin SN, Lix LM, . Fracture prediction from self-reported falls in routine clinical practice: a registry-based cohort study. Osteoporos Int. 2019 Nov;30(11):2195–203. doi: 10.1007/s00198-019-05106-3. PMID: 31372711. Exclusion Code: X3.31372711
261 Leslie WD, Morin SN, Lix LM, . The Effect of Fracture Recency on Observed 10-Year Fracture Probability: A Registry-Based Cohort Study. J Bone Miner Res. 2022 May;37(5):848–55. doi: 10.1002/jbmr.4526. PMID: 35147245. Exclusion Code: X3.35147245
262 Leslie WD, Morin SN, Lix LM, . Performance of FRAX in women with breast cancer initiating aromatase inhibitor therapy: a registry-based cohort study. J Bone Miner Res. 2019 Aug;34(8):1428–35. doi: 10.1002/jbmr.3726. PMID: 31069862. Exclusion Code: X2.31069862
263 Leslie WD, Shevroja E, Johansson H, . Risk-equivalent T-score adjustment for using lumbar spine trabecular bone score (TBS): the Manitoba BMD registry. Osteoporos Int. 2018 Mar;29(3):751–8. doi: 10.1007/s00198-018-4405-0. PMID: 29392355. Exclusion Code: X5.29392355
264 Leslie WD, Tsang JF, Lix LM. Simplified system for absolute fracture risk assessment: clinical validation in Canadian women. J Bone Miner Res. 2009 Feb;24(2):353–60. doi: 10.1359/jbmr.081012 [doi]. PMID: 19514851. Exclusion Code: X7.19514851
265 Lewiecki EM, Blicharski T, Goemaere S, . A phase III randomized placebo-controlled trial to evaluate efficacy and safety of romosozumab in men with osteoporosis. J Clin Endocrinol Metab. 2018 Sep 1;103(9):3183–93. doi: 10.1210/jc.2017-02163. PMID: 29931216. Exclusion Code: X2.29931216
266 Lewiecki EM, Dinavahi RV, Lazaretti-Castro M, . One year of romosozumab followed by two years of denosumab maintains fracture risk reductions: results of the FRAME extension study. J Bone Miner Res. 2019 Mar;34(3):419–28. doi: 10.1002/jbmr.3622. PMID: 30508316. Exclusion Code: X6.30508316
267 Li G, Papaioannou A, Thabane L, . Modifying the phenotypic frailty model in predicting risk of major osteoporotic fracture in the elderly. J Am Med Dir Assoc. 2017 May 1;18(5):414–9. doi: 10.1016/j.jamda.2016.11.015. PMID: 28108205. Exclusion Code: X3.28108205
268 Li GH, Cheung CL, Tan KC, . Development and validation of sex-specific hip fracture prediction models using electronic health records: a retrospective, population-based cohort study. EClinicalMedicine. 2023 Apr;58:101876. doi: 10.1016/j.eclinm.2023.101876. PMID: 36896245. Exclusion Code: X5.36896245
269 Li J, Sun Y, Chen Z, . Effects of Bisphosphonates Treatments in Osteopenic Older Women: A Systematic Review and Meta-Analysis. Front Pharmacol. 2022;13:892091. doi: 10.3389/fphar.2022.892091. PMID: 35662708. Exclusion Code: X3.35662708
270 Li P, Wu X, Li Y, Huang J. Denosumab Versus Bisphosphonates for the Prevention of the Vertebral Fractures in Men with Osteoporosis: An Updated Network Meta-Analysis. Clin Invest Med. 2022 Sep 21;45(3):E14–22. doi: 10.25011/cim.v45i3.38875. PMID: 36149052. Exclusion Code: X3.36149052
271 Li Z, Zhao W, Lin X, Li F. AI algorithms for accurate prediction of osteoporotic fractures in patients with diabetes: an up-to-date review. J Orthop Surg Res. 2023 Dec 12;18(1):956. doi: 10.1186/s13018-023-04446-5. PMID: 38087332. Exclusion Code: X2.38087332
272 Liang BC, Shi ZY, Wang B, . Intravenous zoledronic acid 5 mg on bone turnover markers and bone mineral density in East China subjects with newly diagnosed osteoporosis: a 24-month clinical study. Orthop Surg. 2017 Feb;9(1):103–9. doi: 10.1111/os.12307. PMID: 28276638. Exclusion Code: X8.28276638
273 Lin J, Yang Y, Zhang X, . BFH-OSTM, a new predictive screening tool for identifying osteoporosis in elderly Han Chinese males. Clin Interv Aging. 2017;12:1167–74. doi: 10.2147/cia.S140553. PMID: 28814842. Exclusion Code: X8.28814842
274 Lin SY, Hung MC, Chang SF, . Efficacy and Safety of Postmenopausal Osteoporosis Treatments: A Systematic Review and Network Meta-Analysis of Randomized Controlled Trials. J Clin Med. 2021 Jul 8;10(14)doi: 10.3390/jcm10143043. PMID: 34300210. Exclusion Code: X3.34300210
275 Liu GF, Wang ZQ, Liu L, . A network meta-analysis on the short-term efficacy and adverse events of different anti-osteoporosis drugs for the treatment of postmenopausal osteoporosis. J Cell Biochem. 2018 Jun;119(6):4469–81. doi: 10.1002/jcb.26550. PMID: 29227547. Exclusion Code: X3.29227547
276 Liu Q, Chen D, Ye Z, . Minodronate in the treatment of osteoporosis: a systematic review and meta-analysis. Medicine (Baltimore). 2020 Oct 2;99(40):e22542. doi: 10.1097/md.0000000000022542. PMID: 33019463. Exclusion Code: X5.33019463
277 Livingstone SJ, Guthrie B, McMinn M, . Derivation and validation of the CFracture competing risk fracture prediction tool compared with QFracture in older people and people with comorbidity: a population cohort study. Lancet Healthy Longev. 2023 Jan;4(1):e43–e53. doi: 10.1016/s2666-7568(22)00290-2. PMID: 36610448. Exclusion Code: X5.36610448
278 Lix LM, Leslie WD, Majumdar SR. Measuring improvement in fracture risk prediction for a new risk factor: a simulation. BMC Res Notes. 2018 Jan 22;11(1):62. doi: 10.1186/s13104-018-3178-z. PMID: 29357907. Exclusion Code: X9.29357907
279 Lo JC, Grimsrud CD, Ott SM, . Atypical femur fracture incidence in women increases with duration of bisphosphonate exposure. Osteoporos Int. 2019 Dec;30(12):2515–20. doi: 10.1007/s00198-019-05112-5. PMID: 31555883. Exclusion Code: X6.31555883
280 Lo JC, Nath S, Patel M, . Variation in fracture risk estimation among East Asian women. Am J Manag Care. 2021 Mar 1;27(3):e97–e100. doi: 10.37765/ajmc.2021.88604. PMID: 33720675. Exclusion Code: X3.33720675
281 Lo JC, Neugebauer RS, Ettinger B, . Risk of complete atypical femur fracture with oral bisphosphonate exposure beyond three years. BMC Musculoskelet Disord. 2020 Dec 3;21(1):801. doi: 10.1186/s12891-020-03672-w. PMID: 33272248. Exclusion Code: X6.33272248
282 Logan S, Thu WPP, Lay WK, . Chronic joint pain and handgrip strength correlates with osteoporosis in mid-life women: a Singaporean cohort. Osteoporos Int. 2017 Sep;28(9):2633–43. doi: 10.1007/s00198-017-4095-z. PMID: 28647803. Exclusion Code: X3.28647803
283 Looker AC, Sarafrazi Isfahani N, Fan B, Shepherd JA. FRAX-based estimates of 10-year probability of hip and major osteoporotic fracture among adults aged 40 and over: United States, 2013 and 2014. Natl Health Stat Report. 2017 Mar(103):1–16. PMID: 28459415. Exclusion Code: X6.28459415
284 Lundin H, Sääf M, Strender LE, . Gait speed and one-leg standing time each add to the predictive ability of FRAX. Osteoporos Int. 2017 Jan;28(1):179–87. doi: 10.1007/s00198-016-3818-x. PMID: 27844133. Exclusion Code: X4.27844133
285 Lundin H, Torabi F, Saaf M, . Laser-supported dual energy x-ray absorptiometry (DXL) compared to conventional absorptiometry (DXA) and to FRAX as tools for fracture risk assessments. PLoS One. 2015;10(9):e0137535. doi: 10.1371/journal.pone.0137535. PMID: 26413715. Exclusion Code: X4.26413715
286 Lundin H, Torabi F, Sääf M, . Laser-Supported dual energy x-ray absorptiometry (DXL) compared to conventional absorptiometry (DXA) and to FRAX as tools for fracture risk assessments. PLoS One. 2015;10(9):e0137535. doi: 10.1371/journal.pone.0137535. PMID: 26413715. Exclusion Code: X4.26413715
287 Lyu H, Yoshida K, Zhao SS, . Delayed denosumab injections and fracture risk among patients with osteoporosis: a population-based cohort study. Ann Intern Med. 2020 Oct 6;173(7):516–26. doi: 10.7326/m20-0882. PMID: 32716706. Exclusion Code: X7.32716706
288 Ma Z, Yang Y, Lin J, . BFH-OST, a new predictive screening tool for identifying osteoporosis in postmenopausal Han Chinese women. Clin Interv Aging. 2016;11:1051–9. doi: 10.2147/cia.S107675. PMID: 27536085. Exclusion Code: X8.27536085
289 Makras P, Papapoulos SE, Polyzos SA, . The three-year effect of a single zoledronate infusion on bone mineral density and bone turnover markers following denosumab discontinuation in women with postmenopausal osteoporosis. Bone. 2020 Sep;138:115478. doi: 10.1016/j.bone.2020.115478. PMID: 32534221. Exclusion Code: X6.32534221
290 Martineau P, Leslie WD, Johansson H, . Clinical utility of using lumbar spine trabecular bone score to adjust fracture probability: the Manitoba BMD cohort. J Bone Miner Res. 2017 Jul;32(7):1568–74. doi: 10.1002/jbmr.3124. PMID: 28276598. Exclusion Code: X5.28276598
291 Martins LHI, Ferreira DC, Silva MT, . Frequency of osteonecrosis in bisphosphonate users submitted to dental procedures: A systematic review. Oral Dis. 2023 Jan;29(1):75–99. doi: 10.1111/odi.14003. PMID: 34402147. Exclusion Code: X3.34402147
292 Matsumoto T, Sone T, Soen S, . Abaloparatide Increases Lumbar Spine and Hip BMD in Japanese Patients With Osteoporosis: The Phase 3 ACTIVE-J Study. J Clin Endocrinol Metab. 2022 Sep 28;107(10):e4222–e31. doi: 10.1210/clinem/dgac486. PMID: 35977548. Exclusion Code: X5.35977548
293 Mawatari T, Ikemura S, Matsui G, . Assessment of baseline bone turnover marker levels and response to risedronate treatment: data from a Japanese phase III trial. Bone Rep. 2020 Jun;12:100275. doi: 10.1016/j.bonr.2020.100275. PMID: 32462056. Exclusion Code: X6.32462056
294 McCloskey EV, Fitzpatrick LA, Hu MY, . Effect of abaloparatide on vertebral, nonvertebral, major osteoporotic, and clinical fractures in a subset of postmenopausal women at increased risk of fracture by FRAX probability. Arch Osteoporos. 2019 Feb 5;14(1):15. doi: 10.1007/s11657-019-0564-7. PMID: 30719589. Exclusion Code: X5.30719589
295 McCloskey EV, Johansson H, Harvey NC, . Romosozumab efficacy on fracture outcomes is greater in patients at high baseline fracture risk: a post hoc analysis of the first year of the frame study. Osteoporos Int. 2021 Feb 3;32(8):1601–8. doi: 10.1007/s00198-020-05815-0. PMID: 33537844. Exclusion Code: X5.33537844
296 McCloskey EV, Johansson H, Oden A, . The effect of abaloparatide-SC on fracture risk is independent of baseline FRAX fracture probability: a post hoc analysis of the ACTIVE study. J Bone Miner Res. 2017 Aug;32(8):1625–31. doi: 10.1002/jbmr.3163. PMID: 28474780. Exclusion Code: X2.28474780
297 McCloskey EV, Odén A, Harvey NC, . A meta-analysis of trabecular bone score in fracture risk prediction and its relationship to FRAX. J Bone Miner Res. 2016 May;31(5):940–8. doi: 10.1002/jbmr.2734. PMID: 26498132. Exclusion Code: X5.26498132
298 McClung MR, Bolognese MA, Brown JP, . Skeletal responses to romosozumab after 12 months of denosumab. JBMR Plus. 2021 Jul;5(7):e10512. doi: 10.1002/jbm4.10512. PMID: 34258507. Exclusion Code: X5.34258507
299 McClung MR, Brown JP, Diez-Perez A, . Effects of 24 months of treatment with romosozumab followed by 12 months of denosumab or placebo in postmenopausal women with low bone mineral density: a randomized, double-blind, phase 2, parallel group study. J Bone Miner Res. 2018 Aug;33(8):1397–406. doi: 10.1002/jbmr.3452. PMID: 29694685. Exclusion Code: X7.29694685
300 McClung MR, Harvey NC, Fitzpatrick LA, . Effects of abaloparatide on bone mineral density and risk of fracture in postmenopausal women aged 80 years or older with osteoporosis. Menopause. 2018 Jul;25(7):767–71. doi: 10.1097/gme.0000000000001080. PMID: 29462094. Exclusion Code: X5.29462094
301 McClung MR, Lippuner K, Brandi ML, . Effect of denosumab on trabecular bone score in postmenopausal women with osteoporosis. Osteoporos Int. 2017 Oct;28(10):2967–73. doi: 10.1007/s00198-017-4140-y. PMID: 28748386. Exclusion Code: X7.28748386
302 McClung MR, Siris E, Cummings S, . Prevention of bone loss in postmenopausal women treated with lasofoxifene compared with raloxifene. Menopause. 2006 May–Jun;13(3):377–86. doi: 10.1097/01.gme.0000188736.69617.4f. PMID: 16735934. Exclusion Code: X5.16735934
303 McClung MR, Wagman RB, Miller PD, . Observations following discontinuation of long-term denosumab therapy. Osteoporos Int. 2017 May;28(5):1723–32. doi: 10.1007/s00198-017-3919-1. PMID: 28144701. Exclusion Code: X6.28144701
304 McClung MR, Williams GC, Hattersley G, . Geography of fracture incidence in postmenopausal women with osteoporosis treated with abaloparatide. Calcif Tissue Int. 2018 Jun;102(6):627–33. doi: 10.1007/s00223-017-0375-z. PMID: 29285549. Exclusion Code: X5.29285549
305 McGowan K, Acton C, Ivanovski S, . Systemic comorbidities are associated with medication-related osteonecrosis of the jaws: case-control study. Oral Dis. 2019 May;25(4):1107–15. doi: 10.1111/odi.13046. PMID: 30674072. Exclusion Code: X5.30674072
306 Mendes D, Penedones A, Alves C, . Ibandronate in the Prevention of Vertebral and Nonvertebral Osteoporotic Fractures: A Systematic Review of Experimental and Observational Studies. J Clin Rheumatol. 2023 Mar 1;29(2):78–83. doi: 10.1097/rhu.0000000000001902. PMID: 36731043. Exclusion Code: X3.36731043
307 Meng J, Sun N, Chen Y, . Artificial neural network optimizes self-examination of osteoporosis risk in women. J Int Med Res. 2019 Jul;47(7):3088–98. doi: 10.1177/0300060519850648. PMID: 31179797. Exclusion Code: X8.31179797
308 Meunier PJ, Confavreux E, Tupinon I, . Prevention of early postmenopausal bone loss with cyclical etidronate therapy (a double-blind, placebo-controlled study and 1-year follow-up). J Clin Endocrinol Metab. 1997 Sep;82(9):2784–91. doi: 10.1210/jcem.82.9.4073. PMID: 9284696. Exclusion Code: X5.9284696
309 Meunier PJ, Vignot E, Garnero P, . Treatment of postmenopausal women with osteoporosis or low bone density with raloxifene. Raloxifene study group. Osteoporos Int. 1999;10(4):330–6. doi: 10.1007/s001980050236. PMID: 10692984. Exclusion Code: X5.10692984
310 Migliorini F, Colarossi G, Baroncini A, . Pharmacological management of postmenopausal osteoporosis: a level I evidence based - expert opinion. Expert Rev Clin Pharmacol. 2021 Jan;14(1):105–19. doi: 10.1080/17512433.2021.1851192. PMID: 33183112. Exclusion Code: X1.33183112
311 Miller PD, Chines AA, Christiansen C, . Effects of bazedoxifene on BMD and bone turnover in postmenopausal women: 2-yr results of a randomized, double-blind, placebo-, and active-controlled study. J Bone Miner Res. 2008 Apr;23(4):525–35. doi: 10.1359/jbmr.071206. PMID: 18072873. Exclusion Code: X5.18072873
312 Miller PD, Hattersley G, Lau E, . Bone mineral density response rates are greater in patients treated with abaloparatide compared with those treated with placebo or teriparatide: results from the ACTIVE phase 3 trial. Bone. 2019 Mar;120:137–40. doi: 10.1016/j.bone.2018.10.015. PMID: 30359763. Exclusion Code: X7.30359763
313 Miller PD, Hattersley G, Riis BJ, . Effect of abaloparatide vs placebo on new vertebral fractures in postmenopausal women with osteoporosis: a randomized clinical trial. JAMA. 2016 Aug 16;316(7):722–33. doi: 10.1001/jama.2016.11136. PMID: 27533157. Exclusion Code: X5.27533157
314 Miller PD, Schnitzer T, Emkey R, . Weekly oral alendronic Acid in male osteoporosis. Clin Drug Investig. 2004;24(6):333–41. doi: 10.2165/00044011-200424060-00003. PMID: 17516720. Exclusion Code: X2.17516720
315 Miller SA, St Onge EL, Whalen KL. Romosozumab: A novel agent in the treatment for postmenopausal osteoporosis. J Pharm Technol. 2021 Feb;37(1):45–52. doi: 10.1177/8755122520967632. PMID: 34752536. Exclusion Code: X3.34752536
316 Mirzaei A, Jahed SA, Nojomi M, . A study of the value of trabecular bone score in fracture risk assessment of postmenopausal women. Taiwan J Obstet Gynecol. 2018 Jun;57(3):389–93. doi: 10.1016/j.tjog.2018.04.011. PMID: 29880171. Exclusion Code: X8.29880171
317 Mitsuboshi S, Kotake K. Risks of serious adverse events and kidney injury in patients treated with ibandronate: A systematic review and meta-analysis. Pharmacotherapy. 2022 Aug;42(8):677–86. doi: 10.1002/phar.2713. PMID: 35716279. Exclusion Code: X3.35716279
318 Miyauchi A, Dinavahi RV, Crittenden DB, . Increased bone mineral density for 1 year of romosozumab, vs placebo, followed by 2 years of denosumab in the Japanese subgroup of the pivotal FRAME trial and extension. Arch Osteoporos. 2019 Jun 5;14(1):59. doi: 10.1007/s11657-019-0608-z. PMID: 31168657. Exclusion Code: X5.31168657
319 Miyauchi A, Hamaya E, Yang W, . Romosozumab followed by denosumab in Japanese women with high fracture risk in the FRAME trial. J Bone Miner Metab. 2021 Mar;39(2):278–88. doi: 10.1007/s00774-020-01147-5. PMID: 33057807. Exclusion Code: X5.33057807
320 Modi A, Ebeling PR, Lee MS, . Impact of gastrointestinal events on patient-reported outcomes in Asia-Pacific women with osteoporosis: baseline results of the MUSIC OS-AP study. Arch Osteoporos. 2017 Dec;12(1):65. doi: 10.1007/s11657-017-0350-3. PMID: 28718004. Exclusion Code: X3.28718004
321 Modi A, Fan CPS, Tang J, . Association of gastrointestinal events with osteoporosis treatment initiation and treatment compliance in Germany: an observational study. Bone Reports. 2016 Dec;5:208–13. doi: 10.1016/j.bonr.2016.06.001. PMID: 28580388. Exclusion Code: X3.28580388
322 Modi A, Sajjan S, Michael Lewiecki E, . Relationship between gastrointestinal events and compliance with osteoporosis therapy: an administrative claims analysis of the US managed care population. Clin Ther. 2016 May;38(5):1074–80. doi: 10.1016/j.clinthera.2016.03.027. PMID: 27112533. Exclusion Code: X3.27112533
323 Modi A, Sen S, Adachi JD, . Gastrointestinal symptoms and association with medication use patterns, adherence, treatment satisfaction, quality of life, and resource use in osteoporosis: baseline results of the MUSIC-OS study. Osteoporos Int. 2016 Mar;27(3):1227–38. doi: 10.1007/s00198-015-3388-3. PMID: 26637321. Exclusion Code: X3.26637321
324 Modi A, Sen S, Adachi JD, . The impact of GI events on persistence and adherence to osteoporosis treatment: 3-, 6-, and 12-month findings in the MUSIC-OS study. Osteoporos Int. 2018 Feb;29(2):329–37. doi: 10.1007/s00198-017-4271-1. PMID: 29110061. Exclusion Code: X6.29110061
325 Mohammed Abou-Hashem R, Mostafa Abd-El-Gawad W, Abouseif HA. Modified SCORE tool for prediction of bone mineral density in Egyptian elderly women. Comparison of seven osteoporosis screening tools. Health Care Women Int. 2019 Oct;40(10):1084–100. doi: 10.1080/07399332.2018.1542433. PMID: 30526422. Exclusion Code: X8.30526422
326 Mok J, Brown C, Moore AEB, . Skeletal response to treatment with teriparatide (TPD) after bisphosphonate in post-menopausal women with osteoporosis and a high prevalence of secondary risk factors in real-life setting of a metabolic bone clinic; effect of age and vitamin D status. Endocr Res. 2018 Aug;43(3):195–202. doi: 10.1080/07435800.2018.1454461. PMID: 29652557. Exclusion Code: X6.29652557
327 Momeni M, Asadzadeh M, Mowla K, . Sensitivity and specificity assessment of DWI and ADC for the diagnosis of osteoporosis in postmenopausal patients. Radiol Med. 2020 Jan;125(1):68–74. doi: 10.1007/s11547-019-01080-2. PMID: 31531809. Exclusion Code: X5.31531809
328 Moreira CA, Fitzpatrick LA, Wang Y, Recker RR. Effects of abaloparatide-SC (BA058) on bone histology and histomorphometry: the ACTIVE phase 3 trial. Bone. 2017 Apr;97:314–9. doi: 10.1016/j.bone.2016.11.004. PMID: 27826127. Exclusion Code: X7.27826127
329 Morii H, Ohashi Y, Taketani Y, . Effect of raloxifene on bone mineral density and biochemical markers of bone turnover in Japanese postmenopausal women with osteoporosis: results from a randomized placebo-controlled trial. Osteoporos Int. 2003 Oct;14(10):793–800. doi: 10.1007/s00198-003-1424-1. PMID: 12955333. Exclusion Code: X5.12955333
330 Moshi MR, Nicolopoulos K, Stringer D, . The clinical effectiveness of denosumab (Prolia®) for the treatment of osteoporosis in postmenopausal women, compared to bisphosphonates, selective estrogen receptor modulators (SERM), and placebo: a systematic review and network meta-analysis. Calcif Tissue Int. 2023 Jun;112(6):631–46. doi: 10.1007/s00223-023-01078-z. PMID: 37016189. Exclusion Code: X3.37016189
331 Mueller YK, Monod S, Locatelli I, . Performance of a brief geriatric evaluation compared to a comprehensive geriatric assessment for detection of geriatric syndromes in family medicine: a prospective diagnostic study. BMC Geriatr. 2018 Mar 13;18(1):72. doi: 10.1186/s12877-018-0761-z. PMID: 29534680. Exclusion Code: X5.29534680
332 Nagashima H, Hirayama M, Ohishi H, Oikawa I. Optimizing a single monthly dose of risedronate based on its weekly dose in healthy Japanese postmenopausal women. Japanese J Clin Pharmacol Ther. 2017;48(4):121–9. doi: 10.3999/jscpt.48.121. PMID: CN-01406016. Exclusion Code: X5.
333 Nahar VK, Nelson KM, Ford MA, . Predictors of bone mineral density among Asian Indians in northern Mississippi: a pilot study. J Res Health Sci. 2016 fall;16(4):228–32. PMID: 28087857. Exclusion Code: X5.28087857
334 Nakamura T, Matsumoto T, Sugimoto T, . Clinical trials express: fracture risk reduction with denosumab in Japanese postmenopausal women and men with osteoporosis: denosumab fracture intervention randomized placebo controlled trial (DIRECT). J Clin Endocrinol Metab. 2014 Jul;99(7):2599–607. doi: 10.1210/jc.2013-4175 [doi]. PMID: 24646104. Exclusion Code: X2.24646104
335 Nakano T, Yamamoto M, Hashimoto J, . Higher response with bone mineral density increase with monthly injectable ibandronate 1 mg compared with oral risedronate in the MOVER study. J Bone Miner Metab. 2016 Nov;34(6):678–84. doi: 10.1007/s00774-015-0717-8. PMID: 26462480. Exclusion Code: X6.26462480
336 Napoli N, Pannacciulli N, Vittinghoff E, . Effect of denosumab on fasting glucose in women with diabetes or prediabetes from the FREEDOM trial. Diabetes Metab Res Rev. 2018 May;34(4):e2991. doi: 10.1002/dmrr.2991. PMID: 29430796. Exclusion Code: X7.29430796
337 Nayak S, Greenspan SL. Osteoporosis treatment efficacy for men: a systematic review and meta-analysis. J Am Geriatr Soc. 2017 Mar;65(3):490–5. doi: 10.1111/jgs.14668. PMID: 28304090. Exclusion Code: X3.28304090
338 NCT02791516. A safety and efficacy study to evaluate AMG 785 in South Korean women with osteoporosis. Exclusion Code: X1.
339 NCT03512262. Safety and efficacy of abaloparatide-SC in men with osteoporosis (ATOM). 2018. Exclusion Code: X1.
340 NCT04249232. Abaloparatide and pelvic fracture healing. 2020. Exclusion Code: X2.
341 Nguyen ND, Frost SA, Center JR, . Development of a nomogram for individualizing hip fracture risk in men and women. Osteoporos Int. 2007 Aug;18(8):1109–17. doi: 10.1007/s00198-007-0362-8. PMID: 17370100. Exclusion Code: X7.17370100
342 Nguyen ND, Frost SA, Center JR, . Development of prognostic nomograms for individualizing 5-year and 10-year fracture risks. Osteoporos Int. 2008 Oct;19(10):1431–44. doi: 10.1007/s00198-008-0588-0. PMID: 18324342. Exclusion Code: X3.18324342
343 Niznik JD, Li X, Gilliam MA, . Are nursing home residents with dementia appropriately treated for fracture prevention? J Am Med Dir Assoc. 2021 Jan;22(1):28–35.e3. doi: 10.1016/j.jamda.2020.11.019. PMID: 33321079. Exclusion Code: X2.33321079
344 Nordström P, Bergman J, Ballin M, . Bone-specific drugs and osteonecrosis of sites other than the jaw: a nationwide cohort study. J Bone Miner Res. 2020 Sep;35(9):1703–10. doi: 10.1002/jbmr.4040. PMID: 32379370. Exclusion Code: X10.32379370
345 Oh SM, Song BM, Nam BH, . Development and validation of osteoporosis risk-assessment model for Korean men. Yonsei Med J. 2016 Jan;57(1):187–96. doi: 10.3349/ymj.2016.57.1.187. PMID: 26632400. Exclusion Code: X6.26632400
346 Oka R, Ohira M, Suzuki S, . Fracture risk assessment tool (FRAX) and for the diagnosis of osteoporosis in Japanese middle-aged and elderly women: Chiba bone survey. Endocr J. 2018 Feb 26;65(2):193–202. doi: 10.1507/endocrj.EJ17-0331. PMID: 29151451. Exclusion Code: X6.29151451
347 Okazaki R, Muraoka R, Maehara M, Inoue D. Factors associated with inadequate responses to risedronate in Japanese patients with osteoporosis. J Bone Miner Metab. 2019 Jan;37(1):185–97. doi: 10.1007/s00774-018-0931-2. PMID: 29737412. Exclusion Code: X6.29737412
348 Okubo N, Matsui S, Matsumoto T, . Relationship between bone mineral density and risk of vertebral fractures with denosumab treatment in Japanese postmenopausal women and men with osteoporosis. Calcif Tissue Int. 2020 Dec;107(6):559–66. doi: 10.1007/s00223-020-00750-y. PMID: 32839843. Exclusion Code: X2.32839843
349 Orwoll ES, Scheele WH, Paul S, . The effect of teriparatide [human parathyroid hormone (1-34)] therapy on bone density in men with osteoporosis. J Bone Miner Res. 2003 Jan;18(1):9–17. doi: 10.1359/jbmr.2003.18.1.9. PMID: 12510800. Exclusion Code: X5.12510800
350 Osawa R, Ikegami S, Horiuchi H, . Osteoporosis detection by physical function tests in resident health exams: a japanese cohort survey randomly sampled from a basic resident registry. Journal of Clinical Medicine. 2021 Apr 27;10(9)doi: 10.3390/jcm10091896. PMID: 33925580. Exclusion Code: X5.33925580
351 Oswald AJ, Berg K, Ralston SH, Riches PL. Long-term effects of teriparatide followed by antiresorptive therapy on clinical outcomes in patients with severe spinal osteoporosis. Calcif Tissue Int. 2019 Aug;105(2):148–55. doi: 10.1007/s00223-019-00563-8. PMID: 31115640. Exclusion Code: X3.31115640
352 Papapoulos S, Lippuner K, Roux C, . The effect of 8 or 5 years of denosumab treatment in postmenopausal women with osteoporosis: results from the FREEDOM Extension study. Osteoporos Int. 2015 Dec;26(12):2773–83. doi: 10.1007/s00198-015-3234-7. PMID: 26202488. Exclusion Code: X6.26202488
353 Park JH, Ko HJ. The Association between Treatment with Bisphosphonates and the Risk of Atrial Fibrillation: A Meta-Analysis of Observational Studies. Korean J Fam Med. 2022 Jan;43(1):69–76. doi: 10.4082/kjfm.21.0110. PMID: 35130642. Exclusion Code: X3.35130642
354 Passarelli MN, Newcomb PA, LaCroix AZ, . Oral bisphosphonate use and colorectal cancer incidence in the women’s health initiative. J Bone Miner Res. 2013 Sep;28(9):2043–8. doi: 10.1002/jbmr.1930. PMID: 23519920. Exclusion Code: X10.23519920
355 Passeri E, Mazzaccaro D, Sansoni V, . Effects of 12-months treatment with zoledronate or teriparatide on intima-media thickness of carotid artery in women with postmenopausal osteoporosis: a pilot study. Int J Immunopathol Pharmacol. 2019 Jan–Dec;33:2058738418822439. doi: 10.1177/2058738418822439. PMID: 30791743. Exclusion Code: X3.30791743
356 Pedrassani de Lira C, Toniazzo de Abreu LL, Veiga Silva AC, . Use of data mining to predict the risk factors associated with osteoporosis and osteopenia in women. Comput Inform Nurs. 2016 Aug;34(8):369–75. doi: 10.1097/cin.0000000000000253. PMID: 27270629. Exclusion Code: X3.27270629
357 Pineda-Moncusí M, El-Hussein L, Delmestri A, . Estimating the Incidence and Key Risk Factors of Cardiovascular Disease in Patients at High Risk of Imminent Fracture Using Routinely Collected Real-World Data From the UK. J Bone Miner Res. 2022 Oct;37(10):1986–96. doi: 10.1002/jbmr.4648. PMID: 35818312. Exclusion Code: X5.35818312
358 Pizzato S, Trevisan C, Lucato P, . Identification of asymptomatic frailty vertebral fractures in post-menopausal women. Bone. 2018 Aug;113:89–94. doi: 10.1016/j.bone.2018.05.007. PMID: 29753150. Exclusion Code: X5.29753150
359 Pluskiewicz W, Adamczyk P, Czekajło A, . High fracture probability predicts fractures in a 4-year follow-up in women from the RAC-OST-POL study. Osteoporos Int. 2015 Dec;26(12):2811–20. doi: 10.1007/s00198-015-3196-9. PMID: 26168766. Exclusion Code: X3.26168766
360 Pluskiewicz W, Adamczyk P, Drozdzowska B. Glucocorticoids Increase Fracture Risk and Fracture Prevalence Independently from Bone Mineral Density and Clinical Risk Factors: Results from the Gliwice Osteoporosis (GO) Study. Horm Metab Res. 2022 Jan;54(1):20–4. doi: 10.1055/a-1700-5007. PMID: 34986496. Exclusion Code: X7.34986496
361 Pluskiewicz W, Adamczyk P, Franek E, . The efficacy of pharmacotherapy in postmenopausal osteoporosis: a longitudinal observational study. Endokrynol Pol. 2019;70(6):473–7. doi: 10.5603/EP.a2019.0058. PMID: 31909456. Exclusion Code: X7.31909456
362 Pluskiewicz W, Adamczyk P, Werner A, . POL-RISK: an algorithm for 10-year fracture risk prediction in postmenopausal women from the RAC-OST-POL study. Pol Arch Intern Med. 2023 Mar 29;133(3)doi: 10.20452/pamw.16395. PMID: 36601872. Exclusion Code: X5.36601872
363 Popp AW, Varathan N, Buffat H, . Bone mineral density changes after 1 year of denosumab discontinuation in postmenopausal women with long-term denosumab treatment for osteoporosis. Calcif Tissue Int. 2018 Jul;103(1):50–4. doi: 10.1007/s00223-018-0394-4. PMID: 29380013. Exclusion Code: X6.29380013
364 Poutoglidou F, Samoladas E, Raikos N, Kouvelas D. Efficacy and safety of anti-sclerostin antibodies in the treatment of osteoporosis: A meta-analysis and systematic review. J Clin Densitom. 2022 Jul–Sep;25(3):401–15. doi: 10.1016/j.jocd.2021.11.005. PMID: 34920938. Exclusion Code: X3.34920938
365 Poxleitner P, Engelhardt M, Schmelzeisen R, Voss P. The prevention of medication-related osteonecrosis of the jaw. Dtsch Arztebl Int. 2017 Feb 3;114(5):63–9. doi: 10.3238/arztebl.2017.0063. PMID: 28241916. Exclusion Code: X3.28241916
366 Prochaska M, Taylor E, Vaidya A, Curhan G. Low bone density and bisphosphonate use and the risk of kidney stones. Clin J Am Soc Nephrol. 2017 Aug 7;12(8):1284–90. doi: 10.2215/cjn.01420217. PMID: 28576907. Exclusion Code: X7.28576907
367 Radeva M, Predel D, Winzler S, . Reliability of a risk-factor questionnaire for osteoporosis: a primary care survey study with dual energy x-ray absorptiometry ground truth. Int J Environ Res Public Health. 2021 Jan 28;18(3)doi: 10.3390/ijerph18031136. PMID: 33525339. Exclusion Code: X7.33525339
368 Rahim F, Zaki Zadeh A, Javanmardi P, . Machine learning algorithms for diagnosis of hip bone osteoporosis: a systematic review and meta-analysis study. Biomed Eng Online. 2023 Jul 10;22(1):68. doi: 10.1186/s12938-023-01132-9. PMID: 37430259. Exclusion Code: X5.37430259
369 Real J, Galindo G, Galván L, . Use of oral bisphosphonates in primary prevention of fractures in postmenopausal women: a population-based cohort study. PLoS One. 2015;10(4):e0118178. doi: 10.1371/journal.pone.0118178. PMID: 25861000. Exclusion Code: X3.25861000
370 Reber KC, König HH, Becker C, . Development of a risk assessment tool for osteoporotic fracture prevention: a claims data approach. Bone. 2018 May;110:170–6. doi: 10.1016/j.bone.2018.02.002. PMID: 29421456. Exclusion Code: X3.29421456
371 Reginster J, Minne HW, Sorensen OH, . Randomized trial of the effects of risedronate on vertebral fractures in women with established postmenopausal osteoporosis. Vertebral Efficacy with Risedronate Therapy (VERT) Study Group. Osteoporos Int. 2000;11(1):83–91. doi: 10.1007/s001980050010. PMID: 10663363. Exclusion Code: X1.10663363
372 Reginster JY, Hattersley G, Williams GC, . Abaloparatide is an effective treatment option for postmenopausal osteoporosis: review of the number needed to treat compared with teriparatide. Calcif Tissue Int. 2018 Nov;103(5):540–5. doi: 10.1007/s00223-018-0450-0. PMID: 29951742. Exclusion Code: X3.29951742
373 Reid IR, Horne AM, Mihov B, . Zoledronate slows weight loss and maintains fat mass in osteopenic older women: secondary analysis of a randomized controlled trial. Calcif Tissue Int. 2020 Apr;106(4):386–91. doi: 10.1007/s00223-019-00653-7. PMID: 31897528. Exclusion Code: X7.31897528
374 Reid IR, Horne AM, Mihov B, . Effect of zoledronate on lower respiratory infections in older women: secondary analysis of a randomized controlled trial. Calcif Tissue Int. 2021 Jul;109(1):12–6. doi: 10.1007/s00223-021-00830-7. PMID: 33712919. Exclusion Code: X7.33712919
375 Reyes Domínguez A, Sosa Cabrera N, Saavedra Santana P, . Assessment of the predictive capacity of the Garvan calculator of 10 year risk of fracture in a Spanish population. Revista de Osteoporosis y Metabolismo Mineral. 2017;9:55–61. Exclusion Code: X9.
376 Riar S, Feasel AL, Aghajafari F, . Comparison of 2 fracture risk estimation processes in Alberta: a cross-sectional chart review. CMAJ Open. 2021 Apr–Jun;9(2):E711–e7. doi: 10.9778/cmajo.20200207. PMID: 34162663. Exclusion Code: X3.34162663
377 Ripamonti C, Lisi L, Ciaffi J, . Spine Fragility Fracture Prediction Using TBS and BMD in Postmenopausal Women: A Bayesian Approach. Int J Environ Res Public Health. 2022 Nov 2;19(21)doi: 10.3390/ijerph192114315. PMID: 36361195. Exclusion Code: X5.36361195
378 Rizou S, Aravantinos L, Paganas A, . Assessment of the antiosteoporotic treatment initiation: a retrospective observational study in Greece. J Frailty Sarcopenia Falls. 2017 Dec;2(4):78–82. doi: 10.22540/jfsf-02-078. PMID: 32300684. Exclusion Code: X7.32300684
379 Rocha VM, Gaspar HA, Oliveira CF. Fracture risk assessment in home care patients using the FRAX® tool. Einstein (Sao Paulo). 2018 Sep 6;16(3):eAO4236. doi: 10.1590/s1679-45082018ao4236. PMID: 30208152. Exclusion Code: X7.30208152
380 Rodríguez AJ, Abrahamsen B. Cardiovascular safety of antifracture medications in patients with osteoporosis: a narrative review of evidence from randomized studies. JBMR Plus. 2021 Jul;5(7):e10522. doi: 10.1002/jbm4.10522. PMID: 34258509. Exclusion Code: X3.34258509
381 Rodríguez AJ, Ernst MT, Nybo M, . Oral bisphosphonate use reduces cardiovascular events in a cohort of Danish patients referred for bone mineral density. J Clin Endocrinol Metab. 2020 Oct 1;105(10)doi: 10.1210/clinem/dgaa481. PMID: 32717068. Exclusion Code: X10.32717068
382 Rossini M, Gatti D, Zamberlan N, . Long-term effects of a treatment course with oral alendronate of postmenopausal osteoporosis. J Bone Miner Res. 1994 Nov;9(11):1833–7. doi: 10.1002/jbmr.5650091121. PMID: 7863833. Exclusion Code: X10.7863833
383 Rubin KH, Abrahamsen B, Friis-Holmberg T, . Comparison of different screening tools (FRAX(R), OST, ORAI, OSIRIS, SCORE and age alone) to identify women with increased risk of fracture. A population-based prospective study. Bone. 2013 Sep;56(1):16–22. doi: 10.1016/j.bone.2013.05.002. PMID: 23669650. Exclusion Code: X4.23669650
384 Rubin KH, Möller S, Holmberg T, . A new fracture risk assessment tool (FREM) based on public health registries. J Bone Miner Res. 2018 Nov;33(11):1967–79. doi: 10.1002/jbmr.3528. PMID: 29924428. Exclusion Code: X3.29924428
385 Saag KG, Williams SA, Wang Y, . Effect of abaloparatide on bone mineral density and fracture incidence in a subset of younger postmenopausal women with osteoporosis at high risk for fracture. Clin Ther. 2020 Jun;42(6):1099–107.e1. doi: 10.1016/j.clinthera.2020.04.012. PMID: 32513495. Exclusion Code: X5.32513495
386 Sambrook PN, Flahive J, Hooven FH, . Predicting fractures in an international cohort using risk factor algorithms without BMD. J Bone Miner Res. 2011 Nov;26(11):2770–7. doi: 10.1002/jbmr.503. PMID: 21887705. Exclusion Code: X9.21887705
387 Sanderson J, Martyn-St James M, Stevens J, . Clinical effectiveness of bisphosphonates for the prevention of fragility fractures: a systematic review and network meta-analysis. Bone. 2016 Aug;89:52–8. doi: 10.1016/j.bone.2016.05.013. PMID: 27262775. Exclusion Code: X3.27262775
388 Sandhu SK, Nguyen ND, Center JR, . Prognosis of fracture: evaluation of predictive accuracy of the FRAX algorithm and Garvan nomogram. Osteoporos Int. 2010 May;21(5):863–71. doi: 10.1007/s00198-009-1026-7. PMID: 19633880. Exclusion Code: X9.19633880
389 Satyaraddi A, Shetty S, Kapoor N, . Performance of risk assessment tools for predicting osteoporosis in south Indian rural elderly men. Arch Osteoporos. 2017 Dec;12(1):35. doi: 10.1007/s11657-017-0332-5. PMID: 28378274. Exclusion Code: X8.28378274
390 Seeto AH, Tadrous M, Gebre AK, . Evidence for the cardiovascular effects of osteoporosis treatments in randomized trials of post-menopausal women: A systematic review and Bayesian network meta-analysis. Bone. 2022 Nov 10:116610. doi: 10.1016/j.bone.2022.116610. PMID: 36372197. Exclusion Code: X3.36372197
391 Sheer RL, Barron RL, Sudharshan L, Pasquale MK. Validated prediction of imminent risk of fracture for older adults. Am J Manag Care. 2020 Mar 1;26(3):e91–e7. doi: 10.37765/ajmc.2020.42641. PMID: 32181621. Exclusion Code: X5.32181621
392 Shen J, Ke Z, Dong S, . Pharmacological therapies for osteoporosis: a Bayesian network meta-analysis. Med Sci Monit. 2022 Apr 17;28:e935491. doi: 10.12659/msm.935491. PMID: 35430576. Exclusion Code: X3.35430576
393 Shepherd AJ, Cass AR, Carlson CA, Ray L. Development and internal validation of the male osteoporosis risk estimation score. Ann Fam Med. 2007 Nov–Dec;5(6):540–6. doi: 10.1370/afm.753. PMID: 18025492. Exclusion Code: X9.18025492
394 Shevroja E, Marques-Vidal P, Aubry-Rozier B, . Cohort profile: The OsteoLaus study. Int J Epidemiol. 2019 Aug 1;48(4):1046–7g. doi: 10.1093/ije/dyy276. PMID: 30590566. Exclusion Code: X7.30590566
395 Shevroja E, Mo Costabella F, Gonzalez Rodriguez E, . The fracture predictive ability of lumbar spine BMD and TBS as calculated based on different combinations of the lumbar spine vertebrae. Arch Osteoporos. 2022 Jun 9;17(1):83. doi: 10.1007/s11657-022-01123-8. PMID: 35678937. Exclusion Code: X5.35678937
396 Shi Z, Zhou H, Pan B, . Effectiveness of teriparatide on fracture healing: a systematic review and meta-analysis. PLoS One. 2016;11(12):e0168691. doi: 10.1371/journal.pone.0168691. PMID: 27997614. Exclusion Code: X3.27997614
397 Shi ZY, Zhang XG, Li CW, . Effect of traditional Chinese medicine product, QiangGuYin, on bone mineral density and bone turnover in Chinese postmenopausal osteoporosis. Evid Based Complement Alternat Med. 2017;2017:6062707. doi: 10.1155/2017/6062707. PMID: 28512501. Exclusion Code: X6.28512501
398 Shigematsu T, Muraoka R, Sugimoto T, Nishizawa Y. Risedronate therapy in patients with mild-to-moderate chronic kidney disease with osteoporosis: post-hoc analysis of data from the risedronate phase III clinical trials. BMC Nephrol. 2017 Feb 15;18(1):66. doi: 10.1186/s12882-017-0478-9. PMID: 28201994. Exclusion Code: X6.28201994
399 Shim JG, Kim DW, Ryu KH, . Application of machine learning approaches for osteoporosis risk prediction in postmenopausal women. Arch Osteoporos. 2020 Oct 23;15(1):169. doi: 10.1007/s11657-020-00802-8. PMID: 33097976. Exclusion Code: X3.33097976
400 Shimizu T, Arita K, Murota E, . Effects after starting or switching from bisphosphonate to romosozumab or denosumab in Japanese postmenopausal patients. J Bone Miner Metab. 2021 Apr 13;39(5):1–8. doi: 10.1007/s00774-021-01226-1. PMID: 33847831. Exclusion Code: X6.33439335
401 Shin YH, Shin WC, Kim JW. Effect of osteoporosis medication on fracture healing: an evidence based review. J Bone Metab. 2020 Feb;27(1):15–26. doi: 10.11005/jbm.2020.27.1.15. PMID: 32190605. Exclusion Code: X2.32190605
402 Silverman SL, Wang A, Cheng L, . Comorbidity indices for clinical trials: adaptation of two existing indices for use with the FREEDOM trial in women with postmenopausal osteoporosis. Osteoporos Int. 2016 Jan;27(1):75–80. doi: 10.1007/s00198-015-3215-x. PMID: 26174879. Exclusion Code: X3.26174879
403 Singh S, Dutta S, Khasbage S, . A systematic review and meta-analysis of efficacy and safety of romosozumab in postmenopausal osteoporosis. Osteoporos Int. 2022 Jan;33(1):1–12. doi: 10.1007/s00198-021-06095-y. PMID: 34432115. Exclusion Code: X1.34432115
404 Siris E, McDermott M, Pannacciulli N, . Estimation of long-term efficacy of denosumab treatment in postmenopausal women with osteoporosis: a FRAX- and virtual twin-based post hoc analysis from the FREEDOM and FREEDOM extension trials. JBMR Plus. 2020 Apr;4(4):e10348. doi: 10.1002/jbm4.10348. PMID: 32258966. Exclusion Code: X6.32258966
405 Siris ES, Fan CPS, Yang X, . Association between gastrointestinal events and compliance with osteoporosis therapy. Bone Reports. 2016 Jun;4:5–10. doi: 10.1016/j.bonr.2015.10.006. PMID: 28326336. Exclusion Code: X6.28326336
406 Skjødt MK, Möller S, Hyldig N, . Validation of the Fracture Risk Evaluation Model (FREM) in predicting major osteoporotic fractures and hip fractures using administrative health data. Bone. 2021 Jun;147:115934. doi: 10.1016/j.bone.2021.115934. PMID: 33757901. Exclusion Code: X3.33757901
407 Soen S, Arai Y, Matsuda S, . A 3-year postmarketing study on the safety and effectiveness of once-monthly risedronate in Japanese patients with osteoporosis. Osteoporosis and Sarcopenia. 2020 Dec;6(4):191–8. doi: 10.1016/j.afos.2020.11.002. PMID: 33426308. Exclusion Code: X5.33426308
408 Sone T, Kon N, Gaither KW, . Effects of 3-year denosumab treatment on hip structure in Japanese postmenopausal women and men with osteoporosis. Bone Rep. 2017 Dec;7:164–71. doi: 10.1016/j.bonr.2017.11.002. PMID: 29188222. Exclusion Code: X7.29188222
409 Sontag A, Wan X, Krege JH. Benefits and risks of raloxifene by vertebral fracture status. Curr Med Res Opin. 2010 Jan;26(1):71–6. doi: 10.1185/03007990903427082 [doi]. PMID: 19908937. Exclusion Code: X5.19908937
410 Sorensen HT, Christensen S, Mehnert F, . Use of bisphosphonates among women and risk of atrial fibrillation and flutter: population based case-control study. BMJ. 2008 Apr 12;336(7648):813–6. doi: 10.1136/bmj.39507.551644.BE. PMID: 18334527. Exclusion Code: X3.18334527
411 Söreskog E, Borgström F, Shepstone L, . Long-term cost-effectiveness of screening for fracture risk in a UK primary care setting: the SCOOP study. Osteoporos Int. 2020 Aug;31(8):1499–506. doi: 10.1007/s00198-020-05372-6. PMID: 32239237. Exclusion Code: X3.32239237
412 Steiner ML, Crotti GP, Teodoro JD, . Best laboratory screening in diagnosing secondary osteoporosis and fracture risk assessment tool and the national osteoporosis guideline group performance in determining clinical risk: a cross-sectional evaluation of the bone health in postmenopausal Brazilian women. J Bone Metab. 2023 Feb;30(1):47–57. doi: 10.11005/jbm.2023.30.1.47. PMID: 36950840. Exclusion Code: X8.36950840
413 Ström O, Lauppe R, Ljunggren Ö, . Real-world effectiveness of osteoporosis treatment in the oldest old. Osteoporos Int. 2020 Aug;31(8):1525–33. doi: 10.1007/s00198-020-05380-6. PMID: 32232509. Exclusion Code: X3.32232509
414 Su FM, Liu DH, Chen JF, . Development and validation of an Osteoporosis Self-Assessment Tool for Taiwan (OSTAi) postmenopausal women-a sub-study of the Taiwan OsteoPorosis Survey (TOPS). PLoS One. 2015;10(6):e0130716. doi: 10.1371/journal.pone.0130716. PMID: 26086766. Exclusion Code: X4.26086766
415 Su Y, Kwok TCY, Cummings SR, . Can Classification and regression tree analysis help identify clinically meaningful risk groups for hip fracture prediction in older American men (The MrOS Cohort Study)? JBMR Plus. 2019 Oct;3(10):e10207. doi: 10.1002/jbm4.10207. PMID: 31687643. Exclusion Code: X9.31687643
416 Su Y, Leung J, Hans D, . The added value of trabecular bone score to FRAX® to predict major osteoporotic fractures for clinical use in Chinese older people: the Mr. OS and Ms. OS cohort study in Hong Kong. Osteoporos Int. 2017 Jan;28(1):111–7. doi: 10.1007/s00198-016-3741-1. PMID: 27565645. Exclusion Code: X8.27565645
417 Su Y, Leung J, Kwok T. The role of previous falls in major osteoporotic fracture prediction in conjunction with FRAX in older Chinese men and women: the Mr. OS and Ms. OS cohort study in Hong Kong. Osteoporos Int. 2018 Feb;29(2):355–63. doi: 10.1007/s00198-017-4277-8. PMID: 29067485. Exclusion Code: X8.29067485
418 Su Y, Woo JW, Kwok TCY. The added value of SARC-F to prescreening using FRAX for hip fracture prevention in older community adults. J Am Med Dir Assoc. 2019 Jan;20(1):83–9. doi: 10.1016/j.jamda.2018.08.007. PMID: 30314676. Exclusion Code: X4.30314676
419 Subasinghe H, Lekamwasam S, Ball P, . Performance of Sri Lankan FRAX algorithm without bone mineral density and with quantitative ultrasound data input. Ceylon Med J. 2019 Mar 31;64(1):17–24. doi: 10.4038/cmj.v64i1.8836. PMID: 31055903. Exclusion Code: X6.31055903
420 Subasinghe H, Lekamwasam S, Ball P, . Estimating regional bone mineral density-based t-scores using clinical information; tools validated for postmenopausal women in Sri Lanka. Osteoporos Sarcopenia. 2020 Sep;6(3):122–8. doi: 10.1016/j.afos.2020.08.004. PMID: 33102805. Exclusion Code: X3.33102805
421 Subramaniam S, Chan CY, Soelaiman IN, . Development of osteoporosis screening algorithm for population aged 50 years and above in Klang Valley, Malaysia. Int J Environ Res Public Health. 2020 Apr 7;17(7)doi: 10.3390/ijerph17072526. PMID: 32272697. Exclusion Code: X3.32272697
422 Subramaniam S, Chan CY, Soelaiman IN, . The performance of osteoporosis self-assessment tool for Asians (OSTA) in identifying the risk of osteoporosis among Malaysian population aged 40 years and above. Arch Osteoporos. 2019 Nov 28;14(1):117. doi: 10.1007/s11657-019-0666-2. PMID: 31781876. Exclusion Code: X6.31781876
423 Sugimoto T, Matsumoto T, Hosoi T, . Efficacy of denosumab co-administered with vitamin D and Ca by baseline vitamin D status. J Bone Miner Metab. 2020 Nov;38(6):848–58. doi: 10.1007/s00774-020-01119-9. PMID: 32671481. Exclusion Code: X3.32671481
424 Sugimoto T, Yoshimura T, Uzawa T. Efficacy of once-weekly and twice-weekly injections of teriparatide by patient characteristics: a post hoc analysis of the TWICE study. Osteoporos Sarcopenia. 2021 Mar;7(1):11–6. doi: 10.1016/j.afos.2020.12.001. PMID: 33869800. Exclusion Code: X2.33869800
425 Sun LM, Liang JA, Lin CL, . Cancer risk in patients with osteoporosis: a population-based cohort study. Curr Med Res Opin. 2017 Apr;33(4):733–9. doi: 10.1080/03007995.2017.1278681. PMID: 28044464. Exclusion Code: X5.28044464
426 Sundh V, Hange D, Ahlqwist M, . FRAX and mandibular sparse trabeculation as fracture predictors: a longitudinal study from 1980 to 2002. Eur J Oral Sci. 2017 Apr;125(2):135–40. doi: 10.1111/eos.12341. PMID: 28263008. Exclusion Code: X4.28263008
427 Tamaki J, Iki M, Sato Y, . Does Trabecular Bone Score (TBS) improve the predictive ability of FRAX(®) for major osteoporotic fractures according to the Japanese Population-based OSteoporosis (JPOS) cohort study? J Bone Miner Metab. 2019 Jan;37(1):161–70. doi: 10.1007/s00774-018-0910-7. PMID: 29468478. Exclusion Code: X9.29468478
428 Tanaka S, Kuroda T, Saito M, Shiraki M. Urinary pentosidine improves risk classification using fracture risk assessment tools for postmenopausal women. J Bone Miner Res. 2011 Nov;26(11):2778–84. doi: 10.1002/jbmr.467 [doi]. PMID: 21773990. Exclusion Code: X7.21773990
429 Tang JL, Pan BB, Shu Y, . Evaluation of two tools for the early screening of osteoporosis in postmenopausal Chinese women with type 2 diabetes mellitus. J Int Med Res. 2020 Mar;48(3):300060520903889. doi: 10.1177/0300060520903889. PMID: 32208853. Exclusion Code: X8.32208853
430 Tang Y, Liu J, Tian C, . A novel primary osteoporosis screening tool (POST) for adults aged 50 years and over. Endocrine. 2023 Oct;82(1):190–200. doi: 10.1007/s12020-023-03442-3. PMID: 37450217. Exclusion Code: X8.37450217
431 Tang Y, Liu Z, Wang S, . Development and validation of a novel screening tool for osteoporosis in older US adults: The NHANES cross-sectional study. Endocrine. 2022 May;76(2):446–56. doi: 10.1007/s12020-022-03001-2. PMID: 35122626. Exclusion Code: X5.35122626
432 Thadani SR, Ristow B, Blackwell T, . Relationship of bisphosphonate therapy and atrial fibrillation/flutter: outcomes of Sleep Disorders in Older Men (MrOS Sleep) study. Chest. 2016 May;149(5):1173–80. doi: 10.1016/j.chest.2015.11.022. PMID: 26836889. Exclusion Code: X10.26836889
433 Tinago W, Cotter AG, Sabin CA, . Predictors of longitudinal change in bone mineral density in a cohort of HIV-positive and negative patients. AIDS. 2017 Mar 13;31(5):643–52. doi: 10.1097/qad.0000000000001372. PMID: 28060010. Exclusion Code: X2.28060010
434 Tourolle DC, Dempster DW, Ledoux C, . Ten-year simulation of the effects of denosumab on bone remodeling in human biopsies. JBMR Plus. 2021 Jun;5(6):e10494. doi: 10.1002/jbm4.10494. PMID: 34189383. Exclusion Code: X3.34189383
435 Tran T, Bliuc D, Pham HM, . A risk assessment tool for predicting fragility fractures and mortality in the elderly. J Bone Miner Res. 2020 Oct;35(10):1923–34. doi: 10.1002/jbmr.4100. PMID: 32460361. Exclusion Code: X3.32460361
436 Tripto-Shkolnik L, Fund N, Rouach V, . Fracture incidence after denosumab discontinuation: real-world data from a large healthcare provider. Bone. 2020 Jan;130:115150. doi: 10.1016/j.bone.2019.115150. PMID: 31715340. Exclusion Code: X3.31715340
437 Tsai WH, Tsai MC, Chang CY, . Comparison of Cardiovascular Events among Users of Different Classes of Anti-Osteoporosis Medications. International Journal of Gerontology. 2023;17(4):275–9. doi: 10.6890/IJGE.202310_17(4).0012. Exclusion Code: X4.
438 Tsuda T, Hashimoto Y, Okamoto Y, . Meta-analysis for the efficacy of bisphosphonates on hip fracture prevention. J Bone Miner Metab. 2020 Sep;38(5):678–86. doi: 10.1007/s00774-020-01096-z. PMID: 32236684. Exclusion Code: X3.32236684
439 Turner DA, Khioe RFS, Shepstone L, . The cost-effectiveness of screening in the community to reduce osteoporotic fractures in older women in the UK: economic evaluation of the SCOOP study. J Bone Miner Res. 2018 May;33(5):845–51. doi: 10.1002/jbmr.3381. PMID: 29470854. Exclusion Code: X7.29470854
440 Ullah KA, Rehman F, Anwar M, . Machine learning-based prediction of osteoporosis in postmenopausal women with clinical examined features: A quantitative clinical study. Health Sci Rep. 2023 Oct;6(10):e1656. doi: 10.1002/hsr2.1656. PMID: 37900094. Exclusion Code: X4.37900094
441 Um MJ, Cho EA, Jung H. Combination therapy of raloxifene and alendronate for treatment of osteoporosis in elderly women. J Menopausal Med. 2017 Apr;23(1):56–62. doi: 10.6118/jmm.2017.23.1.56. PMID: 28523260. Exclusion Code: X5.28523260
442 Urano T, Shiraki M, Kuroda T, . Bisphosphonates prevent age-related weight loss in Japanese postmenopausal women. J Bone Miner Metab. 2018 Nov;36(6):734–40. doi: 10.1007/s00774-017-0891-y. PMID: 29236162. Exclusion Code: X7.29236162
443 Valero C, Olmos JM, Llorca J, . Osteoporotic patients treated with bisphosphonates do not show the increased mortality observed in those untreated. J Bone Miner Metab. 2021 Apr 13;39(5):876–82. doi: 10.1007/s00774-021-01228-z. PMID: 33847832. Exclusion Code: X3.33847832
444 van Geel TA, Eisman JA, Geusens PP, . The utility of absolute risk prediction using FRAX(R) and Garvan fracture risk calculator in daily practice. Maturitas. 2014 Feb;77(2):174–9. doi: 10.1016/j.maturitas.2013.10.021. PMID: 24287178. Exclusion Code: X9.24287178
445 van Staa TP, Geusens P, Kanis JA, . A simple clinical score for estimating the long-term risk of fracture in post-menopausal women. QJM. 2006 Oct;99(10):673–82. doi: 10.1093/qjmed/hcl094. PMID: 16998210. Exclusion Code: X7.16998210
446 Vestergaard P. Occurrence of gastrointestinal cancer in users of bisphosphonates and other antiresorptive drugs against osteoporosis. Calcif Tissue Int. 2011 Dec;89(6):434–41. doi: 10.1007/s00223-011-9539-4. PMID: 22002678. Exclusion Code: X10.22002678
447 Vestergaard P, Fischer L, Mele M, . Use of bisphosphonates and risk of breast cancer. Calcif Tissue Int. 2011 Apr;88(4):255–62. doi: 10.1007/s00223-011-9463-7. PMID: 21253712. Exclusion Code: X7.21253712
448 Villa P, Lassandro AP, Moruzzi MC, . A non-invasive prevention program model for the assessment of osteoporosis in the early postmenopausal period: a pilot study on FRAX(®) and QUS tools advantages. J Endocrinol Invest. 2016 Feb;39(2):191–8. doi: 10.1007/s40618-015-0341-4. PMID: 26141076. Exclusion Code: X6.26141076
449 Viswanathan M, Reddy S, Berkman N, . Screening to prevent osteoporotic fractures: updated evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2018 Jun 26;319(24):2532–51. doi: 10.1001/jama.2018.6537. PMID: 29946734. Exclusion Code: X9.29946734
450 Waltman N, Kupzyk KA, Flores LE, . Bone-loading exercises versus risedronate for the prevention of osteoporosis in postmenopausal women with low bone mass: a randomized controlled trial. Osteoporos Int. 2022 Feb;33(2):475–86. doi: 10.1007/s00198-021-06083-2. PMID: 34519832. Exclusion Code: X10.34519832
451 Wang CC, Lu HT, Dusetzina SB, Wu CH. The association between long-term bisphosphonate use and the risk of fracture among women aged 50 or older with osteoporosis. J Womens Health (Larchmt). 2016 Jul;25(7):738–46. doi: 10.1089/jwh.2015.5617. PMID: 27096405. Exclusion Code: X3.27096405
452 Wang G, Sui L, Gai P, . The efficacy and safety of vertebral fracture prevention therapies in post-menopausal osteoporosis treatment: which therapies work best? a network meta-analysis. Bone Joint Res. 2017 Jul;6(7):452–63. doi: 10.1302/2046-3758.67.Bjr-2016-0292.R1. PMID: 28765269. Exclusion Code: X3.28765269
453 Wang JC, Chien WC, Chung CH, . Adverse cardiovascular effects of nitrogen-containing bisphosphonates in patients with osteoporosis: a nationwide population-based retrospective study. Int J Cardiol. 2016 Jul 15;215:232–7. doi: 10.1016/j.ijcard.2016.04.088. PMID: 27128537. Exclusion Code: X10.27128537
454 Wang L, Zhang D, Xu J. Association between the Geriatric Nutritional Risk Index, bone mineral density and osteoporosis in type 2 diabetes patients. J Diabetes Investig. 2020 Jul;11(4):956–63. doi: 10.1111/jdi.13196. PMID: 31828962. Exclusion Code: X8.31828962
455 Wang WY, Chen LH, Ma WJ, You RX. Drug efficacy and safety of denosumab, teriparatide, zoledronic acid, and ibandronic acid for the treatment of postmenopausal osteoporosis: a network meta-analysis of randomized controlled trials. Eur Rev Med Pharmacol Sci. 2023 Sep;27(17):8253–68. doi: 10.26355/eurrev_202309_33586. PMID: 37750653. Exclusion Code: X3.37750653
456 Wang Y, Mehrabi S, Sohn S, . Natural language processing of radiology reports for identification of skeletal site-specific fractures. BMC Med Inform Decis Mak. 2019 Apr 4;19(Suppl 3):73. doi: 10.1186/s12911-019-0780-5. PMID: 30943952. Exclusion Code: X5.30943952
457 Watts NB, Brown JP, Papapoulos S, . Safety observations with 3 years of denosumab exposure: comparison between subjects who received denosumab during the randomized FREEDOM trial and subjects who crossed over to denosumab during the FREEDOM extension. J Bone Miner Res. 2017 Jul;32(7):1481–5. doi: 10.1002/jbmr.3119. PMID: 28277603. Exclusion Code: X6.28277603
458 Watts NB, Grbic JT, Binkley N, . Invasive oral procedures and events in postmenopausal women with osteoporosis treated with denosumab for up to 10 years. J Clin Endocrinol Metab. 2019 Jun 1;104(6):2443–52. doi: 10.1210/jc.2018-01965. PMID: 30759221. Exclusion Code: X6.30759221
459 Watts NB, Hattersley G, Fitzpatrick LA, . Abaloparatide effect on forearm bone mineral density and wrist fracture risk in postmenopausal women with osteoporosis. Osteoporos Int. 2019 Jun;30(6):1187–94. doi: 10.1007/s00198-019-04890-2. PMID: 30899994. Exclusion Code: X5.30899994
460 Wei FL, Gao QY, Zhu KL, . Efficacy and safety of pharmacologic therapies for prevention of osteoporotic vertebral fractures in postmenopausal women. Heliyon. 2023 Feb;9(2):e11880. doi: 10.1016/j.heliyon.2022.e11880. PMID: 36852077. Exclusion Code: X3.36852077
461 Wells GA, Hsieh SC, Zheng C, . Risedronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev. 2022 May 3;5(5):Cd004523. doi: 10.1002/14651858.CD004523.pub4. PMID: 35502787. Exclusion Code: X3.35502787
462 Wen Z, Ding N, Chen R, . Comparison of methods to improve fracture risk assessment in Chinese diabetic postmenopausal women: a case-control study. Endocrine. 2021 Jul;73(1):209–16. doi: 10.1007/s12020-021-02724-y. PMID: 33932202. Exclusion Code: X8.33932202
463 Whittier DE, Samelson EJ, Hannan MT, . A fracture risk assessment tool for high resolution peripheral quantitative computed tomography. J Bone Miner Res. 2023 Sep;38(9):1234–44. doi: 10.1002/jbmr.4808. PMID: 37132542. Exclusion Code: X3.37132542
464 Wingood M, Criss MG, Irwin KE, . Screening for osteoporosis risk among community-dwelling older adults: a scoping review. J Geriatr Phys Ther. 2023 Oct–Dec 01;46(4):E137–e47. doi: 10.1519/jpt.0000000000000381. PMID: 36827688. Exclusion Code: X3.36827688
465 Wolverton D, Elliott DP. Evaluating the evidence behind treating osteoporosis in the oldest adults. Consult Pharm. 2018 Jun 1;33(6):308–16. doi: 10.4140/TCP.n.2018.308. PMID: 29880092. Exclusion Code: X3.29880092
466 Wu Q, Xiao X, Xu Y. Evaluating the performance of the WHO international reference standard for osteoporosis diagnosis in postmenopausal women of varied polygenic score and race. Journal of Clinical Medicine. 2020 Feb 12;9(2)doi: 10.3390/jcm9020499. PMID: 32059423. Exclusion Code: X9.32059423
467 Wu ST, Chen JF, Tsai CJ. The impact of bisphosphonates on mortality and cardiovascular risk among osteoporosis patients after cardiovascular disease. J Formos Med Assoc. 2021 Nov;120(11):1957–66. doi: 10.1016/j.jfma.2020.12.014. PMID: 33358773. Exclusion Code: X8.33358773
468 Wu Y, Chao J, Bao M, Zhang N. Predictive value of machine learning on fracture risk in osteoporosis: a systematic review and meta-analysis. BMJ Open. 2023 Dec 9;13(12):e071430. doi: 10.1136/bmjopen-2022-071430. PMID: 38070927. Exclusion Code: X5.38070927
469 Xiao X, Wu Q. Validation of a genome-wide polygenic score in improving fracture risk assessment beyond the FRAX tool in the Women’s Health Initiative study. PLoS One. 2023;18(6):e0286689. doi: 10.1371/journal.pone.0286689. PMID: 37262069. Exclusion Code: X9.37262069
470 Xie D, Zhou Y, Zhang Y, . Osteoporosis screening based on body mass index, years since menopause and age among postmenopausal women in south central China. Int J Clin Exp Med. 2018;11(3):2543–50. Exclusion Code: X3.
471 Xie Z, Chen Y, Gurbuz S, . Effects of teriparatide in Chinese and Caucasian women with osteoporosis: bridging study on efficacy. Clin Interv Aging. 2019;14:959–68. doi: 10.2147/cia.S181929. PMID: 31213783. Exclusion Code: X3.31213783
472 Xu Z. Alendronate for the treatment of osteoporosis in men: a meta-analysis of randomized controlled trials. Am J Ther. 2017 Mar/Apr;24(2):e130–e8. doi: 10.1097/mjt.0000000000000446. PMID: 27058577. Exclusion Code: X3.27058577
473 Yamamoto T, Tsujimoto M, Sowa H. Safety of daily teriparatide treatment: a post hoc analysis of a phase III study to investigate the possible association of teriparatide treatment with calcium homeostasis in patients with serum procollagen type I N-terminal propeptide elevation. Clin Interv Aging. 2015;10:1101–9. doi: 10.2147/cia.S83549. PMID: 26185429. Exclusion Code: X2.26185429
474 Yang HY, Huang JH, Chiu HW, . Vitamin D and bisphosphonates therapies for osteoporosis are associated with different risks of atrial fibrillation in women: a nationwide population-based analysis. Medicine (Baltimore). 2018 Oct;97(43):e12947. doi: 10.1097/md.0000000000012947. PMID: 30412111. Exclusion Code: X10.30412111
475 Yang L, Kang N, Yang JC, . Drug efficacies on bone mineral density and fracture rate for the treatment of postmenopausal osteoporosis: a network meta-analysis. Eur Rev Med Pharmacol Sci. 2019 Mar;23(6):2640–68. doi: 10.26355/eurrev_201903_17414. PMID: 30964193. Exclusion Code: X3.30964193
476 Yang Q, Cheng H, Qin J, . A Machine Learning-Based Preclinical Osteoporosis Screening Tool (POST): Model Development and Validation Study. JMIR Aging. 2023 Nov 8;6:e46791. doi: 10.2196/46791. PMID: 37986117. Exclusion Code: X5.37986117
477 Yang S, Leslie WD, Morin SN, Lix LM. Administrative healthcare data applied to fracture risk assessment. Osteoporos Int. 2019 Mar;30(3):565–71. doi: 10.1007/s00198-018-4780-6. PMID: 30554259. Exclusion Code: X3.30554259
478 Yang S, Leslie WD, Morin SN, . Antiresorptive therapy and newly diagnosed diabetes in women: a historical cohort study. Diabetes Obes Metab. 2016 Sep;18(9):875–81. doi: 10.1111/dom.12678. PMID: 27097832. Exclusion Code: X7.27097832
479 Yang T, Feng C, Qu Y, . Effect of teriparatide on quality of life in patients with postmenopausal osteoporosis: a retrospective cohort study. J Int Med Res. 2020 Feb;48(2):300060519876744. doi: 10.1177/0300060519876744. PMID: 31601158. Exclusion Code: X7.31601158
480 Yang XC, Deng ZH, Wen T, . Network meta-analysis of pharmacological agents for osteoporosis treatment and fracture prevention. Cell Physiol Biochem. 2016;40(3–4):781–95. doi: 10.1159/000453138. PMID: 27915335. Exclusion Code: X3.27915335
481 Yang Y, Luo X, Xie X, . Influences of teriparatide administration on marrow fat content in postmenopausal osteopenic women using MR spectroscopy. Climacteric. 2016 Jun;19(3):285–91. doi: 10.3109/13697137.2015.1126576. PMID: 26744910. Exclusion Code: X5.26744910
482 Yang Y, Luo X, Yan F, . Effect of zoledronic acid on vertebral marrow adiposity in postmenopausal osteoporosis assessed by MR spectroscopy. Skeletal Radiol. 2015 Oct;44(10):1499–505. doi: 10.1007/s00256-015-2200-y. PMID: 26130070. Exclusion Code: X8.26130070
483 Yavropoulou MP, Kasdagli MI, Makras P, . Nocebo-associated treatment discontinuation with subcutaneous anti-osteoporotic drugs. A systematic review and meta-analysis of placebo-arm dropouts in randomized-controlled trials. Maturitas. 2024 Jan;179:107874. doi: 10.1016/j.maturitas.2023.107874. PMID: 37976923. Exclusion Code: X3.37976923
484 Yin MT, Shiau S, Rimland D, . Fracture prediction with modified-FRAX in older HIV-infected and uninfected men. J Acquir Immune Defic Syndr. 2016 Aug 15;72(5):513–20. doi: 10.1097/qai.0000000000000998. PMID: 27003493. Exclusion Code: X5.27003493
485 Yıldırım Güzelant A, Sarıfakıoğlu AB, Yılmaz İ, . Should the cardiac rhythm be monitored following administration of zoledronic acid in elderly osteoporotic women? Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. 2016;62(3):214–21. doi: 10.5606/tftrd.2016.78871. Exclusion Code: X6.
486 Yu J, Goldshtein I, Shalev V, . Association of gastrointestinal events and osteoporosis treatment initiation in newly diagnosed osteoporotic Israeli women. Int J Clin Pract. 2015 Sep;69(9):1007–14. doi: 10.1111/ijcp.12676. PMID: 26278464. Exclusion Code: X6.26278464
487 Yu R, Leung J, Woo J. Sarcopenia combined with FRAX probabilities improves fracture risk prediction in older Chinese men. J Am Med Dir Assoc. 2014 Dec;15(12):918–23. doi: 10.1016/j.jamda.2014.07.011. PMID: 25262197. Exclusion Code: X4.25262197
488 Yu SF, Chen JF, Chen YC, . Beyond bone mineral density, FRAX-based tailor-made intervention thresholds for therapeutic decision in subjects on glucocorticoid. Medicine (united states). 2017 Feb;96(5) (no pagination):e5959. doi: 10.1097/MD.0000000000005959. PMID: CN-01340713. Exclusion Code: X3.
489 Yu SF, Chen JF, Chen YC, . Beyond bone mineral density, FRAX-based tailor-made intervention thresholds for therapeutic decision in subjects on glucocorticoid: a nationwide osteoporosis survey. Medicine (Baltimore). 2017 Feb;96(5):e5959. doi: 10.1097/md.0000000000005959. PMID: 28151883. Exclusion Code: X9.28151883
490 Yu X, Ye C, Xiang L. Application of artificial neural network in the diagnostic system of osteoporosis. Neurocomputing. 2016;214:376–81. doi: 10.1016/j.neucom.2016.06.023. Exclusion Code: X3.
491 Yuh DY, Chang TH, Huang RY, . The national-scale cohort study on bisphosphonate-related osteonecrosis of the jaw in Taiwan. J Dent. 2014 Oct;42(10):1343–52. doi: 10.1016/j.jdent.2014.05.001. PMID: 24907558. Exclusion Code: X10.24907558
492 Yun H, Delzell E, Ensrud KE, . Predicting hip and major osteoporotic fractures using administrative data. Arch Intern Med. 2010 Nov 22;170(21):1940–2. doi: 10.1001/archinternmed.2010.410. PMID: 21098356. Exclusion Code: X9.21098356
493 Zagórski P, Tabor E, Martela-Tomaszek K, . Five-year fracture risk assessment in postmenopausal women, using both the POL-RISK calculator and the Garvan nomogram: the Silesia osteo active study. Arch Osteoporos. 2021 Feb 16;16(1):32. doi: 10.1007/s11657-021-00881-1. PMID: 33594643. Exclusion Code: X6.33594643
494 Zanchetta MB, Boailchuk J, Massari F, . Significant bone loss after stopping long-term denosumab treatment: a post FREEDOM study. Osteoporos Int. 2018 Jan;29(1):41–7. doi: 10.1007/s00198-017-4242-6. PMID: 28975362. Exclusion Code: X6.28975362
495 Zavras AI, Shanmugham JR. Bisphosphonates, osteoporosis, and osteonecrosis of the jaw: a critical review of a large nested case-control study. J Evid Based Dent Pract. 2016 Jun;16(2):136–8. doi: 10.1016/j.jebdp.2016.05.007. PMID: 27449847. Exclusion Code: X3.27449847
496 Zebaze R, Libanati C, McClung MR, . Denosumab reduces cortical porosity of the proximal femoral shaft in postmenopausal women with osteoporosis. J Bone Miner Res. 2016 Oct;31(10):1827–34. doi: 10.1002/jbmr.2855. PMID: 27082709. Exclusion Code: X7.27082709
497 Zechmann S, Scherz N, Reich O, . Appropriateness of bone density measurement in Switzerland: a cross-sectional study. BMC Public Health. 2018 Apr 2;18(1):423. doi: 10.1186/s12889-018-5305-0. PMID: 29606111. Exclusion Code: X7.29606111
498 Zeng LF, Pan BQ, Liang GH, . Does routine anti-osteoporosis medication lower the risk of fractures in male subjects? An updated systematic review with meta-analysis of clinical trials. Front Pharmacol. 2019;10:882. doi: 10.3389/fphar.2019.00882. PMID: 31447677. Exclusion Code: X3.31447677
499 Zenke Y, Ikeda S, Fukuda F, . Study of atypical femoral fracture cases coupled in a multicenter study. J uoeh. 2016 Sep;38(3):207–14. doi: 10.7888/juoeh.38.207. PMID: 27627968. Exclusion Code: X6.27627968
500 Zhang J, Zhou R, Luo X, . Routine chest CT combined with the osteoporosis self-assessment tool for Asians (OSTA): a screening tool for patients with osteoporosis. Skeletal Radiol. 2023 Jun;52(6):1169–78. doi: 10.1007/s00256-022-04255-7. PMID: 36520217. Exclusion Code: X8.36520217
501 Zhang J, Zhou S, Cai F, Ma Y. The curative effect of the additional administration of ibandronate sodium and calcitriol on elderly patients with osteoporosis. Int J Clin Exp Med. 2020;13(4):2371–8. PMID: CN-02164219. Exclusion Code: X6.
502 Zhang K, Wang M, Han W, . Construction of a predictive model for osteoporosis risk in men: using the IOF 1-min osteoporosis test. J Orthop Surg Res. 2023 Oct 11;18(1):770. doi: 10.1186/s13018-023-04266-7. PMID: 37821993. Exclusion Code: X5.37821993
503 Zhang X, Hamadeh IS, Song S, . Osteonecrosis of the jaw in the United States Food and Drug Administration’s Adverse Event Reporting System (FAERS). J Bone Miner Res. 2016 Feb;31(2):336–40. doi: 10.1002/jbmr.2693. PMID: 26288087. Exclusion Code: X3.26288087
504 Zhang X, Lin J, Yang Y, . Comparison of three tools for predicting primary osteoporosis in an elderly male population in Beijing: a cross-sectional study. Clin Interv Aging. 2018;13:201–9. doi: 10.2147/cia.S145741. PMID: 29440880. Exclusion Code: X8.29440880
505 Zhang ZL, Liao EY, Xia WB, . Alendronate sodium/vitamin D3 combination tablet versus calcitriol for osteoporosis in Chinese postmenopausal women: a 6-month, randomized, open-label, active-comparator-controlled study with a 6-month extension. Osteoporos Int. 2015 Sep;26(9):2365–74. doi: 10.1007/s00198-015-3141-y. PMID: 25929192. Exclusion Code: X6.25929192
506 Zhao S, Zhao W, Du D, . Effect of bisphosphonate on hip fracture in patients with osteoporosis or osteopenia according to age: a meta-analysis and systematic review. J Investig Med. 2022 Mar;70(3):837–43. doi: 10.1136/jim-2021-001961. PMID: 34893517. Exclusion Code: X3.34893517
507 Zheng JQ, Lai HJ, Zheng CM, . Association of stroke subtypes with risk of hip fracture: a population-based study in Taiwan. Arch Osteoporos. 2017 Nov 22;12(1):104. doi: 10.1007/s11657-017-0390-8. PMID: 29167998. Exclusion Code: X5.29167998
508 Zhou J, Ma X, Wang T, Zhai S. Comparative efficacy of bisphosphonates in short-term fracture prevention for primary osteoporosis: a systematic review with network meta-analyses. Osteoporos Int. 2016 Nov;27(11):3289–300. doi: 10.1007/s00198-016-3654-z. PMID: 27273112. Exclusion Code: X3.27273112
509 Zhou J, Wang T, Zhao X, . Comparative efficacy of bisphosphonates to prevent fracture in men with osteoporosis: a systematic review with network meta-analyses. Rheumatol Ther. 2016 Jun;3(1):117–28. doi: 10.1007/s40744-016-0030-6. PMID: 27747517. Exclusion Code: X3.27747517
510 Zysset P, Pahr D, Engelke K, . Comparison of proximal femur and vertebral body strength improvements in the FREEDOM trial using an alternative finite element methodology. Bone. 2015 Dec;81:122–30. doi: 10.1016/j.bone.2015.06.025. PMID: 26141837. Exclusion Code: X7.26141837