# Appendix B Additional Methods

## B.1 Update Search Strategies

### PubMed April 1, 2016, through July 14, 2021

Search | Query | Results
#1 | “Osteoporosis”[mh] OR “Osteoporotic Fractures”[mh] OR “Fractures, Bone/prevention and control”[mh:noexp] OR “Decalcification, Pathologic”[mh] OR ((“Bone Diseases, Metabolic”[mh:noexp] OR “Osteoporosis”[tiab] OR “Osteoporoses”[tiab] OR “osteoporotic”[tiab] OR “osteopenia”[tiab] OR “Age-Related Bone Loss”[tiab] OR “Age-Related Bone Losses”[tiab] OR “Calcaneus”[mh] OR “Menopause”[mh] OR “menopause”[tiab] OR “menopausal”[tiab] OR “postmenopause”[tiab] OR “postmenopausal”[tiab] OR “perimenopause”[tiab] OR “perimenopausal”[tiab] OR “Risk Factors”[Mesh]) AND (“Bone Density”[mh] OR “bone mineral density”[tiab] OR “bone density”[tiab] OR “density of bone”[tiab] OR “density of bones”[tiab] OR “bone loss”[tiab] OR “bone mass”[tiab] OR “brittle bone”[tiab] OR “brittle bones”[tiab] OR “fragile bone”[tiab] OR “fragile bones”[tiab] OR “broken bone”[tiab] OR “broken bones”[tiab] OR “bone health”[tiab] OR “health of bones”[tiab] OR “fractures, bone”[mh] OR “hip fractures”[mh] OR “spinal fractures”[mh] OR “fractures, spontaneous”[mh] OR “femoral fractures”[mh] OR “humeral fractures”[mh] OR “radius fractures”[mh] OR “ulna fractures”[mh] OR “fracture”[tiab] OR “fractures”[tiab] OR “fractured”[tiab] OR “bone turnover”[tiab] OR “bone resorption”[tiab] OR (“bone”[tiab] AND preserve*[tiab]) OR “bone formation”[tiab])) | 110,697
#2 | #1 AND (English[lang] AND (“2016/04/01”[Date - MeSH] : “3000”[Date - MeSH])) NOT (animals[mh] NOT humans[mh]) NOT (rat[ti] OR rats[ti] OR mouse[ti] OR mice[ti]) | 24,747
#3 | #2 AND (“mass screening”[mh:noexp] OR “Diagnostic Screening Programs”[mh] OR “diagnostic imaging”[Subheading] OR “algorithms”[mh:noexp] OR “Surveys and Questionnaires”[mh] OR “risk assessment”[mh] OR screening[ti] OR screening[ot] OR “Absorptiometry, Photon”[mh] OR “Dual-Energy X-Ray Absorptiometry Scan”[tiab] OR “DXA”[tiab] OR “DEXA”[tiab] OR “Densitometry”[mh] OR “densitometry”[tiab] OR “Age Bulk One or Never Estrogens”[tiab] OR “ABONE”[tiab] OR “body weight criterion”[tiab] OR “BWC”[tiab] OR “Brown’’s clinical risk assessment”[tiab] OR “Canadian Risk for Osteoporosis Calculator”[tiab] OR “CAROC”[tiab] OR “fracture absolute risk assessment”[tiab] OR “FARA”[tiab] OR “fracture risk assessment”[tiab] OR “FRAX”[tiab] OR “fracture risk score”[tiab] OR “fracture risk calculator”[tiab] OR “fracture risk tool”[tiab] OR “risk assessment”[ti] OR “risk assessment”[ot] OR “predictive model*”[tiab] OR “prognostic model*”[tiab] OR “Garvan”[tiab] OR “Hong Kong Osteoporosis Study”[tiab] OR “HKOS”[tiab] OR “Male Osteoporosis Risk Estimation Score”[tiab] OR “MORES”[tiab] OR “Osteoporosis Self-assessment Tool”[tiab] OR “OST”[tiab] OR “OSTA”[tiab] OR “OSTAi”[tiab] OR “risk assessment instrument”[tiab] OR “ORAI”[tiab] OR “Osteoporosis Index of Risk”[tiab] OR “OSIRIS”[tiab] OR “Q fracture”[tiab] OR “osteoporosis risk estimate”[tiab] OR “Study of Osteoporotic Fractures”[tiab] OR “SOF”[tiab] OR “SOFSURF”[tiab] OR “Weight-only-EPIDOS”[tiab] OR ((“American Society for Bone and Mineral Research”[tiab] OR “ASBMR”[tiab] OR “International Society for Clinical Densitometry”[tiab] OR “ISCD”[tiab] OR “National Osteoporosis Foundation”[tiab] OR “National Osteoporosis Guideline Group”[tiab] OR “NOGG”[tiab] OR “World Health Organization”[tiab]) AND (“guideline”[tiab] OR “guidelines”[tiab]))) | 8,916
#4 | #2 AND (“Diphosphonates”[mh:noexp] OR “Bisphosphonates”[tiab] OR “Bisphosphonate”[tiab] OR “Alendronate”[mh] OR “Alendronate”[tiab] or “alendronic acid”[tiab] OR “Fosamax”[tiab] OR “Binosto”[tiab] OR “Ibandronic Acid”[mh] OR “Ibandronic Acid”[tiab] OR “Ibandronate”[tiab] OR “Boniva”[tiab] OR “Bonviva”[tiab] OR “Bondronat”[tiab] OR “Risedronic Acid”[mh] OR “Risedronic Acid”[tiab] OR “Atelvia”[tiab] OR “Actonel”[tiab] OR “Risedronate”[tiab] OR “Zoledronic Acid”[mh] OR “Zoledronic Acid”[tiab] OR “Zometa”[tiab] OR “Zoledronate”[tiab] OR “Reclast”[tiab] OR “abaloparatide”[Supplementary Concept] OR “abaloparatide”[tiab] OR “Tymlos”[tiab] OR “Teriparatide”[mh] OR “Teriparatide”[tiab] OR “Forteo”[tiab] OR “Parathar”[tiab] OR “romosozumab”[Supplementary Concept] OR “romosozumab”[tiab] OR “evenity”[tiab] OR “sclerostin inhibitor”[tiab] OR “Denosumab”[mh] OR “Denosumab”[tiab] OR “Prolia”[tiab] OR “Xgeva”[tiab] OR “RANK Ligand”[mh] OR “RANK Ligand”[tiab] OR “Osteoprotegerin Ligand”[tiab] OR “TRANCE Protein”[tiab] OR “RANKL Protein”[tiab] OR “Osteoclast Differentiation Factor”[tiab]) | 3,376
#5 | (#3 OR #4) AND (“randomized controlled trial”[pt] OR “controlled clinical trial”[pt] OR “random allocation”[mh] OR “randomized”[tiab] OR “randomized”[tiab] OR “randomization”[tiab] OR “randomization”[tiab] OR “randomly”[tiab] OR “placebos”[mh] OR placebo[tiab] OR placebos[tiab] OR “multicenter study”[pt] OR “comparative study”[pt] OR “comparative study”[tiab] OR “comparative”[ti] OR “clinical study”[pt:noexp] OR “clinical trial”[pt] OR “clinical trials as topic”[mh] OR “clinical protocols”[mh] OR “clinical trial”[tiab] OR “clinical trials”[tiab] OR ((trial[tiab] OR trials[tiab] OR study[tiab] OR studies[tiab]) AND (“control”[tiab] OR “controlled”[tiab] OR “controls”[tiab] OR group[tiab] OR groups[tiab] OR volunteer*[tiab] OR cohort[tiab] OR cohorts[tiab])) OR “single-blind method”[mh] OR single blind*[tiab] OR “double-blind method”[mh] OR double blind*[tiab] OR triple blind*[tiab] OR ((singl*[tiab] OR doubl*[tiab] OR trebl*[tiab] OR tripl*[tiab]) AND (mask*[tiab] OR blind* [tiab])) OR “treatment outcome”[mh] OR “evaluation studies”[pt] OR “evaluation studies as topic”[mh] OR “evaluation study”[tiab] OR “evaluation studies”[tiab] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR systematic[sb] OR “systematic review”[tiab] OR “meta-analysis”[pt] OR meta-analysis[mh] OR “meta-analysis as topic”[mh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “survival analysis”[mh] OR “systematic overview”[tiab] OR “quantitative review”[tiab] OR “quantitative synthesis”[tiab] OR “quantitative syntheses”[tiab] OR “pooled analysis”[tiab] OR “pooled analyses”[tiab] OR “meta-regression”[tiab] OR “data synthesis”[tiab] OR “data syntheses”[tiab] OR “data extraction”[tiab] OR “data abstraction”[tiab] OR “fixed effect”[tiab] OR “fixed effects”[tiab] OR “indirect comparison”[tiab] OR ((“indirect treatment”[tiab] OR “mixed-treatment”[tiab]) AND (“comparison”[tiab] OR “comparisons”[tiab])) OR “comparative efficacy”[tiab] OR “comparative effectiveness”[tiab]) | 6,683
#6 | (#3 OR #4) AND (“observational study”[pt] OR “observational studies as topic”[mh] OR “observation”[mh] OR “observational”[tiab] OR “cohort studies”[mh] OR “cohort”[tiab] OR “cohorts”[tiab] OR “concurrent study”[tiab] OR “concurrent studies”[tiab] OR “incidence study”[tiab] OR “incidence studies”[tiab] OR “follow-up studies”[mh] OR “follow-up”[tiab] OR “followup”[tiab] OR “longitudinal studies”[mh] OR “longitudinal”[tiab] OR “longitudinally”[tiab] OR “prospective studies”[mh] OR “prospective”[tiab] OR “prospectively”[tiab] OR “case-control studies”[mh] OR “case-control”[tiab] OR “case-crossover”[tiab] OR “retrospective studies”[mh] OR “retrospective”[tiab] OR “nonexperimental”[tiab] OR “non-experimental”[tiab] OR “nonrandomized”[tiab] OR “nonrandomized”[tiab] OR “non-randomised”[tiab] OR “nonrandomized”[tiab] OR “adverse effects”[subheading]) | 6,554
#7 | #3 AND (“predictive value of tests”[mh] OR “models, statistical”[mh] OR “logistic models”[mh] OR “logistic models”[mh] OR “sensitivity and specificity”[mh] OR “roc curve”[mh] OR “proportional hazards models”[mh] OR “area under curve”[mh] OR “analysis of variance”[mh] OR “models, statistical”[mh] OR “fracture prediction”[ot] OR “reproducibility of results”[mh] OR “accuracy”[tiab] OR “discrimination”[tiab] OR “discriminant validity”[tiab] OR “goodness-of-fit”[tiab] OR “Hosmer-Lemeshow”[tiab] OR “c-statistic*”[tiab] OR “cstatistic*”[tiab] OR “calibrat*”[tiab] OR ((“accurac*”[tiab] OR “reliability”[tiab] OR “validity”[tiab] OR “value*”[tiab]) AND “predict*”[tiab]) OR ((“accurac*”[tiab] OR “effectiveness”[tiab] OR “efficac*”[tiab] OR “error*”[tiab] OR “perform*”[tiab] OR “reliability”[tiab] OR “validity”[tiab] OR “value”[tiab] OR “yield*”[tiab]) AND “diagnostic*”[tiab]) OR “receiver operat*”[tiab]) | 2,014
#9 | #5 OR #6 OR #7 | 8,910

### Cochrane Central April 1, 2016, through July 14, 2021

Search | Query | Results
#1 | [mh “Osteoporosis”] OR [mh “Osteoporotic Fractures”] OR [mh ^”Fractures, Bone”/PC] OR [mh “Decalcification, Pathologic”] OR (([mh ^”Bone Diseases, Metabolic”] OR “Osteoporosis”:ti,ab,kw OR “Osteoporoses”:ti,ab,kw OR “osteoporotic”:ti,ab,kw OR “osteopenia”:ti,ab,kw OR “Age-Related Bone Loss”:ti,ab,kw OR “Age-Related Bone Losses”:ti,ab,kw OR [mh “Calcaneus”] OR [mh “Menopause”] OR “menopause”:ti,ab,kw OR “menopausal”:ti,ab,kw OR “postmenopause”:ti,ab,kw OR “postmenopausal”:ti,ab,kw OR “perimenopause”:ti,ab,kw OR “perimenopausal”:ti,ab,kw OR [mh “Risk Factors”]) AND ([mh “Bone Density”] OR “bone mineral density”:ti,ab,kw OR “bone density”:ti,ab,kw OR “density of bone”:ti,ab,kw OR “density of bones”:ti,ab,kw OR “bone loss”:ti,ab,kw OR “bone mass”:ti,ab,kw OR “brittle bone”:ti,ab,kw OR “brittle bones”:ti,ab,kw OR “fragile bone”:ti,ab,kw OR “fragile bones”:ti,ab,kw OR “broken bone”:ti,ab,kw OR “broken bones”:ti,ab,kw OR “bone health”:ti,ab,kw OR “health of bones”:ti,ab,kw OR [mh “fractures, bone”] OR [mh “hip fractures”] OR [mh “spinal fractures”] OR [mh “fractures, spontaneous”] OR [mh “femoral fractures”] OR [mh “humeral fractures”] OR [mh “radius fractures”] OR [mh “ulna fractures”] OR “fracture”:ti,ab,kw OR “fractures”:ti,ab,kw OR “fractured”:ti,ab,kw OR “bone turnover”:ti,ab,kw OR “bone resorption”:ti,ab,kw OR (“bone” NEAR preserve*):ti,ab,kw OR “bone formation”:ti,ab,kw)) | 12,289
#2 | [mh ^”mass screening”] OR [mh “Diagnostic Screening Programs”] OR [mh ^”algorithms”] OR [mh “Surveys and Questionnaires”] OR [mh “risk assessment”] OR “screening”:ti OR [mh “Absorptiometry, Photon”] OR “Dual-Energy X-Ray Absorptiometry Scan”:ti,ab,kw OR “DXA”:ti,ab,kw OR “DEXA”:ti,ab,kw OR [mh “Densitometry”] OR “densitometry”:ti,ab,kw OR “Age Bulk One or Never Estrogens”:ti,ab,kw OR “ABONE”:ti,ab,kw OR “body weight criterion”:ti,ab,kw OR “BWC”:ti,ab,kw OR “Brown’’s clinical risk assessment”:ti,ab,kw OR “Canadian Risk for Osteoporosis Calculator”:ti,ab,kw OR “CAROC”:ti,ab,kw OR “fracture absolute risk assessment”:ti,ab,kw OR “FARA”:ti,ab,kw OR “fracture risk assessment”:ti,ab,kw OR “FRAX”:ti,ab,kw OR “fracture risk score”:ti,ab,kw OR “fracture risk calculator”:ti,ab,kw OR “fracture risk tool”:ti,ab,kw OR “risk assessment”:ti,ab,kw OR (predictive NEXT model*):ti,ab,kw OR (prognostic NEXT model*):ti,ab,kw OR “Garvan”:ti,ab,kw OR “Hong Kong Osteoporosis Study”:ti,ab,kw OR “HKOS”:ti,ab,kw OR “Male Osteoporosis Risk Estimation Score”:ti,ab,kw OR “MORES”:ti,ab,kw OR “Osteoporosis Self-assessment Tool”:ti,ab,kw OR “OST”:ti,ab,kw OR “OSTA”:ti,ab,kw OR “OSTAi”:ti,ab,kw OR “risk assessment instrument”:ti,ab,kw OR “ORAI”:ti,ab,kw OR “Osteoporosis Index of Risk”:ti,ab,kw OR “OSIRIS”:ti,ab,kw OR “Q fracture”:ti,ab,kw OR “osteoporosis risk estimate”:ti,ab,kw OR “Study of Osteoporotic Fractures”:ti,ab,kw OR “SOF”:ti,ab,kw OR “SOFSURF”:ti,ab,kw OR “Weight-only-EPIDOS”:ti,ab,kw OR (“American Society for Bone and Mineral Research” OR “ASBMR” OR “International Society for Clinical Densitometry” OR “ISCD” OR “National Osteoporosis Foundation” OR “National Osteoporosis Guideline Group” OR “NOGG” OR “World Health Organization” NEAR “guideline” OR “guidelines”):ti,ab,kw | 130,942
#3 | [mh ^”Diphosphonates”] OR “Bisphosphonates”:ti,ab,kw OR “Bisphosphonate”:ti,ab,kw OR [mh “Alendronate”] OR “Alendronate”:ti,ab,kw OR “alendronic acid”:ti,ab,kw OR “Fosamax”:ti,ab,kw OR “Binosto”:ti,ab,kw OR [mh “Ibandronic Acid”] OR “Ibandronic Acid”:ti,ab,kw OR “Ibandronate”:ti,ab,kw OR “Boniva”:ti,ab,kw OR “Bonviva”:ti,ab,kw OR “Bondronat”:ti,ab,kw OR [mh “Risedronic Acid”] OR “Risedronic Acid”:ti,ab,kw OR “Atelvia”:ti,ab,kw OR “Actonel”:ti,ab,kw OR “Risedronate”:ti,ab,kw OR [mh “Zoledronic Acid”] OR “Zoledronic Acid”:ti,ab,kw OR “Zometa”:ti,ab,kw OR “Zoledronate”:ti,ab,kw OR “Reclast”:ti,ab,kw OR [mh “abaloparatide”] OR “abaloparatide”:ti,ab,kw OR “Tymlos”:ti,ab,kw OR [mh “Teriparatide”] OR “Teriparatide”:ti,ab,kw OR “Forteo”:ti,ab,kw OR “Parathar”:ti,ab,kw OR [mh “romosozumab”] OR “romosozumab”:ti,ab,kw OR “evenity”:ti,ab,kw OR “sclerostin inhibitor”:ti,ab,kw OR [mh “Denosumab”] OR “Denosumab”:ti,ab,kw OR “Prolia”:ti,ab,kw OR “Xgeva”:ti,ab,kw OR [mh “RANK Ligand”] OR “RANK Ligand”:ti,ab,kw OR “Osteoprotegerin Ligand”:ti,ab,kw OR “TRANCE Protein”:ti,ab,kw OR “RANKL Protein”:ti,ab,kw OR “Osteoclast Differentiation Factor”:ti,ab,kw | 6,619
#4 | #1 AND (OR #2-#3); with Publication Year from 2016 to 2021, with Cochrane Library publication date from Apr 2016 to Jul 2021, in Trials | 1,781

### Embase April 1, 2016, through July 14, 2021

Search | Query | Results
#1 | ‘‘osteoporosis’’/de OR ‘‘fragility fracture’’/de OR ((‘‘metabolic bone disease’’/de OR ‘‘bone demineralization’’/de OR ‘‘Osteoporosis’’:ti,ab OR ‘‘Osteoporoses’’:ti,ab OR ‘‘osteoporotic’’:ti,ab OR ‘‘osteopenia’’:ti,ab OR ‘‘Age-Related Bone Loss’’:ti,ab OR ‘‘Age-Related Bone Losses’’:ti,ab OR ‘‘calcaneus’’/exp OR ‘‘menopause and climacterium’’/exp OR ‘‘menopause’’:ti,ab OR ‘‘menopausal’’:ti,ab OR ‘‘postmenopause’’:ti,ab OR ‘‘postmenopausal’’:ti,ab OR ‘‘perimenopause’’:ti,ab OR ‘‘perimenopausal’’:ti,ab OR ‘‘risk factor’’/exp) AND (‘‘bone density’’/exp OR ‘‘bone mineral density’’:ti,ab OR ‘‘bone density’’:ti,ab OR ‘‘density of bone’’:ti,ab OR ‘‘density of bones’’:ti,ab OR ‘‘bone loss’’:ti,ab OR ‘‘bone mass’’:ti,ab OR ‘‘brittle bone’’:ti,ab OR ‘‘brittle bones’’:ti,ab OR ‘‘fragile bone’’:ti,ab OR ‘‘fragile bones’’:ti,ab OR ‘‘broken bone’’:ti,ab OR ‘‘broken bones’’:ti,ab OR ‘‘bone health’’:ti,ab OR ‘‘health of bones’’:ti,ab OR ‘‘fracture’’/exp OR ‘‘fracture’’:ti,ab OR ‘‘fractures’’:ti,ab OR ‘‘fractured’’:ti,ab OR ‘‘bone turnover’’:ti,ab OR ‘‘bone resorption’’:ti,ab OR (‘‘bone’’ NEAR/6 preserve*):ti,ab OR ‘‘bone formation’’:ti,ab)) AND [humans]/lim AND [english]/lim AND [2016-2021]/py | 46,522
#2 | ‘‘mass screening’’/exp OR ‘‘mass screening’’:ti,ab OR ‘‘diagnostic screening programs’’/exp OR ‘‘diagnostic screening’’:ti,ab OR ‘‘diagnostic imaging’’/exp OR ‘‘diagnostic imaging’’:ti,ab OR ‘‘algorithms’’/de OR ‘‘algorithms’’:ti,ab OR ‘‘surveys and questionnaires’’/de OR ‘‘surveys and questionnaires’’:ti,ab OR ‘‘screening’’/exp OR screening OR ‘‘photon absorptiometry’’/exp OR ‘‘photon absorptiometry’’:ti,ab OR ‘‘dual-energy x-ray absorptiometry scan’’:ti,ab OR ‘‘dxa’’/exp OR ‘‘dxa’’:ti,ab OR ‘‘dexa’’/exp OR ‘‘dexa’’:ti,ab OR ‘‘densitometry’’/exp OR ‘‘densitometry’’:ti,ab OR ‘‘age bulk one or never estrogens’’:ti,ab OR ‘‘abone’’:ti,ab OR ‘‘body weight criterion’’:ti,ab OR ‘‘bwc’’:ti,ab OR ‘‘clinical risk assessment’’:ti,ab OR ‘‘canadian risk for osteoporosis calculator’’:ti,ab OR ‘‘caroc’’:ti,ab OR ‘‘fracture absolute risk assessment’’:ti,ab OR ‘‘fara’’:ti,ab OR ‘‘fracture risk assessment’’/exp OR ‘‘fracture risk assessment’’:ti,ab OR ‘‘frax’’/exp OR ‘‘frax’’:ti,ab OR ‘‘fracture risk score’’:ti,ab OR ‘‘fracture risk calculator’’/exp OR ‘‘fracture risk calculator’’:ti,ab OR ‘‘fracture risk tool’’:ti,ab OR ‘‘risk assessment’’/exp OR ‘‘risk assessment’’:ti,ab OR ‘‘predictive model*’’:ti,ab OR ‘‘prognostic model*’’:ti,ab OR ‘‘garvan’’:ti,ab OR ‘‘hong kong osteoporosis study’’:ti,ab OR ‘‘hkos’’:ti,ab OR ‘‘male osteoporosis risk estimation score’’:ti,ab OR ‘‘mores’’:ti,ab OR ‘‘osteoporosis self-assessment tool’’:ti,ab OR ‘‘ost’’:ti,ab OR ‘‘osta’’:ti,ab OR ‘‘ostai’’:ti,ab OR ‘‘risk assessment instrument’’:ti,ab OR ‘‘orai’’:ti,ab OR ‘‘osteoporosis index of risk’’:ti,ab OR ‘‘osiris’’:ti,ab OR ‘‘q fracture’’:ti,ab OR ‘‘osteoporosis risk estimate’’:ti,ab OR ‘‘study of osteoporotic fractures’’:ti,ab OR ‘‘sof’’:ti,ab OR ‘‘sofsurf’’:ti,ab OR ‘‘weight-only-epidos’’:ti,ab OR ((‘‘American Society for Bone and Mineral Research’’:ti,ab OR ‘‘ASBMR’’:ti,ab OR ‘‘International Society for Clinical Densitometry’’:ti,ab OR ‘‘ISCD’’:ti,ab OR ‘‘National Osteoporosis Foundation’’:ti,ab OR ‘‘National Osteoporosis Guideline Group’’:ti,ab OR ‘‘NOGG’’:ti,ab OR ‘‘World Health Organization’’) AND (‘‘guideline’’:ti,ab OR ‘‘guidelines’’:ti,ab)) | 9,552,835
#3 | ‘‘diphosphonates’’/exp OR ‘‘diphosphonates’’:ti,ab OR ‘‘bisphosphonates’’/exp OR ‘‘bisphosphonates’’:ti,ab OR ‘‘bisphosphonate’’/exp OR ‘‘bisphosphonate’’:ti,ab OR ‘‘alendronate’’/exp OR ‘‘alendronate’’:ti,ab OR ‘‘alendronic acid’’/exp OR ‘‘alendronic acid’’:ti,ab OR ‘‘fosamax’’/exp OR ‘‘fosamax’’:ti,ab OR ‘‘binosto’’/exp OR ‘‘binosto’’:ti,ab OR ‘‘ibandronic acid’’/exp OR ‘‘ibandronic acid’’:ti,ab OR ‘‘ibandronate’’/exp OR ‘‘ibandronate’’:ti,ab OR ‘‘boniva’’/exp OR ‘‘boniva’’:ti,ab OR ‘‘bonviva’’/exp OR ‘‘bonviva’’:ti,ab OR ‘‘bondronat’’/exp OR ‘‘bondronat’’:ti,ab OR ‘‘risedronic acid’’/exp OR ‘‘risedronic acid’’:ti,ab OR ‘‘atelvia’’/exp OR ‘‘atelvia’’:ti,ab OR ‘‘actonel’’/exp OR ‘‘actonel’’:ti,ab OR ‘‘risedronate’’/exp OR ‘‘risedronate’’:ti,ab OR ‘‘zoledronic acid’’/exp OR ‘‘zoledronic acid’’:ti,ab OR ‘‘zometa’’/exp OR ‘‘zometa’’:ti,ab OR ‘‘zoledronate’’/exp OR ‘‘zoledronate’’:ti,ab OR ‘‘reclast’’/exp OR ‘‘reclast’’:ti,ab OR ‘‘abaloparatide’’/exp OR ‘‘abaloparatide’’:ti,ab OR ‘‘tymlos’’/exp OR ‘‘tymlos’’:ti,ab OR ‘‘teriparatide’’/exp OR ‘‘teriparatide’’:ti,ab OR ‘‘forteo’’/exp OR ‘‘forteo’’:ti,ab OR ‘‘parathar’’/exp OR ‘‘parathar’’:ti,ab OR ‘‘romosozumab’’/exp OR ‘‘romosozumab’’:ti,ab OR ‘‘evenity’’/exp OR ‘‘evenity’’:ti,ab OR ‘‘sclerostin inhibitor’’/exp OR ‘‘sclerostin inhibitor’’:ti,ab OR ‘‘denosumab’’/exp OR ‘‘denosumab’’:ti,ab OR ‘‘prolia’’/exp OR ‘‘prolia’’:ti,ab OR ‘‘xgeva’’/exp OR ‘‘xgeva’’:ti,ab OR ‘‘rank ligand’’/exp OR ‘‘rank ligand’’:ti,ab OR ‘‘osteoprotegerin ligand’’/exp OR ‘‘osteoprotegerin ligand’’:ti,ab OR ‘‘trance protein’’:ti,ab OR ‘‘rankl protein’’:ti,ab OR ‘‘osteoclast differentiation factor’’/exp OR ‘‘osteoclast differentiation factor’’:ti,ab | 97,487
#4 | #1 AND (#2 OR #3) | 29,710
#5 | #4 AND ([cochrane review]/lim OR [systematic review]/lim OR [meta analysis]/lim OR [controlled clinical trial]/lim OR [randomized controlled trial]/lim OR ‘‘observational study’’/exp OR ‘‘cohort studies’’/exp OR ‘‘follow-up studies’’/exp OR ‘‘longitudinal studies’’/exp OR ‘‘prospective studies’’/exp OR ‘‘case-control studies’’/exp OR ‘‘retrospective studies’’/exp OR ‘‘adverse effects’’/exp) | 15,163
#6 | #1 AND #2 AND (‘‘predictive value of tests’’/exp OR ‘‘predictive value of tests’’ OR ‘‘logistic models’’/exp OR ‘‘logistic models’’ OR ‘‘sensitivity next specificity’’ OR ‘‘roc curve’’/exp OR ‘‘roc curve’’ OR ‘‘proportional hazards models’’/exp OR ‘‘proportional hazards models’’ OR ‘‘area under curve’’/exp OR ‘‘area under curve’’ OR ‘‘analysis of variance’’/exp OR ‘‘analysis of variance’’ OR ‘‘models, statistical’’/exp OR ‘‘fracture prediction’’ OR ‘‘reproducibility of results’’/exp OR ‘‘reproducibility of results’’ OR ‘‘accuracy’’/exp OR ‘‘accuracy’’ OR ‘‘discrimination’’/exp OR ‘‘discrimination’’ OR ‘‘discriminant validity’’/exp OR ‘‘discriminant validity’’ OR ‘‘goodness-of-fit’’ OR ‘‘hosmer-lemeshow’’ OR ‘‘c-statistic*’’ OR ‘‘cstatistic*’’ OR ‘‘calibrat*’’ OR ((‘‘accurac*’’ OR ‘‘reliability’’ OR ‘‘validity’’ OR ‘‘value*’’) NEAR/4 ‘‘predict*’’) OR ((‘‘accurac*’’ OR ‘‘effectiveness’’ OR ‘‘efficac*’’ OR ‘‘error*’’ OR ‘‘perform*’’ OR ‘‘reliability’’ OR ‘‘validity’’ OR ‘‘value’’ OR ‘‘yield*’’) NEAR/4 ‘‘diagnostic*’’) OR ‘‘receiver operat*’’) | 3,325
| ((#5 OR #6) AND ‘‘osteoporosis’’/dm AND ‘‘article’’/it) NOT [medline]/lim | 903

### Bridge Search PubMed, July 1, 2021, through November 10, 2022

Search | Query | Results
#1 | “Osteoporosis”[mh] OR “Osteoporotic Fractures”[mh] OR “Fractures, Bone/prevention and control”[mh:noexp] OR “Decalcification, Pathologic”[mh] OR ((“Bone Diseases, Metabolic”[mh:noexp] OR “Osteoporosis”[tiab] OR “Osteoporoses”[tiab] OR “osteoporotic”[tiab] OR “osteopenia”[tiab] OR “Age-Related Bone Loss”[tiab] OR “Age-Related Bone Losses”[tiab] OR “Calcaneus”[mh] OR “Menopause”[mh] OR “menopause”[tiab] OR “menopausal”[tiab] OR “postmenopause”[tiab] OR “postmenopausal”[tiab] OR “perimenopause”[tiab] OR “perimenopausal”[tiab] OR “Risk Factors”[Mesh]) AND (“Bone Density”[mh] OR “bone mineral density”[tiab] OR “bone density”[tiab] OR “density of bone”[tiab] OR “density of bones”[tiab] OR “bone loss”[tiab] OR “bone mass”[tiab] OR “brittle bone”[tiab] OR “brittle bones”[tiab] OR “fragile bone”[tiab] OR “fragile bones”[tiab] OR “broken bone”[tiab] OR “broken bones”[tiab] OR “bone health”[tiab] OR “health of bones”[tiab] OR “fractures, bone”[mh] OR “hip fractures”[mh] OR “spinal fractures”[mh] OR “fractures, spontaneous”[mh] OR “femoral fractures”[mh] OR “humeral fractures”[mh] OR “radius fractures”[mh] OR “ulna fractures”[mh] OR “fracture”[tiab] OR “fractures”[tiab] OR “fractured”[tiab] OR “bone turnover”[tiab] OR “bone resorption”[tiab] OR (“bone”[tiab] AND preserve*[tiab]) OR “bone formation”[tiab])) | 118,277
#2 | #1 AND (English[lang] AND (“2021/07/01”[Date - MeSH] : “3000”[Date - MeSH])) NOT (animals[mh] NOT humans[mh]) NOT (rat[ti] OR rats[ti] OR mouse[ti] OR mice[ti]) | 8,340
#3 | #2 AND (“mass screening”[mh:noexp] OR “Diagnostic Screening Programs”[mh] OR “diagnostic imaging”[Subheading] OR “algorithms”[mh:noexp] OR “Surveys and Questionnaires”[mh] OR “risk assessment”[mh] OR screening[ti] OR screening[ot] OR “Absorptiometry, Photon”[mh] OR “Dual-Energy X-Ray Absorptiometry Scan”[tiab] OR “DXA”[tiab] OR “DEXA”[tiab] OR “Densitometry”[mh] OR “densitometry”[tiab] OR “Age Bulk One or Never Estrogens”[tiab] OR “ABONE”[tiab] OR “body weight criterion”[tiab] OR “BWC”[tiab] OR “Brown’s clinical risk assessment”[tiab] OR “Canadian Risk for Osteoporosis Calculator”[tiab] OR “CAROC”[tiab] OR “fracture absolute risk assessment”[tiab] OR “FARA”[tiab] OR “fracture risk assessment”[tiab] OR “FRAX”[tiab] OR “fracture risk score”[tiab] OR “fracture risk calculator”[tiab] OR “fracture risk tool”[tiab] OR “risk assessment”[ti] OR “risk assessment”[ot] OR “predictive model*”[tiab] OR “prognostic model*”[tiab] OR “Garvan”[tiab] OR “Hong Kong Osteoporosis Study”[tiab] OR “HKOS”[tiab] OR “Male Osteoporosis Risk Estimation Score”[tiab] OR “MORES”[tiab] OR “Osteoporosis Self-assessment Tool”[tiab] OR “OST”[tiab] OR “OSTA”[tiab] OR “OSTAi”[tiab] OR “risk assessment instrument”[tiab] OR “ORAI”[tiab] OR “Osteoporosis Index of Risk”[tiab] OR “OSIRIS”[tiab] OR “Q fracture”[tiab] OR “osteoporosis risk estimate”[tiab] OR “Study of Osteoporotic Fractures”[tiab] OR “SOF”[tiab] OR “SOFSURF”[tiab] OR “Weight-only-EPIDOS”[tiab] OR ((“American Society for Bone and Mineral Research”[tiab] OR “ASBMR”[tiab] OR “International Society for Clinical Densitometry”[tiab] OR “ISCD”[tiab] OR “National Osteoporosis Foundation”[tiab] OR “National Osteoporosis Guideline Group”[tiab] OR “NOGG”[tiab] OR “World Health Organization”[tiab]) AND (“guideline”[tiab] OR “guidelines”[tiab]))) | 2,805
#4 | #2 AND (“Diphosphonates”[mh:noexp] OR “Bisphosphonates”[tiab] OR “Bisphosphonate”[tiab] OR “Alendronate”[mh] OR “Alendronate”[tiab] or “alendronic acid”[tiab] OR “Fosamax”[tiab] OR “Binosto”[tiab] OR “Ibandronic Acid”[mh] OR “Ibandronic Acid”[tiab] OR “Ibandronate”[tiab] OR “Boniva”[tiab] OR “Bonviva”[tiab] OR “Bondronat”[tiab] OR “Risedronic Acid”[mh] OR “Risedronic Acid”[tiab] OR “Atelvia”[tiab] OR “Actonel”[tiab] OR “Risedronate”[tiab] OR “Zoledronic Acid”[mh] OR “Zoledronic Acid”[tiab] OR “Zometa”[tiab] OR “Zoledronate”[tiab] OR “Reclast”[tiab] OR “abaloparatide”[Supplementary Concept] OR “abaloparatide”[tiab] OR “Tymlos”[tiab] OR “Teriparatide”[mh] OR “Teriparatide”[tiab] OR “Forteo”[tiab] OR “Parathar”[tiab] OR “romosozumab”[Supplementary Concept] OR “romosozumab”[tiab] OR “evenity”[tiab] OR “sclerostin inhibitor”[tiab] OR “Denosumab”[mh] OR “Denosumab”[tiab] OR “Prolia”[tiab] OR “Xgeva”[tiab] OR “RANK Ligand”[mh] OR “RANK Ligand”[tiab] OR “Osteoprotegerin Ligand”[tiab] OR “TRANCE Protein”[tiab] OR “RANKL Protein”[tiab] OR “Osteoclast Differentiation Factor”[tiab]) | 1,066
#5 | (#3 OR #4) AND (“randomized controlled trial”[pt] OR “controlled clinical trial”[pt] OR “random allocation”[mh] OR “randomized”[tiab] OR “randomized”[tiab] OR “randomization”[tiab] OR “randomization”[tiab] OR “randomly”[tiab] OR “placebos”[mh] OR placebo[tiab] OR placebos[tiab] OR “multicenter study”[pt] OR “comparative study”[pt] OR “comparative study”[tiab] OR “comparative”[ti] OR “clinical study”[pt:noexp] OR “clinical trial”[pt] OR “clinical trials as topic”[mh] OR “clinical protocols”[mh] OR “clinical trial”[tiab] OR “clinical trials”[tiab] OR ((trial[tiab] OR trials[tiab] OR study[tiab] OR studies[tiab]) AND (“control”[tiab] OR “controlled”[tiab] OR “controls”[tiab] OR group[tiab] OR groups[tiab] OR volunteer*[tiab] OR cohort[tiab] OR cohorts[tiab])) OR “single-blind method”[mh] OR single blind*[tiab] OR “double-blind method”[mh] OR double blind*[tiab] OR triple blind*[tiab] OR ((singl*[tiab] OR doubl*[tiab] OR trebl*[tiab] OR tripl*[tiab]) AND (mask*[tiab] OR blind* [tiab])) OR “treatment outcome”[mh] OR “evaluation studies”[pt] OR “evaluation studies as topic”[mh] OR “evaluation study”[tiab] OR “evaluation studies”[tiab] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR systematic[sb] OR “systematic review”[tiab] OR “meta-analysis”[pt] OR meta-analysis[mh] OR “meta-analysis as topic”[mh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “survival analysis”[mh] OR “systematic overview”[tiab] OR “quantitative review”[tiab] OR “quantitative synthesis”[tiab] OR “quantitative syntheses”[tiab] OR “pooled analysis”[tiab] OR “pooled analyses”[tiab] OR “meta-regression”[tiab] OR “data synthesis”[tiab] OR “data syntheses”[tiab] OR “data extraction”[tiab] OR “data abstraction”[tiab] OR “fixed effect”[tiab] OR “fixed effects”[tiab] OR “indirect comparison”[tiab] OR ((“indirect treatment”[tiab] OR “mixed-treatment”[tiab]) AND (“comparison”[tiab] OR “comparisons”[tiab])) OR “comparative efficacy”[tiab] OR “comparative effectiveness”[tiab]) | 2,044
#6 | (#3 OR #4) AND (“observational study”[pt] OR “observational studies as topic”[mh] OR “observation”[mh] OR “observational”[tiab] OR “cohort studies”[mh] OR “cohort”[tiab] OR “cohorts”[tiab] OR “concurrent study”[tiab] OR “concurrent studies”[tiab] OR “incidence study”[tiab] OR “incidence studies”[tiab] OR “follow-up studies”[mh] OR “follow-up”[tiab] OR “followup”[tiab] OR “longitudinal studies”[mh] OR “longitudinal”[tiab] OR “longitudinally”[tiab] OR “prospective studies”[mh] OR “prospective”[tiab] OR “prospectively”[tiab] OR “case-control studies”[mh] OR “case-control”[tiab] OR “case-crossover”[tiab] OR “retrospective studies”[mh] OR “retrospective”[tiab] OR “nonexperimental”[tiab] OR “non-experimental”[tiab] OR “nonrandomized”[tiab] OR “nonrandomized”[tiab] OR “non-randomised”[tiab] OR “nonrandomized”[tiab] OR “adverse effects”[subheading]) | 2,002
#7 | #3 AND (“predictive value of tests”[mh] OR “models, statistical”[mh] OR “logistic models”[mh] OR “logistic models”[mh] OR “sensitivity and specificity”[mh] OR “roc curve”[mh] OR “proportional hazards models”[mh] OR “area under curve”[mh] OR “analysis of variance”[mh] OR “models, statistical”[mh] OR “fracture prediction”[ot] OR “reproducibility of results”[mh] OR “accuracy”[tiab] OR “discrimination”[tiab] OR “discriminant validity”[tiab] OR “goodness-of-fit”[tiab] OR “Hosmer-Lemeshow”[tiab] OR “c-statistic*”[tiab] OR “cstatistic*”[tiab] OR “calibrat*”[tiab] OR ((“accurac*”[tiab] OR “reliability”[tiab] OR “validity”[tiab] OR “value*”[tiab]) AND “predict*”[tiab]) OR ((“accurac*”[tiab] OR “effectiveness”[tiab] OR “efficac*”[tiab] OR “error*”[tiab] OR “perform*”[tiab] OR “reliability”[tiab] OR “validity”[tiab] OR “value”[tiab] OR “yield*”[tiab]) AND “diagnostic*”[tiab]) OR “receiver operat*”[tiab]) | 620
#9 | #5 OR #6 OR #7 | 2,773

### Bridge Search Cochrane Central 2020 through November 10, 2022

Search | Query | Results
#1 | [mh “Osteoporosis”] OR [mh “Osteoporotic Fractures”] OR [mh ^“Fractures, Bone”/PC] OR [mh “Decalcification, Pathologic”] OR (([mh ^“Bone Diseases, Metabolic”] OR “Osteoporosis”:ti,ab,kw OR “Osteoporoses”:ti,ab,kw OR “osteoporotic”:ti,ab,kw OR “osteopenia”:ti,ab,kw OR “Age-Related Bone Loss”:ti,ab,kw OR “Age-Related Bone Losses”:ti,ab,kw OR [mh “Calcaneus”] OR [mh “Menopause”] OR “menopause”:ti,ab,kw OR “menopausal”:ti,ab,kw OR “postmenopause”:ti,ab,kw OR “postmenopausal”:ti,ab,kw OR “perimenopause”:ti,ab,kw OR “perimenopausal”:ti,ab,kw OR [mh “Risk Factors”]) AND ([mh “Bone Density”] OR “bone mineral density”:ti,ab,kw OR “bone density”:ti,ab,kw OR “density of bone”:ti,ab,kw OR “density of bones”:ti,ab,kw OR “bone loss”:ti,ab,kw OR “bone mass”:ti,ab,kw OR “brittle bone”:ti,ab,kw OR “brittle bones”:ti,ab,kw OR “fragile bone”:ti,ab,kw OR “fragile bones”:ti,ab,kw OR “broken bone”:ti,ab,kw OR “broken bones”:ti,ab,kw OR “bone health”:ti,ab,kw OR “health of bones”:ti,ab,kw OR [mh “fractures, bone”] OR [mh “hip fractures”] OR [mh “spinal fractures”] OR [mh “fractures, spontaneous”] OR [mh “femoral fractures”] OR [mh “humeral fractures”] OR [mh “radius fractures”] OR [mh “ulna fractures”] OR “fracture”:ti,ab,kw OR “fractures”:ti,ab,kw OR “fractured”:ti,ab,kw OR “bone turnover”:ti,ab,kw OR “bone resorption”:ti,ab,kw OR (“bone” NEAR preserve*):ti,ab,kw OR “bone formation”:ti,ab,kw)) | 12,906
#2 | [mh ^“mass screening”] OR [mh “Diagnostic Screening Programs”] OR [mh ^“algorithms”] OR [mh “Surveys and Questionnaires”] OR [mh “risk assessment”] OR “screening”:ti OR [mh “Absorptiometry, Photon”] OR “Dual-Energy X-Ray Absorptiometry Scan”:ti,ab,kw OR “DXA”:ti,ab,kw OR “DEXA”:ti,ab,kw OR [mh “Densitometry”] OR “densitometry”:ti,ab,kw OR “Age Bulk One or Never Estrogens”:ti,ab,kw OR “ABONE”:ti,ab,kw OR “body weight criterion”:ti,ab,kw OR “BWC”:ti,ab,kw OR “Brown’s clinical risk assessment”:ti,ab,kw OR “Canadian Risk for Osteoporosis Calculator”:ti,ab,kw OR “CAROC”:ti,ab,kw OR “fracture absolute risk assessment”:ti,ab,kw OR “FARA”:ti,ab,kw OR “fracture risk assessment”:ti,ab,kw OR “FRAX”:ti,ab,kw OR “fracture risk score”:ti,ab,kw OR “fracture risk calculator”:ti,ab,kw OR “fracture risk tool”:ti,ab,kw OR “risk assessment”:ti,ab,kw OR (predictive NEXT model*):ti,ab,kw OR (prognostic NEXT model*):ti,ab,kw OR “Garvan”:ti,ab,kw OR “Hong Kong Osteoporosis Study”:ti,ab,kw OR “HKOS”:ti,ab,kw OR “Male Osteoporosis Risk Estimation Score”:ti,ab,kw OR “MORES”:ti,ab,kw OR “Osteoporosis Self-assessment Tool”:ti,ab,kw OR “OST”:ti,ab,kw OR “OSTA”:ti,ab,kw OR “OSTAi”:ti,ab,kw OR “risk assessment instrument”:ti,ab,kw OR “ORAI”:ti,ab,kw OR “Osteoporosis Index of Risk”:ti,ab,kw OR “OSIRIS”:ti,ab,kw OR “Q fracture”:ti,ab,kw OR “osteoporosis risk estimate”:ti,ab,kw OR “Study of Osteoporotic Fractures”:ti,ab,kw OR “SOF”:ti,ab,kw OR “SOFSURF”:ti,ab,kw OR “Weight-only-EPIDOS”:ti,ab,kw OR (“American Society for Bone and Mineral Research” OR “ASBMR” OR “International Society for Clinical Densitometry” OR “ISCD” OR “National Osteoporosis Foundation” OR “National Osteoporosis Guideline Group” OR “NOGG” OR “World Health Organization” NEAR “guideline” OR “guidelines”):ti,ab,kw | 143,262
#3 | [mh ^“Diphosphonates”] OR “Bisphosphonates”:ti,ab,kw OR “Bisphosphonate”:ti,ab,kw OR [mh “Alendronate”] OR “Alendronate”:ti,ab,kw OR “alendronic acid”:ti,ab,kw OR “Fosamax”:ti,ab,kw OR “Binosto”:ti,ab,kw OR [mh “Ibandronic Acid”] OR “Ibandronic Acid”:ti,ab,kw OR “Ibandronate”:ti,ab,kw OR “Boniva”:ti,ab,kw OR “Bonviva”:ti,ab,kw OR “Bondronat”:ti,ab,kw OR [mh “Risedronic Acid”] OR “Risedronic Acid”:ti,ab,kw OR “Atelvia”:ti,ab,kw OR “Actonel”:ti,ab,kw OR “Risedronate”:ti,ab,kw OR [mh “Zoledronic Acid”] OR “Zoledronic Acid”:ti,ab,kw OR “Zometa”:ti,ab,kw OR “Zoledronate”:ti,ab,kw OR “Reclast”:ti,ab,kw OR [mh “abaloparatide”] OR “abaloparatide”:ti,ab,kw OR “Tymlos”:ti,ab,kw OR [mh “Teriparatide”] OR “Teriparatide”:ti,ab,kw OR “Forteo”:ti,ab,kw OR “Parathar”:ti,ab,kw OR [mh “romosozumab”] OR “romosozumab”:ti,ab,kw OR “evenity”:ti,ab,kw OR “sclerostin inhibitor”:ti,ab,kw OR [mh “Denosumab”] OR “Denosumab”:ti,ab,kw OR “Prolia”:ti,ab,kw OR “Xgeva”:ti,ab,kw OR [mh “RANK Ligand”] OR “RANK Ligand”:ti,ab,kw OR “Osteoprotegerin Ligand”:ti,ab,kw OR “TRANCE Protein”:ti,ab,kw OR “RANKL Protein”:ti,ab,kw OR “Osteoclast Differentiation Factor”:ti,ab,kw | 6,891
#4 | #1 AND (OR #2-#3); with Publication Year from 2020 to 2022, in Trials | 692

### Bridge Search Embase 2021 through November 10, 2022

Search | Query | Results
#1 | ‘osteoporosis’/de OR ‘fragility fracture’/de OR ((‘metabolic bone disease’/de OR ‘bone demineralization’/de OR ‘Osteoporosis’:ti,ab OR ‘Osteoporoses’:ti,ab OR ‘osteoporotic’:ti,ab OR ‘osteopenia’:ti,ab OR ‘Age-Related Bone Loss’:ti,ab OR ‘Age-Related Bone Losses’:ti,ab OR ‘calcaneus’/exp OR ‘menopause and climacterium’/exp OR ‘menopause’:ti,ab OR ‘menopausal’:ti,ab OR ‘postmenopause’:ti,ab OR ‘postmenopausal’:ti,ab OR ‘perimenopause’:ti,ab OR ‘perimenopausal’:ti,ab OR ‘risk factor’/exp) AND (‘bone density’/exp OR ‘bone mineral density’:ti,ab OR ‘bone density’:ti,ab OR ‘density of bone’:ti,ab OR ‘density of bones’:ti,ab OR ‘bone loss’:ti,ab OR ‘bone mass’:ti,ab OR ‘brittle bone’:ti,ab OR ‘brittle bones’:ti,ab OR ‘fragile bone’:ti,ab OR ‘fragile bones’:ti,ab OR ‘broken bone’:ti,ab OR ‘broken bones’:ti,ab OR ‘bone health’:ti,ab OR ‘health of bones’:ti,ab OR ‘fracture’/exp OR ‘fracture’:ti,ab OR ‘fractures’:ti,ab OR ‘fractured’:ti,ab OR ‘bone turnover’:ti,ab OR ‘bone resorption’:ti,ab OR (‘bone’ NEAR/6 preserve*):ti,ab OR ‘bone formation’:ti,ab)) AND [humans]/lim AND [english]/lim AND [2021-2022]/py | 17,571
#2 | ‘mass screening’/exp OR ‘mass screening’:ti,ab OR ‘diagnostic screening programs’/exp OR ‘diagnostic screening’:ti,ab OR ‘diagnostic imaging’/exp OR ‘diagnostic imaging’:ti,ab OR ‘algorithms’/de OR ‘algorithms’:ti,ab OR ‘surveys and questionnaires’/de OR ‘surveys and questionnaires’:ti,ab OR ‘screening’/exp OR screening OR ‘photon absorptiometry’/exp OR ‘photon absorptiometry’:ti,ab OR ‘dual-energy x-ray absorptiometry scan’:ti,ab OR ‘dxa’/exp OR ‘dxa’:ti,ab OR ‘dexa’/exp OR ‘dexa’:ti,ab OR ‘densitometry’/exp OR ‘densitometry’:ti,ab OR ‘age bulk one or never estrogens’:ti,ab OR ‘abone’:ti,ab OR ‘body weight criterion’:ti,ab OR ‘bwc’:ti,ab OR ‘clinical risk assessment’:ti,ab OR ‘canadian risk for osteoporosis calculator’:ti,ab OR ‘caroc’:ti,ab OR ‘fracture absolute risk assessment’:ti,ab OR ‘fara’:ti,ab OR ‘fracture risk assessment’/exp OR ‘fracture risk assessment’:ti,ab OR ‘frax’/exp OR ‘frax’:ti,ab OR ‘fracture risk score’:ti,ab OR ‘fracture risk calculator’/exp OR ‘fracture risk calculator’:ti,ab OR ‘fracture risk tool’:ti,ab OR ‘risk assessment’/exp OR ‘risk assessment’:ti,ab OR ‘predictive model*’:ti,ab OR ‘prognostic model*’:ti,ab OR ‘garvan’:ti,ab OR ‘hong kong osteoporosis study’:ti,ab OR ‘hkos’:ti,ab OR ‘male osteoporosis risk estimation score’:ti,ab OR ‘mores’:ti,ab OR ‘osteoporosis self-assessment tool’:ti,ab OR ‘ost’:ti,ab OR ‘osta’:ti,ab OR ‘ostai’:ti,ab OR ‘risk assessment instrument’:ti,ab OR ‘orai’:ti,ab OR ‘osteoporosis index of risk’:ti,ab OR ‘osiris’:ti,ab OR ‘q fracture’:ti,ab OR ‘osteoporosis risk estimate’:ti,ab OR ‘study of osteoporotic fractures’:ti,ab OR ‘sof’:ti,ab OR ‘sofsurf’:ti,ab OR ‘weight-only-epidos’:ti,ab OR ((‘American Society for Bone and Mineral Research’:ti,ab OR ‘ASBMR’:ti,ab OR ‘International Society for Clinical Densitometry’:ti,ab OR ‘ISCD’:ti,ab OR ‘National Osteoporosis Foundation’:ti,ab OR ‘National Osteoporosis Guideline Group’:ti,ab OR ‘NOGG’:ti,ab OR ‘World Health Organization’) AND (‘guideline’:ti,ab OR ‘guidelines’:ti,ab)) | 10,393,945
#3 | ‘diphosphonates’/exp OR ‘diphosphonates’:ti,ab OR ‘bisphosphonates’/exp OR ‘bisphosphonates’:ti,ab OR ‘bisphosphonate’/exp OR ‘bisphosphonate’:ti,ab OR ‘alendronate’/exp OR ‘alendronate’:ti,ab OR ‘alendronic acid’/exp OR ‘alendronic acid’:ti,ab OR ‘fosamax’/exp OR ‘fosamax’:ti,ab OR ‘binosto’/exp OR ‘binosto’:ti,ab OR ‘ibandronic acid’/exp OR ‘ibandronic acid’:ti,ab OR ‘ibandronate’/exp OR ‘ibandronate’:ti,ab OR ‘boniva’/exp OR ‘boniva’:ti,ab OR ‘bonviva’/exp OR ‘bonviva’:ti,ab OR ‘bondronat’/exp OR ‘bondronat’:ti,ab OR ‘risedronic acid’/exp OR ‘risedronic acid’:ti,ab OR ‘atelvia’/exp OR ‘atelvia’:ti,ab OR ‘actonel’/exp OR ‘actonel’:ti,ab OR ‘risedronate’/exp OR ‘risedronate’:ti,ab OR ‘zoledronic acid’/exp OR ‘zoledronic acid’:ti,ab OR ‘zometa’/exp OR ‘zometa’:ti,ab OR ‘zoledronate’/exp OR ‘zoledronate’:ti,ab OR ‘reclast’/exp OR ‘reclast’:ti,ab OR ‘abaloparatide’/exp OR ‘abaloparatide’:ti,ab OR ‘tymlos’/exp OR ‘tymlos’:ti,ab OR ‘teriparatide’/exp OR ‘teriparatide’:ti,ab OR ‘forteo’/exp OR ‘forteo’:ti,ab OR ‘parathar’/exp OR ‘parathar’:ti,ab OR ‘romosozumab’/exp OR ‘romosozumab’:ti,ab OR ‘evenity’/exp OR ‘evenity’:ti,ab OR ‘sclerostin inhibitor’/exp OR ‘sclerostin inhibitor’:ti,ab OR ‘denosumab’/exp OR ‘denosumab’:ti,ab OR ‘prolia’/exp OR ‘prolia’:ti,ab OR ‘xgeva’/exp OR ‘xgeva’:ti,ab OR ‘rank ligand’/exp OR ‘rank ligand’:ti,ab OR ‘osteoprotegerin ligand’/exp OR ‘osteoprotegerin ligand’:ti,ab OR ‘trance protein’:ti,ab OR ‘rankl protein’:ti,ab OR ‘osteoclast differentiation factor’/exp OR ‘osteoclast differentiation factor’:ti,ab | 105,192
#4 | #1 AND (#2 OR #3) | 11,133
#5 | #4 AND ([cochrane review]/lim OR [systematic review]/lim OR [meta analysis]/lim OR [controlled clinical trial]/lim OR [randomized controlled trial]/lim OR ‘observational study’/exp OR ‘cohort studies’/exp OR ‘follow-up studies’/exp OR ‘longitudinal studies’/exp OR ‘prospective studies’/exp OR ‘case-control studies’/exp OR ‘retrospective studies’/exp OR ‘adverse effects’/exp) | 6,478
#6 | #1 AND #2 AND (‘predictive value of tests’/exp OR ‘predictive value of tests’ OR ‘logistic models’/exp OR ‘logistic models’ OR ‘sensitivity next specificity’ OR ‘roc curve’/exp OR ‘roc curve’ OR ‘proportional hazards models’/exp OR ‘proportional hazards models’ OR ‘area under curve’/exp OR ‘area under curve’ OR ‘analysis of variance’/exp OR ‘analysis of variance’ OR ‘models, statistical’/exp OR ‘fracture prediction’ OR ‘reproducibility of results’/exp OR ‘reproducibility of results’ OR ‘accuracy’/exp OR ‘accuracy’ OR ‘discrimination’/exp OR ‘discrimination’ OR ‘discriminant validity’/exp OR ‘discriminant validity’ OR ‘goodness-of-fit’ OR ‘hosmer-lemeshow’ OR ‘c-statistic*’ OR ‘cstatistic*’ OR ‘calibrat*’ OR ((‘accurac*’ OR ‘reliability’ OR ‘validity’ OR ‘value*’) NEAR/4 ‘predict*’) OR ((‘accurac*’ OR ‘effectiveness’ OR ‘efficac*’ OR ‘error*’ OR ‘perform*’ OR ‘reliability’ OR ‘validity’ OR ‘value’ OR ‘yield*’) NEAR/4 ‘diagnostic*’) OR ‘receiver operat*’) | 1,676
#7 | ((#5 OR #6) AND ‘osteoporosis’/dm AND ‘article’/it) NOT [medline]/lim | 849

### Bridge Search PubMed August 1, 2022, through January 9, 2024

Search | Query | Results
#1 | “Osteoporosis”[mh] OR “Osteoporotic Fractures”[mh] OR “Fractures, Bone/prevention and control”[mh:noexp] OR “Decalcification, Pathologic”[mh] OR ((“Bone Diseases, Metabolic”[mh:noexp] OR “Osteoporosis”[tiab] OR “Osteoporoses”[tiab] OR “osteoporotic”[tiab] OR “osteopenia”[tiab] OR “Age-Related Bone Loss”[tiab] OR “Age-Related Bone Losses”[tiab] OR “Calcaneus”[mh] OR “Menopause”[mh] OR “menopause”[tiab] OR “menopausal”[tiab] OR “postmenopause”[tiab] OR “postmenopausal”[tiab] OR “perimenopause”[tiab] OR “perimenopausal”[tiab] OR “Risk Factors”[Mesh]) AND (“Bone Density”[mh] OR “bone mineral density”[tiab] OR “bone density”[tiab] OR “density of bone”[tiab] OR “density of bones”[tiab] OR “bone loss”[tiab] OR “bone mass”[tiab] OR “brittle bone”[tiab] OR “brittle bones”[tiab] OR “fragile bone”[tiab] OR “fragile bones”[tiab] OR “broken bone”[tiab] OR “broken bones”[tiab] OR “bone health”[tiab] OR “health of bones”[tiab] OR “fractures, bone”[mh] OR “hip fractures”[mh] OR “spinal fractures”[mh] OR “fractures, spontaneous”[mh] OR “femoral fractures”[mh] OR “humeral fractures”[mh] OR “radius fractures”[mh] OR “ulna fractures”[mh] OR “fracture”[tiab] OR “fractures”[tiab] OR “fractured”[tiab] OR “bone turnover”[tiab] OR “bone resorption”[tiab] OR (“bone”[tiab] AND preserve*[tiab]) OR “bone formation”[tiab])) | 124,382
#2 | #1 AND (English[lang] AND (“2022/08/01”[Date - MeSH] : “3000”[Date - MeSH])) NOT (animals[mh] NOT humans[mh]) NOT (rat[ti] OR rats[ti] OR mouse[ti] OR mice[ti]) | 7,171
#3 | #2 AND (“mass screening”[mh:noexp] OR “Diagnostic Screening Programs”[mh] OR “diagnostic imaging”[Subheading] OR “algorithms”[mh:noexp] OR “Surveys and Questionnaires”[mh] OR “risk assessment”[mh] OR screening[ti] OR screening[ot] OR “Absorptiometry, Photon”[mh] OR “Dual-Energy X-Ray Absorptiometry Scan”[tiab] OR “DXA”[tiab] OR “DEXA”[tiab] OR “Densitometry”[mh] OR “densitometry”[tiab] OR “Age Bulk One or Never Estrogens”[tiab] OR “ABONE”[tiab] OR “body weight criterion”[tiab] OR “BWC”[tiab] OR “Brown’s clinical risk assessment”[tiab] OR “Canadian Risk for Osteoporosis Calculator”[tiab] OR “CAROC”[tiab] OR “fracture absolute risk assessment”[tiab] OR “FARA”[tiab] OR “fracture risk assessment”[tiab] OR “FRAX”[tiab] OR “fracture risk score”[tiab] OR “fracture risk calculator”[tiab] OR “fracture risk tool”[tiab] OR “risk assessment”[ti] OR “risk assessment”[ot] OR “predictive model*”[tiab] OR “prognostic model*”[tiab] OR “Garvan”[tiab] OR “Hong Kong Osteoporosis Study”[tiab] OR “HKOS”[tiab] OR “Male Osteoporosis Risk Estimation Score”[tiab] OR “MORES”[tiab] OR “Osteoporosis Self-assessment Tool”[tiab] OR “OST”[tiab] OR “OSTA”[tiab] OR “OSTAi”[tiab] OR “risk assessment instrument”[tiab] OR “ORAI”[tiab] OR “Osteoporosis Index of Risk”[tiab] OR “OSIRIS”[tiab] OR “Q fracture”[tiab] OR “osteoporosis risk estimate”[tiab] OR “Study of Osteoporotic Fractures”[tiab] OR “SOF”[tiab] OR “SOFSURF”[tiab] OR “Weight-only-EPIDOS”[tiab] OR ((“American Society for Bone and Mineral Research”[tiab] OR “ASBMR”[tiab] OR “International Society for Clinical Densitometry”[tiab] OR “ISCD”[tiab] OR “National Osteoporosis Foundation”[tiab] OR “National Osteoporosis Guideline Group”[tiab] OR “NOGG”[tiab] OR “World Health Organization”[tiab]) AND (“guideline”[tiab] OR “guidelines”[tiab]))) | 2,111
#4 | #2 AND (“Diphosphonates”[mh:noexp] OR “Bisphosphonates”[tiab] OR “Bisphosphonate”[tiab] OR “Alendronate”[mh] OR “Alendronate”[tiab] or “alendronic acid”[tiab] OR “Fosamax”[tiab] OR “Binosto”[tiab] OR “Ibandronic Acid”[mh] OR “Ibandronic Acid”[tiab] OR “Ibandronate”[tiab] OR “Boniva”[tiab] OR “Bonviva”[tiab] OR “Bondronat”[tiab] OR “Risedronic Acid”[mh] OR “Risedronic Acid”[tiab] OR “Atelvia”[tiab] OR “Actonel”[tiab] OR “Risedronate”[tiab] OR “Zoledronic Acid”[mh] OR “Zoledronic Acid”[tiab] OR “Zometa”[tiab] OR “Zoledronate”[tiab] OR “Reclast”[tiab] OR “abaloparatide”[Supplementary Concept] OR “abaloparatide”[tiab] OR “Tymlos”[tiab] OR “Teriparatide”[mh] OR “Teriparatide”[tiab] OR “Forteo”[tiab] OR “Parathar”[tiab] OR “romosozumab”[Supplementary Concept] OR “romosozumab”[tiab] OR “evenity”[tiab] OR “sclerostin inhibitor”[tiab] OR “Denosumab”[mh] OR “Denosumab”[tiab] OR “Prolia”[tiab] OR “Xgeva”[tiab] OR “RANK Ligand”[mh] OR “RANK Ligand”[tiab] OR “Osteoprotegerin Ligand”[tiab] OR “TRANCE Protein”[tiab] OR “RANKL Protein”[tiab] OR “Osteoclast Differentiation Factor”[tiab]) | 841
#5 | (#3 OR #4) AND (“randomized controlled trial”[pt] OR “controlled clinical trial”[pt] OR “random allocation”[mh] OR “randomized”[tiab] OR “randomized”[tiab] OR “randomization”[tiab] OR “randomization”[tiab] OR “randomly”[tiab] OR “placebos”[mh] OR placebo[tiab] OR placebos[tiab] OR “multicenter study”[pt] OR “comparative study”[pt] OR “comparative study”[tiab] OR “comparative”[ti] OR “clinical study”[pt:noexp] OR “clinical trial”[pt] OR “clinical trials as topic”[mh] OR “clinical protocols”[mh] OR “clinical trial”[tiab] OR “clinical trials”[tiab] OR ((trial[tiab] OR trials[tiab] OR study[tiab] OR studies[tiab]) AND (“control”[tiab] OR “controlled”[tiab] OR “controls”[tiab] OR group[tiab] OR groups[tiab] OR volunteer*[tiab] OR cohort[tiab] OR cohorts[tiab])) OR “single-blind method”[mh] OR single blind*[tiab] OR “double-blind method”[mh] OR double blind*[tiab] OR triple blind*[tiab] OR ((singl*[tiab] OR doubl*[tiab] OR trebl*[tiab] OR tripl*[tiab]) AND (mask*[tiab] OR blind* [tiab])) OR “treatment outcome”[mh] OR “evaluation studies”[pt] OR “evaluation studies as topic”[mh] OR “evaluation study”[tiab] OR “evaluation studies”[tiab] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR systematic[sb] OR “systematic review”[tiab] OR “meta-analysis”[pt] OR meta-analysis[mh] OR “meta-analysis as topic”[mh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “survival analysis”[mh] OR “systematic overview”[tiab] OR “quantitative review”[tiab] OR “quantitative synthesis”[tiab] OR “quantitative syntheses”[tiab] OR “pooled analysis”[tiab] OR “pooled analyses”[tiab] OR “meta-regression”[tiab] OR “data synthesis”[tiab] OR “data syntheses”[tiab] OR “data extraction”[tiab] OR “data abstraction”[tiab] OR “fixed effect”[tiab] OR “fixed effects”[tiab] OR “indirect comparison”[tiab] OR ((“indirect treatment”[tiab] OR “mixed-treatment”[tiab]) AND (“comparison”[tiab] OR “comparisons”[tiab])) OR “comparative efficacy”[tiab] OR “comparative effectiveness”[tiab]) | 1,502
#6 | (#3 OR #4) AND (“observational study”[pt] OR “observational studies as topic”[mh] OR “observation”[mh] OR “observational”[tiab] OR “cohort studies”[mh] OR “cohort”[tiab] OR “cohorts”[tiab] OR “concurrent study”[tiab] OR “concurrent studies”[tiab] OR “incidence study”[tiab] OR “incidence studies”[tiab] OR “follow-up studies”[mh] OR “follow-up”[tiab] OR “followup”[tiab] OR “longitudinal studies”[mh] OR “longitudinal”[tiab] OR “longitudinally”[tiab] OR “prospective studies”[mh] OR “prospective”[tiab] OR “prospectively”[tiab] OR “case-control studies”[mh] OR “case-control”[tiab] OR “case-crossover”[tiab] OR “retrospective studies”[mh] OR “retrospective”[tiab] OR “nonexperimental”[tiab] OR “non-experimental”[tiab] OR “nonrandomized”[tiab] OR “nonrandomized”[tiab] OR “non-randomised”[tiab] OR “nonrandomized”[tiab] OR “adverse effects”[subheading]) | 1,522
#7 | #3 AND (“predictive value of tests”[mh] OR “models, statistical”[mh] OR “logistic models”[mh] OR “logistic models”[mh] OR “sensitivity and specificity”[mh] OR “roc curve”[mh] OR “proportional hazards models”[mh] OR “area under curve”[mh] OR “analysis of variance”[mh] OR “models, statistical”[mh] OR “fracture prediction”[ot] OR “reproducibility of results”[mh] OR “accuracy”[tiab] OR “discrimination”[tiab] OR “discriminant validity”[tiab] OR “goodness-of-fit”[tiab] OR “Hosmer-Lemeshow”[tiab] OR “c-statistic*”[tiab] OR “cstatistic*”[tiab] OR “calibrat*”[tiab] OR ((“accurac*”[tiab] OR “reliability”[tiab] OR “validity”[tiab] OR “value*”[tiab]) AND “predict*”[tiab]) OR ((“accurac*”[tiab] OR “effectiveness”[tiab] OR “efficac*”[tiab] OR “error*”[tiab] OR “perform*”[tiab] OR “reliability”[tiab] OR “validity”[tiab] OR “value”[tiab] OR “yield*”[tiab]) AND “diagnostic*”[tiab]) OR “receiver operat*”[tiab]) | 530
#8 | #5 OR #6 OR #7 | 2,108

### Bridge Search Cochrane Central 2022 through January 9, 2024

Search | Query | Results
#1 | [mh “Osteoporosis”] OR [mh “Osteoporotic Fractures”] OR [mh ^“Fractures, Bone”/PC] OR [mh “Decalcification, Pathologic”] OR (([mh ^“Bone Diseases, Metabolic”] OR “Osteoporosis”:ti,ab,kw OR “Osteoporoses”:ti,ab,kw OR “osteoporotic”:ti,ab,kw OR “osteopenia”:ti,ab,kw OR “Age-Related Bone Loss”:ti,ab,kw OR “Age-Related Bone Losses”:ti,ab,kw OR [mh “Calcaneus”] OR [mh “Menopause”] OR “menopause”:ti,ab,kw OR “menopausal”:ti,ab,kw OR “postmenopause”:ti,ab,kw OR “postmenopausal”:ti,ab,kw OR “perimenopause”:ti,ab,kw OR “perimenopausal”:ti,ab,kw OR [mh “Risk Factors”]) AND ([mh “Bone Density”] OR “bone mineral density”:ti,ab,kw OR “bone density”:ti,ab,kw OR “density of bone”:ti,ab,kw OR “density of bones”:ti,ab,kw OR “bone loss”:ti,ab,kw OR “bone mass”:ti,ab,kw OR “brittle bone”:ti,ab,kw OR “brittle bones”:ti,ab,kw OR “fragile bone”:ti,ab,kw OR “fragile bones”:ti,ab,kw OR “broken bone”:ti,ab,kw OR “broken bones”:ti,ab,kw OR “bone health”:ti,ab,kw OR “health of bones”:ti,ab,kw OR [mh “fractures, bone”] OR [mh “hip fractures”] OR [mh “spinal fractures”] OR [mh “fractures, spontaneous”] OR [mh “femoral fractures”] OR [mh “humeral fractures”] OR [mh “radius fractures”] OR [mh “ulna fractures”] OR “fracture”:ti,ab,kw OR “fractures”:ti,ab,kw OR “fractured”:ti,ab,kw OR “bone turnover”:ti,ab,kw OR “bone resorption”:ti,ab,kw OR (“bone” NEAR preserve*):ti,ab,kw OR “bone formation”:ti,ab,kw)) | 13,958
#2 | [mh ^“mass screening”] OR [mh “Diagnostic Screening Programs”] OR [mh ^“algorithms”] OR [mh “Surveys and Questionnaires”] OR [mh “risk assessment”] OR “screening”:ti OR [mh “Absorptiometry, Photon”] OR “Dual-Energy X-Ray Absorptiometry Scan”:ti,ab,kw OR “DXA”:ti,ab,kw OR “DEXA”:ti,ab,kw OR [mh “Densitometry”] OR “densitometry”:ti,ab,kw OR “Age Bulk One or Never Estrogens”:ti,ab,kw OR “ABONE”:ti,ab,kw OR “body weight criterion”:ti,ab,kw OR “BWC”:ti,ab,kw OR “Brown’s clinical risk assessment”:ti,ab,kw OR “Canadian Risk for Osteoporosis Calculator”:ti,ab,kw OR “CAROC”:ti,ab,kw OR “fracture absolute risk assessment”:ti,ab,kw OR “FARA”:ti,ab,kw OR “fracture risk assessment”:ti,ab,kw OR “FRAX”:ti,ab,kw OR “fracture risk score”:ti,ab,kw OR “fracture risk calculator”:ti,ab,kw OR “fracture risk tool”:ti,ab,kw OR “risk assessment”:ti,ab,kw OR (predictive NEXT model*):ti,ab,kw OR (prognostic NEXT model*):ti,ab,kw OR “Garvan”:ti,ab,kw OR “Hong Kong Osteoporosis Study”:ti,ab,kw OR “HKOS”:ti,ab,kw OR “Male Osteoporosis Risk Estimation Score”:ti,ab,kw OR “MORES”:ti,ab,kw OR “Osteoporosis Self-assessment Tool”:ti,ab,kw OR “OST”:ti,ab,kw OR “OSTA”:ti,ab,kw OR “OSTAi”:ti,ab,kw OR “risk assessment instrument”:ti,ab,kw OR “ORAI”:ti,ab,kw OR “Osteoporosis Index of Risk”:ti,ab,kw OR “OSIRIS”:ti,ab,kw OR “Q fracture”:ti,ab,kw OR “osteoporosis risk estimate”:ti,ab,kw OR “Study of Osteoporotic Fractures”:ti,ab,kw OR “SOF”:ti,ab,kw OR “SOFSURF”:ti,ab,kw OR “Weight-only-EPIDOS”:ti,ab,kw OR (“American Society for Bone and Mineral Research” OR “ASBMR” OR “International Society for Clinical Densitometry” OR “ISCD” OR “National Osteoporosis Foundation” OR “National Osteoporosis Guideline Group” OR “NOGG” OR “World Health Organization” NEAR “guideline” OR “guidelines”):ti,ab,kw | 164,755
#3 | [mh ^“Diphosphonates”] OR “Bisphosphonates”:ti,ab,kw OR “Bisphosphonate”:ti,ab,kw OR [mh “Alendronate”] OR “Alendronate”:ti,ab,kw OR “alendronic acid”:ti,ab,kw OR “Fosamax”:ti,ab,kw OR “Binosto”:ti,ab,kw OR [mh “Ibandronic Acid”] OR “Ibandronic Acid”:ti,ab,kw OR “Ibandronate”:ti,ab,kw OR “Boniva”:ti,ab,kw OR “Bonviva”:ti,ab,kw OR “Bondronat”:ti,ab,kw OR [mh “Risedronic Acid”] OR “Risedronic Acid”:ti,ab,kw OR “Atelvia”:ti,ab,kw OR “Actonel”:ti,ab,kw OR “Risedronate”:ti,ab,kw OR [mh “Zoledronic Acid”] OR “Zoledronic Acid”:ti,ab,kw OR “Zometa”:ti,ab,kw OR “Zoledronate”:ti,ab,kw OR “Reclast”:ti,ab,kw OR [mh “abaloparatide”] OR “abaloparatide”:ti,ab,kw OR “Tymlos”:ti,ab,kw OR [mh “Teriparatide”] OR “Teriparatide”:ti,ab,kw OR “Forteo”:ti,ab,kw OR “Parathar”:ti,ab,kw OR [mh “romosozumab”] OR “romosozumab”:ti,ab,kw OR “evenity”:ti,ab,kw OR “sclerostin inhibitor”:ti,ab,kw OR [mh “Denosumab”] OR “Denosumab”:ti,ab,kw OR “Prolia”:ti,ab,kw OR “Xgeva”:ti,ab,kw OR [mh “RANK Ligand”] OR “RANK Ligand”:ti,ab,kw OR “Osteoprotegerin Ligand”:ti,ab,kw OR “TRANCE Protein”:ti,ab,kw OR “RANKL Protein”:ti,ab,kw OR “Osteoclast Differentiation Factor”:ti,ab,kw | 7,271
#4 | #1 AND (OR #2-#3); with Publication Year from 2022 to 2024, in Trials | 413

### Bridge Search Embase 2022 through January 9, 2024

Search | Query | Results
#1 | ‘osteoporosis’/de OR ‘fragility fracture’/de OR ((‘metabolic bone disease’/de OR ‘bone demineralization’/de OR ‘Osteoporosis’:ti,ab OR ‘Osteoporoses’:ti,ab OR ‘osteoporotic’:ti,ab OR ‘osteopenia’:ti,ab OR ‘Age-Related Bone Loss’:ti,ab OR ‘Age-Related Bone Losses’:ti,ab OR ‘calcaneus’/exp OR ‘menopause and climacterium’/exp OR ‘menopause’:ti,ab OR ‘menopausal’:ti,ab OR ‘postmenopause’:ti,ab OR ‘postmenopausal’:ti,ab OR ‘perimenopause’:ti,ab OR ‘perimenopausal’:ti,ab OR ‘risk factor’/exp) AND (‘bone density’/exp OR ‘bone mineral density’:ti,ab OR ‘bone density’:ti,ab OR ‘density of bone’:ti,ab OR ‘density of bones’:ti,ab OR ‘bone loss’:ti,ab OR ‘bone mass’:ti,ab OR ‘brittle bone’:ti,ab OR ‘brittle bones’:ti,ab OR ‘fragile bone’:ti,ab OR ‘fragile bones’:ti,ab OR ‘broken bone’:ti,ab OR ‘broken bones’:ti,ab OR ‘bone health’:ti,ab OR ‘health of bones’:ti,ab OR ‘fracture’/exp OR ‘fracture’:ti,ab OR ‘fractures’:ti,ab OR ‘fractured’:ti,ab OR ‘bone turnover’:ti,ab OR ‘bone resorption’:ti,ab OR (‘bone’ NEAR/6 preserve*):ti,ab OR ‘bone formation’:ti,ab)) AND [humans]/lim AND [english]/lim AND [2022-2024]/py | 20,539
#2 | ‘mass screening’/exp OR ‘mass screening’:ti,ab OR ‘diagnostic screening programs’/exp OR ‘diagnostic screening’:ti,ab OR ‘diagnostic imaging’/exp OR ‘diagnostic imaging’:ti,ab OR ‘algorithms’/de OR ‘algorithms’:ti,ab OR ‘surveys and questionnaires’/de OR ‘surveys and questionnaires’:ti,ab OR ‘screening’/exp OR screening OR ‘photon absorptiometry’/exp OR ‘photon absorptiometry’:ti,ab OR ‘dual-energy x-ray absorptiometry scan’:ti,ab OR ‘dxa’/exp OR ‘dxa’:ti,ab OR ‘dexa’/exp OR ‘dexa’:ti,ab OR ‘densitometry’/exp OR ‘densitometry’:ti,ab OR ‘age bulk one or never estrogens’:ti,ab OR ‘abone’:ti,ab OR ‘body weight criterion’:ti,ab OR ‘bwc’:ti,ab OR ‘clinical risk assessment’:ti,ab OR ‘canadian risk for osteoporosis calculator’:ti,ab OR ‘caroc’:ti,ab OR ‘fracture absolute risk assessment’:ti,ab OR ‘fara’:ti,ab OR ‘fracture risk assessment’/exp OR ‘fracture risk assessment’:ti,ab OR ‘frax’/exp OR ‘frax’:ti,ab OR ‘fracture risk score’:ti,ab OR ‘fracture risk calculator’/exp OR ‘fracture risk calculator’:ti,ab OR ‘fracture risk tool’:ti,ab OR ‘risk assessment’/exp OR ‘risk assessment’:ti,ab OR ‘predictive model*’:ti,ab OR ‘prognostic model*’:ti,ab OR ‘garvan’:ti,ab OR ‘hong kong osteoporosis study’:ti,ab OR ‘hkos’:ti,ab OR ‘male osteoporosis risk estimation score’:ti,ab OR ‘mores’:ti,ab OR ‘osteoporosis self-assessment tool’:ti,ab OR ‘ost’:ti,ab OR ‘osta’:ti,ab OR ‘ostai’:ti,ab OR ‘risk assessment instrument’:ti,ab OR ‘orai’:ti,ab OR ‘osteoporosis index of risk’:ti,ab OR ‘osiris’:ti,ab OR ‘q fracture’:ti,ab OR ‘osteoporosis risk estimate’:ti,ab OR ‘study of osteoporotic fractures’:ti,ab OR ‘sof’:ti,ab OR ‘sofsurf’:ti,ab OR ‘weight-only-epidos’:ti,ab OR ((‘American Society for Bone and Mineral Research’:ti,ab OR ‘ASBMR’:ti,ab OR ‘International Society for Clinical Densitometry’:ti,ab OR ‘ISCD’:ti,ab OR ‘National Osteoporosis Foundation’:ti,ab OR ‘National Osteoporosis Guideline Group’:ti,ab OR ‘NOGG’:ti,ab OR ‘World Health Organization’) AND (‘guideline’:ti,ab OR ‘guidelines’:ti,ab)) | 11,145,144
#3 | ‘diphosphonates’/exp OR ‘diphosphonates’:ti,ab OR ‘bisphosphonates’/exp OR ‘bisphosphonates’:ti,ab OR ‘bisphosphonate’/exp OR ‘bisphosphonate’:ti,ab OR ‘alendronate’/exp OR ‘alendronate’:ti,ab OR ‘alendronic acid’/exp OR ‘alendronic acid’:ti,ab OR ‘fosamax’/exp OR ‘fosamax’:ti,ab OR ‘binosto’/exp OR ‘binosto’:ti,ab OR ‘ibandronic acid’/exp OR ‘ibandronic acid’:ti,ab OR ‘ibandronate’/exp OR ‘ibandronate’:ti,ab OR ‘boniva’/exp OR ‘boniva’:ti,ab OR ‘bonviva’/exp OR ‘bonviva’:ti,ab OR ‘bondronat’/exp OR ‘bondronat’:ti,ab OR ‘risedronic acid’/exp OR ‘risedronic acid’:ti,ab OR ‘atelvia’/exp OR ‘atelvia’:ti,ab OR ‘actonel’/exp OR ‘actonel’:ti,ab OR ‘risedronate’/exp OR ‘risedronate’:ti,ab OR ‘zoledronic acid’/exp OR ‘zoledronic acid’:ti,ab OR ‘zometa’/exp OR ‘zometa’:ti,ab OR ‘zoledronate’/exp OR ‘zoledronate’:ti,ab OR ‘reclast’/exp OR ‘reclast’:ti,ab OR ‘abaloparatide’/exp OR ‘abaloparatide’:ti,ab OR ‘tymlos’/exp OR ‘tymlos’:ti,ab OR ‘teriparatide’/exp OR ‘teriparatide’:ti,ab OR ‘forteo’/exp OR ‘forteo’:ti,ab OR ‘parathar’/exp OR ‘parathar’:ti,ab OR ‘romosozumab’/exp OR ‘romosozumab’:ti,ab OR ‘evenity’/exp OR ‘evenity’:ti,ab OR ‘sclerostin inhibitor’/exp OR ‘sclerostin inhibitor’:ti,ab OR ‘denosumab’/exp OR ‘denosumab’:ti,ab OR ‘prolia’/exp OR ‘prolia’:ti,ab OR ‘xgeva’/exp OR ‘xgeva’:ti,ab OR ‘rank ligand’/exp OR ‘rank ligand’:ti,ab OR ‘osteoprotegerin ligand’/exp OR ‘osteoprotegerin ligand’:ti,ab OR ‘trance protein’:ti,ab OR ‘rankl protein’:ti,ab OR ‘osteoclast differentiation factor’/exp OR ‘osteoclast differentiation factor’:ti,ab | 111,931
#4 | #1 AND (#2 OR #3) | 13,017
#5 | #4 AND ([cochrane review]/lim OR [systematic review]/lim OR [meta analysis]/lim OR [controlled clinical trial]/lim OR [randomized controlled trial]/lim OR ‘observational study’/exp OR ‘cohort studies’/exp OR ‘follow-up studies’/exp OR ‘longitudinal studies’/exp OR ‘prospective studies’/exp OR ‘case-control studies’/exp OR ‘retrospective studies’/exp OR ‘adverse effects’/exp) | 7,503
#6 | #1 AND #2 AND (‘predictive value of tests’/exp OR ‘predictive value of tests’ OR ‘logistic models’/exp OR ‘logistic models’ OR ‘sensitivity next specificity’ OR ‘roc curve’/exp OR ‘roc curve’ OR ‘proportional hazards models’/exp OR ‘proportional hazards models’ OR ‘area under curve’/exp OR ‘area under curve’ OR ‘analysis of variance’/exp OR ‘analysis of variance’ OR ‘models, statistical’/exp OR ‘fracture prediction’ OR ‘reproducibility of results’/exp OR ‘reproducibility of results’ OR ‘accuracy’/exp OR ‘accuracy’ OR ‘discrimination’/exp OR ‘discrimination’ OR ‘discriminant validity’/exp OR ‘discriminant validity’ OR ‘goodness-of-fit’ OR ‘hosmer-lemeshow’ OR ‘c-statistic*’ OR ‘cstatistic*’ OR ‘calibrat*’ OR ((‘accurac*’ OR ‘reliability’ OR ‘validity’ OR ‘value*’) NEAR/4 ‘predict*’) OR ((‘accurac*’ OR ‘effectiveness’ OR ‘efficac*’ OR ‘error*’ OR ‘perform*’ OR ‘reliability’ OR ‘validity’ OR ‘value’ OR ‘yield*’) NEAR/4 ‘diagnostic*’) OR ‘receiver operat*’) | 2,251
#7 | ((#5 OR #6) AND ‘osteoporosis’/dm AND ‘article’/it) NOT [medline]/lim | 1,016

## B2 Detailed Eligibility Criteria

Category | Included | Excluded
Population | KQs 1–3 (Screening benefits, accuracy, harms): Adults age 40 years or older without known osteoporosis or history of fragility fractures; KQs 4, 5 (Treatment benefits and harms): Adults age 40 years or older with osteoporosis, low bone mass, or increased fracture risk (as defined by study authors); Studies in which less than 50% of the enrolled population includes persons with conditions or medications listed as excluded will be included, and results will be stratified if possible.; Subpopulations of interest include men, women age 65 years or older, and postmenopausal women younger than 65 years. * | All KQs: Studies that exclusively enroll adults younger than age 40 years; KQs 1–3: Studies that exclusively enroll:; - Adults with known osteoporosis or prior history of fragility fracture; - Adults with cancer, metabolic bone diseases, or medical conditions associated with bone loss, including but not limited to hyperparathyroidism, premature ovarian failure, hypogonadism, untreated hyperthyroidism, acromegaly, adrenal insufficiency, Cushing’s syndrome, celiac disease, inflammatory bowel disease, history of gastric bypass surgery, anorexia, chronic liver disease, multiple myeloma, chronic kidney disease, rheumatoid arthritis, lupus, multiple sclerosis, spinal cord injury; - Adults taking chronic medications associated with bone loss or strengthening, including glucocorticosteroids, select antiepileptic medications, hypogonadism-inducing agents (e.g., aromatase inhibitors, medroxyprogesterone acetate, gonadotropin-releasing hormone agonists), thiazolidinediones, calcineurin inhibitors, antiretroviral therapy, and testosterone; KQs 4, 5: Studies that exclusively enroll or in which the majority of the population has:; - Secondary osteoporosis because of an underlying medical condition or chronic use of a medication associated with bone loss or; - Prior fragility fracture; In addition, studies that exclusively enroll participants who have failed prior medication use for osteoporosis are not eligible.
Screening Interventions | KQs 1–3 (Screening benefits, accuracy, and harms):; - FRA or ORA that has been evaluated in at least two independent cohorts external to the development cohort (unless males are included, then only one independent cohort external to the development cohort is required); - DXA measurement of BMD at the femoral neck (T-scores based on NHANES III reference range) or lumbar spine (local reference range); - A combination of FRA or ORA and DXA together or in sequence (e.g., two-step approach) | - FRAs or ORAs that are not publicly available; - Studies of FRAs or ORAs using split sample validation; - Fall risk assessments (i.e., instruments validated to predict falls, not fractures); - FRAs or ORAs using risk factors not readily available or feasible within primary care settings; - Quantitative ultrasound; - Quantitative CT; - Magnetic resonance imaging; - Trabecular bone score; - Vertebral fracture assessment; - DXA measured at peripheral skeletal sites (e.g., radius, wrist, heel); - DXA measured at central skeletal sites, but hip T-scores based on local reference ranges; - Bone turnover biomarkers; - Finite element analysis; - Hip structural analysis; - Opportunistic screening for osteoporosis on images taken for other indications (e.g., dental X-rays, abdominal CT)
Screening Comparators | KQs 1, 3 (Screening benefits and harms):; - No screening; - FRA/ORA or BMD or both, but no results shared with patient or their primary care provider; KQ 2 (Accuracy):; - For predictive accuracy: Observed fracture incidence from nationally representative and verified sources; - For diagnostic accuracy: DXA-measured BMD at the femoral neck (T-scores based on NHANES III reference range) or lumbar spine | KQs 1, 3:; - No control group; - Another screening strategy (active comparator); KQ 2: Any comparator not specifically identified as included
Treatment Interventions | KQs 4, 5 (Treatment benefits and harms): Bisphosphonates with FDA-approved indications for the treatment of osteoporosis (i.e., alendronate, ibandronate, risedronate, zoledronic acid), denosumab; Males only: Teriparatide, abaloparatide, and romosozumab are also eligible^†^ | KQs 4, 5:; - Bisphosphonates that do not have FDA-approved indications for the treatment of osteoporosis (e.g., etidronate, pamidronate); - Estrogen (with or without progesterone), raloxifene, or bazedoxifene^†^; - Females only: Teriparatide, abaloparatide, or romosozumab^†^; - Medications that are sometimes used off-label to treat osteoporosis (e.g., testosterone, tamoxifen); - Treatments that are no longer used in practice or that have been recalled, specifically calcitonin and parathyroid hormone 1-84; - Vitamin D or calcium supplements alone (these are considered adjuncts to treatment); - Dietary supplements; - Nonpharmacologic treatments (e.g., exercise, fall prevention interventions)
Treatment Comparators | KQs 4, 5 (Treatment benefits and harms): Placebo, vitamin D or calcium or both, no treatment | - Active drug comparators (e.g., head-to-head comparisons of active drugs or comparisons of multiple drugs in combination or in sequence with monotherapy); - Nonpharmacologic interventions (e.g., exercise)
Outcomes | KQs 1, 4 (Screening and treatment benefits):; - All-cause mortality; - Fracture-related mortality; - Fractures (all-cause, hip, major osteoporotic fractures^‡^, clinical vertebral fractures, any clinical fragility fractures); - Fracture-related morbidity (e.g., disability); KQ 2 (Accuracy):; 1. Calibration outcomes (e.g., observed vs. Expected ratio, calibration slope, calibration plot, Hosmer-Lemeshow goodness-of-fit), overall prediction model performance (e.g., Brier score, explained variation [R^2^]); 2. Discrimination outcomes (e.g., c-statistic, discrimination slope, sensitivity, specificity, area under the receiver operating characteristic curve); KQ 3 (Screening harms):; 1 Overdiagnosis; 1 Unnecessary treatment from inaccurate risk prediction; 2 Radiation exposure; - Anxiety from labeling; KQ 5 (Treatment harms):; - Total adverse events; - Total serious adverse events; - Specific serious adverse events: Major cardiovascular events (i.e., myocardial infarction, stroke, cardiovascular death), atrial fibrillation, osteonecrosis of the jaw, atypical femur fractures, incident gastrointestinal cancer, serious gastrointestinal events, rebound fractures after discontinuing denosumab treatment; - Discontinuations because of adverse events | KQs 1, 4:; - Radiographic (i.e., morphometric) vertebral fractures; - Fractures based on patient self-report without verification/confirmation; - BMD; - Other outcomes not specifically identified as included; KQs 2, 3, 5: Outcomes not specifically identified as included
Timing | KQs 1, 4 (Screening and treatment benefits): Followup for at least 1 year; KQ 2 (Accuracy):; - For predictive accuracy of FRAs or ORAs, observed fracture incidence over at least a median or mean of 80% of the time specified by the FRA (e.g., at least 8 years for a tool designed to predict 10-year risk). For FRAs or ORAs that do not specify a prediction interval, a minimum of 3 years of observed incidence is required; - For predictive accuracy of DXA, observed fracture incidence over at least 1 year; - For diagnostic accuracy of risk assessments, no longer than 8 weeks between FRA or ORA and BMD measurement; KQs 3, 5 (Screening and treatment harms): Any length of followup | - Timing that does not meet inclusion criteria
Study Design | KQs 1, 3 (Screening benefits and harms): RCTs, clinical controlled trials, or systematic reviews of RCTs or controlled trials. Cohort studies and systematic reviews of cohort studies are also eligible for KQ 3 only.; KQ 2 (Accuracy): Recent (published in the last 5 years) systematic reviews of cohort or test accuracy studies, cohort studies designed for evaluating predictive accuracy (i.e., prognosis for fracture risk) or diagnostic accuracy (for identification of osteoporosis), comparative studies in which a single group is treated as a cohort for purposes of evaluating predictive or diagnostic accuracy are also eligible; KQs 4, 5 (Treatment benefits and harms): RCTs and controlled trials (including those in which participants serve as their own controls); controlled cohort studies are also eligible for KQ 5 only | All KQs: Case series; case reports; case-control studies; conference abstracts, posters, or proceedings without data or information available to assess risk of bias; unpublished data; editorials; commentaries; narrative reviews; KQs 4, and 5: Systematic reviews are not eligible but will be hand searched to identify studies potentially missed by our search
Settings | KQs 1, 3, 4, 5 (Screening and treatment benefits and harms): Primary care settings in countries designated as “very high” on the 2020 Human Development Index (as defined by the United Nations Development Programme)^104^; KQ 2 (Accuracy): Predictive accuracy: United States or countries with similar hip fracture incidence as the United States^§^ for synthesis of any primary research studies | KQs 1, 3, 4, 5: Long-term care settings such as nursing homes, inpatient settings; KQs 1, 3: Specialty medical settings (e.g., endocrinology, rheumatology); KQ 2: Predictive accuracy: studies in single countries with high or low fracture incidence
Study Quality | KQ 1, 2c, 3, 4, 5: Good or fair quality as determined by standard risk of bias instruments and existing USPSTF criteria tailored to study design; KQ 2a and KQ 2b: Poor quality studies were also included | KQ 1, 2c, 3, 4, 5: Poor quality; KQ 2c: Any study quality were allowed

* For the purposes of this review, we use the terms men and women consistent with how they are typically used in the underlying evidence base for this topic. Men refers to persons assigned male sex at birth. Women refers to persons assigned female sex at birth. Studies that include gender-diverse individuals, including those who have undergone gender-affirming therapy (e.g., transmen, transwomen), were not excluded from the scope of this review. However, studies that exclusively enrolled populations who take hormone therapy that affects bone density were excluded from this review, consistent with our criteria that exclude studies that focused on populations with secondary osteoporosis or who took chronic medications that have known effects on bone metabolism. For such populations, individualized clinical decisions about bone density testing in the context of condition and medication management are required.

† This review is not intended as a comprehensive review of all available pharmacologic therapies. Second-line therapies (abaloparatide, teriparatide, romosozumab) were excluded for women because the USPSTF is likely to have sufficient evidence to determine the net benefit of treatment based on the evidence for FDA-approved bisphosphonates and denosumab, as determined by the most recent review before this update. We only consider these drugs for men given the paucity of treatment studies generally available for men. Although romosozumab is not currently FDA approved for men, it is currently in Phase 3 studies for men, so it was included in this update. Hormone therapy and selective estrogen receptor modulators were reviewed in a separate USPSTF review on hormone therapy, so they were not included in this update.

‡ Major osteoporotic fracture is typically defined as fractures of the hip, wrist, and humerus and clinical vertebral fractures.

§ Countries with “moderate” hip fracture incidence in addition to the United States include Australia, Canada, Chile, Estonia, Finland, France, Israel, Japan, Kuwait, Lithuania, Malaysia, Mexico, the Netherlands, New Zealand, Poland, Portugal, Russia, South Korea, Spain, and Thailand.^105^

Abbreviations: BMD=bone mineral density; CT=computerized tomography; DXA=dual-energy X-ray absorptiometry; FDA=Food and Drug Administration; FRA=fracture risk assessment; KQ=key question; NHANES=National Health and Nutrition Examination Survey; ORA=osteoporosis risk assessment; RCT=randomized, controlled trial; USPSTF=U.S. Preventive Services Task Force.

## B.3 U.S. Preventive Services Task Force Quality Rating Criteria

### Criteria for Randomized, Controlled Trials and Cohort Studies

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

### Definition of Ratings Based on Above Criteria Randomized, Controlled Trials and Cohort Studies

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.

Poor: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Criteria for Systematic Reviews

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

### Definition of Ratings Based on Above Criteria for Systematic Reviews

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions

Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies

Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

Sources: U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. 2017^420^; Harris et al, 2001.^421^