# Appendix A Additional Background and Contextual Questions 2, 3, and 4

## Prevalence and Burden

Appendix A Table 1 Age-Standardized Hip Fracture Incidence (per 1,000 Person-Years) in a Large Cohort (N=1,841,263) of Medicare Advantage Enrollees^35^

Year | Age Strata | Overall | Males | Females
2007 | 50 to 64 | 5.90 | 4.32 | 7.39
| ≥65 | 20.51 | 12.00 | 27.49
2013 | 50 to 64 | 5.67 | 4.20 | 7.09
| ≥65 | 17.01 | 10.72 | 22.08
2017 | 50 to 64 | 6.03 | 4.33 | 7.73
| ≥65 | 19.35 | 12.04 | 24.92

Abbreviations: N=number.

Appendix A Figure 1 FRAX Estimates of the 10-Year Risk for Major Osteoporotic Fracture and Hip Fracture at a Bone Mineral Density T-Score of −2.5 and Body Mass Index of 25 at Ages 50 and 70 Years With No Other Clinical Risks^322^

Abbreviations: FRAX=Fracture Risk Assessment Tool; MOF=major osteoporotic fracture defined as fracture of the hip, spine (clinical), wrist, or humerus; U.K.=United Kingdom; U.S.=United States.

This figure illustrates a bar plot comparing Fracture Risk Assessment Tool (FRAX) estimates of the 10-year risk for major osteoporotic fractures and hip fractures. The y-axis ranges from 0 percent to 16 percent. The x-axis shows 8 groups: Female major osteoporotic fracture (MOF) age 50, Female MOF age 70, Female Hip age 50, Female Hip age 70, Male MOF age 50, Male MOF age 70, Male Hip age 50, Male Hip age 70. Each group is further categorized into six racial, ethnic, or national populations shown left to right: U.S. Caucasian (unfilled bar), U.S. Black (solid bar), U.S. Hispanic (sparsely dotted bar), U.S. Asian (horizontally striped bar), Canada (diagonally striped bar), and the United Kingdom (densely dotted bar). MOF risk is higher than hip fracture risk in all racial, ethnic, or national populations. Ten-year estimated fracture risks are highest for U.S. Caucasian females and U.S. Caucasian males and are lowest for U.S. Black males and females for both fracture types and both age groups. Ten-year fracture risks for Canadian persons are lower than U.K. persons, but higher than estimated risks for U.S. Asian and Hispanic persons, which are similar.

## Risk Assessment Instruments

Appendix A Table 2 Risk Assessment Instruments for Identifying Osteoporosis or Predicting Fracture

Purpose/Risk Factor | ABONE | AMMEB | FRAX | FRC | FRISC | FRISK | Garvan FRC | MORES | MOST | MSCORE | NOF | ORAI | OSIRIS | OST | OSTA | QFracture | SCORE | SOF | SOFSURF | wHI
Osteoporosis Identification (OI) or Fracture Risk Prediction (FRP) | OI | OI | FRP | FRP | FRP | FRP | FRP | OI | OI | OI | OI | OI | OI | OI | OI | FRP | OI | OI | OI | FRP
Age | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X
Sex | F | F | F, M | F, M | F | F | F, M | M | M | M | F | F | F | F | F | F, M | F | F | F | F
Race/ethnicity | | | X^*^ | X | | | | | | | | | | | Asian only | X | X | X | | X
Weight or BMI | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X
BMD | | | X^†^ | X^†^ | X^ǂ^ | X^†^ | X^†^ | | | | | | | | | | | | | X^†^
Prior fragility fracture | | | X | X | | X | X | | | X | X | | X | | | X | X | X | X | X
Maternal/parental history of fracture | | | X | X | | | | | | | X | | | | | X | | X | | X
History of falls | | | | | | X | X | | | | | | | | | X
Current smoking | | | X | X | | | | | | | X | | | | | X | | | X | X
Alcohol consumption | | | X | X | | | | | | | | | | | | X
Secondary osteoporosis | | | X | X
Corticosteroid use | | | X | X | | | | | | | | | | | | X | | X | | X
Anticonvulsant use | | | | | | | | | | | | | | | | X
Antidepressant/benzodiazepine use | | | | | | | | | | | | | | | | X
Estrogen Related
Menopausal status | | | | | X
Menopausal symptoms | | | | | | | | | | | | | | | | X
Hormone therapy | X | | | | | | | | | | | X | X | | | X | X | X
Age at menarche | | X
Years postmenopausal | | X
Medical Conditions
Asthma | | | | | | | | | | | | | | | | X
Back pain | | | | | X
Cancer | | | | | | | | | | | | | | | | X
Cardiovascular disease | | | | | | | | | | | | | | | | X
COPD | | | | | | | | X | | X | | | | | | X
Chronic liver disease | | | | | | | | | | | | | | | | X
Chronic renal disease | | | | | | | | | | | | | | | | X
Dementia | | | | | X | | | | | | | | | | | X | | X
Diabetes (type 1) | | | | | | | | | | | | | | | | Type I | | | | X
Endocrine problems | | | | | | | | | | | | | | | | X
Epilepsy | | | | | | | | | | | | | | | | X
Gastrectomy | | | | | | | | | | X
Gastrointestinal malabsorption | | | | | | | | | | | | | | | | X
Rheumatoid arthritis | | | X | X | | | | | | | | | | | | X | X
Parkinson’s disease | | | | | | | | | | | | | | | | X
Other Factors
Global health | | | | | | | | | | | | | | | | | | | | X
Heart rate >80 | | | | | | | | | | | | | | | | | | X
Living in a care or nursing home | | | | | | | | | | | | | | | | X
Needs help getting up | | | | | | | | | | | | | | | | | | X
On feet more than 4 hours per day | | | | | | | | | | | | | | | | | | X
Quantitative ultrasound index | | | | | | | | | X
Walk for exercise | | | | | | | | | | | | | | | | | | X

* Separate risk calculators are available for U.S. Caucasian, Black, Hispanic, and Asian persons.

† Can be used with or without BMD either at femoral neck, lumbar spine, or both depending on instrument.

ǂ Must include BMD at lumbar spine.

Note: this table does not include the Fracture Risk Evaluation Model, which uses age, sex, and 38 clinical risk factors for women and 43 risk factors for men.

Abbreviations: ABONE=assessing age, body size, and estrogen use; AMMEB=Age, years after Menopause, age at Menarche; BMI=body mass index; BMD=bone mineral density; COPD=chronic obstructive pulmonary disease; FRAX=Fracture Risk Assessment Tool; FRC=Fracture Risk Calculator; FRISC=Fracture and Immobilization Score; FRISK=Fracture Risk Score; FRC=Fracture Risk Calculator; FRP=Fracture Risk Prediction; MORES=Multiple Outcomes of Raloxifene Trial; MOST=Male Osteoporosis Screening Tool; MSCORE=Male Simple Calculated Osteoporosis Risk Estimation; NOF=National Osteoporosis Foundation; OI=Osteoporosis Identification; ORAI=Osteoporosis Risk Assessment Instrument; OSIRIS=Osteoporosis Index of Risk; OST=osteoporosis self-assessment tool; OSTA=Osteoporosis Self-assessment Tool for Asians; SCORE=Simple Calculated Osteoporosis Risk Estimate; SOF=Study of Osteoporotic Fractures; SOFSURF=Study of Osteoporotic Fractures Simple Useful Risk Factors; U.S.=United States; WHI=Women’s Health Initiative.

### Additional Information: Fracture Risk Assessment Tool

The most studied fracture risk assessment instrument is Fracture Risk Assessment Tool (FRAX), released in 2008 and developed by the University of Sheffield in the United Kingdom during the time the University hosted the World Health Organization’s (WHO’s) Collaborating Centre for Metabolic Bone Disease (1991 to 2010).^12,^ ^71^ FRAX predicts the 10-year probability of hip fracture or major osteoporotic fractures (MOFs) (hip, spine, wrist, shoulder) for persons ages 40 to 90 years using demographic and clinical factors alone or in combination with bone mineral density (BMD) measured at the femoral neck (FN).^89^ Risks predicted by FRAX without BMD are not as accurate when compared with FRAX with the use of BMD; however, risks predicted by FRAX without BMD are similar to risks predicted by BMD alone.^323^

FRAX was derived from nine cohorts in Europe, the United States, Japan, and Canada and further validated in an additional 11 cohort studies.^12,^ ^71^ As of spring 2021, 73 different country-specific versions of FRAX were available that have been calibrated using country-specific fracture incidence and mortality data (which is considered a competing risk in the model).^78^ For the United States, four different versions of FRAX are available that have been calibrated based on racial- and ethnic-specific fracture incidence data, including unique versions for non-Hispanic Caucasians, non-Hispanic Blacks, Hispanics, and non-Hispanic Asians.^69^ We note that the group labels used to describe the race-specific FRAX calculators may not be consistent with current preferred terminology for various racial and ethnic groups.

As of 2016, FRAX was incorporated into 120 guidelines worldwide and added into dual-energy X-ray absorptiometry (DXA) software following regulatory approval by the U.S. Food and Drug Administration (FDA) and has been incorporated into clinical decision support tools within electronic health record systems.^89^ The most commonly cited limitations of the FRAX instrument include use of binary exposure to glucocorticoids and alcohol use (yes/no vs. quantified dose exposure), lack of use of lumbar spine (LS) BMD or trabecular bone score, no information collected about history of falls, frailty, and lack of medical conditions such as diabetes that may portend an increased risk.^69,^ ^84,^ ^324^ Falls and propensity to fall become increasingly important risk factors with advancing age. Further, FRAX has only been validated for use with FN BMD, and using FRAX in persons with low BMD at the LS but relatively normal BMD at the FN may underestimate fracture risk.^84^ Because hip fracture incidence in the United States is lower in most non-White racial and ethnic groups, predicted fracture risk estimates for persons in these racial and ethnic groups will always be lower than for White persons of the same age, sex, weight, BMD, and clinical risks used in the FRAX model. See Appendix A Contextual Question 2 for additional information about the use of race and ethnicity in FRAX.

### USPSTF’s Prior Recommendations Related to Use of FRAX

In the last two updates to its recommendations, the USPSTF has recommended BMD testing in all women age 65 years or older but only recommended BMD testing for women ages 50 to 64 years who are at increased risk of osteoporosis, as determined by a formal clinical risk assessment tool (topline recommendation).^1^ In the clinical considerations, the USPSTF suggests that one approach in women younger than age 65 years is to screen individuals when their risk of a 10-year MOF is equivalent to that of a 65-year-old White woman with no other clinical risks.^1^ In the 2011 recommendation, this risk was 9.3 percent based on risk for a White women with BMI of 25 kg/m^2^. In the 2018 recommendation, this risk was 8.4 percent based on the risk for a White woman of average height and weight in the United States, which was a BMI slightly higher than 25 kg/m^2^.

The usefulness of the USPSTF’s approach in younger women is unclear. Identifying persons with a T-score less than −2.5 is important because that is the population for whom trial evidence supports treatment. However, tools other than FRAX that were developed specially to identify osteoporosis are simpler and have higher diagnostic accuracy than FRAX.^139^ Several studies have retrospectively applied the USPSTF FRAX criteria to a sample of women to evaluate accuracy for identifying osteoporosis;^141,^ ^195,^ ^220,^ ^234,^ ^236^ these are included in key question (KQ) 2c of this update.

Although the use of FRAX does have limitations, the field has evolved toward trying to identify those at risk for fracture and not just those with osteoporosis because most fragility fractures occur in persons with T-scores greater than −2.5. Age is a large driver of fracture risk relative to the T-score in older populations, and because fracture risk has greater between-country variability than BMD does, some researchers argue that treatment decisions should probably be based on fracture risk and not BMD alone.^89^ For example, in a 65-year-old female, the 10-year MOF risk of 20 percent (the treatment threshold in the United States) corresponds to a FN T-score of −4.6 in Venezuela but only −2.0 in Iceland.^89^ For these reasons, some experts and organizations recommend fracture risk assessment as the initial screening approach for all ages, with subsequent BMD testing for persons at an intermediate or higher risk (see Appendix A Table 4 in the subsequent section). Randomized, controlled trials (RCTs) are now available (see KQ 1 of main report) that compare a screening strategy that uses FRAX risk calculation followed by BMD in selected patients who score above a certain risk threshold; however, no published studies have been designed to evaluate a treatment strategy based on FRAX, although some treatment trials may now report baseline characteristics related to fracture risk and provide results stratified by fracture risk.^89^

## Pharmacologic Treatment of Osteoporosis

Appendix A Table 3 FDA-Approved Pharmacologic Agents for the Prevention or Treatment of Osteoporosis Included in this Review

Drug Generic (Brand Name[s]) | FDA-Approved Indications Related to Osteoporosis | Dose and Route of Administration for Osteoporosis | Date First Approved for Osteoporosis
Alendronate (Binosto, Fosamax, Fosamax plus D and generics) | Binosto, Fosamax, Fosamax plus D; - Treatment of osteoporosis in postmenopausal women; - Treatment to increase bone mass in men with osteoporosis; Fosamax only; - Prevention of osteoporosis in postmenopausal women; - Treatment of glucocorticoid-induced osteoporosis | Fosamax; - Treatment: 10 mg daily or 70 mg (tablet or oral solution) once weekly; - Prevention: 5 mg daily or 35 mg once weekly; - Glucocorticoid-induced osteoporosis: 5 mg daily or 10 mg daily; Fosamax plus D; - 70-mg alendronate/2,800 or 5,600 IU vitamin D3 once weekly; Binosto (no generics available); - 70-mg effervescent tablet once weekly | 09/29/1995
Zoledronic acid (Reclast and generics) | - Treatment and prevention of postmenopausal osteoporosis; - Treatment to increase bone mass in men with osteoporosis; - Treatment and prevention of glucocorticoid-induced osteoporosis | - Infusion given intravenously over no less than 15 minutes; - Treatment in women and men or treatment and prevention of glucocorticoid-induced osteoporosis: 5 mg once a year; - Prevention: 5 mg once every 2 years | 4/16/2007
Risedronate (Actonel, Actonel with calcium, Atelvia, and generics) | Actonel, Actonel with calcium; - Treatment and prevention of postmenopausal osteoporosis; Actonel only; - Treatment to increase bone mass in men with osteoporosis; - Treatment and prevention of glucocorticoid-induced osteoporosis; Atelvia; - Treatment of postmenopausal osteoporosis | Actonel; - Prevention or treatment in women and men: 5 mg daily, 35 mg once a week; - Prevention or treatment in women: 75 mg on 2 consecutive days each month, 150 mg once a month; - Prevention or treatment of glucocorticoid-induced osteoporosis: 5 mg daily; Actonel with calcium; - One 35-mg tablet orally, taken once a week followed by one 1,250-mg calcium carbonate tablet (500-mg elemental calcium) orally, taken with food daily on each of the remaining 6 days of the week; Atelvia; - One 35-mg delayed-release tablet once a week | 3/27/1998
Ibandronate (Boniva and generics) | Boniva; - Treatment and prevention of postmenopausal osteoporosis | Boniva; - One 150-mg tablet once monthly on the same day each month | 5/16/2003
Denosumab (Prolia) | - Treatment of postmenopausal women with osteoporosis at high risk for fracture; - Treatment to increase bone mass in men with osteoporosis at high risk for fracture; - Treatment of glucocorticoid-induced osteoporosis in men and women at high risk for fracture; - Treatment to increase bone mass in men at high risk for fracture receiving androgen deprivation therapy for nonmetastatic prostate cancer; - Treatment to increase bone mass in women at high risk for fracture receiving adjuvant aromatase inhibitor therapy for breast cancer | 60-mg subcutaneous injection every 6 months | 6/2/2010

Abbreviation: FDA=Food and Drug Administration.

## Recommendations and Guidelines for Screening From Professional Organizations

Recommendations for screening developed by various organizations and specialty societies share commonalities but also have significant differences (Appendix A Table 4). In general, most guidelines focus on postmenopausal women and use the WHO standard for defining osteoporosis. One important difference among guidelines is that some recommend screening for fracture risk via fracture risk assessment tools such as FRAX, while some recommend screening for osteoporosis via BMD measured through DXA. Current guidelines from several organizations recommend a combination of fracture risk assessment and DXA screening.

The most recent guideline recommending a combination approach is the 2023 Canadian Task Force on Preventive Health Care (CTFPHC) recommendation for screening to prevent primary fragility fractures.^90^ The CTFPHC recommends screening women age 65 years or older with the Canadian FRAX tool to facilitate shared decision making about pharmacotherapy. If pharmacotherapy is considered, it then recommends ordering DXA testing in order to facilitate re-estimation of fracture risk with a BMD input. The CTFPHC recommends against screening in men age 40 or older and in women younger than age 65 years.

Other examples include the 2020 American Association of Clinical Endocrinologists (AACE) Guideline, which recommends evaluating all women age 50 years or older for fracture risk and consider BMD measurement based on clinical fracture risk profile.^91^ The AACE guidelines state that osteoporosis should be diagnosed based on a T-score of −2.5 or lower in the LS, FN, total hip (TH), and/or distal third of the radius in the absence of a prevalent fracture, or in patients with a T-score between −1.0 and −2.5 and increased fracture risk using FRAX country-specific thresholds. Similarly, the 2017 National Institutes for Health and Care Excellence (NICE) (United Kingdom) recommended fracture risk–based screening for all women age 65 years or older and all men age 75 years or older (i.e., using FRAX or the QFracture), followed by BMD screening if indicated.^325^ The NICE guidelines also recommended screening in women younger than age 65 years and men younger than age 75 years in the presence of fracture risk factors. In 2019, the Endocrine Society updated its guidelines for postmenopausal women and noted that screening should be determined using country-specific clinical fracture risk assessment tools (e.g., FRAX) and patient preference, though the guidelines for women are ambiguous with respect to whether BMD should be used to determine fracture risk.^326^ The Osteoporosis Canada 2023 Guideline Update Group recommends assessing all men and postmenopausal women age 50 or older with the Canadian FRAX or the Canadian Association of Radiologists and Osteoporosis Canada 10-year fracture risk assessment tool, CAROC. Then, based on age, prior fractures, and risk profile criteria, obtain BMD and calculate 10-year fracture risk with BMD.^327^

Other guidelines focus on osteoporosis screening via DXA measurement of BMD. The International Society for Clinical Densitometry (ISCD) 2019 guidelines recommend central skeletal site BMD screening in all women age 65 years or older and all men age 70 years or older.^11^ It also recommends BMD screening for postmenopausal women younger than age 65 years and men younger than age 70 years who have risk factors for osteoporosis.^11^ The American College of Obstetricians and Gynecologists recommends BMD screening with DXA beginning at age 65 years in all women and selective screening with BMD in women younger than age 65 years who have an elevated risk of osteoporosis based on a formal clinical risk assessment tool, with repeat screening no sooner than 2 years after initial screening for those with a BMD near a treatment threshold at the time of initial screening.^328^ The National Osteoporosis Foundation’s (NOF’s), now the Bone Health and Osteoporosis Foundation, most recent clinical guideline (2022) recommends BMD evaluation in all women age 65 years or older and all men age 70 years or older. It also recommends BMD testing in postmenopausal women, women in menopausal transition, men ages 50 to 69 years with clinical risk factors, and adults with fractures at age 50 years or older.^84^

An outlier in recommending against screening, the United Kingdom National Screening Committee, reviewed three recent RCTs^120,^ ^124,^ ^126^ on screening for fracture risk (SCOOP, ROSE, SOS) and did not find the evidence compelling enough to recommend a screening program and continues to favor case finding. Other guidelines remain mostly unchanged from the last time the USPSTF reviewed this topic (2018), including those from the American College of Preventive Medicine and the American College of Radiology.

Appendix A Table 4 Recommendations for Fracture or Osteoporosis Screening by Organization

Organization, Year | Population | Recommendations
American Association of Clinical Endocrinology, 2020^91^ | Postmenopausal women | Screening; - Evaluate all postmenopausal women age 50 years or older for osteoporosis risk; - Include a detailed history, physical examination, and clinical fracture risk assessment with FRAX or other risk assessment tool in the initial evaluation for osteoporosis; - Consider BMD testing based on clinical fracture risk profile; Treatment; - When BMD is measured, use DXA measurement (spine and hip, 1/3 radius if indicated); - Osteoporosis should be diagnosed based on presence of fragility fractures even in the absence of metabolic bone disorders or a normal T-score or on a T-score of −2.5 or lower in the lumbar spine, femoral neck, total hip, or 1/3 radius even in the absence of a prevalent fracture, and the diagnosis persists even if subsequent measures improve; - Osteoporosis may also be diagnosed in patients with a T-score between −1.0 and −2.5 and increased fracture risk using FRAX (Fracture Risk Assessment Tool) country-specific thresholds; - Approved agents with efficacy to reduce hip, nonvertebral, and spine fractures, including alendronate, denosumab, risedronate, and zoledronate, are appropriate as initial therapy for most osteoporotic patients with high fracture risk; - Abaloparatide, denosumab, romosozumab, teriparatide, and zoledronate should be considered for patients unable to use oral therapy and as initial therapy for patients at very high fracture risk; - Ibandronate and raloxifene may be appropriate initial therapy in some cases for patients requiring drugs with spine-specific efficacy
American Academy of Family Physicians, 2021^329^ | Postmenopausal women; Men | Same recommendations as the 2018 USPSTF recommendations:; - Women age 65 years or older (B); - In younger women whose fracture risk is equal to or greater than that of a 65-year-old White woman who has no additional risk factors (B); - Insufficient evidence to assess the balance of benefits and harms of screening for osteoporosis in men
American College of Obsetrics and Gynecology, 2021^328^ | Women | Screening by DXA:; - Postmenopausal patients age 65 years or older; - Younger postmenopausal patients if they are at elevated risk of osteoporosis based on a formal clinical risk assessment tool; - Repeat screening no sooner than 2 years after initial screening for postmenopausal patients with BMD near treatment thresholds at the time of initial screening
American College of Physicians, 2023^318^ | Postmenopausal women; Men | Screening: No specific guideline related to screening; Treatment; - Bisphosphonates for initial pharmacologic treatment in postmenopausal females (high certainty) and males (low certainty) diagnosed with primary osteoporosis; - Denosumab for second-line treatment in postmenopausal females (moderate certainty) and males (low certainty) diagnosed with primary osteoporosis; - Romosozumab or rPTH followed by bisphosphonate for females with very high risk of fracture (conditional recommendation); - Individualized approach regarding whether to start bisphosphonate treatment in females older than age 65 years with low bone mass (osteopenia) (low certainty)
American College of Preventive Medicine, 2009^330^ | Women age 65 years or older; Men age 70 years or older | Screening: Recommend DXA; - All women age 65 years or older and men age 70 years or older and not more frequently than every 2 years; - Younger postmenopausal women and men ages 50 to 69 years should undergo screening if they have at least one major or two minor risk factors for osteoporosis; - Osteoporosis risk assessment tools that estimate absolute fracture risk can be useful supplements to BMD testing, improving the sensitivity and specificity of either approach (BMD or risk assessment) alone; risk assessment can also be used if BMD testing is not readily available or feasible
American College of Radiology, 2017^63^ | Asymptomatic BMD screening for individuals with established or clinically suspected low BMD | - All women age 65 years or older and men age 70 years or older (asymptomatic screening); - Women younger than age 65 years who have additional risk for osteoporosis, based on medical history and other findings. Additional risk factors for osteoporosis include:; a. Estrogen deficiency; b. A history of maternal hip fracture that occurred after the age of 50 years; c. Low body mass (<127 lb or 57.6 kg); d. History of amenorrhea (>1 year before age 42 years); - Women younger than age 65 years or men younger than age 70 years who have additional risk factors, including:; a. Current use of cigarettes; b. Loss of height, thoracic kyphosis
The Bone Health and Osteoporosis Foundation, 2022^84^ | Men age 50 years or older and postmenopausal women | Screening with DXA; - Women age 65 years or older and men age 70 years or older; - Postmenopausal women and men ages 50 to 69 years with clinical risk factors; - Adults with fractures at age 50 years or older; Treatment; - Consider for postmenopausal women and men age 50 years or older with T-scores −2.5 or worse; - Consider for postmenopausal women and men age 50 years or older with T-scores between −1.0 and −2.5 and a 10-year FRAX probability of major osteoporosis-related fracture ≥20%
Canadian Task Force on Preventive Health Care, 2023^90^ | Men and women age 40 or older | Screening with DXA; - Screen women age 65 years or older with Canadian version of FRAX to facilitate shared decision making about pharmacotherapy; if pharmacotherapy is considered, obtain DXA and re-estimate FRAX with BMD input; - Recommend against screening in women younger than age 65 years and men
Endocrine Society, 2012^331^; 2019^326^; 2020^332^ | Screening for higher-risk men; Screening and treatment for postmenopausal women | Screening in men: Recommend BMD screening by central DXA in:; - Men age 70 years or older; - Men ages 50 to 69 years with risk factors (e.g., low body weight, prior fracture as an adult, smoking); Screening and treatment in postmenopausal women; - The risk of future fractures in postmenopausal women should be determined using country-specific assessment tools to guide decision making. The guidelines are ambiguous with respect to whether BMD should be evaluated to determine fracture risk.; - Patient preferences should be incorporated into treatment planning.; - Nutritional and lifestyle interventions and fall prevention should accompany all pharmacologic regimens to reduce fracture risk.; - Multiple pharmacologic therapies are capable of reducing fracture rates in postmenopausal women at risk with acceptable risk-benefit and safety profiles.
International Society of Clinical Densitometry, 2019^11^ | Men and postmenopausal women | BMD screening; - Women age 65 years or older; - Postmenopausal women younger than age 65 years with risk factors for low bone mass; - Women during the menopausal transition with clinical risk factors for fracture, such as low body weight, prior fracture, or high-risk medication use; - Men age 70 years or older; - Men younger than age 70 years with clinical risk factors for low bone mass; Diagnosis; - Recommends the WHO international reference standard for osteoporosis diagnosis: a T-score of −2.5 or less at the femoral neck. The reference standard from which the T-score is calculated is the female, White, ages 20 to 29 years, NHANES III database.; - Osteoporosis may be diagnosed in postmenopausal women and in men age 50 years or older if the T-score of the lumbar spine, total hip, or femoral neck is −2.5 or less. In certain circumstances, the 1/3 radius may be used.
National Institute for Health and Care Excellence (U.K.), 2017^325^ | Persons presenting in any healthcare setting | Screening; - In all women age 65 years or older and all men age 75 years or older; - In women younger than age 65 years and men younger than age 75 years in the presence of risk factors, for example:; a. History of falls; b. Family history of hip fracture; c. Low BMI (<18.5 kg/m^2^); d. Smoking; e. Alcohol intake more than 14 units per week (women) or more than 21 units per week (men); - Do not routinely assess fracture risk in people younger than age 50 years unless they have major risk factors (e.g., current or frequent recent use of oral or systemic glucocorticoids, untreated premature menopause, or previous fragility fracture), because they are unlikely to be at high risk.; - Estimate absolute risk when screening. Consider measuring BMD with DXA in people whose absolute fracture risk (via FRAX or QFracture) is in the region of an intervention threshold for a proposed treatment and recalculate FRAX with BMD value.
National Osteoporosis Guideline Group (U.K.), 2022^333^ | Postmenopausal women; men age 50 years or older | - FRAX assessment should be done in any postmenopausal woman or in any man age 50 years or older with a clinical risk factor for fragility fracture to guide BMD measurement.
North American Menopause Society, 2021^334^ | Postmenopausal women | Screening with DXA; - Postmenopausal women with history of fracture after menopause; - All women with medical causes of bone loss (e.g., steroid use, hyperparathyroidism), regardless of age; - Consider for postmenopausal women younger than age 65 years with specified risk factors (see below); a Discontinued estrogen with additional risk factors for fracture; b Thinness (body weight <127 lb [57.7 kg] or BMI <21 kg/m^2^); c History of hip fracture in a parent; c Current smoker; d Alcohol intake of more than two units per day (one unit is 12 oz of beer, 4 oz of wine, or 1 oz of liquor); e Long-term use of medications associated with bone loss; Treatment; - A variety of nonpharmacologic treatments reviewed such as nutrition, mineral and vitamin use, exercise, fall prevention, and smoking cessation; routine use of calcium and vitamin D supplements is not recommended except when daily targets are not achieved from dietary sources; - All postmenopausal women who experienced vertebral or hip fracture; - All postmenopausal women who have BMD values consistent with osteoporosis (i.e., T-scores equal to or worse than −2.5) at the lumbar spine, femoral neck, or total hip region; - All postmenopausal women who have T-scores from −1.0 to −2.5 and any of the following: increased fracture risk based on country-specific FRAX threshold; history of proximal humerus, pelvis, or distal forearm fracture; or history of multiple fractures at other sites excluding face, feet, and hands; - Several pharmacologic options are available for osteoporosis therapy, including bisphosphonates, the selective estrogen receptor modulator (SERM; also known as estrogen agonist/antagonist) raloxifene, PTH, estrogens, and calcitonin. Bisphosphonates are the first-line drugs for treating postmenopausal women with osteoporosis.
Osteoporosis Canada 2023 Guideline Update Group, 2023^327^ | Men and postmenopausal women age 50 years or older | Screening; - Assess all men and postmenopausal women age 50 years or older for fracture risk factors using the Canada-specific FRAX tool, or alternatively the CAROC.; - Obtain BMD and calculate 10-year fracture risk with BMD using FRAX or CAROC for all postmenopausal women and men ages 50 to 64 years with previous fracture or 2 or more risk factors, ages 65 to 69 years with 1 risk factor, or age 70 years or older with no risk factors.; - Reassess BMD and fracture risk in 3 years for patients who initiated pharmacotherapy. Reassess BMD and fracture risk for those not taking pharmacotherapy based on 10-year fracture risk:; - <10%, reassess in 5 to 10 years; - 10% to 15%, reassess in 5 years; - ≥15%, reassess in 3 years; Treatment; - Recommend pharmacotherapy to postmenopausal women or men age 50 years or older with previous hip or spine fracture or 2 or more fracture events, those with high absolute risk (≥20% probability for major osteoporotic fracture over 10 years), and those with T-score ≤−2.5% and age 70 years or older.; - Suggest pharmacologic therapy to patients with 15% to 19.9% probability for major osteoporotic fracture over 10 years and those with T-score ≤−2.5 and age less than 70 years.; - A variety of nonpharmacologic treatments were reviewed, including nutrition and exercise for fall and fracture prevention.
United Kingdom National Screening Committee, 2019^335^ | Postmenopausal women | After a review of the SALT-SOS, ROSE, and SCOOP trials, a systematic screening program for osteoporosis is not recommended in the United Kingdom. However, hip fracture is an important outcome, and future work should focus attention on this area.
World Health Organization, 2007^5,^ ^12^ | Men and women ages 40 to 90 years | Screening; - Population-based (i.e., public health) prevention programs are appropriate for all Member States and should include attention to nutritional factors, particularly calcium and vitamin D. Cigarette smoking, prevention of excessive alcohol consumption, and the avoidance of immobility are also recommended as public health measures.; - In Member States without access to densitometry, case-finding strategies can be pursued with use of clinical risk factors alone. The performance characteristics of the FRAX model are at least as good as those provided by peripheral assessment of BMD.; - In Member States where BMD is universally recommended (e.g., at age 65 years or older in North America), the stratification of risk can be improved by considering clinical risk factors in conjunction with BMD. This is particularly valuable in the context of younger individuals for hip fracture prediction.; - In Member States with limited access to DXA, clinical risk factors can be used to stratify target populations to those at very high risk in whom a BMD test would not alter their risk category, those with very low risk in whom a BMD would not alter their risk category, and those at intermediate risk where a BMD test would be helpful for the characterization of fracture probability.; Treatment; - The validation of BMD measurements and the increase in epidemiological information permit diagnostic criteria for osteoporosis to be more precisely defined than previously. The international reference standard for the description of osteoporosis in postmenopausal women and in men age 50 years or older is a femoral neck BMD of 2.5 SD or more below the young female adult mean, using normative data from the NHANES reference database on Caucasian women ages 20 to 29 years.; - Although the reference standard for the description of osteoporosis is BMD at the femoral neck, other central sites (e.g., lumbar spine, total hip) can be used for diagnosis in clinical practice.; - T-scores should be reserved for diagnostic use in postmenopausal women and men age 50 years or older. With other technologies, and other populations, measurement values should be expressed as Z-scores, units of measurement, or preferably in units of fracture risk.

Abbreviations: BMD=bone mineral density; BMI=body mass index; CAROC=Canadian Association of Radiologists and Osteoporosis Canada 10-year fracture risk assessment tool; DXA=dual-energy X-ray absorptiometry; FDA=U.S. Food and Drug Administration; FRAX=Fracture Risk Assessment Tool; IU/day=international unit per day; NHANES=National Health and Nutrition Examination Survey; PTH=parathyroid hormone: Promising Developments in Osteoporosis Treatment; ROSE=Risk-Stratified Osteoporosis Strategy Evaluation study; SALT-SOS=Stichting Artsen Laboratorium en Trombosedienst Osteoporosis Study; SCOOP=Screening in the Community to Reduce Fractures in Older Women study; SD=standard deviation; SERM=selective estrogen receptor modulator; UKNSC=United Kingdom National Screening Committee; USPSTF=U.S. Preventive Services Task Force.

## Contextual Questions 2–4

### CQ 2 How Do Various Risk Assessment Tools Use Race and Ethnicity in Osteoporosis or Fracture Risk Calculations?

#### Summary

Although several fracture risk estimators have been developed, only two that are commonly used in clinical practice incorporate race or ethnicity: the FRAX, calibrated for use internationally, and QFracture, developed in the United Kingdom.^77^ Several other fracture risk assessment models have been developed—the Women’s Health Initiative (WHI) model,^187^ the Established Populations for the Epidemiologic Study of the Elderly (EPESE) model,^336^ the American Bone Health Fracture Risk Calculator (FRC),^73,^ ^337^ and the Study of Osteoporotic Fracture (SOF)-based screening tool^52^—but these models are not commonly used. The only osteoporosis risk assessment tool that incorporates race or ethnicity into the assessment is the Simple Calculated Osteoporosis Risk Estimation (SCORE) tool.^76^

#### Fracture Risk Assessments

##### FRAX

FRAX, the most widely used fracture risk assessment tool, is a tool that was developed for use internationally with country-specific estimates derived through calibrating fracture risk to country-specific fracture incidence and mortality data.^71,^ ^338,^ ^339^ FRAX was originally calibrated to the U.S. White population using population-based data from Olmsted County, MN, prior to the availability of the Nationwide Inpatient Sample (NIS), a large U.S. hospital discharge database; however, the data from Olmsted County have been subsequently shown to be similar to NIS data.^12,^ ^71,^ ^340–342^ For Black, Asian, and Hispanic populations, race-specific FRAX calculators were created by applying the ratio of race- and sex-specific hip fracture incidence rates (0.43 and 0.53 for Black women and men, 0.53 and 0.58 for Hispanic women and men, and 0.50 and 0.64 for Asian women and men) derived from multiple epidemiologic studies to the calculators developed for the U.S. White population.^80^

Because hip fracture incidence in the United States is lower in these racial and ethnic groups, predicted risk estimates for persons in these racial and ethnic groups will always be lower than for White persons of the same age, sex, weight, BMD, and clinical risks used in the FRAX model (see Appendix F.2, CQ5 for further details). In the wake of recent attention to racial bias in clinical algorithms, some have raised questions regarding the validity of race-specific FRAX calculators. The relationships between age and clinical risk factors (including BMD) with fracture incidence are the same across all racial groups in FRAX;^80^ however, the predicted risk for persons of different races or ethnicities occurs because of calibration of the race-specific calculators, which use race-specific hip fracture incidence data. Of note, although FRAX is available for countries with multiracial populations such as Canada and the United Kingdom, the only countries with race and ethnicity-specific FRAX models are Singapore, South Africa, and the United States.^343^

Whether these differences in absolute fracture risk reflect bias in the FRAX prediction model or whether these differences simply reflect the end result of using a model calibrated to race-specific incidence data is a matter of debate. Some experts state the lower absolute risks produced by FRAX for Black, Asian, and Hispanic populations simply reflect the underlying epidemiology of fractures in those populations.^344^ Other experts have acknowledged the limitations of race in FRAX, where it likely serves as a proxy for environmental factors; does not account for multiracial people; and minimizes the diversity within racial groups, which, for BMD, may be even greater than the diversity between racial groups.^324^ These acknowledged limitations are all consistent with the USPSTF’s current perspective on race as a social, not a biologic, construct.^345^ However, experts also note some biological differences within and between populations that may explain some of the observed variability in fracture incidence.^343^ This is discussed further in Contextual Question 3 below.

Because treatment recommendations that incorporate predicted fracture risk in the United States are based on fixed predicted risk thresholds (e.g., FRAX ≥20% MOF risk or ≥3% hip fracture risk) that are not specific to race, Black, indigenous, and persons of color (https://www.merriam-webster.com/dictionary/person%20of%20color) populations may be less likely to be identified as high risk and offered treatment compared with White persons of the same age, BMD, and clinical risk profile.^324,^ ^344^ Similarly, other conditions that increase fracture risk and that disproportionately affect persons of color (e.g., diabetes) may result in biased underestimates of risk.^324,^ ^344^ This in turn may lead to less treatment for at-risk individuals belonging to “low-risk” racial groups if these underestimates result in misclassification below the fixed risk thresholds used to recommend treatment. Studies evaluating the sequelae of fracture have found greater postfracture morbidity and mortality in Black women than in White women.^346^ For these reasons, many recommend avoiding strict application of treatment thresholds at the individual level to account for additional risks that are not taken into account by the FRAX model.^343,^ ^344^

Other acknowledged limitations of the current versions of race-specific U.S. FRAX models are that they do not use the most currently available data for race-specific fracture incidence (estimates are from cohort studies in the 1980s and 1990s) and the mortality data used as a competing risk are from 2004 and have not been updated, which would perpetuate underestimates of fracture risk that don’t reflect recent gains in life expectancy across racial and ethnic groups.^324^ Further, because FRAX incorporates age-, race-, and sex-specific mortality data as a competing risk,^340^ residual differences in life expectancy by race and ethnicity may reflect the impact of structural racism on health and this may result in continued underestimates of fracture risk in non-White populations.^324^

##### QFracture

In contrast to FRAX, QFracture uses what its developers define as ethnicity as a variable in its sex-specific equations estimating fracture risk.^147^ The ethnic groups used in QFracture differ from those in FRAX, suggesting that conceptualizations of race and ethnicity and their relevance to disease risk differ between societies. The ethnicities used in QFracture are White, Indian, Pakistani, Bangladeshi, other Asian, Black African, Black Caribbean, Chinese, and other including “mixed.” Notably, Hispanics are not included, likely because Hispanic is an ethnic group created in the United States and is not recognized as an ethnic group elsewhere.^347^ In the 2012 version of QFracture, White women (and those with unknown racial category) have the highest predicted risk of fracture, while Black Caribbean (hazard ratio [HR], 0.23 relative to White women), Bangladeshi (HR, 0.44), Pakistani (HR, 0.46), and Black African (HR, 0.48) women have the lowest predicted fracture rates.^147^ Among men, White persons (and those with unknown racial category) have the highest predicted risk of fracture, while Bangladeshi (HR, 0.29 relative to White men), Black Caribbean (HR, 0.38), Black African (HR, 0.52), and persons from “other” ethnic groups (HR, 0.57) have the lowest predicted fracture rates.^147^ QFracture has been updated with 2016 data not described in the literature, but a review of the tool suggests similar associations between ethnicity and fracture persist.^348^ Nevertheless, Black persons are less than 3.5 percent of the U.K. population and are not a representative sample of Caribbean and African persons.^349–351^ Little data exist regarding the distribution of nationalities among the U.K. Black population, but data suggest that Black Africans primarily comprise Nigerians, Ghanaians, and Somalis,^351^ and Black Caribbeans have majority Jamaican ancestry.^352^

##### Other Models

Other models that include race in fracture risk estimation include the WHI,^187^ the EPESE models,^336^ the American Bone Health FRC,^73,^ ^337^ and the SOF-based screening tool.^52^ In the WHI and the EPSE models, race is dichotomized as White vs. non-White and is used as one of eight and 11 fracture risk factors, respectively, in multivariable models predicting fracture risk. The WHI model, which was developed in the United States, includes Hispanic persons in the non-White group, so White is presumed to mean non-Hispanic White (NHW) in that model. Hispanic ethnicity was not discussed in the EPESE model. The coefficients in the multivariable analyses used to create both models were then translated into a point system for which White persons receive more points, indicating greater fracture risk. The SOF tool includes 12 risk factors that were found to be associated with hip fracture in multivariate models. The presence of each factor is assigned 1 point; three additional factors can result in a point being subtracted from the overall score, and African American race is one of those three factors. We did not identify any studies evaluating the EPESE or SOF tool that met eligibility criteria for inclusion in KQ 2 of this update.

#### Osteoporosis Risk Assessments

The SCORE tool was developed initially to identify a patient’s risk of osteoporosis (i.e., T-score <−2.5) as opposed to fracture risk.^76^ Race is dichotomized in SCORE; however, the categories used by SCORE are Black vs. non-Black. Race is one of six factors used in this additive model.^76^ The SCORE equation was developed from multivariable linear regressions estimating BMD. The coefficients from the model were then translated into a point system representing osteoporosis risk. Individuals with a SCORE value greater than 6 are at moderate to high risk of osteoporosis. Of note, identifying as non-Black adds 5 points to SCORE, whereas identifying as Black adds 0 points.

### CQ 3 What Is the Incidence of Fractures Among Persons of Different Races and Ethnicities in the United States in the Last 10 to 15 Years, and What Factors Might Explain Differences in Incidence Among Different Races and Ethnicities?

#### Summary

The few studies documenting differences in fracture incidence have found that non-Hispanic Black (NHB) and Asian Americans have lower rates of fracture compared with NHW and Hispanic Americans. Racial differences in fracture incidence have been attributed to differences in bone quality, bone morphology, and fall frequency. Studies have reported that NHB Americans have higher BMD than other racial groups, and Asian Americans (who have lower fracture risk) have been primarily found to have lower BMD than NHW Americans. However, studies comparing NHW Americans with NHB and Asian U.S. subpopulations (i.e., Black immigrants and Asian ethnic subgroups) and studies comparing White and Black persons outside the United States have mixed findings. Studies evaluating racial difference in bone quality (architecture, hip axis length) and fall frequency were also inconclusive.

#### Fracture Incidence

U.S. studies evaluating fracture incidence among persons of different races and ethnicities have been primarily conducted with White persons as the comparator group; therefore, our discussion here reflects that approach. To our knowledge, only three studies using data from the last 15 years have been conducted to evaluate racial differences in fracture incidence. Two were clinic-based cohort studies^57,^ ^58^ and one used administrative data.^59^ Liu et al used 2010 Kaiser Permanente Northern California data to calculate age-adjusted hip fracture incidence rates (per 100,000) that were highest among NHW men (137) and lowest among Asian men (45), with Hispanic (98) and NHB (80) men in between (see Appendix A Table 5).^57^ A study using 2012 Kaiser data found White women had the highest age-adjusted incidence of hip fracture (288 per 100,000), followed by Hispanic (198), Asian (148), and NHB women (87).^58^ Authors also found that Asian women had the highest rate of femoral diaphyseal fractures (27 per 100,000), followed by NHB (10), Hispanic (6), and NHW (5) women. Finally, the incidences of osteoporotic fracture (per 10,000) among Medicare fee-for-service 2016 beneficiaries were 389, 381.9, 271.8, 259.6, and 166.8 for Native American, NHW, Hispanic, Asian, and Black persons, respectively.^59^ After adjusting for age and sex, the order of fracture incidence by race remained unchanged.

Appendix A Table 5 Fracture Incidence (per 100,000) by Study Year, Fracture Type, Race and Ethnicity, and Sex^57–59^

| 2010^*^ | 2012^*^ | 2012^*^ | 2016
Fracture type | Hip | Hip | Femoral diaphysis | Several ^†^
Sex | Male | Female | Female | Male and Female
Asian | 45 | 148 | 27 | 2,596
Hispanic | 98 | 198 | 6 | 2,718
NHB | 80 | 87 | 10 | 1,668
NHW | 137 | 288 | 5 | 3,819
North American Native | | | | 3,890

* Age-adjusted.

† Hip, distal femur shaft/distal femur, pelvis/sacrum, tibia/fibula, radius/ulna, clavicle, spine, rib.

Abbreviations: NHB=non-Hispanic Black; NHW=non-Hispanic White.

Racial or ethnic differences in fracture incidence have primarily been attributed to differences in BMD, bone microarchitecture, hip geometry, and fall frequency, each of which we discuss in the following section.

#### Bone Mineral Density

Studies of men and women have consistently demonstrated that NHB Americans have greater age-adjusted BMD than NHW^353–358^ and Hispanic Americans.^353,^ ^355,^ ^356,^ ^359^ Differences in body size (height, weight, or both) explain some differences but residual differences after adjusting for body size are unexplained.

Studies comparing White and Black Americans without consideration of Hispanic ethnicity have shown Black Americans to have greater age-adjusted BMD than White Americans.^358,^ ^360–364^ A study of older adolescent American girls found Black Americans to have greater BMD than White and Asian Americans.^365^ Black American men and women have also been shown to have slower rates of BMD decline with age than White Americans.^360,^ ^366^

Comparisons between NHW, Hispanic, and Asian Americans have had varied findings. Studies of BMD in Hispanic and NHW Americans have found mixed results, including lower,^367^ greater,^353^ and similar^354,^ ^356,^ ^368^ BMD in Hispanic Americans compared with NHW Americans. One study also found faster rates of bone density decline in Hispanic Americans compared with NHB and NHW Americans.^353^ Asian Americans have primarily been found to have lower BMD than White Americans, although this difference has been explained by differences in body size.^60,^ ^354,^ ^356^

##### Racial Differences in BMD Among U.S. Subpopulations, U.S. Immigrant, and Non-U.S. Populations

Although NHB persons have greater BMD than other U.S. racial groups, little is known about why this racial difference exists, whether racial differences in BMD exist outside the United States, or whether Black immigrants differ from Black American-born persons. To our knowledge, only two studies have evaluated BMD in Black African immigrants residing in the United States. Gong and colleagues studied 55 male and 88 premenopausal female immigrants from South Sudan.^369^ The authors found that the South Sudanese immigrants had lower lumbar BMD but similar hip and total body BMD compared with White and Black American normative values.^369^ Melton et al found that compared with White American women, Somali-born women in the United States had a similar BMD at the LS but a greater BMD at the FN.^370^

Studies evaluating BMD in Black persons living outside the United States are few, often small in size, and have mixed findings. Demeke and colleagues found that Somali immigrant women (N=67) living in Sweden had lower BMD (LS and left and right hip) than a Black American reference group and lower LS BMD (but similar left and right hip) than a White American reference group.^371^ A comparison between Black Gambian women living in Gambia and White British women living in the United Kingdom age 45 years or older (N=586) found that after adjusting for weight, age, and height, Gambian-born women had lower BMD at the LS.^372^ In a study comparing Black Gambian-born U.K. immigrants and White U.K. residents (N=39), Black Gambian-born men had greater BMD at the FN alone but similar BMD at the LS, hip trochanter, radius, and whole body compared with White men.^373^ In this same study, Gambian-born women and British women had similar BMD.^373^ A study of South African Black and White women (N=294) found similar distal radius and lumbar BMD but greater femoral BMD among Black women.^374^

Likewise, few studies have been conducted evaluating Hispanic subgroups to determine whether patterns seen in the larger Hispanic population are present in Hispanic subpopulations (e.g., Mexican Americans, Puerto Rican Americans). Of note, studies evaluating differences in BMD between Hispanic and White persons in other countries could not be conducted because Hispanics are only defined as a population in the United States. Studies using National Health and Nutrition Examination Survey (NHANES) data have shown that Mexican American men and women had a higher prevalence of osteoporosis^375^ and lower lumbar BMD^355^ than NHW and NHB men and women. A study by Noel et al—using Boston Puerto Rican Osteoporosis Study and the NHANES 2005–2010 data—found that Puerto Rican men had a higher prevalence of osteoporosis than NHW and NHB men and a similar prevalence of osteoporosis to Mexican American men.^359^ Puerto Rican women were found to have similar rates of osteoporosis as NHW and Mexican women but higher rates than NHB women.

Studies of U.S. Asian subpopulations have generally shown lower or similar BMD when compared with White women. For example, a study of FN BMD among older Asian Americans of Filipino, Chinese, or Japanese descent and White American women found that the Asian women had similar BMD, which was lower than those of NHW women.^60^ The difference between Asian American and NHW women decreased when BMD was adjusted for height.^60^ In a study of premenopausal women ages 42 to 52 years, Finkelstein and colleagues reported that Chinese and Japanese Americans had similar lumbar, spine, and FN BMD as White Americans, when adjusted for age, age at menarche, weight, years of oral contraceptive use, physical activity, number of prior pregnancies, educational level, total calcium intake, cigarette smoking, and alcohol intake, but lower than Black Americans (though this difference was not significant for Chinese American women at the LS).^376^ When the analysis was limited to women weighing less than 70 kg, Chinese and Japanese American women had similar LS BMD as Black Americans and slightly greater (though not significantly so) than White Americans. In the subset of women weighing less than 70 kg, Japanese, Chinese, and White American women had similar FN BMD, which was lower than those of Black Americans (though this difference was not significant for Chinese American women). Other studies of Chinese American women have found lower BMD at LS, TH, and FN than White American women.^61,^ ^62^ However, a study of Filipina, Hispanic, and NHW American women found that Filipinas had higher total body (but similar hip and LS) BMD than the other two groups.^368^

#### Bone Microarchitecture

Bone microarchitecture includes cortical and trabecular volumetric BMD, cortical and trabecular area, cortical and trabecular thickness, cortical porosity, cortical perimeter, trabecular separation, and trabecular number. Trabecular bone score is correlated with trabecular microarchitecture.^377^ Studies evaluating racial and ethnic differences in bone microarchitecture associations are few and findings were sometimes mixed. Compared with White Americans, Black Americans have microarchitecture favoring reduced^362,^ ^365,^ ^378,^ ^379^ and increased fracture risk.^355^ A study by Jain and colleagues found that among women younger than age 60 years, White women had higher trabecular bone scores than Black women but similar scores among those age 60 years or older.^380^ Black older adolescent girls have also been shown to have better bone microarchitecture than their Asian counterparts.^365^ Studies comparing Asian and White American women found Asian women have greater cortical^381,^ ^382^ and trabecular^382^ thickness than White women, both of which are associated with lower fracture risk.

#### Hip Geometry

Studies evaluating racial differences in hip geometry have varied findings. Differences in hip axis length have been posited as explaining racial differences in fracture: shorter hip axis length is associated with lower risk of fracture.^383^ Some studies on hip axis length have found Black Americans to have shorter hip axis lengths than White Americans;^379,^ ^384,^ ^385^ others have found that NHB Americans have hip axis lengths similar to NHW^358,^ ^386^ and Mexican Americans.^386^ In one study, Asian Americans were found to have a shorter hip axis length^384^ than White Americans, but in a different study, Japanese Americans had a similar hip axis length as White Americans after adjusting for height.^387^

#### Fall Frequency

A possible explanation for racial and ethnic differences in fracture incidence is differences in fall frequency among older adults. In three studies, White adults reported a greater number of falls compared with Black adults, but in two of these studies, differences in fall frequency were not medically or statistically meaningful.^388^ Shumway-Cook and colleagues examined falls using Medicare Current Beneficiary Survey data and found that NHW adults were more likely (odds ratio [OR], 1.40 [95% confidence interval (CI),^260^ 1.20 to 1.63]) to report at least one fall in the prior year than those who identified with other racial groups.^388^ However, there was no significant difference in medically injurious falls (falls for which participants sought medical assistance) between NHW adults and the non-White racial group when the analysis was limited to those who had fallen.^388^ In contrast, a study of Black and White older adults in the Boston area found that White participants were more likely (risk ratio [RR], 1.77 [95% CI, 1.14 to 2.74]) than Black participants to experience injurious falls.^389^ However, not all studies indicated racial differences in fall frequency. Finally, a study by Faulkner and colleagues found that although White women had numerically higher fall rates, these rates were not significantly different than Black women’s rates (RR, 1.30 [95% CI, 0.93 to 1.83]).^390^

### CQ 4 What Are the Differences in Rates of Screening or Treatment Initiation Among Persons of Different Races and Ethnicities, and What Might Explain These Differences?

#### Summary

Racial disparities in screening and treatment were found. Black women are less likely to be screened and treated for osteoporosis than White women.^79^ Studies comparing Hispanic and NHW women had mixed results regarding screening but consistently found that Hispanic women were more likely to be treated for osteoporosis. In two different studies, Asian women were found to have similar rates of screening as White women but higher rates of treatment. Differences in screening and treatment could be attributed to patient factors (such as awareness of osteoporosis, competing health issues that require greater attention), clinician factors (e.g., knowledge and bias), and system factors related to differences in where patients access care.

#### Detailed Information

Racial disparities in osteoporosis screening and treatment exist (see Appendix A Tables 6 and 7). In the United States, Black women are less likely than White women to be screened^79,^ ^391–397^ and treated for osteoporosis,^97,^ ^398–400^ even after diagnosis of fracture.^401–405^ They are also less likely than White women to receive preventive antiosteoporosis treatment after steroid initiation.^406^ For example, in a 2015 retrospective clinic-based cohort study of women without prior treatment, screening, or diagnosis of osteoporosis (N=50,995), Black women were far less likely than White women (HR, 0.60 [95% CI, 0.54 to 0.65]) to have an incident DXA.^391^ Comparisons between White women and other racial groups were mixed and sometimes inconsistent. Compared with White women, studies reported inconsistent findings: depending on the study, Hispanic women had lower,^397^ similar,^391^ or higher^394^ rates of incident DXA. Hispanic women were also found to have higher rates of treatment after fracture^402,^ ^403^ and after a diagnosis of osteoporosis^400^ than White women. Asian women were also found to have similar rates of incident DXA^391^ but higher rates of treatment^400^ after a diagnosis of osteoporosis compared with White women.^407^

Appendix A Table 6 Racial Differences in BMD Testing for Osteoporosis in Women Age 60 Years or Older

Race/Ethnicity | HR (95% CI) | | OR (95% CI) | | | | Proportion Receiving Testing
White | Referent group^61^ | Referent group^64^ | 5.96 (3.01 to 11.79)^62^ | Referent group^65^ | Referent group^66^ | Referent group^67^ | 38.4% (p<0.05)^63^
Asian | 1.04 (0.96 to 1.13)
Black | 0.60 (0.54 to 0.65) | 0.695 (p<0.05) | Reference group | 0.39 (0.22 to 0.68) | 0.47 (0.39 to 0.58) | 0.52 (0.43 to 0.62) | 29.8%
Hispanic | 0.93 (0.86 to 1.01) | 1.571 (p<0.05) | | | | 0.66 (0.54 to 0.80)
Other | 0.95 (0.87 to 1.04)
Unknown | 1.01 (0.96 to 1.06)

Abbreviations: BMD=bone mineral density; CI=confidence interval; HR=hazard ratio; OR=odds ratio.

Appendix A Table 7 Racial Differences in Osteoporosis Treatment

Race/Ethnicity | OR (95% CI) | | | Marginal Effects^*^ | Proportion Receiving Treatment
White | Referent group^66^ | 2.23 (1.76 to 2.84)^68^ | Referent group^69^ | Referent group^71^ | 89.2% (p<0.05)^63^
Asian | | | | 0.175 (0.139 to 0.211)
Black | 0.35 (0.30 to 0.41) | Referent group | 0.36 (0.31 to 0.42) | −0.024 (−0.046 to −0.002) | 79.6%
Hispanic | | | | 0.076 (0.051 to 0.103)
Other | | 1.76 (1.21 to 2.55) | | 0.041 (−0.010 to 0.092)
Unknown | | | | Included in “other”

* From logistic regression models; represent the change in predicted probability of treatment. Positive values represent higher likelihood of receiving treatment compared with White persons; negative values indicate lower likelihood of receiving treatment compared with White persons.

Abbreviations: CI=confidence interval; OR=odds ratio.

In Burgess and colleagues’ review of provider contributions to racial health disparities, the authors described how ecological fallacies, whereby an individual is presumed to represent the racial population to which they belong, can contribute to disparities.^408^ As such, the data indicating that White women are at greatest risk of fractures may result in reduced osteoporosis screening and treatment for those who do not share that identity. In fact, in a Canadian qualitative study of adults ages 50 to 79 years with a history of fracture, the authors found that provider understanding about racial differences in bone fragility was a barrier to BMD testing and treatment in a group of adults for which BMD testing would most certainly be indicated.^409^ In a breakout session examining barriers to equitable osteoporosis care, participants identified lack of knowledge regarding the need to screen racially minoritized patients as a barrier.^410^ Thus, racial disparities in fracture risk at a population level can translate into underscreening and undertreatment among racially and ethnically minoritized people.

Differences in care could also be attributed to provider bias, although we did not find any studies examining bias as it relates to osteoporosis screening or treatment. A study by Van Ryn and colleagues found that physicians held negative views of Black patients compared with White patients.^411^ Additionally, studies showing racial disparities in pain management indicated that provider bias has significant impacts on patient care.^412^ Racial animosity may unconsciously result in less time spent counseling and educating patients on their risk of osteoporosis and less interest in motivating and encouraging patients to complete screening. A recent study found that provider assumptions about the values held by racially and ethnically minoritized persons presented a barrier to advanced care planning.^413^ Likewise, beliefs about patients’ values regarding preventive care may also be associated with the extent to which clinicians spend time educating patients on osteoporosis and fracture risk and the effort they invest in ensuring that their patients get screened.

Racial differences in where patients access care may also be a contributor to racial differences in osteoporosis management. Racial and ethnic minorities are more likely than White patients to be seen by resident physicians,^414^ who offer little patient continuity.^415^ Lack of continuity may result in disengagement in preventive services. Few studies have been conducted evaluating resident and faculty care, with mixed results. One study found that residents and faculty scored similarly on health counseling metrics.^414^ A more recent study found that residents’ patients fared worse in chronic disease management and cancer screening than those of faculty.^416^

Patient factors also contribute to racial differences in osteoporosis screening and treatment. Solomon and colleagues found that patients who did not identify as White were less likely to adhere to osteoporosis treatment than those who did identify as White.^405^ There are many explanations for this finding, for example, differences in care seeking for preventive care in general or the belief by patients themselves that Black women do not get osteoporosis could lead to reduced uptake of preventive treatments. In a qualitative study evaluating osteoporosis treatment preferences and medication adherence, some African American participants reported lack of interest in osteoporosis treatment given their low risk of fracture.^417^ In this study, prescription fatigue was also a reason patients described for not taking medications, a problem of greater relevance to populations with a higher burden of disease. Medication cost could also be a factor: lower-income patients reduce pill burden to save money. Racial differences in educational achievement, a function of structural racism^418^ that results in economic and educational inequity, likely translate into racial differences in osteoporosis knowledge,^419^ which has an impact on treatment adherence.