# References

1 U. S. Preventive Services Task Force, Grossman DC, Bibbins-Domingo K, . Screening for Obesity in Children and Adolescents: US Preventive Services Task Force Recommendation Statement. JAMA. 2017;317(23):2417–26. PMID: 28632874. 10.1001/jama.2017.6803 28632874
2 U. S. Preventive Services Task Force, Curry SJ, Krist AH, . Behavioral Weight Loss Interventions to Prevent Obesity-Related Morbidity and Mortality in Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2018;320(11):1163–71. PMID: 30326502. 10.1001/jama.2018.13022 30326502
3 Centers for Disease Control and Prevention. Defining Childhood Weight Status. https://www.cdc.gov/obesity/childhood/defining.html. Accessed: 11/1/2021.
4 Hampl SE, Hassink SG, Skinner AC, . Clinical Practice Guideline for the Evaluation and Treatment of Children and Adolescents With Obesity. Pediatrics. 2023. PMID: 36622115. 10.1542/peds.2022-060640 36622115
5 Kuczmarski RJ, Ogden CL, Guo SS, . 2000 CDC Growth Charts for the United States: methods and development. Vital Health Stat 11. 2002(246):1–190. PMID: 12043359.12043359
6 Flegal KM, Ogden CL. Childhood obesity: are we all speaking the same language? Adv Nutr. 2011;2(2):159S–66S. PMID: 22332047. 10.3945/an.111.000307 22332047
7 Hales CM, Freedman DS, Akinbami L, . Evaluation of Alternative Body Mass Index (BMI) Metrics to Monitor Weight Status in Children and Adolescents With Extremely High BMI Using CDC BMI-for-age Growth Charts. Vital Health Stat 1. 2022(197):1–42. PMID: 36598420.36598420
8 Puhl RM, Himmelstein MS. Adolescent preferences for weight terminology used by health care providers. Pediatr Obes. 2018;13(9):533–40. PMID: 29573233. 10.1111/ijpo.12275 29573233
9 Krebs NF, Himes JH, Jacobson D, . Assessment of child and adolescent overweight and obesity. Pediatrics. 2007;120 Suppl 4:S193–228. PMID: 18055652. 10.1542/peds.2007-2329D 18055652
10 Barlow SE, Dietz WH. Obesity evaluation and treatment: Expert Committee recommendations. The Maternal and Child Health Bureau, Health Resources and Services Administration and the Department of Health and Human Services. Pediatrics. 1998;102(3):E29. PMID: 9724677. 10.1542/peds.102.3.e29 9724677
11 Cole TJ, Bellizzi MC, Flegal KM, . Establishing a standard definition for child overweight and obesity worldwide: international survey. Bmj. 2000;320(7244):1240–3. PMID: 10797032. 10.1136/bmj.320.7244.1240 10797032
12 Ryder JR, Kaizer AM, Rudser KD, . Utility of Body Mass Index in Identifying Excess Adiposity in Youth Across the Obesity Spectrum. J Pediatr. 2016;177:255–61 e2. PMID: 27496270. 10.1016/j.jpeds.2016.06.059 27496270
13 Kumar S, Kelly AS. Review of Childhood Obesity: From Epidemiology, Etiology, and Comorbidities to Clinical Assessment and Treatment. Mayo Clin Proc. 2017;92(2):251–65. PMID: 28065514. 10.1016/j.mayocp.2016.09.017 28065514
14 Flegal KM, Ogden CL, Yanovski JA, . High adiposity and high body mass index-for-age in US children and adolescents overall and by race-ethnic group. Am J Clin Nutr. 2010;91(4):1020–6. PMID: 20164313. 10.3945/ajcn.2009.28589 20164313
15 Stierman B, Afful J, Carroll MD, . National Health and Nutrition Examination Survey 2017–March 2020 Prepandemic Data Files—Development of Files and Prevalence Estimates for Selected Health Outcomes. https://www.cdc.gov/nchs/data/nhsr/nhsr158-508.pdf. Accessed: 2/28/2024.
16 Fryer C, Carroll M, Afful J. Prevalence of Overweight, Obesity, and Severe Obesity Among Children and Adolescents Aged 2–19 Years: United States, 1963–1965 Through 2017–2018. https://www.cdc.gov/nchs/data/hestat/obesity-child-17-18/obesity-child.htm#Suggested%20citation. Accessed: 2/28/2024.
17 Centers for Disease Control and Prevention. High School YRBS: 2019 Results. https://nccd.cdc.gov/youthonline/app/Results.aspx?LID=XX. Accessed: 9/7/2023.
18 Martin CB, Herrick KA, Sarafrazi N, . Attempts to Lose Weight Among Adults in the United States, 2013-2016. NCHS Data Brief. 2018;Jul(313):1–8. PMID: 30044214.30044214
19 Han L., You D., Zeng F., . Trends in Self-perceived Weight Status, Weight Loss Attempts, and Weight Loss Strategies Among Adults in the United States, 1999-2016. JAMA Netw Open. 2019;2(11):e1915219. PMID: 31722029. 10.1001/jamanetworkopen.2019.15219 31722029
20 U. S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. https://www.uspreventiveservicestaskforce.org/uspstf/sites/default/files/inline-files/procedure-manual-2021_0.pdf. Accessed: 2/28/2024.
21 LeBlanc EL, Patnode CD, Webber EM, . Behavioral and Pharmacotherapy Weight Loss Interventions to Prevent Obesity-Related Morbidity and Mortality in Adults: An Updated Systematic Review for the U.S. Preventive Services Task Force. https://www.ncbi.nlm.nih.gov/pubmed/30354042. Accessed: 2/28/2024.
22 Singh N, Stewart RAH, Benatar JR. Intensity and duration of lifestyle interventions for long-term weight loss and association with mortality: a meta-analysis of randomised trials. BMJ Open. 2019;9(8):e029966. PMID: 31427335. 10.1136/bmjopen-2019-029966 31427335
23 Jacobs DR, Jr., Woo JG, Sinaiko AR, . Childhood Cardiovascular Risk Factors and Adult Cardiovascular Events. N Engl J Med. 2022;386(20):1877–88. PMID: 35373933. 10.1056/NEJMoa2109191 35373933
24 Nuotio J, Laitinen TT, Sinaiko AR, . Obesity during childhood is associated with higher cancer mortality rate during adulthood: the i3C Consortium. Int J Obes (Lond). 2022;46(2):393–9. PMID: 34728776. 10.1038/s41366-021-01000-3 34728776
25 Hu T, Jacobs DR, Jr., Sinaiko AR, . Childhood BMI and Fasting Glucose and Insulin Predict Adult Type 2 Diabetes: The International Childhood Cardiovascular Cohort (i3C) Consortium. Diabetes Care. 2020;43(11):2821–9. PMID: 32873588. 10.2337/dc20-0822 32873588
26 Yan Y, Bazzano LA, Juonala M, . Long-Term Burden of Increased Body Mass Index from Childhood on Adult Dyslipidemia: The i3C Consortium Study. J Clin Med. 2019;8(10). PMID: 31635325. 10.3390/jcm8101725 31635325
27 Simmonds M, Llewellyn A, Owen CG, . Predicting adult obesity from childhood obesity: a systematic review and meta-analysis. Obes Rev. 2016;17(2):95–107. PMID: 26696565. 10.1111/obr.12334 26696565
28 Woo JG, Zhang N, Fenchel M, . Prediction of adult class II/III obesity from childhood BMI: the i3C consortium. Int J Obes (Lond). 2020;44(5):1164–72. PMID: 31597933. 10.1038/s41366-019-0461-6 31597933
29 Global B.M.I. Mortality Collaboration, Di Angelantonio E, Bhupathiraju Sh N, . Body-mass index and all-cause mortality: individual-participant-data meta-analysis of 239 prospective studies in four continents. Lancet. 2016;388(10046):776–86. PMID: 27423262. 10.1016/S0140-6736(16)30175-1 27423262
30 Flegal KM, Kit BK, Orpana H, . Association of all-cause mortality with overweight and obesity using standard body mass index categories: a systematic review and meta-analysis. JAMA. 2013;309(1):71–82. PMID: 23280227. 10.1001/jama.2012.113905 23280227
31 Aune D, Sen A, Prasad M, . BMI and all cause mortality: systematic review and non-linear dose-response meta-analysis of 230 cohort studies with 3.74 million deaths among 30.3 million participants. Bmj. 2016;353:i2156. PMID: 27146380. 10.1136/bmj.i2156 27146380
32 Barry VW, Baruth M, Beets MW, . Fitness vs. fatness on all-cause mortality: a meta-analysis. Prog Cardiovasc Dis. 2014;56(4):382–90. PMID: 24438729. 10.1016/j.pcad.2013.09.002 24438729
33 Matheson EM, King DE, Everett CJ. Healthy lifestyle habits and mortality in overweight and obese individuals. J Am Board Fam Med. 2012;25(1):9–15. PMID: 22218619. 10.3122/jabfm.2012.01.110164 22218619
34 Madsen KA, Thompson HR, Linchey J, . Effect of School-Based Body Mass Index Reporting in California Public Schools: A Randomized Clinical Trial. JAMA Pediatrics. 2021;175(3):251–9. PMID: 33196797. 10.1001/jamapediatrics.2020.4768 33196797
35 Haqq AM, Kebbe M, Tan Q, . Complexity and Stigma of Pediatric Obesity. Child Obes. 2021;17(4):229–40. PMID: 33780639. 10.1089/chi.2021.0003 33780639
36 Hunger JM, Tomiyama AJ. Weight labeling and obesity: a longitudinal study of girls aged 10 to 19 years. JAMA Pediatr. 2014;168(6):579–80. PMID: 24781349. 10.1001/jamapediatrics.2014.122 24781349
37 Hunger JM, Tomiyama AJ. Weight Labeling and Disordered Eating Among Adolescent Girls: Longitudinal Evidence From the National Heart, Lung, and Blood Institute Growth and Health Study. J Adolesc Health. 2018;63(3):360–2. PMID: 29705495. 10.1016/j.jadohealth.2017.12.016 29705495
38 Neumark-Sztainer D, Wall M, Larson NI, . Dieting and disordered eating behaviors from adolescence to young adulthood: findings from a 10-year longitudinal study. J Am Diet Assoc. 2011;111(7):1004–11. PMID: 21703378. 10.1016/j.jada.2011.04.012 21703378
39 Solmi F, Sharpe H, Gage SH, . Changes in the Prevalence and Correlates of Weight-Control Behaviors and Weight Perception in Adolescents in the UK, 1986-2015. JAMA Pediatrics. 2021;175(3):267–75. PMID: 33196811. 10.1001/jamapediatrics.2020.4746 33196811
40 Neumark-Sztainer D, Wall M, Guo J, . Obesity, disordered eating, and eating disorders in a longitudinal study of adolescents: how do dieters fare 5 years later? J Am Diet Assoc. 2006;106(4):559–68. PMID: 16567152. 10.1016/j.jada.2006.01.003 16567152
41 Davison KK, Birch LL. Weight status, parent reaction, and self-concept in five-year-old girls. Pediatrics. 2001;107(1):46–53. PMID: 11134433. 10.1542/peds.107.1.46 11134433
42 Sattler E. Your Child’s Weight: Helping without Harming (Birth through Adolescence). Madison, WI: Kelcy Press; 2005.
43 Palad CJ, Yarlagadda S, Stanford FC. Weight stigma and its impact on paediatric care. Curr Opin Endocrinol Diabetes Obes. 2019;26(1):19–24. PMID: 30516550. 10.1097/MED.0000000000000453 30516550
44 Richmond TK, Thurston IB, Sonneville KR. Weight-Focused Public Health Interventions—No Benefit, Some Harm. JAMA Pediatrics. 2021;175(3):238–9. PMID: 33196761. 10.1001/jamapediatrics.2020.4777 33196761
45 Unger ES, Kawachi I, Milliren CE, . Protective Misperception? Prospective Study of Weight Self-Perception and Blood Pressure in Adolescents With Overweight and Obesity. J Adolesc Health. 2017;60(6):680–7. PMID: 28214169. 10.1016/j.jadohealth.2016.12.017 28214169
46 Pont SJ, Puhl R, Cook SR, . Stigma Experienced by Children and Adolescents With Obesity. Pediatrics. 2017;140(6). PMID: 29158228. 10.1542/peds.2017-3034 29158228
47 Zhu X, Smith RA, Buteau E. A meta-analysis of weight stigma and health behaviors. Stigma and Health. 2022;7(1):1–13. 10.1037/sah0000352
48 Schvey NA, Shank LM, Tanofsky-Kraff M, . Weight-based teasing in youth: Associations with metabolic and inflammatory markers. Pediatric Obesity. 2021;16(3):e12729. PMID: 33059389. 10.1111/ijpo.12729 33059389
49 Puhl RM, Lessard LM. Weight Stigma in Youth: Prevalence, Consequences, and Considerations for Clinical Practice. Curr Obes Rep. 2020;9(4):402–11. PMID: 33079337. 10.1007/s13679-020-00408-8 33079337
50 Rubino F, Puhl RM, Cummings DE, . Joint international consensus statement for ending stigma of obesity. Nat Med. 2020;26(4):485–97. PMID: 32127716. 10.1038/s41591-020-0803-x 32127716
51 Puhl R, Suh Y. Health Consequences of Weight Stigma: Implications for Obesity Prevention and Treatment. Curr Obes Rep. 2015;4(2):182–90. PMID: 26627213. 10.1007/s13679-015-0153-z 26627213
52 Phelan SM, Burgess DJ, Yeazel MW, . Impact of weight bias and stigma on quality of care and outcomes for patients with obesity. Obes Rev. 2015;16(4):319–26. PMID: 25752756. 10.1111/obr.12266 25752756
53 Eyal N. Denial of Treatment to Obese Patients-the Wrong Policy on Personal Responsibility for Health. Int J Health Policy Manag. 2013;1(2):107–10. PMID: 24596846. 10.15171/ijhpm.2013.18 24596846
54 Puhl RM, Heuer CA. The stigma of obesity: a review and update. Obesity. 2009;17(5):941–64. PMID: 19165161. 10.1038/oby.2008.636 19165161
55 Huizinga MM, Bleich SN, Beach MC, . Disparity in physician perception of patients’ adherence to medications by obesity status. Obesity (Silver Spring). 2010;18(10):1932–7. PMID: 20186132. 10.1038/oby.2010.35 20186132
56 Amy NK, Aalborg A, Lyons P, . Barriers to routine gynecological cancer screening for White and African-American obese women. Int J Obes (Lond). 2006;30(1):147–55. PMID: 16231037. 10.1038/sj.ijo.0803105 16231037
57 Gudzune KA, Beach MC, Roter DL, . Physicians build less rapport with obese patients. Obesity (Silver Spring). 2013;21(10):2146–52. PMID: 23512862. 10.1002/oby.20384 23512862
58 Gudzune KA, Bennett WL, Cooper LA, . Patients who feel judged about their weight have lower trust in their primary care providers. Patient Educ Couns. 2014;97(1). PMID: 25049164. 10.1016/j.pec.2014.06.019 25049164
59 Davis-Coelho K, Waltz J, Davis-Coelho B. Awareness and prevention of bias against fat clients in psychotherapy. Professional Psychology: Research and Practice. 2000;31(6). 10.1037/0735-7028.31.6.682
60 Greves Grow H, Mollie, Cook, . Child obesity associated with social disadvantage of children’s neighborhoods. Social Science & Medicine. 2010;71(3):584–91. PMID: 20541306. 10.1016/j.socscimed.2010.04.018 20541306
61 Patrick H, Nicklas TA. A review of family and social determinants of children’s eating patterns and diet quality. J Am Coll Nutr. 2005;24(2):83–92. PMID: 15798074. 10.1080/07315724.2005.10719448 15798074
62 Centers for Disease Control and Prevention. Childhood Obesity Causes & Consequences. https://www.cdc.gov/obesity/childhood/causes.html. Accessed: 11/23/2020.
63 Motevalli M, Drenowatz C, Tanous DR, . Management of Childhood Obesity—Time to Shift from Generalized to Personalized Intervention Strategies. Nutrients. 2021;13(4):1200. PMID: 33917383. 10.3390/nu13041200 33917383
64 Davison KK, Birch LL. Childhood overweight: a contextual model and recommendations for future research. Obes Rev. 2001;2(3):159–71. PMID: 12120101. 10.1046/j.1467-789x.2001.00036.x 12120101
65 Bouchard C. Genetic determinants of regional fat distribution. Hum Reprod. 1997;12 Suppl 1:1–5. PMID: 9403316. 10.1093/humrep/12.suppl_1.1 9403316
66 Silventoinen K, Jelenkovic A, Sund R, . Genetic and environmental effects on body mass index from infancy to the onset of adulthood: an individual-based pooled analysis of 45 twin cohorts participating in the COllaborative project of Development of Anthropometrical measures in Twins (CODATwins) study. Am J Clin Nutr. 2016;104(2):371–9. PMID: 27413137. 10.3945/ajcn.116.130252 27413137
67 Maclean PS, Bergouignan A, Cornier MA, . Biology’s response to dieting: the impetus for weight regain. Am J Physiol Regul Integr Comp Physiol. 2011;301(3):R581–600. PMID: 21677272. 10.1152/ajpregu.00755.2010 21677272
68 Woo Baidal JA, Locks LM, Cheng ER, . Risk Factors for Childhood Obesity in the First 1,000 Days: A Systematic Review. American Journal of Preventive Medicine. 2016;50(6):761–79. PMID: 26916261. 10.1016/j.amepre.2015.11.012 26916261
69 Voerman E, Santos S, Patro Golab B, . Maternal body mass index, gestational weight gain, and the risk of overweight and obesity across childhood: An individual participant data meta-analysis. PLOS Medicine. 2019;16(2):e1002744. PMID: 30742624. 10.1371/journal.pmed.1002744 30742624
70 Schroeder K, Schuler BR, Kobulsky JM, . The association between adverse childhood experiences and childhood obesity: A systematic review. Obes Rev. 2021;22(7):e13204. PMID: 33506595. 10.1111/obr.13204 33506595
71 Baranowski T, Motil KJ, Moreno JP. Multi-etiological Perspective on Child Obesity Prevention. Curr Nutr Rep. 2019. PMID: 30649714. 10.1007/s13668-019-0256-3 30649714
72 U. S. Department of Agriculture, U. S. Department of Health and Human Services. Dietary Guidelines for Americans: 2020-2025. https://www.dietaryguidelines.gov/sites/default/files/2021-03/Dietary_Guidelines_for_Americans-2020-2025.pdf. Accessed: 2/28/2024, 9th Edition.
73 U. S. Department of Health and Human Services. Physical Activity Guidelines for Americans. https://health.gov/sites/default/files/2019-09/Physical_Activity_Guidelines_2nd_edition.pdf. Accessed: 2/28/2024.
74 Centers for Disease Control and Prevention. Trends in the Prevalence of Physical Activity and Sedentary Behaviors National YRBS: 1991—2019. https://www.cdc.gov/healthyyouth/data/yrbs/pdf/trends/2019_physical_trend_yrbs.pdf. Accessed: 11/23/2022.
75 Guthold R, Stevens GA, Riley LM, . Global trends in insufficient physical activity among adolescents: a pooled analysis of 298 population-based surveys with 1·6 million participants. Lancet Child Adolesc Health. 2020;4(1):23–35. PMID: 31761562. 10.1016/S2352-4642(19)30323-2 31761562
76 Paruthi S, Brooks LJ, D’Ambrosio C, . Recommended Amount of Sleep for Pediatric Populations: A Consensus Statement of the American Academy of Sleep Medicine. J Clin Sleep Med. 2016;12(6):785–6. PMID: 27250809. 10.5664/jcsm.5866 27250809
77 Centers for Disease Control and Prevention. Children (4 months to 14 years) Sleep Data. https://www.cdc.gov/sleep/data-and-statistics/children.html. Accessed: 11/23/2022.
78 Centers for Disease Control and Prevention. High School Students Sleep Data. https://www.cdc.gov/sleep/data-and-statistics/high-school-students.html. Accessed: 11/23/2022.
79 American Academy of Pediatrics Council on Communications and Media, Hill D, Ameenuddin N, . Media Use in School-Aged Children and Adolescents. Pediatrics. 2016;138(5):e20162592. PMID: 27940794. 10.1542/peds.2016-2592 27940794
80 The Mayo Clinic. Childhood Obesity: Diagnosis and Treatment. https://www.mayoclinic.org/diseases-conditions/childhood-obesity/diagnosis-treatment/drc-20354833. Accessed: 12/6/2021.
81 Food and Drug Administration. NDA 20-766/S-018. https://www.accessdata.fda.gov/drugsatfda_docs/appletter/2003/20766se5-018ltr.pdf. Accessed: 2/28/2024.
82 Mehta A, Marso SP, Neeland IJ. Liraglutide for weight management: a critical review of the evidence. Obes Sci Pract. 2017;3(1):3–14. PMID: 28392927. 10.1002/osp4.84 28392927
83 U. S. Food & Drug Administration. FDA approves weight management drug for patients aged 12 and older. https://www.fda.gov/drugs/news-events-human-drugs/fda-approves-weight-management-drug-patients-aged-12-and-older. Accessed: 11/23/2022.
84 U. S. Food & Drug Administration. New Drug Therapy Approvals 2022. https://www.fda.gov/drugs/new-drugs-fda-cders-new-molecular-entities-and-new-therapeutic-biological-products/new-drug-therapy-approvals-2022#pediatric. Accessed: March 24, 2023.
85 U. S. Food & Drug Administration. FDA approves treatment for chronic weight management in pediatric patients aged 12 years and older. https://www.fda.gov/drugs/news-events-human-drugs/fda-approves-treatment-chronic-weight-management-pediatric-patients-aged-12-years-and-older. Accessed: 11/23/2022.
86 Lonneman DJ Jr, Rey JA, McKee BD. Phentermine/Topiramate extended-release capsules (qsymia) for weight loss. Pharmacy and Therapeutics. 2013;38(8):446–52. PMID: 24222976.24222976
87 Eisenberg D, Shikora SA, Aarts E, . 2022 American Society of Metabolic and Bariatric Surgery (ASMBS) and International Federation for the Surgery of Obesity and Metabolic Disorders (IFSO) Indications for Metabolic and Bariatric Surgery. Obes Surg. 2022. PMID: 36336720. 10.1007/s11695-022-06332-1 36336720
88 Pratt JSA, Browne A, Browne NT, . ASMBS pediatric metabolic and bariatric surgery guidelines, 2018. Surg Obes Relat Dis. 2018;14(7):882–901. PMID: 30077361. 10.1016/j.soard.2018.03.019 30077361
89 Armstrong SC, Bolling CF, Michalsky MP, . Pediatric Metabolic and Bariatric Surgery: Evidence, Barriers, and Best Practices. Pediatrics. 2019;144(6):12. PMID: 31656225. 10.1542/peds.2019-3223 31656225
90 U. S. Preventive Services Task Force, Mangione CM, Barry MJ, . Screening for Prediabetes and Type 2 Diabetes in Children and Adolescents: US Preventive Services Task Force Recommendation Statement. JAMA. 2022;328(10):963–7. PMID: 36098719. 10.1001/jama.2022.14543 36098719
91 U. S. Preventive Services Task Force, Davidson KW, Barry MJ, . Screening for Eating Disorders in Adolescents and Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2022;327(11):1061–7. PMID: 35289876. 10.1001/jama.2022.1806 35289876
92 U. S. Preventive Services Task Force, Krist AH, Davidson KW, . Screening for High Blood Pressure in Children and Adolescents: US Preventive Services Task Force Recommendation Statement. JAMA. 2020;324(18):1878–83. PMID: 33170248. 10.1001/jama.2020.20122 33170248
93 U. S. Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Screening for Lipid Disorders in Children and Adolescents: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;316(6):625–33. PMID: 27532917. 10.1001/jama.2016.9852 27532917
94 O’Connor EA, Evans CV, Burda BU, . Screening for Obesity and Interventions for Weight Management in Children and Adolescents: A Systematic Evidence Review for the U.S. Preventive Services Task Force. https://www.ncbi.nlm.nih.gov/pubmed/29364619. Accessed: 2/28/2024.
95 O’Connor EA, Evans CV, Rushkin MC, . Behavioral Counseling Interventions to Promote a Healthy Diet and Physical Activity for Cardiovascular Disease Prevention in Adults With Cardiovascular Risk Factors: Updated Systematic Review for the U.S. Preventive Services Task Force. https://www.ncbi.nlm.nih.gov/pubmed/33332064. Accessed: 2/28/2024.
96 Cooper C, Varley-Campbell J, Carter P. Established search filters may miss studies when identifying randomized controlled trials. J Clin Epidemiol. 2019;112:12–9. PMID: 30986533. 10.1016/j.jclinepi.2019.04.002 30986533
97 Lefebvre C, Glanville J, Briscoe S, . Chapter 4: Searching for and selecting studies. In: Higgins J, Thomas J, Chandler J, Cumpston M, Li T, Page M, ., editors. Cochrane Handbook for Systematic Reviews of Interventions version 6.2 Cochrane; 2021.
98 Epstein LH, Wilfley DE, Kilanowski C, . Family-Based Behavioral Treatment for Childhood Obesity Implemented in Pediatric Primary Care: A Randomized Clinical Trial. JAMA. 2023;329(22):1947–56. PMID: 37314275. 10.1001/jama.2023.8061 37314275
99 United Nations Development Programme. The Next Frontier: Human Development and the Antropocene. https://hdr.undp.org/content/human-development-report-2020. Accessed: 2/28/2024.
100 Ryder JR, Kelly AS, Freedman DS. Metrics matter: Toward consensus reporting of BMI and weight-related outcomes in pediatric obesity clinical trials. Obesity (Silver Spring). 2022;30(3):571–2. PMID: 35043581. 10.1002/oby.23346 35043581
101 Boudreau AD, Kurowski DS, Gonzalez WI, . Latino families, primary care, and childhood obesity: a randomized controlled trial. Am J Prev Med. 2013;44(3 Suppl 3):S247–57. PMID: 23415190. 10.1016/j.amepre.2012.11.026 23415190
102 Raudenbush S. Analyzing effect sizes: Random-effects models. In: Cooper H H L, Valentine JC, editor. The Handbook of Research Synthesis and Meta-Analysis. New York, New York: Russell Sage Foundation; 2009. p. 296–314.
103 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693–710. PMID: 12939780. 10.1002/sim.1482 12939780
104 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. https://www.ncbi.nlm.nih.gov/books/NBK47095/. Accessed: 2/28/2024.
105 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1). PMID: 15615589. 10.1186/1472-6963-4-38 15615589
106 Boutelle KN, Zucker N, Peterson CB, . An intervention based on Schachter’s externality theory for overweight children: The Regulation of Cues pilot. J Pediatr Psychol. 2014;39(4):405–17. PMID: 24459240. 10.1093/jpepsy/jst142 24459240
107 Broccoli S, Davoli AM, Bonvicini L, . Motivational interviewing to treat overweight children: 24-month Followup of a randomized controlled trial. Pediatrics. 2016;137(1):1–10. PMID: 26702030. 10.1542/peds.2015-1979 26702030
108 Bryant M, Farrin A, Christie D, . Results of a feasibility randomised controlled trial (RCT) for WATCH IT: a programme for obese children and adolescents. Clin. 2011;8(6):755–64. PMID: 22024104. 10.1177/1740774511424766 22024104
109 Croker H, Viner RM, Nicholls D, . Family-based behavioural treatment of childhood obesity in a UK National Health Service setting: randomized controlled trial. Int J Obes (Lond). 2012;36(1):16–26. PMID: 21931327. 10.1038/ijo.2011.182 21931327
110 Davis JN, Ventura EE, Tung A, . Effects of a randomized maintenance intervention on adiposity and metabolic risk factors in overweight minority adolescents. Pediatr Obes. 2012;7(1):16–27. PMID: 22434736. 10.1111/j.2047-6310.2011.00002.x 22434736
111 DeBar LL, Stevens VJ, Perrin N, . A primary care-based, multicomponent lifestyle intervention for overweight adolescent females. Pediatrics. 2012;129(3):e611–20. PMID: 22331335. 10.1542/peds.2011-0863 22331335
112 Derwig M, Tiberg I, Bjork J, . A child-centered health dialogue for the prevention of obesity in child health services in Sweden - A randomized controlled trial including an economic evaluation. Obes Sci Pract. 2022;8(1):77–90. PMID: 35127124. 10.1002/osp4.547 35127124
113 Gerards SM, Dagnelie PC, Gubbels JS, . The effectiveness of lifestyle triple p in the Netherlands: a randomized controlled trial. PLoS One. 2015;10(4):e0122240. PMID: 25849523. 10.1371/journal.pone.0122240 25849523
114 Golley RK, Magarey AM, Baur LA, . Twelve-month effectiveness of a parent-led, family-focused weight-management program for prepubertal children: a randomized, controlled trial. Pediatrics. 2007;119(3):517–25. PMID: 17332205. 10.1542/peds.2006-1746 17332205
115 Ho J, Pedersen SD, Virtanen H, . Family Intervention for Obese/Overweight Children Using Portion Control Strategy (FOCUS) for Weight Control: A Randomized Controlled Trial. Glob. 2016;3:2333794X16669014. PMID: 27699184. 10.1177/2333794X16669014 27699184
116 Hofsteenge GH, Chinapaw MJ, Delemarre-van de Waal HA, . Long-term effect of the Go4it group treatment for obese adolescents: a randomised controlled trial. Clin Nutr. 2014;33(3):385–91. PMID: 23810626. 10.1016/j.clnu.2013.06.002 23810626
117 Kalarchian MA, Levine MD, Arslanian SA, . Family-based treatment of severe pediatric obesity: randomized, controlled trial. Pediatrics. 2009;124(4):1060–8. PMID: 19786444. 10.1542/peds.2008-3727 19786444
118 Kalavainen MP, Korppi MO, Nuutinen OM. Clinical efficacy of group-based treatment for childhood obesity compared with routinely given individual counseling. Int J Obes (Lond). 2007;31(10):1500–8. PMID: 17438555. 10.1038/sj.ijo.0803628 17438555
119 Kong AS, Sussman AL, Yahne C, . School-based health center intervention improves body mass index in overweight and obese adolescents. J Obes. 2013;2013:575016. PMID: 23589771. 10.1155/2013/575016 23589771
120 Kose S, Yildiz S. Motivational support programme to enhance health and well-being and promote weight loss in overweight and obese adolescents: A randomized controlled trial in Turkey. Int J Nurs Pract. 2021;27(1):e12878. PMID: 32808423. 10.1111/ijn.12878 32808423
121 Lison JF, Real-Montes JM, Torro I, . Exercise intervention in childhood obesity: a randomized controlled trial comparing hospital-versus home-based groups. Acad Pediatr. 2012;12(4):319–25. PMID: 22634075. 10.1016/j.acap.2012.03.003 22634075
122 Looney SM, Raynor HA. Examining the effect of three low-intensity pediatric obesity interventions: a pilot randomized controlled trial. Clin Pediatr (Phila). 2014;53(14):1367–74. PMID: 25006118. 10.1177/0009922814541803 25006118
123 Love-Osborne K, Fortune R, Sheeder J, . School-based health center-based treatment for obese adolescents: feasibility and body mass index effects. Child Obes. 2014;10(5):424–31. PMID: 25259781. 10.1089/chi.2013.0165 25259781
124 McCallum Z, Wake M, Gerner B, . Outcome data from the LEAP (Live, Eat and Play) trial: a randomized controlled trial of a primary care intervention for childhood overweight/mild obesity. Int J Obes (Lond). 2007;31(4):630–6. PMID: 17160087. 10.1038/sj.ijo.0803509 17160087
125 Mellin LM, Slinkard LA, Irwin CE, Jr. Adolescent obesity intervention: validation of the SHAPEDOWN program. J Am Diet Assoc. 1987;87(3):333–8. PMID: 3819254.3819254
126 Nemet D, Barkan S, Epstein Y, . Short- and long-term beneficial effects of a combined dietary-behavioral-physical activity intervention for the treatment of childhood obesity. Pediatrics. 2005;115(4):e443–e9. PMID: 15805347. 10.1542/peds.2004-2172 15805347
127 Norman G, Huang J, Davila EP, . Outcomes of a 1-year randomized controlled trial to evaluate a behavioral ‘stepped-down’ weight loss intervention for adolescent patients with obesity. Pediatr Obes. 2016;11(1):18–25. PMID: 25702630. 10.1111/ijpo.12013 25702630
128 O’Connor TM, Hilmers A, Watson K, . Feasibility of an obesity intervention for paediatric primary care targeting parenting and children: Helping HAND. Child Care Health Dev. 2013;39(1):141–9. PMID: 22066521. 10.1111/j.1365-2214.2011.01344.x 22066521
129 Patrick K, Norman GJ, Davila EP, . Outcomes of a 12-month technology-based intervention to promote weight loss in adolescents at risk for type 2 diabetes. J Diabetes Sci Technol. 2013;7(3):759–70. PMID: 23759410. 10.1177/193229681300700322 23759410
130 Raynor HA, Osterholt KM, Hart CN, . Efficacy of U.S. paediatric obesity primary care guidelines: two randomized trials. Pediatr Obes. 2012;7(1):28–38. PMID: 22434737. 10.1111/j.2047-6310.2011.00005.x 22434737
131 Reinehr T, Schaefer A, Winkel K, . An effective lifestyle intervention in overweight children: findings from a randomized controlled trial on “Obeldicks light”. Clin Nutr. 2010;29(3):331–6. PMID: 20106567. 10.1016/j.clnu.2009.12.010 20106567
132 Resnicow K, McMaster F, Bocian A, . Motivational interviewing and dietary counseling for obesity in primary care: an RCT. Pediatrics. 2015;135(4):649–57. PMID: 25825539. 10.1542/peds.2014-1880 25825539
133 Sacher PM, Kolotourou M, Chadwick PM, . Randomized controlled trial of the MEND program: a family-based community intervention for childhood obesity. Obesity (Silver Spring). 2010;18 Suppl 1. PMID: 20107463. 10.1038/oby.2009.433 20107463
134 Saelens BE, Sallis JF, Wilfley DE, . Behavioral weight control for overweight adolescents initiated in primary care. Obes Res. 2002;10(1):22–32. PMID: 11786598. 10.1038/oby.2002.4 11786598
135 Savoye M, Shaw M, Dziura J, . Effects of a weight management program on body composition and metabolic parameters in overweight children: a randomized controlled trial. JAMA. 2007;297(24):2697–704. PMID: 17595270. 10.1001/jama.297.24.2697 17595270
136 Savoye M, Caprio S, Dziura J, . Reversal of early abnormalities in glucose metabolism in obese youth: results of an intensive lifestyle randomized controlled trial. Diabetes Care. 2014;37(2):317–24. PMID: 24062325. 10.2337/dc13-1571 24062325
137 Sherwood NE, Levy RL, Seburg EM, . The Healthy Homes/Healthy Kids 5-10 Obesity Prevention Trial: 12 and 24-month outcomes. Pediatric Obesity. 2019;14(8):e12523. PMID: 30873752. 10.1111/ijpo.12523 30873752
138 Smith JD, Berkel C, Carroll AJ, . Health behaviour outcomes of a family based intervention for paediatric obesity in primary care: A randomized type II hybrid effectiveness-implementation trial. Pediatric Obesity. 2021;16(9):e12780. PMID: 33783104. 10.1111/ijpo.12780 33783104
139 Stark LJ, Spear S, Boles R, . A pilot randomized controlled trial of a clinic and home-based behavioral intervention to decrease obesity in preschoolers. Obesity (Silver Spring). 2011;19(1):134–41. PMID: 20395948. 10.1038/oby.2010.87 20395948
140 Stark LJ, Clifford LM, Towner EK, . A pilot randomized controlled trial of a behavioral family-based intervention with and without home visits to decrease obesity in preschoolers. J Pediatr Psychol. 2014;39(9):1001–12. PMID: 25080605. 10.1093/jpepsy/jsu059 25080605
141 Stark LJ, Spear Filigno S, Bolling C, . Clinic and Home-Based Behavioral Intervention for Obesity in Preschoolers: A Randomized Trial. Journal of Pediatrics. 2018;192:115–21.e1. PMID: 29150147. 10.1016/j.jpeds.2017.09.063 29150147
142 Stettler N, Wrotniak BH, Hill DL, . Prevention of excess weight gain in paediatric primary care: beverages only or multiple lifestyle factors. The Smart Step Study, a cluster-randomized clinical trial. Pediatr Obes. 2014. PMID: 25251166. 10.1111/ijpo.260 25251166
143 Tanofsky-Kraff M, Wilfley DE, Young JF, . A pilot study of interpersonal psychotherapy for preventing excess weight gain in adolescent girls at-risk for obesity. Int J Eat Disord. 2010;43(8):701–6. PMID: 19882739. 10.1002/eat.20773 19882739
144 Tanofsky-Kraff M, Shomaker LB, Wilfley DE, . Targeted prevention of excess weight gain and eating disorders in high-risk adolescent girls: a randomized controlled trial. Am J Clin Nutr. 2014;100(4):1010–8. PMID: 25240070. 10.3945/ajcn.114.092536 25240070
145 Taveras EM, Gortmaker SL, Hohman KH, . Randomized controlled trial to improve primary care to prevent and manage childhood obesity: the High Five for Kids study. Arch Pediatr Adolesc Med. 2011;165(8):714–22. PMID: 21464376. 10.1001/archpediatrics.2011.44 21464376
146 Taveras EM, Marshall R, Kleinman KP, . Comparative effectiveness of childhood obesity interventions in pediatric primary care: a cluster-randomized clinical trial. JAMA Pediatr. 2015;169(6):535–42. PMID: 25895016. 10.1001/jamapediatrics.2015.0182 25895016
147 Taveras EM, Marshall R, Sharifi M, . Comparative Effectiveness of Clinical-Community Childhood Obesity Interventions: A Randomized Clinical Trial. JAMA Pediatrics. 2017;171(8):e171325. PMID: 28586856. 10.1001/jamapediatrics.2017.1325 28586856
148 Taylor RW, Cox A, Knight L, . A tailored family-based obesity intervention: a randomized trial. Pediatrics. 2015;136(2):281–9. PMID: 26195541. 10.1542/peds.2015-0595 26195541
149 van Grieken A, Veldhuis L, Renders CM, . Population-based childhood overweight prevention: outcomes of the ‘Be active, eat right’ study. PLoS ONE. 2013;8(5):e65376. PMID: 23741491. 10.1371/journal.pone.0065376 23741491
150 Viner RM, Kinra S, Christie D, . Improving the assessment and management of obesity in UK children and adolescents: the PROMISE research programme including a RCT. NIHR Journals Library. 2020;3:3. PMID: 32250582. 10.3310/pgfar08030 32250582
151 Vos RC, Wit JM, Pijl H, . Long-term effect of lifestyle intervention on adiposity, metabolic parameters, inflammation and physical fitness in obese children: a randomized controlled trial. Nutr Diabetes. 2011;1:e9. PMID: 23455021. 10.1038/nutd.2011.5 23455021
152 Wake M, Baur LA, Gerner B, . Outcomes and costs of primary care surveillance and intervention for overweight or obese children: the LEAP 2 randomised controlled trial. Bmj. 2009;339:b3308. PMID: 19729418. 10.1136/bmj.b3308 19729418
153 Wake M, Lycett K, Clifford SA, . Shared care obesity management in 3-10 year old children: 12 month outcomes of HopSCOTCH randomised trial. Bmj. 2013;346:f3092. PMID: 23751902. 10.1136/bmj.f3092 23751902
154 Weigel C, Kokocinski K, Lederer P, . Childhood obesity: concept, feasibility, and interim results of a local group-based, long-term treatment program. J Nutr Educ Behav. 2008;40(6):369–73. PMID: 18984493. 10.1016/j.jneb.2007.07.009 18984493
155 Danne T, Biester T, Kapitzke K, . Liraglutide in an Adolescent Population with Obesity: A Randomized, Double-Blind, Placebo-Controlled 5-Week Trial to Assess Safety, Tolerability, and Pharmacokinetics of Liraglutide in Adolescents Aged 12-17 Years. Journal of Pediatrics. 2017;181:146–53.e3. PMID: 27979579. 10.1016/j.jpeds.2016.10.076 27979579
156 Kelly AS, Auerbach P, Barrientos-Perez M, . A Randomized, Controlled Trial of Liraglutide for Adolescents with Obesity. N Engl J Med. 2020;382(22):2117–28. PMID: 32233338. 10.1056/NEJMoa1916038 32233338
157 Mastrandrea LD, Witten L, Carlsson Petri KC, . Liraglutide effects in a paediatric (7-11 y) population with obesity: A randomized, double-blind, placebo-controlled, short-term trial to assess safety, tolerability, pharmacokinetics, and pharmacodynamics. Pediatric Obesity. 2019;14(5):e12495. PMID: 30653847. 10.1111/ijpo.12495 30653847
158 Chanoine JP, Hampl S, Jensen C, . Effect of orlistat on weight and body composition in obese adolescents: a randomized controlled trial. JAMA. 2005;293(23):2873–83. PMID: 15956632. 10.1001/jama.293.23.2873 15956632
159 Maahs D, de Serna DG, Kolotkin RL, . Randomized, double-blind, placebo-controlled trial of orlistat for weight loss in adolescents. Endocr Pract. 2006;12(1):18–28. PMID: 16524859. 10.4158/EP.12.1.18 16524859
160 Hsia DS, Gosselin NH, Williams J, . A randomized, double-blind, placebo-controlled, pharmacokinetic and pharmacodynamic study of a fixed-dose combination of phentermine/topiramate in adolescents with obesity. Diabetes, Obesity & Metabolism 2020. p. 480–91. PMID: 31696603. 10.1111/dom.13910 31696603
161 Kelly Aaron S, Bensignor Megan O, Hsia Daniel S, . Phentermine/Topiramate for the Treatment of Adolescent Obesity. NEJM Evidence. 2022;1(6):EVIDoa2200014. 10.1056/EVIDoa2200014
162 Weghuber D, Barrett T, Barrientos-Perez M, . Once-Weekly Semaglutide in Adolescents with Obesity. N Engl J Med. 2022;387(24):2245–57. PMID: 36322838. 10.1056/NEJMoa2208601 36322838
163 Kelly S, Melnyk BM, Hoying J. Adolescents as Agents of Parental Healthy Lifestyle Behavior Change: COPE Healthy Lifestyles TEEN Program. Journal of Pediatric Health Care. 2020;34(6):575–83. PMID: 32917424. 10.1016/j.pedhc.2020.06.012 32917424
164 Ray D, Sniehotta F, McColl E, . Barriers and facilitators to implementing practices for prevention of childhood obesity in primary care: A mixed methods systematic review. Obes Rev. 2022;23(4):e13417. PMID: 35064723. 10.1111/obr.13417 35064723
165 Belay B, Frintner MP, Liebhart JL, . US Pediatrician Practices and Attitudes Concerning Childhood Obesity: 2006 and 2017. Journal of Pediatrics. 2019;211:78–84.e2. PMID: 31113716. 10.1016/j.jpeds.2019.04.030 31113716
166 Hansen AR, Duncan DT, Woo Baidal JA, . An increasing trend in health-care professionals notifying children of unhealthy weight status: NHANES 1999-2014. Int J Obes (Lond). 2016;40(10):1480–5. PMID: 27143033. 10.1038/ijo.2016.85 27143033
167 National Committee for Quality Assurance (NCQA). HEDIS 2014: Healthcare Effectiveness Data and Information Set. http://www.ncqa.org/hedis-quality-measurement/hedis-measures. Accessed: 2/28/2024.
168 National Committee for Quality Assurance (NCQA). Weight Assessment and Counseling for Nutrition and Physical Activity for Children/Adolescents (WCC). https://www.ncqa.org/hedis/measures/weight-assessment-and-counseling-for-nutrition-and-physical-activity-for-children-adolescents/. Accessed: 12/7/2022.
169 Satti KF, Tanski SE, Jiang Y, . Improving Care for Childhood Obesity: A Quality Improvement Initiative. Pediatr Qual Saf. 2021;6(3):e412–e. PMID: 34046541. 10.1097/pq9.0000000000000412 34046541
170 Harvey I, Boudreau A, Stephens JM. Adipose tissue in health and disease. Open Biol. 2020;10(12):200291. PMID: 33292104. 10.1098/rsob.200291 33292104
171 Flegal KM, Shepherd JA, Looker AC, . Comparisons of percentage body fat, body mass index, waist circumference, and waist-stature ratio in adults. Am J Clin Nutr. 2009;89(2):500–8. PMID: 19116329. 10.3945/ajcn.2008.26847 19116329
172 Tomiyama AJ, Hunger JM, Nguyen-Cuu J, . Misclassification of cardiometabolic health when using body mass index categories in NHANES 2005-2012. Int J Obes (Lond). 2016;40(5):883–6. PMID: 26841729. 10.1038/ijo.2016.17 26841729
173 Dugas LR, Cao G, Luke AH, . Adiposity is not equal in a multi-race/ethnic adolescent population: NHANES 1999-2004. Obesity (Silver Spring). 2011;19(10):2099–101. PMID: 21436795. 10.1038/oby.2011.52 21436795
174 Martin CB, Stierman B, Yanovski JA, . Body fat differences among US youth aged 8-19 by race and Hispanic origin, 2011-2018. Pediatr Obes. 2022;17(7):e12898. PMID: 35135038. 10.1111/ijpo.12898 35135038
175 Heymsfield SB, Peterson CM, Thomas DM, . Why are there race/ethnic differences in adult body mass index-adiposity relationships? A quantitative critical review. Obes Rev. 2016;17(3):262–75. PMID: 26663309. 10.1111/obr.12358 26663309
176 Freedman DS, Wang J, Thornton JC, . Racial/ethnic differences in body fatness among children and adolescents. Obesity (Silver Spring). 2008;16(5):1105–11. PMID: 18309298. 10.1038/oby.2008.30 18309298
177 Deurenberg P, Deurenberg-Yap M, Foo LF, . Differences in body composition between Singapore Chinese, Beijing Chinese and Dutch children. Eur J Clin Nutr. 2003;57(3):405–9. PMID: 12627175. 10.1038/sj.ejcn.1601569 12627175
178 Deurenberg P, Deurenberg-Yap M, Guricci S. Asians are different from Caucasians and from each other in their body mass index/body fat per cent relationship. Obes Rev. 2002;3(3):141–6. PMID: 12164465. 10.1046/j.1467-789x.2002.00065.x 12164465
179 Deurenberg P, Yap M, van Staveren WA. Body mass index and percent body fat: a meta analysis among different ethnic groups. International journal of obesity and related metabolic disorders : journal of the International Association for the Study of Obesity. 1998;22(12):1164–71. PMID: 9877251. 10.1038/sj.ijo.0800741 9877251
180 Aggarwal R, Bibbins-Domingo K, Yeh RW, . Diabetes Screening by Race and Ethnicity in the United States: Equivalent Body Mass Index and Age Thresholds. Ann Intern Med. 2022;175(6):765–73. PMID: 35533384. 10.7326/M20-8079 35533384
181 American Diabetes Association. 2. Classification and Diagnosis of Diabetes: Standards of Medical Care in Diabetes-2020. Diabetes Care. 2020;43(Suppl 1):S14–S31. PMID: 31862745. 10.2337/dc20-S002 31862745
182 Strings S, Wells C, Bell C, . The association of body mass index and odds of type 2 diabetes mellitus varies by race/ethnicity. Public Health. 2023;215:27–30. PMID: 36634403. 10.1016/j.puhe.2022.11.017 36634403
183 Llewellyn A, Simmonds M, Owen CG, . Childhood obesity as a predictor of morbidity in adulthood: a systematic review and meta-analysis. Obesity Reviews. 2016;17(1):56–67. PMID: 26440472. 10.1111/obr.12316 26440472
184 Cleland V, Tian J, Buscot MJ, . Body-mass index trajectories from childhood to mid-adulthood and their sociodemographic predictors: Evidence from the International Childhood Cardiovascular Cohort (i3C) Consortium. EClinicalMedicine. 2022;48:101440. PMID: 35706485. 10.1016/j.eclinm.2022.101440 35706485
185 Flegal KM, Ioannidis JPA. A meta-analysis but not a systematic review: an evaluation of the Global BMI Mortality Collaboration. J Clin Epidemiol. 2017;88:21–9. PMID: 28435099. 10.1016/j.jclinepi.2017.04.007 28435099
186 Mathur MB, VanderWeele TJ. Assessing Uncontrolled Confounding in Associations of Being Overweight With All-Cause Mortality. JAMA Netw Open. 2022;5(3):e222614. PMID: 35344049. 10.1001/jamanetworkopen.2022.2614 35344049
187 Wing RR, Bolin P, Brancati FL, . Cardiovascular effects of intensive lifestyle intervention in type 2 diabetes. N Engl J Med. 2013;369(2):145–54. PMID: 23796131. 10.1056/NEJMoa1212914 23796131
188 Look Ahead Research Group, Gregg EW, Jakicic JM, . Association of the magnitude of weight loss and changes in physical fitness with long-term cardiovascular disease outcomes in overweight or obese people with type 2 diabetes: a post-hoc analysis of the Look AHEAD randomised clinical trial. Lancet Diabetes Endocrinol. 2016;4(11):913–21. PMID: 27595918. 10.1016/S2213-8587(16)30162-0 27595918
189 Aphramor L. Validity of claims made in weight management research: a narrative review of dietetic articles. Nutr J. 2010;9(30). PMID: 20646282. 10.1186/1475-2891-9-30 20646282
190 Gaesser GA, Angadi SS. Obesity treatment: Weight loss versus increasing fitness and physical activity for reducing health risks. iScience. 2021;24(10):102995. 10.1016/j.isci.2021.102995 34755078
191 Sutin AR, Terracciano A. Body weight misperception in adolescence and incident obesity in young adulthood. Psychol Sci. 2015;26(4):507–11. PMID: 25749701. 10.1177/0956797614566319 25749701
192 Faith MS, Berkowitz RI, Stallings VA, . Parental feeding attitudes and styles and child body mass index: prospective analysis of a gene-environment interaction. Pediatrics. 2004;114(4):e429–36. PMID: 15466068. 10.1542/peds.2003-1075-L 15466068
193 Musher-Eizenman DR, Holub SC, Hauser JC, . The relationship between parents’ anti-fat attitudes and restrictive feeding. Obesity (Silver Spring). 2007;15(8):2095–102. PMID: 17712128. 10.1038/oby.2007.249 17712128
194 Birch LL, Davison KK. Family environmental factors influencing the developing behavioral controls of food intake and childhood overweight. Pediatr Clin North Am. 2001;48(4):893–907. PMID: 11494642. 10.1016/s0031-3955(05)70347-3 11494642
195 Linde JA, Wall MM, Haines J, . Predictors of initiation and persistence of unhealthy weight control behaviours in adolescents. Int J Behav Nutr Phys Act. 2009;6:72. PMID: 19874599. 10.1186/1479-5868-6-72 19874599
196 Neumark-Sztainer D, Hannan PJ, Story M, . Weight-control behaviors among adolescent girls and boys: implications for dietary intake. J Am Diet Assoc. 2004;104(6):913–20. PMID: 15175589. 10.1016/j.jada.2004.03.021 15175589
197 Stice E, Gau JM, Rohde P, . Risk factors that predict future onset of each DSM-5 eating disorder: Predictive specificity in high-risk adolescent females. J Abnorm Psychol. 2017;126(1):38–51. PMID: 27709979. 10.1037/abn0000219 27709979
198 Gillison FB, Lorenc AB, Sleddens EF, . Can it be harmful for parents to talk to their child about their weight? A meta-analysis. Preventive Medicine. 2016;93:135–46. PMID: 27746340. 10.1016/j.ypmed.2016.10.010 27746340
199 Ciciurkaite G, Perry BL. Body weight, perceived weight stigma and mental health among women at the intersection of race/ethnicity and socioeconomic status: insights from the modified labelling approach. Sociol Health Illn. 2018;40(1):18–37. PMID: 28980335. 10.1111/1467-9566.12619 28980335
200 El-Medany AYM, Birch L, Hunt LP, . What Change in Body Mass Index Is Required to Improve Cardiovascular Outcomes in Childhood and Adolescent Obesity through Lifestyle Interventions: A Meta-Regression. Child Obes. 2020;16(7):449–78. PMID: 32780648. 10.1089/chi.2019.0286 32780648
201 Ford AL, Hunt LP, Cooper A, . What reduction in BMI SDS is required in obese adolescents to improve body composition and cardiometabolic health? Arch Dis Child. 2010;95(4):256–61. PMID: 19966092. 10.1136/adc.2009.165340 19966092
202 Reinehr T, Andler W. Changes in the atherogenic risk factor profile according to degree of weight loss. Arch Dis Child. 2004;89(5):419–22. PMID: 15102630. 10.1136/adc.2003.028803 15102630
203 Kolsgaard ML, Joner G, Brunborg C, . Reduction in BMI z-score and improvement in cardiometabolic risk factors in obese children and adolescents. The Oslo Adiposity Intervention Study - a hospital/public health nurse combined treatment. BMC Pediatr. 2011;11(47). PMID: 21619652. 10.1186/1471-2431-11-47 21619652
204 Reinehr T, Lass N, Toschke C, . Which Amount of BMI-SDS Reduction Is Necessary to Improve Cardiovascular Risk Factors in Overweight Children? J Clin Endocrinol Metab. 2016;101(8):3171–9. PMID: 27285295. 10.1210/jc.2016-1885 27285295
205 Kirk S, Zeller M, Claytor R, . The relationship of health outcomes to improvement in BMI in children and adolescents. Obes Res. 2005;13(5):876–82. PMID: 15919841. 10.1038/oby.2005.101 15919841
206 Centers for Disease Control and Prevention. Losing Weight. https://www.cdc.gov/healthyweight/losing_weight/index.html. Accessed: 04, 2023.
207 Douketis JD, Macie C, Thabane L, . Systematic review of long-term weight loss studies in obese adults: clinical significance and applicability to clinical practice. Int J Obes (Lond). 2005;29(10):1153–67. PMID: 15997250. 10.1038/sj.ijo.0802982 15997250
208 U. S. Food and Drug Administration, Center for Drug Evaluation and Research. Developing Products for Weight Management Revision 1. https://www.fda.gov/regulatory-information/search-fda-guidance-documents/developing-products-weight-management-revision-1. Accessed: 12/13/2022.
209 Alobaida M, Alrumayh A, Oguntade AS, . Cardiovascular Safety and Superiority of Anti-Obesity Medications. Diabetes Metab Syndr Obes. 2021;14:3199–208. PMID: 34285527. 10.2147/DMSO.S311359 34285527
210 Knowler WC, Barrett-Connor E, Fowler SE, . Diabetes Prevention Program Research Group. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393–403. PMID: 11832527. 10.1056/NEJMoa012512 11832527
211 Poirier P, Giles TD, Bray GA, . Obesity and cardiovascular disease: pathophysiology, evaluation, and effect of weight loss: an update of the 1997 American Heart Association Scientific Statement on Obesity and Heart Disease from the Obesity Committee of the Council on Nutrition, Physical Activity, and Metabolism. Circulation. 2006;113(6):898–918. PMID: 16380542. 10.1161/CIRCULATIONAHA.106.171016 16380542
212 Abrams P, Levitt Katz LE, Moore RH, . Threshold for improvement in insulin sensitivity with adolescent weight loss. J Pediatr. 2013;163(3):785–90. PMID: 23706362. 10.1016/j.jpeds.2013.04.003 23706362
213 Kumanyika S. The Sociocultural Context for Obesity Prevention and Treatment in Children and Adolescents: Influences of Ethnicity and Gender. In: Freemark M., editor. Pediatric Obesity: Etiology, Pathogenesis and Treatment: Humana Cham; 2018. p. 695–713.
214 Sawyer ADM, van Lenthe F, Kamphuis CBM, . Dynamics of the complex food environment underlying dietary intake in low-income groups: a systems map of associations extracted from a systematic umbrella literature review. Int J Behav Nutr Phys Act. 2021;18(1). PMID: 34256794. 10.1186/s12966-021-01164-1 34256794
215 Bailey ZD, Krieger N, Agénor M, . Structural racism and health inequities in the USA: evidence and interventions. Lancet. 2017;389(10077):1453–63. PMID: 28402827. 10.1016/S0140-6736(17)30569-X 28402827
216 National Center for Chronic Disease Prevention and Health Promotion. Nutrition, Physical Activity, and Obesity: Data, Trend and Maps. https://www.cdc.gov/nccdphp/dnpao/data-trends-maps/index.html. Accessed: 12/5/2022.
217 Zhong D, Gunnar MR, Kelly AS, . Household food insecurity and obesity risk in preschool-aged children: A three-year prospective study. Social Science & Medicine. 2022;307:1–8. PMID: 35816836. 10.1016/j.socscimed.2022.115176 35816836
218 Nobari TZ, Whaley SE, Crespi CM, . Widening socio-economic disparities in early childhood obesity in Los Angeles County after the Great Recession. Public Health Nutrition. 2018;21(12):2301–10. PMID: 29607794. 10.1017/S1368980018000666 29607794
219 Soltero EG, O’Connor TM, Thompson D, . Opportunities to Address Obesity Disparities Among High-Risk Latino Children and Adolescents. Curr Obes Rep. 2021;10(3):332–41. PMID: 34263434. 10.1007/s13679-021-00445-x 34263434
220 Fiechtner L, Kleinman K, Melly SJ, . Effects of Proximity to Supermarkets on a Randomized Trial Studying Interventions for Obesity. Am J Public Health. 2016;106(3):557–62. PMID: 26794159. 10.2105/AJPH.2015.302986 26794159
221 Hill DC, Moss RH, Sykes-Muskett B, . Stress and eating behaviors in children and adolescents: Systematic review and meta-analysis. Appetite. 2018;123:14–22. PMID: 29203444. 10.1016/j.appet.2017.11.109 29203444
222 Thompson C. Dietary health in the context of poverty and uncertainty around the social determinants of health. Proc Nutr Soc. 2022;81(2):134–40. PMID: 34602117. 10.1017/S0029665121003657 34602117
223 Jansen EC, Kasper N, Lumeng JC, . Changes in household food insecurity are related to changes in BMI and diet quality among Michigan Head Start preschoolers in a sex-specific manner. Social Science & Medicine. 2017;181:168–76. PMID: 28407601. 10.1016/j.socscimed.2017.04.003 28407601
224 Yu D, Fang C. How Neighborhood Characteristics Influence Neighborhood Crimes: A Bayesian Hierarchical Spatial Analysis. Int J Environ Res Public Health. 2022;19(18). PMID: 36141688. 10.3390/ijerph191811416 36141688
225 Reuben A, Rutherford GW, James J, . Association of neighborhood parks with child health in the United States. Preventive Medicine: An International Journal Devoted to Practice and Theory Vol 141 2020, ArtID 106265. 2020;141. PMID: 33035547. 10.1016/j.ypmed.2020.106265 33035547
226 Pan X, Zhao L, Luo J, . Access to bike lanes and childhood obesity: A systematic review and meta-analysis. Obesity Reviews. 2021;22 Suppl 1:e13042. PMID: 32419305. 10.1111/obr.13042 32419305
227 Armstrong B, Covington LB, Hager ER, . Objective sleep and physical activity using 24-hour ankle-worn accelerometry among toddlers from low-income families. Sleep Health. 2019;5(5):459–65. PMID: 31171491. 10.1016/j.sleh.2019.04.005 31171491
228 Bowen DJ, Quintiliani LM, Bhosrekar SG, . Changing the housing environment to reduce obesity in public housing residents: a cluster randomized trial. BMC Public Health. 2018;18(1):883. PMID: 30012120. 10.1186/s12889-018-5777-y 30012120
229 Childstats: Forum on Child and Family Statistics. Health Insurance Coverage. https://www.childstats.gov/americaschildren21/care1.asp. Accessed: 11/1/2022.
230 Abdus S, Selden TM. Well-Child Visit Adherence. JAMA Pediatr. 2022;176(11):1143–5. PMID: 35994255. 10.1001/jamapediatrics.2022.2954 35994255
231 Childstats: Forum on Child and Family Statistics. Usual Source of Health Care. https://www.childstats.gov/americaschildren21/care2.asp. Accessed: 11/1/2022.
232 Kelley CP, Sbrocco G, Sbrocco T. Behavioral Modification for the Management of Obesity. Prim Care. 2016;43(1):159–75. PMID: 26896208. 10.1016/j.pop.2015.10.004 26896208
233 Drury CA, Louis M. Exploring the association between body weight, stigma of obesity, and health care avoidance. J Am Acad Nurse Pract. 2002;14(12):554–61. PMID: 12567923. 10.1111/j.1745-7599.2002.tb00089.x 12567923
234 Galli C, Li T. Racial Differences in Diagnosis of Overweight and Obesity: Results from the National Health and Nutrition Examination Survey (NHANES) 2009-2016. J Racial Ethn Health Disparities. 2022:Online ahead of print. PMID: 35394620. 10.1007/s40615-022-01297-4 35394620
235 Bertakis KD, Azari R. The impact of obesity on primary care visits. Obes Res. 2005;13(9):1615–23. PMID: 16222065. 10.1038/oby.2005.198 16222065
236 Lorts C, Ohri-Vachaspati P. Disparities in Who Receives Weight-Loss Advice From a Health Care Provider: Does Income Make a Difference? Prev Chronic Dis. 2016;13:160183. PMID: 27710763. 10.5888/pcd13.160183 27710763
237 Halbert CH, Jefferson M, Melvin CL, . Provider Advice About Weight Loss in a Primary Care Sample of Obese and Overweight Patients. J Prim Care Community Health. 2017;8(4):239–46. PMID: 28643551. 10.1177/2150131917715336 28643551
238 Mooney V, Baur LA, Bereket A, . The views of teenagers with obesity, their caregivers, and doctors: a plain language summary of the ACTION Teens global survey. J Comp Eff Res. 2023;12(1):e220164. PMID: 36264113. 10.2217/cer-2022-0164 36264113
239 Bomberg EM, Palzer EF, Rudser KD, . Anti-obesity medication prescriptions by race/ethnicity and use of an interpreter in a pediatric weight management clinic. Ther. 2022;13:20420188221090009. PMID: 35432917. 10.1177/20420188221090009 35432917
240 GoodRx. Weight Loss Medications. https://www.goodrx.com/conditions/weight-loss/drugs. Accessed: 11/1/2022.
241 Gomez G, Stanford FC. US health policy and prescription drug coverage of FDA-approved medications for the treatment of obesity. Int J Obes (Lond). 2018;42(3):495–500. PMID: 29151591. 10.1038/ijo.2017.287 29151591
242 Lemstra ME, Rogers M. Mental health and socioeconomic status impact adherence to youth activity and dietary programs: a meta-analysis. Obesity Research & Clinical Practice. 2021;15(4):309–14. PMID: 33992571. 10.1016/j.orcp.2021.05.003 33992571
243 Ligthart KAM, Buitendijk L, Koes BW, . The association between ethnicity, socioeconomic status and compliance to pediatric weight-management interventions - A systematic review. Obesity Research & Clinical Practice. 2017;11(5 Suppl 1):1–51. PMID: 27108215. 10.1016/j.orcp.2016.04.001 27108215
244 Lobstein T, Neveux M, Brown T, . Social disparities in obesity treatment for children age 3–10 years: A systematic review. Obesity Reviews. 2021;22(2):e13153. PMID: 33462935. 10.1111/obr.13153 33462935
245 Rees R, Oliver K, Woodman, J., Thomas, J. The views of young children in the UK about obesity, body size, shape and weight: a systematic review. BMC Public Health. 2011;11(188). PMID: 21439062. 10.1186/1471-2458-11-188 21439062
246 Vitolins MZ, Crandall S, Miller D, . Obesity educational interventions in U.S. medical schools: a systematic review and identified gaps. Teach Learn Med. 2012;24(3):267–72 PMID: 22775792. 10.1080/10401334.2012.692286 22775792
247 Callahan D. Obesity: chasing an elusive epidemic. Hastings Cent Rep. 2013;43(1):34–40. PMID: 23254867. 10.1002/hast.114 23254867
248 Puhl RM, Heuer CA. Obesity stigma: important considerations for public health. Am J Public Health. 2010;100(6):1019–28. PMID: 20075322. 10.2105/AJPH.2009.159491 20075322
249 Schwimmer JB, Burwinkle TM, Varni JW. Health-related quality of life of severely obese children and adolescents. JAMA. 2003;289(14):1813–9. PMID: 12684360. 10.1001/jama.289.14.1813 12684360
250 Spiel EC, Paxton SJ, Yager Z. Weight attitudes in 3- to 5-year-old children: age differences and cross-sectional predictors. Body Image. 2012;9(4):524–7. PMID: 22890168. 10.1016/j.bodyim.2012.07.006 22890168
251 Su W, Disanto A. Preschool children’s perceptions of overweight peers. Journal of Early Childhood Research 2012. p. 19–31. 10.1177/1476718X11407411
252 Lumeng JC, Forrest P, Appugliese DP, . Weight status as a predictor of being bullied in third through sixth grades. Pediatrics. 2010;125(6):e1301–7. PMID: 20439599. 10.1542/peds.2009-0774 20439599
253 Patel SL, Holub SC. Body size matters in provision of help: factors related to children’s willingness to help overweight peers. Obesity (Silver Spring). 2012;20(2):382–8. PMID: 21996656. 10.1038/oby.2011.314 21996656
254 Griffiths LJ, Wolke D, Page AS, . Obesity and bullying: different effects for boys and girls. Arch Dis Child. 2006;91(2):121–5. PMID: 16174642. 10.1136/adc.2005.072314 16174642
255 Puhl RM, Luedicke J, Heuer C. Weight-based victimization toward overweight adolescents: observations and reactions of peers. J Sch Health. 2011;81(11):696–703. PMID: 21972990. 10.1111/j.1746-1561.2011.00646.x 21972990
256 Bucchianeri MM, Eisenberg ME, Neumark-Sztainer D. Weightism, racism, classism, and sexism: shared forms of harassment in adolescents. J Adolesc Health. 2013;53(1):47–53. PMID: 23566562. 10.1016/j.jadohealth.2013.01.006 23566562
257 MacCann C, RD. R. Just as smart but not as successful: obese students obtain lower school grades but equivalent test scores to nonobese students. Int J Obes (Lond). 2013;37(1):40–6. PMID: 22531092. 10.1038/ijo.2012.47 22531092
258 Fikkan J, Rothblum ED. Weight bias in employment. In: K. D. Brownell R P, M. B. Schwartz, & L. Rudd, editor. Weight bias: Nature, consequences and remedies. New York, NY: Guilford Press; 2005. p. 15–28.
259 Incollingo Rodriguez AC, White ML, Standen EC, . Body mass index and educational inequality: An update of Crandall (1995). Stigma and Health. 2019;4(3):357–63. 10.1037/sah0000149
260 Puhl RM, Brownell KD. Confronting and coping with weight stigma: an investigation of overweight and obese adults. Obesity (Silver Spring). 2006;14(10):1802–15. PMID: 17062811. 10.1038/oby.2006.208 17062811
261 Sabin JA, Marini M, Nosek BA. Implicit and explicit anti-fat bias among a large sample of medical doctors by BMI, race/ethnicity and gender. PLoS One. 2012;7(11). PMID: 23144885. 10.1371/journal.pone.0048448 23144885
262 Tomiyama AJ, Finch LE, Belsky AC, . Weight bias in 2001 versus 2013: contradictory attitudes among obesity researchers and health professionals. Obesity (Silver Spring). 2015;23(1):46–53. PMID: 25294247. 10.1002/oby.20910 25294247
263 Phelan SM, Dovidio JF, Puhl RM, . Implicit and explicit weight bias in a national sample of 4,732 medical students: the medical student CHANGES study. Obesity (Silver Spring). 2014;22(4):1201–8. PMID: 24375989. 10.1002/oby.20687 24375989
264 McGuigan RD, Wilkinson JM. Obesity and Healthcare Avoidance: A Systematic Review. AIMS Public Health. 2015;2(1):56–63. PMID: 29546095. 10.3934/publichealth.2015.1.56 29546095
265 Cohen ML, Tanofsky-Kraff M, Young-Hyman D, . Weight and its relationship to adolescent perceptions of their providers (WRAP): a qualitative and quantitative assessment of teen weight-related preferences and concerns. J Adolesc Health. 2005;37(2). PMID: 16026727. 10.1016/j.jadohealth.2004.08.025 16026727
266 Neumark-Sztainer D. Preventing obesity and eating disorders in adolescents: what can health care providers do? J Adolesc Health. 2009;44(3):206–13. PMID: 19237105. 10.1016/j.jadohealth.2008.11.005 19237105
267 Puhl RM, Peterson JL, Luedicke J. Parental perceptions of weight terminology that providers use with youth. Pediatrics. 2011;128(4):e786–93. PMID: 21949145. 10.1542/peds.2010-3841 21949145
268 Institute of Medicine, Food and Nutrition Board, Committee on Accelerating Progress in Obesity Prevention. Accelerating Progress in Obesity Prevention: Solving the Weight of the Nation. Accessed: 2/28/2024.
269 Appel LJ, Clark JM, Yeh HC, . Comparative effectiveness of weight-loss interventions in clinical practice. N Engl J Med. 2011;365(21):1959–68. PMID: 22085317. 10.1056/NEJMoa1108660 22085317
270 Hopkins KF D C, Elliott L. How can primary care providers manage pediatric obesity in the real world? J Am Acad Nurse Pract. 2011;23(6):278–88. PMID: 21649770. 10.1111/j.1745-7599.2011.00614.x 21649770
271 Kushner RF, Zeiss DM, Feinglass JM, . An obesity educational intervention for medical students addressing weight bias and communication skills using standardized patients. BMC Med Educ. 2014;14(53). PMID: 24636594. 10.1186/1472-6920-14-53 24636594
272 Matharu K, Shapiro JF, Hammer RR, . Reducing obesity prejudice in medical education. Educ Health (Abingdon). 2014;27(3):231–7. PMID: 25758385. 10.4103/1357-6283.152176 25758385
273 O’Brien KS, Puhl RM, Latner JD, . Reducing anti-fat prejudice in preservice health students: a randomized trial. Obesity (Silver Spring). 2010;18(11):2138–44. PMID: 20395952. 10.1038/oby.2010.79 20395952
274 Persky S, Eccleston CP. Impact of genetic causal information on medical students’ clinical encounters with an obese virtual patient: health promotion and social stigma. Ann Behav Med. 2011;41(3):363–72. PMID: 21136226. 10.1007/s12160-010-9242-0 21136226
275 Poustchi Y, Saks NS, Piasecki AK, . Brief intervention effective in reducing weight bias in medical students. Fam Med. 2013;45(5):345–8. PMID: 23681687.23681687
276 Swift JA, Tischler V, Markham S, . Are anti-stigma films a useful strategy for reducing weight bias among trainee healthcare professionals? Results of a pilot randomized control trial. Obes Facts. 2013;6(1):91–102. PMID: 23466551. 10.1159/000348714 23466551
277 National Institute for Health and Care Excellence. Obesity: identification, assessment and management (Clinical guideline [CG189]). https://www.nice.org.uk/guidance/cg189/resources/obesity-identification-assessment-and-management-pdf-35109821097925. Accessed: 11/11/2022.
278 Browne NT. Obesity and Children. Nurs Clin North Am. 2021;56(4):583–97. PMID: 34749897. 10.1016/j.cnur.2021.07.006 34749897
279 Loveman E, Frampton GK, Shepherd J, . The clinical effectiveness and cost-effectiveness of long-term weight management schemes for adults: a systematic review. Health Technol Assess. 2011;15(2):1–182. PMID: 21247515. 10.3310/hta15020 21247515
280 Wu T, Gao X, Chen M, . Long-term effectiveness of diet-plus-exercise interventions vs. diet-only interventions for weight loss: a meta-analysis. Obes Rev. 2009;10(3):313–23. PMID: 19175510. 10.1111/j.1467-789X.2008.00547.x 19175510
281 Mann T, Tomiyama AJ, Westling E, . Medicare’s search for effective obesity treatments: diets are not the answer. Am Psychol. 2007;62(3):220–33. PMID: 17469900. 10.1037/0003-066x.62.3.220 17469900
282 Neumark-Sztainer D, Wall M, Haines J, . Why does dieting predict weight gain in adolescents? Findings from project EAT-II: a 5-year longitudinal study. J Am Diet Assoc. 2007;107(3):448–55. PMID: 17324664. 10.1016/j.jada.2006.12.013 17324664
283 Call CC, D’Adamo L, Butryn ML, . Examining weight suppression as a predictor and moderator of intervention outcomes in an eating disorder and obesity prevention trial: A replication and extension study. Behaviour Research and Therapy. 2021;141. PMID: 33839586. 10.1016/j.brat.2021.103850 33839586
284 Lowe MR, Marti CN, Lesser EL, . Weight suppression uniquely predicts body fat gain in first-year female college students. Eat. 2019;32:60–4. PMID: 30594109. 10.1016/j.eatbeh.2018.11.005 30594109
285 Ogden LG, Stroebele N, Wyatt HR, . Cluster analysis of the national weight control registry to identify distinct subgroups maintaining successful weight loss. Obesity (Silver Spring). 2012;20(10):2039–47. PMID: 22469954. 10.1038/oby.2012.79 22469954
286 Aronne LJ, Hall KD, J M J, . Describing the Weight-Reduced State: Physiology, Behavior, and Interventions. Obesity (Silver Spring). 2021;29 Suppl 1(Suppl 1):S9–s24. PMID: 33759395. 10.1002/oby.23086 33759395
287 Most J, LM. R. Impact of calorie restriction on energy metabolism in humans. Exp Gerontol. 2020;133(110875). PMID: 32057825. 10.1016/j.exger.2020.110875 32057825
288 Polidori D, Sanghvi A, Seeley RJ, . How Strongly Does Appetite Counter Weight Loss? Quantification of the Feedback Control of Human Energy Intake. Obesity (Silver Spring). 2016;24(11):2289–95. PMID: 27804272. 10.1002/oby.21653 27804272
289 Mackie GM, Samocha-Bonet D, Tam CS. Does weight cycling promote obesity and metabolic risk factors? Obes Res Clin Pract. 2017;11(2):131–9. PMID: 27773644. 10.1016/j.orcp.2016.10.284 27773644
290 Pietiläinen KH, Saarni SE, Kaprio J, . Does dieting make you fat? A twin study. Int J Obes (Lond). 2012;36(3):456–64. PMID: 21829159. 10.1038/ijo.2011.160 21829159
291 Fonvig CE, Hamann SA, Nielsen TRH, . Subjective evaluation of psychosocial well-being in children and youths with overweight or obesity: The impact of multidisciplinary obesity treatment. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care & Rehabilitation. 2017;26(12):3279–88. PMID: 28762099. 10.1007/s11136-017-1667-5 28762099
292 Jebeile H, Gow ML, Baur LA, . Treatment of obesity, with a dietary component, and eating disorder risk in children and adolescents: A systematic review with meta-analysis. Obesity Reviews. 2019;20(9):1287–98. PMID: 31131531. 10.1111/obr.12866 31131531
293 Stice E, Desjardins CD. Interactions between risk factors in the prediction of onset of eating disorders: Exploratory hypothesis generating analyses. Behav Res Ther. 2018;105:52–62. PMID: 29653254. 10.1016/j.brat.2018.03.005 29653254
294 Stice E, Rohde P, Shaw H, . Weight suppression increases odds for future onset of anorexia nervosa, bulimia nervosa, and purging disorder, but not binge eating disorder. Am J Clin Nutr. 2020;112(4):941–7. PMID: 32534455. 10.1093/ajcn/nqaa146 32534455
295 Grilo CM, Masheb RM. Onset of dieting vs binge eating in outpatients with binge eating disorder. International journal of obesity and related metabolic disorders : journal of the International Association for the Study of Obesity. 2000;24(4):404–9. PMID: 10805495. 10.1038/sj.ijo.0801171 10805495
296 Liang JH, Zhao Y, Chen YC, . Face-to-face physical activity incorporated into dietary intervention for overweight/obesity in children and adolescents: a Bayesian network meta-analysis. BMC Med. 2022;20(1):325. PMID: 36056358. 10.1186/s12916-022-02462-6 36056358
297 Epstein LH, Paluch RA, Roemmich JN, . Family-based obesity treatment, then and now: twenty-five years of pediatric obesity treatment. Health Psychol. 2007;26(4):381–91. PMID: 17605557. 10.1037/0278-6133.26.4.381 17605557
298 Simmonds M, Burch J, Llewellyn A, . The use of measures of obesity in childhood for predicting obesity and the development of obesity-related diseases in adulthood: a systematic review and meta-analysis. Health Technol Assess. 2015;19(43):1–336. PMID: 26108433. 10.3310/hta19430 26108433
299 O’Hara L, Taylor J. What’s Wrong With the ‘War on Obesity?’ A Narrative Review of the Weight-Centered Health Paradigm and Development of the 3C Framework to Build Critical Competency for a Paradigm Shift. SAGE Open. 2018;8(2). 10.1177/2158244018772888
300 Strings S. Fearing the Black Body: The Racial Origins of Fat Phobia. New York, NY: New York University Press; 2019.
301 Harrison DL. Belly of the Beast: The Politics of Anti-Fatness as Anti-Blackness. Laymon FbK, editor. Berkeley, CA: North Atlantic Books; 1996.
302 U. S. Food & Drug Administration. Highlights of Prescribing Information: QSYMIA. https://www.accessdata.fda.gov/drugsatfda_docs/label/2022/022580s021lbl.pdf. Accessed: 2/28/2024.
303 U. S. Food & Drug Administration. Highlights of Prescribing Information:: WEGOVY (semaglutide) injection. https://www.accessdata.fda.gov/drugsatfda_docs/label/2022/215256s005lbl.pdf. Accessed: 2/28/2024.
304 Varni JW, Burwinkle TM, Seid M, . The PedsQL 4.0 as a pediatric population health measure: feasibility, reliability, and validity. Ambul Pediatr. 2003;3(6):329–41. PMID: 14616041. 10.1367/1539-4409(2003)003<0329:tpaapp>2.0.co;2 14616041
305 Hilliard ME, Lawrence JM, Modi AC, . Identification of minimal clinically important difference scores of the PedsQL in children, adolescents, and young adults with type 1 and type 2 diabetes. Diabetes Care. 2013;36(7):1891–7. PMID: 23340884. 10.2337/dc12-1708 23340884
306 Jayadevappa R, Cook R, Chhatre S. Minimal important difference to infer changes in health-related quality of life-a systematic review. J Clin Epidemiol. 2017;89:188–98. PMID: 28676426. 10.1016/j.jclinepi.2017.06.009 28676426
307 Jebeile H, Gow ML, Baur LA, . Association of Pediatric Obesity Treatment, Including a Dietary Component, With Change in Depression and Anxiety: A Systematic Review and Meta-analysis. JAMA Pediatrics. 2019;173(11):e192841. PMID: 31524933. 10.1001/jamapediatrics.2019.2841 31524933
308 Plečko D, Bennett N, Mårtensson J, . The obesity paradox and hypoglycemia in critically ill patients. Crit Care. 2021;25(1):378. PMID: 34724956. 10.1186/s13054-021-03795-z 34724956
309 Lee H, Shin H, Oh J, . Association between Body Mass Index and Outcomes in Patients with Return of Spontaneous Circulation after Out-of-Hospital Cardiac Arrest: A Systematic Review and Meta-Analysis. Int J Environ Res Public Health. 2021;18(16):8389. PMID: 34444142. 10.3390/ijerph18168389 34444142
310 Dotan I, Shochat T, Shimon I, . The Association Between BMI and Mortality in Surgical Patients World J Surg. 2021;45(5):1390–9. PMID: 33481082. 10.1007/s00268-021-05961-4 33481082
311 Lin S, Ge S, He W, . Association between Body Mass Index and Short-Term Clinical Outcomes in Critically Ill Patients with Sepsis: A Real-World Study. Biomed Res Int. 2020:5781913. PMID: 33123579. 10.1155/2020/5781913 33123579
312 Barrera SC, Sanford EJ, Ammerman SB, . Postoperative Complications in Obese Patients After Tracheostomy. OTO Open. 2020;4(3):2473974X20953090. PMID: 32923919. 10.1177/2473974X20953090 32923919
313 Bouslama M, Perez HJ, Barreira CM, . Body Mass Index and Clinical Outcomes in Large Vessel Occlusion Acute Ischemic Stroke after Endovascular Therapy. Interv Neurol. 2020;8(2–6):144–51. PMID: 32508896. 10.1159/000496703 32508896
314 Fildes A, Charlton J, Rudisill C, . Probability of an Obese Person Attaining Normal Body Weight: Cohort Study Using Electronic Health Records. Am J Public Health. 2015;105(9):e54–e9. PMID: 26180980. 10.2105/AJPH.2015.302773 26180980
315 Hunger JM, Smith JP, Tomiyama AJ. An evidence-based rationale for adopting weight-inclusive health policy. Social Issues and Policy Review. 2020;14(1):73–107. 10.1111/sipr.12062
316 McPhail D, Orsini M. Fat acceptance as social justice. Cmaj. 2021;193(35):E1398–E9. PMID: 34493569. 10.1503/cmaj.210772 34493569
317 Hoelscher DM, Brann LS, O’Brien S, . Prevention of Pediatric Overweight and Obesity: Position of the Academy of Nutrition and Dietetics Based on an Umbrella Review of Systematic Reviews. J Acad Nutr Diet. 2022;122(2):410–23.e6. PMID: 35065817. 10.1016/j.jand.2021.11.003 35065817
318 Association for Size Diversity and Health (ASDAH). About Health at Every Size (HAES). http://asdah.org/health-at-every-size-haes-approach. Accessed: 12/13/2022.
319 Warren JM, Smith N, Ashwell M. A structured literature review on the role of mindfulness, mindful eating and intuitive eating in changing eating behaviours: effectiveness and associated potential mechanisms. Nutr Res Rev. 2017;30(2):272–83. PMID: 28718396. 10.1017/S0954422417000154 28718396
320 Hazzard VM, Telke SE, Simone M, . Intuitive eating longitudinally predicts better psychological health and lower use of disordered eating behaviors: findings from EAT 2010-2018. Eat Weight Disord. 2021;26(1):287–94. PMID: 32006391. 10.1007/s40519-020-00852-4 32006391
321 Kitzmann KM, Beech BM. Family-based interventions for pediatric obesity: methodological and conceptual challenges from family psychology. J Fam Psychol. 2006;20(2):175–89. PMID: 16756393. 10.1037/0893-3200.20.2.175 16756393
322 Woo JG. Using body mass index Z-score among severely obese adolescents: a cautionary note. Int J Pediatr Obes. 2009;4(4):405–10. PMID: 19922058. 10.3109/17477160902957133 19922058
323 Guide to Community Preventive Services. Summary of CPSTF Findings and Evidence: Intervention Approaches to Prevent and Control Obesity in Schools. https://www.thecommunityguide.org/pages/summary-cpstf-findings-evidence-intervention-approaches-prevent-control-obesity-schools.html. Accessed: 12/12/2022.
324 Guide to Community Preventive Services. Obesity. https://www.thecommunityguide.org/topics/obesity.html#cc-widget-019f. Accessed: 12/12/2022.
325 Obesity Action Coalition. People-first Language for Obesity. https://www.obesityaction.org/wp-content/uploads/1033162_FirstPersonOne-Pager01_041921.pdf. Accessed: 04, 2023.
326 Meadows A, Danielsdottir S. What’s in a Word? On Weight Stigma and Terminology. Front Psychol. 2016;7:1527. PMID: 27761122. 10.3389/fpsyg.2016.01527 27761122
327 Dennett C. The Perils of Person-First Language. Todays Dietitian [serial on the Internet]. 2022: Available from: https://www.todaysdietitian.com/enewsletter/enews_0118_01.shtml.
328 Bau AM, Ernert A, Krude H, . Hormonal regulatory mechanisms in obese children and adolescents after previous weight reduction with a lifestyle intervention: maintain - paediatric part - a RCT from 2009-15. BMC Obesity. 2016;3:29. PMID: 27298729. 10.1186/s40608-016-0110-8 27298729
329 Soltero EG, Olson ML, Williams AN, . Effects of a Community-Based Diabetes Prevention Program for Latino Youth with Obesity: A Randomized Controlled Trial. Obesity. 2018;26(12):1856–65. PMID: 30426694. 10.1002/oby.22300 30426694
330 Hoare JK, Lister NB, Garnett SP, . Weight-neutral interventions in young people with high body mass index: A systematic review. Nutr Diet. 2023;80(1):8–20. PMID: 35411702. 10.1111/1747-0080.12729 35411702
331 Dorenbos E, Drummen M, Rijks J, . PREVIEW (Prevention of Diabetes Through Lifestyle Intervention and Population Studies in Europe and Around the World) study in children aged 10 to 17 years: Design, methods and baseline results. Diabetes, Obesity & Metabolism. 2018;20(5):1096–101. PMID: 29322617. 10.1111/dom.13216 29322617
332 Soltero EG, Konopken YP, Olson ML, . Preventing diabetes in obese Latino youth with prediabetes: a study protocol for a randomized controlled trial. BMC Public Health. 2017;17(1):261. PMID: 28302101. 10.1186/s12889-017-4174-2 28302101
333 Williams AN, Konopken YP, Keller CS, . Culturally-grounded diabetes prevention program for obese Latino youth: Rationale, design, and methods. Contemporary Clinical Trials. 2017;54:68–76. PMID: 28104469. 10.1016/j.cct.2017.01.004 28104469
334 Patnode CD, Redmond N, Iacocca MO, . Behavioral Counseling Interventions to Promote a Healthy Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Known Cardiovascular Disease Risk Factors: Updated Systematic Review for the U.S. Preventive Services Task Force. https://www.ncbi.nlm.nih.gov/books/NBK583091/. Accessed: 2/28/2024.
335 Kirk S, Ogata B, Wichert E, . Treatment of Pediatric Overweight and Obesity: Position of the Academy of Nutrition and Dietetics Based on an Umbrella Review of Systematic Reviews. J Acad Nutr Diet. 2022;122(4):848–61. 10.1016/j.jand.2022.01.008 35063666
336 American Psychological Association--Clinical Practice Guideline Panel. Clinical practice guideline for multicomponent behavioral treatment of obesity and overweight in children and adolescents: Current state of the evidence and research needs. https://www.apa.org/about/offices/directorates/guidelines/obesity-clinical-practice-guideline.pdf. Accessed: 2/28/2024.
337 American Academy of Pediatrics. Recommendations for Preventive Pediatric Health Care. https://downloads.aap.org/AAP/PDF/periodicity_schedule.pdf?_ga=2.231878815.1413452381.1668206139-1862393775.1661884606. Accessed: 11/11/2022, 2022.
338 Styne DM, Arslanian SA, Connor EL, . Pediatric Obesity-Assessment, Treatment, and Prevention: An Endocrine Society Clinical Practice Guideline. J Clin Endocrinol Metab. 2017;102(3):709–57. PMID: 28359099. 10.1210/jc.2016-2573 28359099
339 Committee on Adolescent Health Care. Committee Opinion No. 714: Obesity in Adolescents. Obstet Gynecol. 2017;130(3):e127–e40. PMID: 28832485. 10.1097/AOG.0000000000002297 28832485
340 Canadian Task Force on Preventive Health Care. Recommendations for growth monitoring, and prevention and management of overweight and obesity in children and youth in primary care. Cmaj. 2015;187(6):411–21. PMID: 25824498. 10.1503/cmaj.141285 25824498
341 National Association of Pediatric Nurse Practitioners. Position Statement on the Identification and Prevention of Overweight and Obesity in the Pediatric Population. Journal of Pediatric Health Care. 2021;35(4):425–7. PMID: 19882803. 10.1016/j.pedhc.2009.07.004 19882803
342 Polfuss ML, Duderstadt KG, Kilanowski JF, . Childhood Obesity: Evidence-Based Guidelines for Clinical Practice-Part One. J Pediatr Health Care. 2020;34(3):283–90. PMID: 32005502. 10.1016/j.pedhc.2019.12.003 32005502
343 National Heart Lung and Blood Institute. Expert panel on integrated guidelines for cardiovascular health and risk reduction in children and adolescents: summary report. Pediatrics. 2011;128 Suppl 5:S213–56. PMID: 22084329. 10.1542/peds.2009-2107C 22084329
344 The Society for Adolescent Health and Medicine. Preventing and Treating Adolescent Obesity: A Position Paper of the Society for Adolescent Health and Medicine. J Adolesc Health. 2016;59(5):602–6. PMID: 27772662. 10.1016/j.jadohealth.2016.08.020 27772662
345 Field AE, Byers T, Hunter DJ, . Weight cycling, weight gain, and risk of hypertension in women. Am J Epidemiol. 1999;150(6):573. 10.1093/oxfordjournals.aje.a010055 10489996
346 French SA, Folsom AR, Jeffery RW, . Weight variability and incident disease in older women: the Iowa Women’s Health Study. International journal of obesity and related metabolic disorders : journal of the International Association for the Study of Obesity. 1997;21(3):217–23. PMID: 9080261. 10.1038/sj.ijo.0800390 9080261
347 Kataja-Tuomola M, Sundell J, Männistö S, . Short-term weight change and fluctuation as risk factors for type 2 diabetes in Finnish male smokers. Eur J Epidemiol. 2010;25(5):333–9. PMID: 20352298. 10.1007/s10654-010-9444-6 20352298
348 Neamat-Allah J, Barrdahl M, Hüsing A, . Weight cycling and the risk of type 2 diabetes in the EPIC-Germany cohort Diabetologia. 2015;58(12):2718–25. PMID: 26376796. 10.1007/s00125-015-3755-9 26376796
349 Waring ME, Eaton CB, Lasater TM, . Incident diabetes in relation to weight patterns during middle age. Am J Epidemiol. 2010;171(5):550–6. PMID: 20110286. 10.1093/aje/kwp433 20110286
350 Delahanty LM, Pan Q, Jablonski KA, . Effects of weight loss, weight cycling, and weight loss maintenance on diabetes incidence and change in cardiometabolic traits in the Diabetes Prevention Program. Diabetes Care. 2014;37(10):2738–45. PMID: 25024396. 10.2337/dc14-0018 25024396
351 Cereda E, Malavazos AE, Caccialanza R, . Weight cycling is associated with body weight excess and abdominal fat accumulation: a cross-sectional study. Clin Nutr. 2011;30(6):718–23. PMID: 21764186. 10.1016/j.clnu.2011.06.009 21764186
352 Hanson RL, Narayan KM M D, Pettitt DJ, . Rate of weight gain, weight fluctuation, and incidence of NIDDM. Diabetes. 1995;44(3):261–6. PMID: 7883111. 10.2337/diab.44.3.261 7883111