# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Iris Mabry-Hernandez, MD, MPH, at the Agency for Healthcare Research and Quality; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Centers for Disease Control and Prevention; Eunice Kennedy Shriver National Institute of Child Health and Human Development; National Institute of Diabetes and Digestive and Kidney Diseases; and National Heart, Lung, and Blood Institute for providing federal partner review of the draft report; Aaron Kelly, PhD; Janet Tomiyama, PhD; William Dietz, MD, PhD; Katherine Flegal, PhD; and Ihuoma Eneli, MD, who provided expert review of the draft report; Jennifer Lin, MD, for mentoring and project oversight; and Melinda Davies, MA, and Jill Pope, BA, for technical and editorial assistance at the Center for Health Research.