# Chapter 4 Discussion

## Summary of Evidence

The evidence in this review demonstrated that structured behavioral weight management interventions in children and adolescents typically resulted in modest reductions in weight (~2 to 3 kg) compared to control groups for up to 1 year, particularly interventions with at least 26 hours of contact and that included physical activity sessions (Table 23). The clinical significance of this amount of weight loss is unclear. Very limited evidence suggests that these higher-dose interventions also resulted in small reductions in blood pressure, fasting glucose, and quality of life but had no apparent impact on lipid levels, other psychosocial outcomes, dietary pattern, or minutes per week of physical activity outside of the intervention sessions. Lower-contact interventions generally had minimal impact on weight or other outcomes, although some individual lower-contact trials did show a benefit. A fairly large (n=452) trial of a 26-session family-based behavioral intervention published after our search was completed supports our finding that behavioral interventions are associated with small weight changes.^98^ In this study, group differences were maintained for up to 24 months with continued intervention; children in the intervention group had returned to baseline BMI percentile after 24 months, while those in the usual care group had a 6.5 percent increase in their percent above median BMI. There was a larger effect among White children than among Black children in this study. The impact on quality of life, cardiometabolic parameters, or longer-term followup was not reported. A summary of intervention characteristics for trials that were effective in reducing weight is available in Appendix D Table 20.

Table 23 Summary of Evidence

Key Question | Studies (k); Observations (n); Study Designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
Key Question 1 (health outcomes); Behavioral interventions | 14 RCTs; N=2,674 | Very few studies found any statistically significant improvements in quality of life at any timepoint. However, pooled analyses found small increases in total and physical quality of life after 6 to 12 months, reported in only a very small subset of the included trials (e.g., total quality of life: MD, 1.9 [95% CI, 0.2 to 3.5]; 11 RCTs [n=1,922]). Other health outcomes were very sparsely reported, and none suggested a benefit. | Quality of life: Consistent, imprecise; Other health outcomes, consistency inconsistent or NA, imprecise | Sparse reporting of health outcomes.; Quality of life: Only one study included a weight-specific quality of life instrument; studies varied in the use of child report vs. parent proxy report of QoL; variation in the use of subscales vs. total QoL scales. | Quality of life: Low; Other health outcomes: Insufficient | 6 trials conducted in the US.; Limited information on effects in specific populations at risk of health inequities and higher than average BMI (Black, Hispanic, Native American, limited financial resources or other social needs).
Key Question 1 (health outcomes); Liraglutide | 1 RCT; N=251 | No group differences in mean change in either weight-related quality of life (MD, 1.3 [95% CI, −1.6 to 4.2]) or depression incidence (RR, 1.71 [95% CI, 0.40 to 7.31]) after 13 months of treatment. | Consistency NA, imprecise | Body of evidence limited to 1 study, followup limited to 13 months, no post-treatment followup. | Insufficient | Multinational study, including cites in Belgium, Mexico, Russia, Sweden, and the US.
Key Question 1 (health outcomes); Semaglutide | 1 RCT; N=201 | Semaglutide was associated with small improvement in weight-related quality of life (MD, 4.3 [95% CI, 0.2 to 8.3]) on a 100-point scale. | Consistency NA, imprecise | Body of evidence limited to 1 study, followup limited to 16 months, no post-treatment followup. | Insufficient | Multinational study, including cites in Austria, Belgium, Croatia, Ireland, Mexico, Russian Federation, UK, and the US
Key Question 1 (health outcomes); Orlistat | 2 RCTs; N=579 | One trial each reported weight-related quality of life and depression incidence, with no group differences on either outcome after 6 to 12 months. | Consistency NA, imprecise | Very small body of evidence, followup limited to 6 to 12 months, no post-treatment followup. | Insufficient | Both studies conducted in the US, recruited from healthcare settings; smaller study (n=40) included 62% Hispanic/Latino participants.
Key Question 1 (health outcomes); Phentermine/Topiramate | 1 RCT; N=227 | No group differences in quality of life or depression incidence | Consistency NA, imprecise | Body of evidence limited to 1 study, followup limited to 13 months, no post-treatment followup. | Insufficient | Study conducted in the US, included 32% Hispanic/Latino participants, 27% Black participants.
Key Question 2 (intermediate outcomes); Behavioral interventions: Weight or adiposity | 50 RCTs; N= 8,798 | Pooled analysis indicated average small reductions in BMI with weight management interventions compared to control conditions in the short term (6–12 months; MD, −0.65 kg/m^2^ [95% CI, −0.98 to −0.32]; 29 RCTs [n=4,639]). Effects on BMI were larger for interventions offering an estimated ≥26 hours of contact and for those that provided physical activity sessions. Evidence was extremely limited beyond 12 months and very limited evidence suggested attenuation of effects after treatment ended. Other weight and adiposity outcomes showed similar patterns of results. | Consistent, Precise | Could not disentangle the impact of contact hours and inclusion of physical activity sessions during intervention sessions.; Clinical significance of the effect is unknown.; Minimal information on effects after 12 months or maintenance after treatment ends. | High for benefit up to 12 months | Limited information on effects in specific populations at risk of health inequities and higher than average BMI (Black, Hispanic, Native American, limited financial resources or other social needs)
Key Question 2 (intermediate outcomes); Behavioral Interventions: Other intermediate outcomes | 16 RCTs; N=1,700 | Pooled effects indicated no impact on measures of cholesterol but suggested slightly larger improvements in blood pressure and fasting plasma glucose compared to control groups, only in trials offering ≥26 hrs of contact, almost all of which also offered physical activity sessions. For example, among trials with ≥26 contact hrs, MD (95% CI):; HDL: 0.8 mg/dL (−1.6 to 3.2); 4 RCTs; SBP: −3.6 mm Hg (−5.7 to −1.5); 8 RCTs; DBP: −3.0 mm Hg (−5.2 to −0.7); 8 RCTs; FPG: −1.9 mg/dL (−2.7 to −1.2); 4 RCTs | Blood Pressure, fasting plasma glucose: Consistent (that benefit only seen with >26 hrs), Imprecise; Lipids: Inconsistent, Imprecise | Very few trials reporting.; Could not disentangle the impact of contact hours and inclusion of physical activity sessions during intervention sessions.; Clinical significance of the effects is unknown.; No information on effects after 12 months, minimal information on maintenance after treatment ends. | Blood Pressure, Fasting plasma glucose: Low (benefit only with higher contact hours and physical activity sessions); Lipids: Low (no benefit) | Limited information on effects in specific populations at risk of health inequities and higher than average BMI (Black, Hispanic, Native American, limited financial resources or other social needs)
Key Question 2 (intermediate outcomes); Liraglutide | 1 RCT; N=251 | Pharmacotherapy was associated with larger mean BMI reduction than placebo after 13 months (MD, −1.6 kg/m^2^ [95% CI, −2.5 to −0.7]), which translated to 4.5 kg greater weight reduction (MD, −4.5 [95% CI, −7.2 to −1.8]). Group differences were not maintained 6 months after treatment ended (BMI MD, −1.0 kg/m^2^ [95% CI, −2.0 to 0.01]).; Liraglutide was associated with very small increases in all lipid measures, including HDL, LDL, total cholesterol, and triglycerides (e.g., LDL MD, 1.0 [95% CI, 0.94 to 1.05]), but had no impact on blood pressure or glucose metabolism after 13 months of treatment. | Consistency NA, precise | Evidence is limited to one trial.; Clinical significance of the effects is unknown.; Effect on weight deteriorated after treatment ended, impact on other intermediate outcomes after treatment ended is unknown. | Weight: Low for benefit at up to 13 months; IOs: Low with mixed findings | Multinational study, including cites in Belgium, Mexico, Russia, Sweden, and the US.
Key Question 2 (intermediate outcomes); Semaglutide | 1 RCT; N=201 | Pharmacotherapy was associated with larger mean BMI reduction than placebo after 16 months (MD, −6.0 kg/m^2^ [95% CI, −7.3 to −4.6]), which translated to 4.5 kg greater weight reduction (MD, −17.7 [95% CI, −21.8 to −13.7]). Group differences were not reported after discontinuation.; Semaglutide was associated with greater percent reductions in LDL, total cholesterol, and triglycerides from baseline levels (e.g., LDL MD, −7.0% [95% CI, −11.9 to −1.8]) and a statistically nonsignificant increase in HDL (MD, 4.7% [95% CI, −1 to 10.7]), but had no impact on blood pressure or glucose metabolism after 16 months of treatment. | Consistency NA, precise | Evidence is limited to one trial with no followup after medication was discontinued; Clinical significance of the effects on cardiometabolic outcomes is unknown | Low for benefit | Multinational study, including cites in Austria, Belgium, Croatia, Ireland, Mexico, Russian Federation, UK, and the US
Key Question 2 (intermediate outcomes); Orlistat | 2 RCTs; N=579 | Pharmacotherapy was associated with larger mean BMI reduction than placebo after 12 months in 1 of the 2 included trials (MD, −0.9 kg/m^2^ [95% CI, NR; p=0.001]; n=537), which was associated with 2.6 kg greater weight reduction (CI NR).; One orlistat study (n=537) found no improvement in lipid levels, glucose, or SBP with orlistat use compared to placebo after 12 months, but a slightly larger improvement in DBP compared with placebo (MD, −1.8 kg/m^2^ [95% CI, NR]; p=0.04). | Consistent, precise | Evidence is limited to two trials.; Clinical significance of the effects is unknown.; No information on maintenance of effects after treatment ended. | Weight: Low for benefit at up to 12 months; IOs: Low for no benefit | Both studies conducted in the US, recruited from healthcare settings; smaller study (n=40) included 62% Hispanic/Latino participants.
Key Question 2 (intermediate outcomes); Phentermine/Topiramate | 1 RCT; N=227 | After 13 months, phentermine/topiramate was associated with greater reductions in BMI:; - 15/92 mg dose: MD, −5.4 kg/m^2^ (95% CI, −6.4 to −4.3); - 7.5/46 mg dose: MD, −3.7 kg/m^2^ (95% CI, −5.0 to −2.5).; and weight:; - 15/92 mg dose: MD, −15.8 kg (95% CI, −18.8 to −12.8); - 7.5/46 mg dose: MD, −12.1 kg (95% CI, −15.6 to 8.6).; HDL cholesterol increased from baseline by 9 to 10 percentage points more with phentermine/topiramate than placebo, and the lower-dose arm of the phentermine/topiramate study showed a reduction in DBP, but no group differences were found for SBP or insulin sensitivity at either dose level. | Consistency NA, Precise | Evidence is limited to one trial.; Clinical significance of the effects on cardiometabolic outcomes is unknown.; No information on maintenance of effects after treatment ended. | Low for benefit | Study conducted in the US, included 32% Hispanic/Latino participants, 27% Black participants.
Key Question 3 (behavioral outcomes); Behavioral Interventions | 23 RCTs; N=3,459 | Most evidence and meta-analyses indicated no impact on minutes per day of physical activity or sedentary behavior: Physical activity: MD, 5.2 (95% CI, −2.0 to 12.4); 10 RCTs Sedentary behavior: MD, −13.3 (95% CI, −26.9 to 0.4); 11 RCTs.; Findings were mixed among 5 trials reporting overall dietary pattern. | Physical activity, sedentary behavior: consistent, imprecise; Dietary pattern: inconsistent, imprecise | Sparse reporting of behavioral outcomes.; Heterogeneity in specific measures. | Low for no benefit | Limited information on effects in specific populations at risk of health inequities and higher than average BMI (Black, Hispanic, Native American, limited financial resources or other social needs)
Key Question 3 (behavioral outcomes); Pharmacotherapy | 0 studies | NA | NA | NA | Insufficient | NA
Key Question 4 (harms); Behavioral interventions | 18 RCTs; N= 2,539 | None of the 18 trials reporting potential harms of behavioral weight management interventions found an increase in the risk of: any adverse events, serious adverse events, self-esteem, body satisfaction, or disordered eating. Outcomes were reported 6 to 12 months after baseline assessments. | Consistent, Imprecise | Very sparse evidence for all outcomes.; No information was available on the risk of harm beyond 12 months.; Body satisfaction and self-esteem may be culturally influenced, but the evidence was insufficient to examine cross-culturally.; Outcomes address only immediate harms of the intervention, and none examined larger impacts related, for example, to labelling, stigma, or potential weight regain. | Low for no increased risk of harm | Limited information on effects in specific populations at risk of health inequities and higher than average BMI (Black, Hispanic, Native American, limited financial resources or other social needs)
Key Question 4 (harms); Liraglutide | 3 RCTs; N=296 | The best data, from the largest study (n=251), indicated an increased risk of gastrointestinal effects (RR, 3.20 [95% CI, 1.91 to 5.36]; 65% vs. 36%) and discontinuation due to adverse effects (RR, 30.36 [95% CI, 2.78 to 516.57]; 10% vs. 0%). | Consistent, imprecise | There may be rare harms that RCTs were underpowered to detect.; No information on harms of long-term use. | Serious AEs: Insufficient; Any AEs: Low for increased harm | Largest trial providing most of the evidence was a multinational study, including cites in Belgium, Mexico, Russia, Sweden, and the US.
Key Question 4 (harms); Semaglutide | 1 RCTs; N=201 | Gastrointestinal side effects were the most common harm (RR, 2.24 [95% CI, 1.23 to 4.07]; 62% vs. 42%). Although not significantly different, five participants taking semaglutide (3.8%) developed gallstones, compared to none taking placebo (calculated RR, 5.8 [95% CI, 0.3 to 106.1]) | Consistent, imprecise | There may be rare harms that RCTs were underpowered to detect.; No information on harms of long-term use. | Serious AEs: Insufficient; Any AEs: High for increased harm | Multinational study, including cites in Austria, Belgium, Croatia, Ireland, Mexico, Russian Federation, UK, and the US
Key Question 4 (harms); Orlistat | 2 RCTs; N=579 | Gastrointestinal side effects were more common with orlistat use, including flatus with discharge (RR, 8.74 [95% CI, 3.46 to 22.07]; 20% vs. 3%) and fecal incontinence (RR, 17.38 [95% CI, 2.35 to 128.4] in the larger study; 9% vs. 1%) in the larger study. Discontinuation and serious AEs did not differ between groups. | Consistent, imprecise | There may be rare harms that RCTs were underpowered to detect.; No information on harms of long-term use. | Serious AE: Insufficient; Any AEs: Low for increased harm | Both studies conducted in the US, recruited from healthcare settings; smaller study (n=40) included 62% Hispanic/Latino participants.
Key Question 4 (harms); Phentermine/topiramate | 2 RCTs; N=269 | Combining both studies, withdrawals due to AEs was 2.4% in both participants taking phentermine/topiramate and those taking placebo. Two persons experienced serious AEs: bile duct stone and depression with suicidal ideation.; In the larger study, the side effects that were slightly more common with higher-dose phentermine/topiramate were musculoskeletal (experienced by 10 persons [8.8%] with phentermine/topiramate vs. 1 [1.8%] with placebo) and psychiatric (10 persons [8.8%] with phentermine/topiramate vs. 1 [1.8%] with placebo), although group differences were not statistically significant | Consistent, imprecise | There may be rare harms that RCTs were underpowered to detect.; No information on harms of long-term use. | Serious AE: Insufficient; Any AEs: Low for increased harm | Larger study conducted in the US, included 32% Hispanic/Latino participants, 27% Black participants.

Abbreviations: AEs = Adverse events; BMI = Body mass index; CI = Confidence Interval; DBP = Diastolic blood pressure; FPG = Fasting plasma glucose; HDL = High-density lipoprotein; Hrs = Hours; IOs = Intermediate outcomes; Kg/m^2^ = Kilograms per meters squared; LDL = low-density lipoprotein; MD = Mean difference; Mg/dL = Milligrams per deciliter; mmHg = Milligrams mercury; NA = Not applicable; NR = Not reported; QoL = Quality of Life; RCT = Randomized controlled trial; RR = Relative risk; SBP = Systolic blood pressure; SD = Standard deviation; SMD = Standardized mean difference; US = United States.

Very limited evidence was available on whether weight loss was maintained beyond 1 year, and we found no information on longer-term impacts on health or psychosocial well-being. Very minimal evidence suggested that behavioral interventions did not have negative impact on self-esteem, body satisfaction, or disordered eating; an interpersonal therapy intervention that primarily addressed psychosocial aspects of eating (rather than diet and physical activity) reduced binge eating. Potential harms of behavioral interventions were reported in just a small subset of trials reporting weight outcomes and reporting was highly variable; thus, the strength of evidence for harms is much lower than for weight outcomes. These findings are consistent with those of the previous USPSTF review on this topic,^94^ as well as another recently published review, which found difference in BMI ranging from −0.87 kg/m^2^ (95% credible interval, −1.63 to −0.09) to 0.98 kg/m^2^ (95% credible interval, −1.19 to −0.77) across several different types of behavioral interventions.^296^

In terms of pharmacotherapy, orlistat showed a similar effect size to behavioral interventions, and no information on weight maintenance after discontinuation of orlistat was provided, as was the case in the previous review. Liraglutide and phentermine/topiramate showed larger effects on weight (~4 to 16 kg) than was observed with behavioral interventions. However, group differences with liraglutide and phentermine/topiramate plateaued at approximately 6 months to 1 year, and weight began to rebound quickly when liraglutide was discontinued. No information was provided on whether weight loss was maintained after the phentermine/topiramate was discontinued. Gastrointestinal complaints were common with orlistat and liraglutide in the short term, and there was no information on the harms of medication use beyond 13 months, which is problematic if long-term use of medications is necessary to maintain the weight loss. As with the behavioral interventions, pharmacotherapy trials reported that their interventions were not associated with an increased risk of harmful psychosocial outcomes such as poorer quality of life, mental health, body dissatisfaction, or disordered eating. However, these outcomes were measured in the short term, when young people had, on average, reduced their weight and may have been appreciative of this outcome, as it moved them closer to cultural beauty standards and in a direction widely presumed to improve their health.

## Long-Term Weight Maintenance

The lack of evidence on long-term maintenance of weight loss is a critical limitation of this literature, and weight relapse after weight management interventions is acknowledged as common by the AAP.^4^ Epstein and colleagues, who conducted much of the formative work in the area of family-based weight management interventions for children, published 10-year followup results from 176 children participating in four trials of a family-based comprehensive weight management intervention, which involved an estimated 30 or more hours of contact.^297^ They found that 52.5 percent of the children undergoing these interventions met criteria for obesity at the 10-year followup. For comparison, a separate systematic review of naturalistic longitudinal studies found that approximately 65 percent of children who met criteria for obesity continued to meet criteria in adulthood.^298^ This evidence suggests that higher-contact family-based weight management programs might improve the likelihood of avoiding future obesity, at least during early adulthood. However, this is the only long-term study we found, and it included only 176 children. Further, the comparability of participants in the treatment trials to participants in the naturalistic longitudinal studies is unknown. More data are needed.

Studies conducted in adults show that weight loss is typically followed by weight gain (see Contextual Question 8).^281–284^ Limited evidence among the studies included in this review suggested that weight may also commonly rebound for children and adolescents. This is not surprising, given the known weight gain–promoting physiologic adaptations in hormone signaling and energy expenditure in response to weight loss and calorie restriction.^286^ Evidence among adults suggests that multiple cycles of weight loss and regain increase the risk of higher ultimate weight, and may also increase the likelihood of diabetes incidence.^289^

## Potential Harms of Weight Management Interventions

Another systematic review confirmed our finding that studies of weight management interventions among children and adolescents do not demonstrate psychosocial harms in the short term.^292^ However, evidence on the etiology of eating disorders suggests that dieting combined with body dissatisfaction is an important risk factor for binging- and purging-spectrum eating disorders.^197,^ ^293,^ ^294^ While formal, sensitively delivered weight management programs appear not to show associations with disordered eating, and may even reduce it with interpersonal therapy as a treatment modality,^143,^ ^144^ it is unknown whether such experiences would inoculate young people from developing eating disorders who continue to receive messages that they should lose weight over many years. We found no studies of adults reflecting on the psychosocial impact of weight management interventions during childhood or adolescence.

A panoply of critiques have been published about the weight-centered health paradigm (i.e., discourse about health that centers on the importance of body weight), raising concerns about the harms of treating higher weight as a problem that must be solved or a disease that must be treated.^299^ Their arguments center on the widespread and harmful stigma and inequities faced by people with higher weight. Some critiques also point out that maltreatment of people with high weight has racist historic roots^300^ and disproportionately affects people who are already disadvantaged by stigma and prejudice, such as people who are Black, Native American, and gender nonconforming.^299,301^ This is particularly unfortunate given that economic factors have an impact on diet, access to food, and safe physical activity spaces, which disproportionately affect Black, Hispanic/Latino, and Native American communities in the United States (Contextual Question 5), who also may have more limited access to weight management resources (Contextual Question 6).

Citing the association of high BMI with harmful health and social consequences, the AAP developed a series of recommendations for assessment, treatment, and monitoring of high BMI and potentially related comorbidities.^4^ This report seeks to limit harm by emphasizing the need to avoid stigmatizing language and urges clinicians to be supportive, empathetic, and nonjudgmental. The report states that “the natural course of obesity across the lifespan is characterized by responses to treatment and relapse when treatment ends; thus, children and adolescents with obesity will need appropriate reassessments of medical and psychological risks and comorbidities and appropriate modifications to their treatment plan throughout childhood and adolescence into young adulthood.” While many young people may benefit from participation in a thoughtful and sensitively-developed weight management treatment that incorporates disordered eating prevention, they do not discuss when and whether to shift the focus away from weight outcomes to other health-promoting outcomes if children continue to fail to meet weight-related goals. However, their endorsement of shared decision making creates an important opportunity for such discussions.

The included pharmacotherapy intervention trials also showed no increased risk of serious harm. However, FDA materials suggest that there may be a risk of serious harms. For phentermine/topiramate, the FDA materials note that it may increase the risk of cleft lip and cleft palate in offspring if taken during pregnancy.^302^ Other FDA warnings for phentermine/topiramate include increased heart rate, suicidal thoughts, and serious eye problems that can lead to permanent vision loss if not treated. Also, phentermine/topiramate is a federally controlled substance (Schedule IV) because it contains phentermine and can be abused or lead to drug dependence. Liraglutide and semaglutide are also contraindicated during pregnancy and are associated with an increased risk of thyroid tumors, including cancer, as well as pancreatitis, gall bladder problems, acute kidney injury, serious allergic reaction, heart rate increase, depression, thoughts of suicide, and, among patients with type 2 diabetes, hypoglycemia and vision changes.^303^ Very limited evidence suggests that weight loss is not maintained when these medications are discontinued, so young people may need to continuing using the medication for years to decades to maintain lower weight, and the impact of many years of use are not known.

## Evidence on Health Benefits of Weight Loss

The only improvement in health outcomes identified in the included studies was a small increase in quality of life, which was statistically significant among the high-contact (but not the lower-contact) behavioral interventions and with semaglutide. The semaglutide and the higher-contact trials showed consistent improvements of approximately 4 points more than control groups on (mostly) 100-point scales. We found published minimal clinically important differences (MCID) for the PedsQL:

- Enrollees in California State’s Children’s Health Insurance Program: 4.5 for parent report, 4.4 for child report^304^
- Youth with type 2 diabetes mellitus: 6.3 for parent report, 5.4 for youth report^305^
- Youth with type 1 diabetes mellitus: 4.9 for parent report, 4.7 for youth report^305^

These MCIDs are based on standard error of measurement rather than the preferred anchor-based method. The anchor-based method is more patient-centered and uses direct response from the patient on some other measure of impact on the patient to elucidate the meaning of a particular degree of change.^306^ The two higher-contact intervention trials that used the PedsQL found improvements of 6.7 to 10.2 points in the intervention groups, and 2.9- to 6.1-point improvements in the control groups.^111,^ ^129^ While this evidence is promising, it represents only two of the 17 trials of higher-56contact interventions, so must be interpreted with caution.^106,^ ^109,^ ^111,^ ^117,^ ^118,^ ^121,^ ^126,^ ^127,^ ^129,^ ^131,^ ^133,^ ^135,^ ^138,^ ^139,^ ^141,^ ^151,^ ^154^ Few other health outcomes were reported in the included studies and none showed a benefit. A separate systematic review did show reductions in depression (standardized mean difference, −0.31 [95% CI, −0.39 to −0.22]; 36 studies [N=1,878]) and anxiety (standardized mean difference, −0.38 [95% CI, −0.57 to −0.19]; 10 studies [N=530]) after 6 to 16 months among young people with high BMI participating in weight management interventions. This review included a wide range of study designs, including noncontrolled pre-post studies, and followup beyond 16 months was extremely limited.^307^

Evidence from large cohort studies suggests that high BMI in childhood is associated with an increased risk of premature mortality, but this evidence is observational in nature and cannot control for potentially important confounding factors such genetic predisposition for early mortality and behavioral factors such as fitness, diet, or engagement with healthcare (Contextual Question 2). Further, we found no evidence on whether weight loss in children and adolescents would help prevent poor health outcomes in the future, so it is unclear if the excess premature deaths associated with high childhood BMI could be prevented by weight loss.

Even among adults, there is some uncertainty about the extent to which high BMI harms an individual’s health, especially in the range of 25 to 35 kg/m^2^ (see Contextual Question 2). The evidence on the impact of BMI on mortality and cardiovascular events in adults has some important limitations: it is primarily observational in nature; some studies have found that the associations are eliminated or substantially attenuated by cardiorespiratory fitness and other healthy lifestyle habits; and other potential confounders are not accounted for, such as the impact of weight stigma (e.g., via the chronic stress of discrimination and abuse related to weight, treatment delays, and inferior medical treatment stemming from weight stigma [see Contextual Question 7]). Further, some studies show no increased risk or even improved survival for adults experiencing certain acute health events with BMI in the 25 to 35 kg/m^2^ range, suggesting a potentially protective effect in some instances, although this evidence is again observational only.^308–313^ The applicability of evidence in adults to children may be limited, however, since most adults with BMI of 30 kg/m^2^ or higher did not have higher BMI as children.^27^

Conclusions about clinically important differences in weight change are difficult to draw because most evidence does not attempt to disentangle potential benefits from improved diet and physical activity from potential benefits of weight loss alone. In our review, the mean difference between intervention and control groups in BMI and weight was typically in the range of 1 to 2 kg/m^2^ or 2 to 3 kg, which is similar to the range in adults.^21^ The clinical significance of this level of weight loss is unclear (see Contextual Question 4). The most robust evidence in pediatric populations suggests that zBMI reductions of at least 0.7 are needed to confer benefit for cardiometabolic measures. Mean reductions in zBMI found in the behavioral intervention trials included in our review were far smaller, generally ranging from 0.2 to 0.4 with higher-contact interventions and 0 to 0.2 in lower-contact interventions. Semaglutide use was associated with zBMI reductions in this range, however, with a 1.1 zBMI reduction (compared to 0.1 reduction among those receiving a placebo injection).

The weight changes found in our review likely leave most participants with a BMI that would still put them in the “overweight” or “obese” categories after the intervention ended. One large 20-year prospective study of adults found that the annual probability of attaining “normal weight” was 0.005 for men and 0.008 women with BMI in the 30 to 34.9 kg/m^2^ range, and was 0.0008 for men and 0.001 for women with BMI in the 40 to 44.9 kg/m^2^ range.^314^ Even if the rates of these levels of weight change are substantially higher in children than in adults, it suggests that weight loss in an amount needed to achieve BMI below the 85th percentile for age and sex will be the exception. It follows, then, that even after successful participation in weight loss programs, many young people will still be faced with continued pressure to continue to lose more weight, which may be an essentially impossible task for those at the highest weight levels, given what we know about physiologic adaptations to weight loss (see Contextual Question 8).

This issue raises the question of whether continued emphasis on weight is helpful after initial efforts, particularly given the association of weight cycling with ultimate weight gain and the known association between dieting and eating disorders, particularly in the context of body dissatisfaction (see Contextual Question 8). Weight stigma is pervasive and damaging (see Contextual Question 7), and young people who perceive themselves as being too heavy are prone to potentially damaging weight loss methods and poor psychosocial outcomes (see Contextual Question 4). Youth are getting that message that they should lose weight; data from the Youth Risk Factor Behavior Surveillance System show that 48.3 percent of U.S.-based ninth to 12th graders were trying to lose weight in 2019, with dramatically higher rates among females (59.8%) than males (37.0%).^17^ While monitoring weight may be an important part of medical care for young people, telling pediatric patients that they have overweight or obesity may have some unintended negative consequences for some patients and should be handled carefully and sensitively, as noted in the AAP guidance.^4^

## Approaches for Improving the Health of Children and Adolescents With High Weight

Understanding individual patients’ preferences and concerns seems paramount, given the complex, heterogeneous, and poorly understood etiology of high BMI; growing evidence that weight is largely influenced by factors that are not under control of the individual; limited information on longer-term outcomes; and relatively modest weight loss associated with most weight management interventions. The AAP clinical practice guideline supports shared decision making and encourages clinicians to consider patients’ circumstances, preferences, underlying conditions, special needs, and developmental status.^4^

Some advocates and researchers have called for a change to a more weight-inclusive paradigm of health, which focuses on promotion of high-quality, non-stigmatizing healthcare designed to promote health in a manner that is equitable across the weight spectrum, including a focus on health-enhancing eating and body movement rather than weight loss for people with high weight.^190,^ ^315–317^ For example, the position statement by the Academy of Nutrition and Dietetics on prevention of childhood and adolescent obesity states that “Evidence supports that improvements in diet and physical activity can improve metabolic health in youth independent of weight loss and that a singular focus on weight loss can have harmful effects (i.e., weight stigma) among minority youth.”^317^ The “Health at Every Size” organization principles encourage “Eating for well-being,” which they describe as promoting “flexible, individualized eating based on hunger, satiety, nutritional needs, and pleasure, rather than any externally regulated eating plan focused on weight control.”^318^ Mindful and “Intuitive Eating” approaches promote focusing on eating in response to hunger and satiety clues.^319^ Intervention trials among adults indicate that mindfulness-based approaches may be effective in addressing binge eating, emotional eating, and eating in response to external cues, and may help prevent weight gain,^319^ and interventions in children commonly include advice and instruction on attending to internal satiety signals. Intuitive eating was found to predict better psychological health and lower use of disordered eating behaviors in an 8-year longitudinal study of adolescents followed into young adulthood.^320^ Further, a systematic review of intuitive eating interventions delivered to children and adolescents to prevent high BMI found that the interventions were associated with changes in eating habits, food portions, reduction of stress, or reduction of cravings. While some of the interventions included in our review likely provided coaching in identifying hunger and satiety signals, none of the studies specifically mentioned “mindful” or “intuitive” approaches in their interventions, suggesting that these alternate approaches have not been widely studied in children and adolescents with high BMI.

## Applicability of the Included Studies to the U.S. Population

Sixty percent of the included trials were conducted in the United States. Most participants were non-Hispanic White, but persons of Hispanic/Latino heritage were fairly well represented in these studies as well. Four studies were focused on populations with financial challenges. One author has pointed out, however, that families who have participated in research trials are likely to be relatively high functioning and have a certain level of organization and cohesion in order to be able to participate in an intervention program and to complete the program over the course of many weeks.^321^ The included interventions that showed the greatest weight loss were quite resource-intensive for the participating families, in terms of time spent at the intervention sessions, transportation, and possibly babysitting for other children in the family, which could be prohibitive for families with limited resources. In addition, many families would have to pay out-of-pocket for participation outside of research studies, while study participants received the interventions for free. Few of the studies included in our review had elements that addressed social risk factors, and we were unable to determine the impact of these efforts in the studies that did attempt to address barriers related to social risk, since the mitigation efforts were highly heterogeneous and could not be disentangled from other factors such as contact time.

In addition, psychosocial outcomes may be subject to social desirability bias (i.e., desire to report outcomes that are socially normative or that are perceived to be expected or hoped for by those conducting the study) and demand characteristics (i.e., cues that may indicate the purpose of the study), since participants in weight management interventions cannot be blinded to their intervention status. Thus, the effect sizes seen in the included studies may be more favorable than those found in typical clinical settings.

## Methodologic Differences Between the Previous and Current Reviews

Despite similar findings, there were some methodologic differences between the previous USPSTF review^94^ on this topic and the current review. First, because height and weight measures are the standard of care for children and adolescents, we did not address KQs on screening for high BMI, which is consistent with the adult weight management review conducted for the USPSTF.^21^ Second, the included medications changed. Liraglutide, semaglutide, and phentermine/topiramate were newly included because they received FDA approval for use in young people since the previous review. Metformin was previously included but excluded in the current review because it is not FDA-approved for weight management. Third, we did not include nonrandomized trials of interventions in the current review but had previously included such studies. Sensitivity analyses including nonrandomized studies of interventions showed no to minimal impact on effect size (data not shown).

Finally, there were also differences in the approaches to data analysis. Most importantly, the previous review used BMI z-score or standard deviation score (zBMI) as the primary outcome and did not pool change in BMI or weight. The rationale was that zBMI is more directly comparable across the age spectrum than other weight outcomes; however, more recent research has shown that zBMI does a poor job of capturing change in weight above the 97th percentile of weight for age and sex and has other problematic properties.^100,^ ^322^ The CDC recently modified its z-scores and percentiles to more accurately characterize children with a BMI at or above the 95th percentile, but most of the included studies were published prior to this update.^7^ And, z-scores and percentiles published by CDC, World Health Organization, and IOTF were developed using different methods and normative samples, so may exhibit different properties, which could result in different conclusions across systems. We used BMI as the primary outcome in this review because it was the most widely-reported outcome among those recommended for measuring weight outcomes in children.^100^ Both BMI and weight were quantitatively pooled. We report zBMI as a secondary outcome because many studies do report this measure, and to allow comparison with the prior review. Finally, the previous review stratified the results by four levels of intervention contact hours (0–5, 6–26, 26–51, ≥52). In the current review, we stratified results by two levels of intervention contact hours (<26, ≥26), which allowed for more robust estimates with more studies per strata and was consistent with the clinical considerations of the existing USPSTF recommendation statement.^1^

## Limitations of Our Review

We did not include some evidence that may have relevance for understanding the impact of weight management interventions in young people. Because our review was scoped for weight management interventions as a clinical preventive service, we did not include studies that did not have a connection to a healthcare setting. However, given the broad reach of diet and physical activity considerations in everyday life and in typical community settings, many of which may also address weight concerns, there are bodies of evidence not captured by our review. The Community Preventive Services Task Force has issued several findings for community-based intervention approaches to prevent and control “obesity,” including eight reviews of school-based interventions.^323,^ ^324^

Our review included studies among children and adolescents meeting criteria for higher BMI, such as being at or above the 85th percentile for age and sex, and in some cases, inclusion criteria had even lower thresholds.^137,^ ^142,^ ^143,^ ^144^ We found no differences in effect sizes for BMI between studies limited to young people with BMI at or above the 95th percentile for age and sex compared to lower weight thresholds for study participation. However, contextual evidence suggests that misclassification of young people with high adiposity is common below the 95th percentile threshold, so future updates to this review may consider a more narrow focus on the young people meeting a higher weight threshold. Further, our review did not address the promotion of healthy behaviors in children and adolescents with a BMI less than the 85th percentile. Given the findings that weight management interventions have only modest effects, and given the harms associated with weight labeling and weight stigma, it may be valuable to consider the role and effectiveness of broad interventions to promote healthy diet and physical activity in children and adolescents of all weights.

We limited our examination of pharmacotherapy to agents that were approved by the FDA for long-term use for weight loss in children or adolescents as of December 12, 2022. Thus, while metformin is used in practice, it was excluded from the current review. Our previous review found that it was associated with BMI reductions of −0.86 kg/m^2^ (95% CI, −1.44 to −0.29; k=6; I^2^=0%), with most trials limited to youth with insulin or glucose metabolism abnormalities, most of whom met adult criteria for severe obesity.^94^

Surgical interventions were excluded from the current review, as they were from previous reviews for the USPSTF on this topic, although they may be relevant for some adolescents and are recommended by some organizations under certain circumstances.^4^ However, we focused on first- and second-line treatment, which we consider to fall most clearly under the umbrella of preventive services (vs. disease management), and therefore limited the included interventions to behavioral and pharmacotherapy.

To maximize applicability of the evidence to U.S.-based primary care settings, this review was limited to studies conducted in countries rated as having very high development. And, consistent with the methods of the USPSTF, we included only studies that were rated as fair- and good-quality studies. Due to resource constraints, we only included studies published in English.

## Future Research Needs

A list of ongoing studies can be found in Appendix F. Several areas of further research are urgently needed to help the field understand the impact of weight management programs in children and adolescents:

1. Longer-term followup of weight management interventions. The minimal evidence available in children suggests that group differences in weight diminish beyond 1 year with behavioral interventions. Evidence on pharmacotherapy indicates that weight loss is maximized after 6 to 12 months and rebounds when medication is discontinued. If children and adolescents must continue medications indefinitely in order to maintain weight loss, study of the harms of long-term use is essential, as is the long-term efficacy of the medications. Since most medical conditions that are associated with high weight take many years to develop, temporary weight loss may not have an important impact on longer-term health. Recommended outcomes for such longer-term studies include absolute change in BMI and BMI change expressed as a percentage of the median and of the 95th percentile for age and sex. Despite its limitations, it would also be useful to report zBMI change as a secondary outcome for comparison with previous studies.
2. Long-term psychosocial outcomes. For example, qualitative research is needed to understand the impact of child weight management interventions from the perspective of adults who participated as children, from a broad, representative sample of people. Anecdotal reports suggest a risk of harm in terms of eating disorders, body image issues, and other mental health challenges related to participation in weight management interventions in childhood, but we found no systematic approach to examining these harms. These harms may not be apparent to children in the moment when they are reducing their BMI percentile, but may become more clear in retrospect. Researchers may seek to understand what proportion are vulnerable to harms, and more broadly whether harm stems from being labeled as having “overweight” or “obesity” in the medical setting, participation in a weight management program, or self-initiated attempts outside of the clinical setting. Further understanding of what characteristics are associated with longer-term harms, and if there are elements that could mitigate the risk of longer-term emotional harms would be beneficial.
3. Best practices for weight-related discussions. Given the sensitivity of discussions with children and parents about children’s weight, continued work is needed to understand best practices for clinicians from the patient perspective, to promote trust, respectful language, and shared decision making. Research should include best practices for counseling parents in how they can best communicate with their child, as research suggests parent-child communication surrounding weight has an impact on child well-being. Research should also include preferred terminology. While the Obesity Action Coalition recommends “person-first” language (i.e., “person with obesity” rather than “obese person”),^325^ this does not appear to be universally preferred.^326,^ ^327^ Further, preferences may differ between treatment-seeking and non-treatment–seeking individuals, so a broad cross-section of individuals with high BMI should inform this research.^326^
4. Biochemical compensatory responses to weight loss in children and adolescents. Studies in adults have identified a number of hormonal and other biochemical compensatory mechanisms that promote weight regain after weight loss, but information on such mechanisms in children and adolescents is lacking. We are aware of one study that is underway with the aim of examining hormonal regulatory mechanisms,^328^ but more research is needed.
5. Benefits and harms of weight-neutral interventions among children and adolescents with high BMI. RCTs are needed that examine the health (including psychosocial) and behavioral outcomes of interventions that focus on healthy lifestyle interventions in young people with high weight, without promoting weight loss. We are aware of examples of this approach in the youth population,^329^ but a recent systematic review confirms very limited evidence on weight-neutral interventions in young people with high BMI.^330^ Several studies are underway to examine behavioral interventions to prevent diabetes incidence among youth with high BMI and prediabetes that do not appear to have a strong weight loss aim.^331–333^ A systematic review commissioned by the USPSTF evaluating the effects of behavioral counseling to promote a healthy diet and physical activity in adults without cardiovascular risk factors shows that such interventions may be promising for intermediate and behavioral outcomes.^334^ Studies with weight loss as a primary aim were excluded in this review and thus approximate a weight neutral approach. Although studies were not limited to adults with higher BMI, the mean BMI was between 25.0 and 29.9 kg/m^2^ in nearly half of the included studies (k=54/79) and 30 kg/m^2^ or higher in 18 of 79 included studies. This review found that weight-neutral behavioral counseling interventions in this population of adults were associated with small statistically significant reductions in blood pressure, LDL cholesterol level, measures of adiposity, improvements in dietary outcomes, and physical activity. For example, behavioral counseling interventions were associated with a mean increase of approximately 33 minutes of physical activity per week (95% CI, 21.9 to 44.2). This review found no association between behavioral counseling interventions and mortality, CVD outcomes, quality of life, or harms; however, these outcomes were sparsely reported.
6. Overall dietary pattern. Reporting of dietary pattern quality is scant (e.g., HEI). Improved understanding of the impact on overall diet quality of these interventions would be valuable.
7. Weight-related quality of life. Very few trials reported quality of life measures that were specific to weight concerns, such as impacts on physical comfort, body esteem, social life, and family relations due to their weight. While the impact on overall quality of life and functioning are important, it would also be helpful to understand the impact on aspects of quality of life that are most directly affected by weight.
8. Intervention timing. Very limited information was available to determine whether intervention effects varied by age. It would be useful to better understand how development intersects with interventions for weight management and whether there are certain ages that provide a higher likelihood of benefit. Future studies could take a life course perspective and identify key periods where certain types of interventions may be most beneficial.

## Conclusion

Weight management interventions led to improvement in weight status in children and adolescents that ranged in size from modest (for behavioral interventions, orlistat, and liraglutide) to substantial (for semaglutide and phentermine/topiramate), with no evidence of serious harm and modest impact on health or intermediate cardiometabolic outcomes. Evidence is lacking about how weight management interventions affect weight beyond 1 year and after medication discontinuation, the longer-term impacts on psychosocial outcomes, and adverse events associated with pharmacotherapy.