# Chapter 3 Results

## Overview of Included Studies

We screened 6,878 abstracts and 351 full-text articles for inclusion (Appendix A Figure 1). After reviewing the full-text articles and performing critical appraisal, 58 RCTs (reported in 121 publications) fully met our inclusion criteria and were included (N=10,143).^106–161^ One publication reported the results of two separate studies.^130^ Fifty trials examined a behavioral intervention (i.e., involved counseling and education without the use of weight-loss medication; see Table 2). Forty of the behavioral trials were included in the previous review and 10 were newly published since the previous review.^112,^ ^115,^ ^120,^ ^129,^ ^137,^ ^138,^ ^141,^ ^144,^ ^147,^ ^150^ Eight trials examined the effects of pharmacotherapy. Three trials examined liraglutide,^155–157^ one examined semaglutide,^162^ two examined orlistat,^158,^ ^159^ and two trials examined two dosing schemes for the combination of phentermine and topiramate (Table 3).^160,^ ^161^ Three of the medication trials only followed participants for 2 months or less and were therefore only included for KQ4 (harms): two liraglutide trials^155,^ ^157^ and one trial of phentermine/topiramate.^160^ Of the medication trials, only the orlistat trials were included in the previous review.^158,^ ^159^

Table 2 Study Characteristics of Trials of Behavioral Interventions for Weight Management

Author, Year and Quality | Setting | N Rand | Population | Intervention | Offered PA session | Est hrs contact (Sessions) | Months duration | Assessment months (Retention @ 12 months or closest) | KQ 1 | KQ 2 | KQ 3 | KQ 4
Boutelle, 2014^106^; Fair | US Other | 44 | 8- to 12-year-olds meeting criteria for eating in the absence of hunger and BMI ≥85th percentile (CDC) | IG1: Regulation of Cues (ROC) program | | 28 (14) | 4 | 8 (89%) | | X
Broccoli, 2016^107^; Good | Italy Primary Care | 372 | 4- to 7-year-olds with BMI in 85th-95th percentile (CDC) | IG1: Motivational Interviewing | | 3.75 (5) | 3 | 12; 24 (95%) | | X | X
Bryant, 2011^108^; Fair | UK Other | 70 | 8- to 16-year-olds with BMI >98th percentile (norms NR) | IG1: WATCH IT | X | 24 (16) | 12 | 12 (76%) | | X
Croker, 2012^109^; Fair | UK Health Care^*^ | 72 | 8- to 12-year-olds with BMI classified as overweight or with obesity (IOTF) | IG1: Family-based behavioral therapy | | 37.5 (15) | 6 | 6 (68%) | | X | | X
Davis, 2012^110^; Fair | US Other | 61 | Black or Latino youth in grades 9 through 12 who had completed initial 4-month weight loss intervention with BMI ≥85th percentile prior to weight loss (CDC) | IG1: Maintenance (Group classes) | X | 16 (14) | 8 | 8 (87%) | | X
DeBar, 2012^111^; Good | US Primary Care | 208 | 12- to 17-year-old girls BMI ≥90th percentile (CDC) | IG1: Multicomponent behavioral intervention | X | 36.5 (18) | 5 | 6; 12 (83%) | X | X | X | X
Derwig, 2022^112^; Fair | Sweden Primary Care | 490 | 4-year-olds with BMI classified as overweight (and not obese) (IOTF) | IG1: Targeted Child-Centered Health Dialogue | | 1.9 (2) | 4.5 | 12 (97%) | | X | | X
Gerards, 2015^113^; Fair | Netherlands Primary Care | 86 | 4- to 8-year-olds with BMI classified as overweight or having obesity (IOTF) | IG1: Lifestyle Triple P | | 16.5 (14) | 3.5 | 12 (78%) | | X | X
Golley, 2007^114^; Fair | Australia Health Care^*^ | 111 | 6- to 9-year-olds with BMI classified as overweight or having obesity, but zBMI ≤3.5 (IOTF) | IG1: Triple P + healthy lifestyle group; IG2: Triple P | X | IG1: 23.75 (18); IG2: 9.75 (11) | 5 | 12 (82%) | | X | X
Ho, 2016^115^; Fair | Canada Health Care^*^ | 99 | 8- to 16-year-olds with BMI ≥85th percentile (norm criteria NR) | IG1: Nutrition counseling and portion control strategy | | 1.25 (1) | 6 | 6 (74%) | | X | | X
Hofsteenge, 2014^116^; Fair | Netherlands Health Care^*^ | 122 | 11- to 18-year-olds with BMI classified as overweight or with obesity (IOTF) | IG1: Go4it | | 16.5 (11) | 6 | 6 (80%) | X | X | | X
Kalarchian, 2009^117^; Fair | US Health Care^*^ | 192 | 8- to 12-year-olds with BMI ≥97th percentile (CDC) | IG1: Family-based lifestyle intervention | | 43.75 (26) | 12 | 6;12;18 (72%) | X | X
Kalavainen, 2007^118^; Fair | Finland Health Care^*^ | 70 | 7- to 9-year-olds with weight for height 120%–200% of median (UK norms) | IG1: Health-promoting lifestyle | X | 43.5 (15) | 6 | 6;12;24;36 (99%) | | X
Kong, 2013^119^; Fair | US Primary Care | 60 | Students in 9th to 11th grades with BMI ≥85th percentile (CDC) | IG1: ACTION | | 4.25 (16) | 9 | 6 (85%) | | X | X
Kose, 2021^120^; Fair | Turkey Primary Care | 80 | 12- to 18-year-olds with BMI categorized as overweight or with obesity (IOTF) | IG1: Motivational support programme | | 6 (9) | 6 | 6 (80%) | X | X
Lison, 2012^121^; Fair | Spain Health Care^*^ | 110 | 6- to 16-year-old White youth with BMI ≥85th percentile but zBMI ≤2.5 (IOTF) | IG1: Hospital-based group exercise; IG2: Home-based exercise | X | IG1: 122 (122); IG2: 2 (2) | 6 | 6 (76%) | | X
Looney, 2014^122^; Fair | US Primary Care | 22 | 4- to 10-year-olds with BMI ≥85th percentile (CDC) | IG1: Newsletters + Growth Monitoring + Family-based Behavioral Counseling; IG2: Newsletters + Growth Monitoring | | IG1: 2.5 (6); IG2: 1.25 (6) | 6 | 6 (95%) | | X | X
Love-Osborne, 2014^123^; Fair | US Primary Care | 165 | Middle and high school students at schools with high percentages of underserved, largely ethnic minority students with BMI ≥85th percentile (norms NR) | IG1: Health educator visits | | NR (5) | 8 | 8 (90%) | | X
McCallum, 2007^124^; Good | Australia Primary Care | 163 | 5- to 9-year-olds with BMI classified as overweight or having mild obesity, but zBMI <3.0 (IOTF) | IG1: LEAP | | NR (4) | 3 | 9.1; 15.0 (90%) | X | X | X | X
Mellin, 1987^125^; Fair | US Health Care^*^ | 66 | 12- to 18-year-olds, weight criteria NR; mean weight 136% of mean for age and sex (norms NR) | IG1: SHAPEDOWN | X | 24 (16) | 3 | 6 (96%) | | X
Nemet, 2005^126^; Fair | Israel Health Care^*^ | 54 | 6- to 16-year-olds with “obesity” (definition NR) | IG1: Dietitian + PA sessions | X | 32.5 (34) | 3 | 12 (74%) | | X | X
Norman, 2016^127^; Fair | US Primary Care | 106 | 11- to 13-year-olds with BMI ≥95 percentile (CDC) | IG1: Stepped-down Care | | NR (27) | 12 | 8; 12 (80%) | | X
O’Connor, 2013^128^; Fair | US Primary Care | 40 | 5- to 8-year-olds with BMI in 85th to 98th percentile (CDC) | IG1: Helping HAND | | NR (12) | 7 | 7 (85%) | | X | X
Patrick, 2013^129^; Fair | US Other | 101 | 12- to 16-year-olds at high risk for T2DM with BMI >85th percentile, weight and height >85th percentile, or weight >120% of ideal for height (CDC) | IG1: Group sessions + website; IG2: Website + text messages; IG3: Website alone | X | IG1: 26 (36); IG2: 0 (0); IG3: 0 (0) | 12 | 6;12 (65%) | X | X | X | X
Raynor, 2012a^130^; Fair | US Other | 101 | 4- to 9-year-olds with BMI ≥85th percentile (CDC) | IG1: DECREASE + Growth Monitoring; IG2: INCREASE + Growth Monitoring | | IG1: 6 (8); IG2: 6 (8) | 6 | 6; 12 (89%) | | X | | X
Raynor, 2012b^130^; Fair | US Other | 81 | 4- to 9-year-olds with BMI ≥85th percentile (CDC) | IG1: TRADITIONAL + Growth Monitoring; IG2: SUBSTITUTES + Growth Monitoring | | IG1: 6 (8); IG2: 6 (8) | 6 | 6; 12 (91%) | | X | X | X
Reinehr, 2010^131^; Fair | Germany Health Care^*^ | 71 | 8 -to 16-year-olds with BMI in 90th to 97th percentile (German norms) | IG1: Obeldicks light | X | 67 (37) | 6 | 6 (84%) | | X | X | X
Resnicow, 2015^132^; Fair | US Primary Care | 645 | 2- to 8-year-olds with BMI 85th to 97th percentile (CDC) | IG1: PCP + RD MI; IG2: PCP MI | | IG1: NR (10); IG2: NR (4) | 24 | 24 (71%) | | X
Sacher, 2010^133^; Fair | United Kingdom Other | 116 | 8- to 12-year-olds with BMI ≥98th percentile (UK norms) | IG1: MEND | X | 36 (18) | 2.25 | 6 (71%) | | X | X | X
Saelens, 2002^134^; Fair | US Primary Care | 44 | 12- to 16-year-olds who are 20% to 100% above median for BMI (NHANES) | IG1: Healthy Habits Intervention | | 3.75 (13) | 4 | 7 (84%) | | X | X | X
Savoye, 2007^135^; Fair | US Health Care^*^ | 209 | 8- to 16-year-olds with BMI >95th percentile (CDC) | IG1: Bright Bodies | X | 82.33 (64) | 12 | 6; 12 (68%) | | X
Savoye, 2014^136^; Fair | US Health Care^*^ | 75 | 10- to 16-year-olds with BMI >95th percentile (CDC) | IG1: Bright Bodies | X | 78 (52) | 6 | 6 (77%) | | X
Sherwood, 2019^137^; Fair | US Primary Care | 421 | 5- to 10-year-olds with BMI in 70th to 95th percentile (CDC) | IG1: Healthy Homes/Healthy Kids 5-10 | | 3.5 () | 12 | 12; 24 (86%) | | X | X
Smith, 2021^138^; Fair | US Primary Care | 240 | 5.5- to 12-year-olds with BMI ≥85th percentile (CDC) | IG1: Family Check-Up 4 Health (FCU4Health) | | 53.79 (3) | 6 | 6; 12 (78%) | | X | X
Stark, 2011^139^; Fair | US Primary Care | 18 | 2- to 5-year-olds with at least one parent with BMI ≥25 and who have BMI ≥95th percentile but <100% above the mean BMI (CDC) | IG1: LAUNCH | | 38.25 (18) | 6 | 6; 12 (89%) | X | X | X
Stark, 2014^140^; Fair | US Primary Care | 27 | 2- to 5-year-olds with at least one parent with BMI ≥25 and who have BMI ≥95th percentile but <100% above the mean BMI (CDC) | IG1: LAUNCH-clinic | | 30 (10) | 6 | 6; 12 (78%) | | X | X
Stark, 2018^141^; Fair | US Primary Care | 167 | 2- to 5-year-olds with at least one parent with BMI ≥25 and who have BMI ≥95th percentile but <100% above the mean BMI (CDC) | IG1: LAUNCH; IG2: Motivational interviewing | | IG1: 38 (NR); IG2: 7.5 (NR) | 6 | 6; 12; 18 (76%) | | X | X | X
Stettler, 2014^142^; Fair | US Primary Care | 173 | 8- to 12-year-olds with BMI in 75th to 95th percentile (CDC) and consuming average of ≥4 ounces of sugar sweetened beverages/day | IG1: Multiple-behavior change; IG2: Combined; IG3: Beverage-only intervention | | IG1: 4 (12); IG2: 4 (12); IG3: 4 (12) | 12 | 6;12;24 (70%) | | X
Tanofsky-Kraff, 2010^143^; Fair | US Other | 38 | Adolescent girls with BMI in 75th to 97th percentile (norms NR) | IG1: IPT-Weight Gain Prevention | | 17.9 (13) | 3 | 6; 12 (92%) | | X | | X
Tanofsky-Kraff, 2014^144^; Fair | US Other | 116 | 12- to 17-year-old girls with BMI in 75th to 97th percentile (CDC), and loss-of-control eating in the past month | IG1: Interpersonal psychotherapy | | 19.5 (13) | 3 | 6; 12; 36 (84%) | X | X | | X
Taveras, 2011^145^; Good | US Primary Care | 475 | 2- to 6-year-olds with BMI ≥85th percentile (CDC) and have a parent with BMI ≥25, or with BMI ≥95th percentile (CDC) | IG1: MI + enhanced EMR and training | | 2.67 (8) | 12 | 12; 24 (94%) | | X | X
Taveras, 2015^146^; Good | US Primary Care | 549 | 6- to 12-years-olds with BMI ≥95th percentile (CDC) | IG1: CDS+coaching; IG2: CDS | | IG1: 1.25 (5); IG2: 0.25 (1) | 12 | 12 (94%) | | X
Taveras, 2017^147^; Good | US Primary Care | 721 | 2- to 12-year-olds with BMI ≥85th percentile (CDC) | IG1: Enhanced primary care and coaching | | 1.75 (6) | 12 | 12 (92%) | X | X
Taylor, 2015^148^; Good | New Zealand University and home | 206 | 4- to 8-years-old with BMI ≥85th percentile (CDC) | IG1: Tailored lifestyle support | | 7.2 (14) | 24 | 12; 24 (88%) | X | X | X
Van Grieken, 2013^149^; Fair | Netherlands Primary Care | 637 | 5-year-olds with BMI classifed as overweight but do not have obesity (IOTF) | IG1: Be Active Eat Right | | NR (4) | 12 | 24 (80%) | | X
Viner, 2020^150^; Fair | UK Primary Care | 174 | 12- to 19-year-olds with BMI >95th percentile (UK norms) | IG1: Healthy Eating and Lifestyle Program (HELP) | | 12 (12) | 6 | 6; 12 (66%) | X | X | | X
Vos, 2011^151^; Fair | Netherlands Primary Care | 81 | 8- to 17-year-olds with BMI classified as with obesity (IOTF) | IG1: Family-based multidisciplinary lifestyle intervention | X | 37.5 (14) | 24 | 12 (83%) | X | X
Wake, 2009^152^; Good | Australia Primary Care | 258 | 5- to 10-year-olds with BMI classified as overweight or having obesity but zBMI <3.0 (IOTF and UK norms) | IG1: LEAP-2 | | NR (4) | 3 | 6; 12 (95%) | X | X | X | X
Wake, 2013^153^; Good | Australia Primary Care | 118 | 3- to 10-year-olds with BMI ≥95th percentile (CDC) | IG1: HopSCOTCH | | 2.5 (6) | 12 | 12 (91%) | X | X | X | X
Weigel, 2008^154^; Fair | Germany Other | 73 | 7- to 15-year-olds BMI >97th percentile (German norms) | IG1: Sea Lion Club | X | 114.1 (104) | 12 | 6; 12 (90%) | | X

* Broad health system recruitment, not specifically primary care.

Abbreviations: BMI = Body mass index; CDC = Centers for Disease Control and Prevention; CDS = Clinical decision support; EMR = Electronic medical record; Est = Estimated; Hrs = Hours; IG = Intervention group; IOTF = International Obesity Task Force; KQ = key question; MI = Motivational interviewing; NHANES = National Health and Nutrition Examination Survey; NR = Not reported; PA = Physical activity; PCP = Primary care physician; Rand = Randomized; RD = Registered dietician; ROC = Regulation of Cues; T2DM = Type II Diabetes mellitus; UK = United Kingdom; US = United States.

Table 3 Study Characteristics of Trials of Pharmacotherapy for Weight Management, Sorted by Type of Medication

Author, Year and Quality | Setting | N Rand | Population | Drug | Daily dose (mg) | Mo duration | Assessment months (Retention @ 12 mos or closest) | Control | KQ 1 | KQ 2 | KQ 4
Danne, 2017^155^; Fair | Germany Health Care | 21 | Adolescents, BMI ≥95th percentile and a BMI between 30 and 45 kg/m^2^ | Liraglutide | 3.0 | 1.25 | 1.25 (95%) | Placebo | | | X
Kelly, 2020^156^; Good | Belgium, Mexico, Russia, Sweden, and the US Health Care | 251 | 12- to <18-year-olds with BMI categorized as with obesity (IOTF) | Liraglutide | 3.0 | 13 | 13;19 (80%) | Placebo | X | X | X
Mastrandrea, 2019^157^; Fair | US Health Care | 24 | 7- to 11-year-olds with BMI ≥95th percentile and BMI categorized as with obesity (IOTF) | Liraglutide | 3.0 | 2 | 2 (83%) | Placebo | | | X
Weghuber, 2022^162^; Good | Austria, Belgium, Croatia, Ireland, Mexico, Russian Federation, UK, and US Other | 201 | Adolescents age ≥12 and <18 years with BMI ≥95th percentile or ≥85th percentile for age and sex (CDC) with ≥1 weight-related comorbidity | Semaglutide | 2.4/wk | 17 | 17 (90%) | Placebo | X | X | X
Chanoine, 2005^158^; Fair | US and Canada Health Care | 539 | 12- to 16-year-olds ≥2 BMI units above US mean for 95th percentile, and BMI <44 kg/m^2^ | Orlistat | 360 | 12 | 12 (65%) | Placebo + Diet, PA, and Behavior Therapy | X | X | X
Maahs, 2006^159^; Fair | US Other | 40 | 14- to 18-year-olds with BMI >85th percentile (norms NR) | Orlistat | 360 | 6 | 6 (85%) | Placebo + dietician counseling | X | X | X
Hsia, 2019^160^; Fair | US Health Care | 42 | Adolescents ages 12 to 17 years, BMI ≥95th percentile for age and sex | PHEN/TPM | IG1: 15/92; IG2: 7.5/45 | 2 | 2 (88%) | Placebo | | | X
Kelly, 2022^161^; Good | US Other | 227 | Adolescents age ≥12 and <17 years with BMI ≥95th percentile for age and sex (CDC) | PHEN/TPM | IG1: 15/92; IG2: 7.5/45 | 13 | 13 (61.2%) | Placebo + diet and PA training | X | X | X

Abbreviations: BMI = Body mass index; IOTF = International Obesity Task Force; Kg/m^2^ = kilograms/meters^2^; KQ = key question; Mg = milligrams; Mos = Months; NR = Not reported; PA = Physical activity; PHEN = Phentermine; TPM = Topiramate; US = United States.

## Description of Included Studies

### Behavioral Interventions

#### Study Characteristics

A summary of the characteristics of the behavioral intervention trials is presented in Table 4. Of the 50 included trials (n=8,798), 28 (56%) were conducted in the United States and the remaining trials were conducted in Europe, Canada, Australia, New Zealand, Israel, or Turkey. Twenty-seven (54%) of the trials were conducted in primary care, and the remaining were conducted in other healthcare settings, such as medical research facilities or outpatient clinics covering a wide range of specialties. Twelve studies (24%) recruited patients via population-based screening, seven (14%) through clinician referral, seven (14%) recruited volunteers using various types of advertising and media announcements, and the remaining used multiple recruitment approaches, typically clinician referral plus advertising and announcements.

Table 4 Summary of Study Characteristics of Trials of Behavioral Interventions (N randomized = 8,798)

Characteristics | No. studies | %
All studies | 50 | 100
Study design
RCT | 44 | 88
Cluster RCT | 6 | 12
Quality rating^*^
Good | 9 | 18
Fair | 41 | 82
Conducted in the US | 28 | 56
Weight focus
85th to <95th percentile for age and sex (or comparable) | 6 | 12
≥85th percentile (or comparable) | 29 | 58
≥95th percentile (or comparable) | 15 | 30
Recruitment setting
Primary care | 21 | 42
Other health care (only) | 8 | 16
Mixed or other | 20 | 40
Not reported | 1 | 2
Median sample size (IQR), Range | 108; (70 to 206) | 18 to 721
Median % followup at 6 to 12 months (IQR), Range | 84; (76 to 90) | 65 to 99

* Eight additional studies were rated as poor quality and excluded from the review.

Abbreviations: IQR = Interquartile range; No. = Number; RCT = Randomized controlled trial; US = United States.

#### Populations

A summary of the population characteristics of the behavioral intervention trials is presented in Table 5 and study-level details are provided in Appendix D Table 1. Specific weight criteria varied across the studies. Most trials included children who had a BMI at or above the 85th percentile or the 95th percentile for their age or sex according to CDC or country-specific norms or meet criteria for overweight or obesity according to IOTF norms. Five of the trials specifically targeted youth who were above the 75th or 85th percentile for age and sex but below the 95th percentile, or used similar criteria based on IOTF norms.^107,^ ^112,^ ^137,^ ^142,^ ^149^ In addition, 13 trials put an upper limit on weight, including: a BMI no higher than the 97th^131,^ ^132,^ ^143,^ ^144^ or 98th percentile^128^ for age and sex; a zBMI no greater than 2.5,^121^ 3.0,^124^ or 3.5;^114^ or a BMI no more than 100 percent^134,^ ^139–141^ or 200 percent^118^ of the median. On the other hand, four trials were limited to children with a BMI in a higher range (≥97th or 98th percentile for their age and sex), conducted in the United States,^117^ United Kingdom,^133^ and Germany.^108,^ ^154^ Baseline average BMI percentile ranged from 84.9 to 99.2 across studies, and the weighted average across all studies was 93.0. Average weighted baseline BMI was 18.4 kg/m^2^ in trials of preschool-aged children, 23.3 kg/m^2^ in trials of elementary-aged children, and 31.3 kg/m^2^ in trials of adolescents.

Table 5 Summary of Population Characteristics of Trials of Behavioral Interventions (N randomized = 8,798)

Characteristics | No. of trials | % of all trials or SD
Age; Mean, SD^*^ | 9 | 3
Age group
Preschool (~2–5) | 7 | 14
Elementary (~6–12) | 18 | 36
Adolescent (~13–18) | 12 | 24
Wide age range | 13 | 26
Majority Hispanic/Latino or Black^†^ | 10 | 20
| Total % across all trials reporting | Range (No. trials reporting)
Female | 57 | 33 to 100 (50)
Race^ǂ^
% Asian | 4 | 1 to 11 (11)
% Black | 21 | 3 to 47 (18)
% Native American | 3 | 0 to 6 (4)
% White | 52 | 5 to 90 (25)
Hispanic ethnicity | 25 | 1 to 88 (18)
BMI percentile for age and sex, Mean (SD)
Overall | 93 (5) | 85 to 99 (16)
Preschool (~2–5) | 93 (4) | 91 to 99 (3)
Elementary (~6–12) | 90 (7) | 85 to 99 (4)
Adolescent (~13–18) | 95 (3) | 88 to 98 (6)
Wide age range | 93 (3) | 92 to 99 (3)
BMI, Mean (SD)
Overall | 24 (6) | 18 to 36 (38)
Preschool (~2–5) | 18 (1) | 18 to 19 (4)
Elementary (~6–12) | 23 (4) | 18 to 32 (14)
Adolescent (~13–18) | 31 (2) | 25 to 35 (9)
Wide age range | 27 (5) | 23 to 36 (11)

* Mean across all trials, weighted by number randomized in each trial.

† Limited to trials conducted in the United States (28 trials).

ǂ Assuming majority non-Hispanic White if race and ethnicity were not reported.

Abbreviations: BMI = Body mass index; SD = Standard deviation.

The behavioral intervention trials included children as young as 2 years^132,^ ^139–141,^ ^145,^ ^147^ up to age 18 or 19 years.^150^ Eighteen (36%) of the trials primarily included elementary-aged children, generally from age 6 to 8 years up to age 12 years, and an additional 13 (26%) included a wider range of ages, covering elementary-aged and either preschool-aged children or adolescents. Twelve trials targeted adolescents only^110,^ ^111,^ ^116,^ ^119,^ ^120,^ ^123,^ ^125,^ ^129,^ ^134,^ ^143,^ ^144,^ ^150^ and seven targeted preschool- to kindergarten-aged children.^107,^ ^112,^ ^139–141,^ ^145,^ ^149^ Three trials were limited to girls only^111,^ ^143,^ ^144^ (all were studies of adolescents) and the remaining trials included both boys and girls (percent female across all trials, 57.2%).

Most trials either had a predominantly White sample of participants or failed to report the race and ethnicity distribution of study participants. However, somewhat broader representation of racial and ethnic groups was seen in studies conducted in the United States, where an estimated 52.4 percent of participants were White (among 25 trials reporting on percent White); 20.5 percent were Black (18 trials reporting) and 25.0 percent reported Hispanic/Latino heritage (24 trials reporting). However, there was very limited inclusion of Native American or Alaska Native participants (2.9% total among four studies reporting) or young people with Asian heritage (4.2% among 11 studies reporting). Seven studies included samples in which a majority of participants were Hispanic/Latino.^119,^ ^123,^ ^127–129,^ ^138,^ ^159^ Black children were not as widely represented; however, in eight studies in the United States and the United Kingdom, 26 to 47 percent of participants were Black.^117,^ ^135,^ ^136,^ ^142,^ ^143,^ ^147,^ ^150,^ ^157^ Altogether, 13 studies of behavioral interventions (all conducted in the United States) reported that at least 50 percent of participants were Black or Hispanic/Latino.^110,^ ^119,^ ^123,^ ^127–129,^ ^135,^ ^136,^ ^138,^ ^143,^ ^147,^ ^157,^ ^159^

Studies broadly reported socioeconomic status, but just four studies included a majority of participants facing socioeconomic challenges. Socioeconomic challenge was variably defined in these studies, including: explicit description by the authors that most participants were “economically disadvantaged,”^108^ 77 to 100 percent of participants being Medicaid recipients,^128,^ ^138^ or 80 percent of children living in homes with incomes less than $30,000 (published in 2014, year of data collection unknown).^136^

#### Interventions

The 50 included studies of behavioral interventions included 62 active intervention arms (Table 6, Appendix D Tables 2 and 3). Forty-seven of the 50 included trials provided at least dietary counseling and some information about behavior change principles. Most of these trials also provided counseling regarding physical activity or sedentary behavior. Two trials used interpersonal therapy as the primary treatment approach, linking overeating and loss-of-control eating to interpersonal functioning with apparently little to no counseling or education about eating a healthy diet and increasing physical activity.^143,^ ^144^ Another study also did not appear to provide content on healthy diet or physical activity, but instead examined a “regulation of cues” intervention based on appetite awareness and handling cues that trigger the desire to eat other than hunger.^106^ Another trial tested the impact of a calibrated dinner plate and breakfast bowl to aid in portion control.^115^ Most trials focused on initial weight management, but one trial addressed longer-term weight maintenance after participation in a weight management program.^110^

Table 6 Summary of Intervention Characteristics of Trials of Behavioral Interventions (62 Intervention Arms)

Characteristics | Median (IQR) | Range
Median months duration (IQR), Range | 6 (5 to 12) | 2.2 to 24
Median no. sessions (IQR), Range | 12 (6 to 16) | 0 to 122
Median estimated planned contact hours (IQR), Range | 16.2 (4 to 37.5) | 0 to 122
| No. groups | %
≥26 hours contact (estimated) | 19 | 30.6
Physical activity sessions | 16 | 25.8
Intervention participant
Child only | 5 | 8.1
Child and parent | 47 | 75.8
Parent only | 10 | 16.1
Format
Individual counseling only (in person or telephone-based) | 31 | 50.0
Individual and group sessions | 17 | 27.4
Group sessions only | 14 | 22.6
Electronic delivery
Computer-based component | 10 | 16.1
Computer-based (only, other than print materials) | 1 | 1.6
Components
Dietary advice | 57 | 91.9
Physical activity advice | 51 | 82.3
Behavior change advice | 59 | 95.2
Primary care clinician or staff involved in intervention delivery | 22 | 35.5

Abbreviations: IQR = Interquartile range; No = Number.

Intervention contact time varied considerably among studies. The number of sessions with a live interventionist (over the phone or in person) ranged from zero to 122 over a time period ranging from 2.25 to 24 months. The median number of sessions was 12 (interquartile range [IQR], 6 to 16), involving an estimated 16.2 hours of contact with an interventionist (IQR, 4 to 37.5 hours) over 6 months (IQR, 5 to 12 months). Only one study examined interventions that did not involve contact with an interventionist, but instead were delivered via website and print materials, with or without text messages.^129^ This study had another intervention arm that did include contact with a health counselor. Many of the most intensive interventions included supervised physical activity sessions and usually included group meetings, with or without individual parent or family meetings as well (Figure 4). These more intensive group interventions frequently involved separate groups for parents and children, as well as joint activities. In addition to providing practical information on such topics as healthy eating, safe exercising, and reading food labels, behavioral interventions typically incorporated behavior change techniques such as goal setting, monitoring diet and activity behaviors, and problem-solving. The lower-contact interventions generally did not include group sessions. These interventions were frequently conducted in primary care settings with the involvement of the primary care provider and sometimes included motivational interviewing by the primary care provider or another healthy lifestyle counselor.

Figure 4 Estimated Contact Hours and Number of Sessions for Behavioral Intervention Trials, Stratified by Whether Physical Activity Sessions Were Offered

Abbreviation: PA = Physical activity.

Figure 4 shows the estimated contact hours and number of sessions for behavioral intervention trials, stratified by whether physical activity sessions were offered

Most trials reported some measure of participation in the intervention. Studies most commonly reported a measure related to the percent of sessions attended, or the percent who attended at least some threshold number of sessions. Where reported, the average percent of sessions completed generally ranged from the mid-60s to low-80s. The percentage of participants who attended all planned sessions ranged from 31 to 93 in nine trials that reported this outcome.^110,^ ^119,^ ^132,^ ^138,^ ^140,^ ^149–152^

#### Quality Assessment

Nine studies were rated as “good” quality^107,^ ^111,^ ^124,^ ^145–148,^ ^152,^ ^153^ and the rest were rated as “fair” quality. Among the fair-quality trials, three reported generally good methods but were downgraded to fair because attrition was greater than 15 percent.^113,^ ^114,^ ^136^ More typically, there was more than one concern if studies received a fair rating. Aside from attrition, common concerns included unblinded outcomes assessment, or failure to report one or more of: allocation concealment, randomization methods, outcomes assessment blinding, information about intervention fidelity, or patient adherence or attendance. Many trials had small sample sizes; the median sample size was 108 (IQR, 70 to 206), equating to approximately 50 participants per study group. In addition, eight studies were rated as “poor” quality and excluded from the review. Among the studies excluded for poor quality, the most common issues were high attrition (>40%) or differential attrition (>20 percentage-point difference between groups).

### Pharmacotherapy

Three trials examined the impact of liraglutide (n=296),^155–157^ one examined semaglutide (n=201),^162^ two examined orlistat (n=579),^158,^ ^159^ and two trials examined two dosing schemes for the combination of phentermine and topiramate (n=269)^160,^ ^161^ (Table 3). Three of these trials only followed participants for 2 months or less and were therefore only included for KQ4 (harms): two liraglutide trials^155,^ ^157^ and one trial of phentermine/topiramate.^160^ Only one included trial, examining liraglutide, reported weight loss maintenance more than 1 month after treatment had ended.^156^ Of the pharmacotherapy trials, only the orlistat trials were included in the previous review.^158,^ ^159^ Seven of the eight trials were either conducted entirely in the United States or had study sites in the United States, and the remaining trial was conducted in Germany.^155^ One trial examining harms of short-term (8-week) use of liraglutide included children ages 7 to 11 years,^157^ and the remaining included adolescents age 12 years or older or 14 years or older (Appendix D Table 4). Mean baseline BMI was higher in trials of pharmacotherapy, ranging from 35.6 to 40.4 kg/m^2^ among trials of adolescents. The mean baseline zBMI for the study in younger children was 3.9. There was representation of Hispanic/Latino adolescents in trials of liraglutide (22% to 38% of participants), orlistat (62.5% in one small study), and phentermine/topiramate (32.3%). Only one short-term trial of liraglutide included substantial representation of Black children (42.0%). Daily dosing was 3 mg given by injection for liraglutide, three 120 mg tablets taken daily for orlistat, and combination tablets of either 15 mg phentermine/92 mg topiramate or 7.5 mg phentermine/46 mg topiramate (Appendix D Table 5). Semaglutide was administered by a weekly injection of 2.4 mg. Five of the studies of pharmacotherapy included behavioral counseling components along with the medication or placebo.^156,^ ^158,^ ^159,^ ^161,^ ^162^ Those that did not appear to include behavioral counseling were the short-term trials focused on establishing the safety of the medications that were only included for KQ4 (harms).^155,^ ^157,^ ^160^

## KQ1 Do Primary Care–Relevant Behavioral, Pharmacotherapy, or Combined Weight Management Interventions for Children and Adolescents With Higher BMI Improve Health Outcomes?

### Summary of Results

Health outcomes were rarely reported. Among the 14 trials of behavioral interventions reporting a health outcome (n=2,558), very few found any statistically significant improvements in quality of life at any followup time point (Appendix D Table 6). However, pooled analyses indicated small increases in total and physical quality of life after 6 to 12 months, reported in only a very small subset of the included trials (Total: mean difference in change [MD], 1.9 [95% CI, 0.2 to 3.5]; 11 RCTs [n=1,922]; I^2^=48.4%; Physical: MD, 1.7 [95% CI, 0.1 to 3.4]; 4 RCTs [n=1,216]; I^2^=0% for studies with <26 hours estimated contact; Table 7, Figure 5, and Appendix E Figure 1; most scales range from 0 to 100). Evidence from only one to four trials suggested that behavioral interventions had no impact on psychosocial quality of life, depression, or social adjustment. Among the four pharmacotherapy studies that included a health outcome, semaglutide was associated with a 5.3-point greater improvement in weight-related quality of life (MD, 5.3 [95% CI, 0.2 to 8.3]) but the remaining three found no between-group differences in change in quality of life or depression incidence compared with placebo after 6 to 13 months.^156,^ ^158,^ ^159^

Table 7 Meta-Analysis Results for Quality of Life for Behavioral Interventions

Outcome | All Studies in MA | | | <26 Contact hrs | | | ≥26 Contact hrs | | | P-value
| K (N) | I^2^, % | Mean Diff in Change (95% CI) | K (N) | I^2^, % | Mean Diff in Change (95% CI) | K (N) | I^2^, % | Mean Diff in Change (95% CI) | (diff b/t dose levels)
Total score, MD | 11 (1922) | 48.4 | 1.9; (0.2 to 3.5) | 7 (1459) | 64.4 | 1.3; (−1.1 to 3.8) | 4 (463) | 0.0 | 3.8; (3.6 to 4.1) | 0.173
Total score, SMD | 8 (1457) | 47.3 | 0.2; (0.0 to 0.5) | 4 (994) | 84.6 | 0.3; (−0.4 to 1.1) | 4 (463) | 0.0 | 0.2; (0.1 to 0.4) | 0.607
Physical domain, MD | 5 (1232) | 87.5 | 4.6; (−2.6 to 11.9) | 4 (1216) | 0.0 | 1.7; (0.1 to 3.4) | 1 (16) | - | 16.5; (9.5 to 23.5) | <0.001
Psychosocial domain, MD | 4 (1216) | 0.0 | 0.7; (−0.6 to 1.9) | 4 (1216) | 0.0 | 0.7; (−0.6 to 1.9) | 0 (0) | | N/A | N/A

Abbreviations: B/t = Between; CI = Confidence interval; Diff = Difference; Hrs = Hours; K = Number of studies; MA = Meta-analysis; MD = Mean difference (in native units); N/A = Not applicable; SMD = Standardized mean difference.

Figure 5 Pooled Analysis of Change in Total or Global Quality of Life in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CHQ = Child Health Questionnaire; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; IWQOL = Impact of Weight on Quality of Life; MnChg = Mean change; Mos = Months; n = Number of participants; PA = Physical activity; PedsQL = Pediatric Quality of Life Inventory; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment.

Figure 5 shows a pooled analysis of change in total or global quality of life in behavioral interventions compared with controls, by estimated contact hours.

### Detailed Results by Intervention Type and Outcome

#### Behavioral Interventions

Fourteen of the behavioral intervention trials reported health outcomes (N=2,674).^111,^ ^116,^ ^117,^ ^120,^ ^124,^ ^129,^ ^139,^ ^144,^ ^147,^ ^148,^ ^150–153^ Detailed results for all health outcomes are shown in Appendix D Table 6. Six of these trials were conducted in the United States.^111,^ ^117,^ ^129,^ ^139,^ ^144,^ ^147^ Two included a majority of participants who were Black or Hispanic/Latino (conducted in the United States),^147^ or Black or Asian (conducted in the United Kingdom).^150^ None of these studies focused specifically on families facing financial or other social challenges.

##### Quality of Life

Thirteen of the 14 trials reporting a health outcome reported quality of life, measured by the Pediatric Quality of Life Inventory (PedsQL),^111,^ ^116,^ ^120,^ ^124,^ ^129,^ ^139,^ ^144,^ ^147,^ ^148,^ ^152,^ ^153^ the Child Health Questionnaire (CHQ),^116,^ ^117^ the DISAKIDS questionnaire (DISAKIDS),^151^ or the Impact of Weight on Quality of Life--Kids (IWQOL).^150^ Only three trials found statistically significant group differences at any time point, on any measure of quality of life.^116,^ ^119,^ ^139^ Eleven of these trials reported a total or global score, completed by either the child or the parent. Among those with sufficient data to include in meta-analysis, the intervention groups increased by 1.9 points more than the control groups, typically on 100-point scales (MD, 1.9 [95% CI, 0.2 to 3.5]; 11 RCTs [n=1,922]; I^2^=48.4%, Figure 5 and Appendix E Figure 2). Effect sizes were similar between interventions with higher (≥26 hours) and lower (<26 hours) estimated contact time. Physical quality of life scores also showed a very small impact when pooled in four lower-contact trials (MD, 1.7 [95% CI, 0.1 to 3.4]; 4 RCTs [n=1,216]; I^2^=0%, Appendix E Figure 1), but one very small study (n=16) of young children reported a large improvement (MD, 16.5 [95% CI, 9.5 to 23.5]) after 12 months.^139^ The same four lower-contact trials showed no benefit on psychosocial quality of life (MD, 0.7 [95% CI, −0.6 to 1.9]; 4 RCTs [n=1,216]; I^2^=0%, Appendix E Figure 3). Effects sizes in studies with higher representation of Black, Hispanic, and Asian children were similar to those in other studies.^129,^ ^147,^ ^150^

##### Depression

Three studies of adolescents reported depression.^111,^ ^129,^ ^144^ None of these studies found group differences at any time point. For example, the best-quality study^111^ reported no group differences in the percent with depression according to the Mood module of the Adolescent version of the Patient Health Questionnaire (PHQ) at either 6 months (relative risk [RR], 0.81 [95% CI, 0.24 to 2.74]; 5.9% in the control group vs. 4.8% in the intervention group) or 12 months (RR, 1.37 [95% CI, 0.37 to 5.04]; 5.3% in the control group vs. 7.1% in the intervention group).

##### Social Adjustment

One study found no group difference on the Social Adjustment Scale-Self-Report at 6- or 12-month followup (MD, 6-month: −0.3 [95% CI, −0.6 to 0]; 12-month: −0.1 [95% CI, −0.4 to 0.2]).^144^

#### Glucagon-Like Peptide-1 Agonists

One study each of liraglutide^156^ (n=251) and semaglutide^162^ (n=201) reported health outcomes (Table 8). Weight-related quality of life scores did not differ at the end of treatment with liraglutide; after 13 months scores increased by 7.9 (standard deviation [SD], 11.6) with liraglutide and 6.6 (SD, 11.9) with placebo (MD, 1.3 [95% CI, −1.6 to 4.2]) on a 100-point scale. Weight-related quality of life showed greater improvement with semaglutide than placebo at the end of the 16-month treatment period; scores increased by 5.3 points with semaglutide, compared to 1.0 with placebo, on a 100-point scale (MD, 5.3 [95% CI, 0.2 to 8.3]). Four percent (5/125) of participants taking liraglutide developed depression, compared with 2.4 percent (3/126) taking placebo (RR, 1.7 [95% CI, 0.4 to 7.3]). This study also conducted an analysis among people who endorsed at least moderate-level depression symptomatology on the PHQ-9. When categorized into moderate, moderate-to-high, and high symptom severity, participants receiving liraglutide were more likely to endorse severe levels of symptoms and less likely to endorse moderate levels of symptoms than those receiving placebo injections.

Table 8 Health Outcomes for Glucagon-Like Peptide-1 at End of Treatment^156,^ ^162^

Study | Medication | FU, mos | Outcome | IG BL mean (SD) | CG BL mean (SD) | IG FU change mean (SD) | IG N | CG FU change mean (SD) | CG N | Stat | Between-group difference (95% CI) | Study-reported p-value
| | | Quality of life
Kelly, 2020^156^ | Liraglutide | 13 | IWQOL, Total (range 0–100, higher is better) | 84.5 (12.4) | 82.4 (14.5) | 7.9 (11.6) | 125 | 6.6 (11.9) | 126 | MD in change | 1.3 (−1.6 to 4.2) | NR
Weghuber, 2022^162^ | Semaglutide | 16 | IWQOL, Total (range 0–100, higher is better) | 84.2 (15.0) | 83.5 (14.6) | 5.3 (NR) | 134 | 1.0 (NR) | 67 | MD in change | 5.3 (0.2 to 8.3) | NR
| | | Depression | | | IG n events (%) | | CG n events (%)
Kelly, 2020^156^ | Liraglutide | 13 | Depression incidence, % | N/A | N/A | 5 (4) | 125 | 3 (2.4) | 126 | RR | 1.71 (0.40 to 7.31) | NR
Kelly, 2020^156^ | Liraglutide | 13 | PHQ-9 Score Moderate (10 to <15), % | N/A | N/A | 13 (10.4) | 125 | 26 (20.6) | 126 | RR | 0.45 (0.22 to 0.92) | NR
Kelly, 2020^156^ | Liraglutide | 13 | PHQ-9 Score Moderate to Severe (15 to <20), % | N/A | N/A | 4 (3.2) | 125 | 7 (5.6) | 126 | RR | 0.56 (0.16 to 1.97) | NR
Kelly, 2020^156^ | Liraglutide | 13 | PHQ-9 Score Severe (20+), % | N/A | N/A | 6 (4.8) | 125 | 2 (1.6) | 126 | RR | 3.13 (0.62 to 15.8) | NR

Abbreviations: BL = Baseline; CG = Control group; CI = Confidence interval; FU = Followup; IG = Intervention group; IWQOL = The Impact of Weight on Quality of Life; MD = Mean difference; Mos = Months; N/A = Not applicable; NR = Not reported; PHQ = Patient Health Questionnaire; RR = Relative risk; SD = Standard deviation; Stat = Statistic; Tx = Treatment.

#### Orlistat

One study each reported on quality of life (n=40)^159^ and depression incidence (n=539)^158^ (Table 9). There were no differences in either quality of life after 6 months (detailed data not provided) or depression incidence after 1 year (0.6% [2/352] with orlistat, 0% [0/181] with placebo; RR, 2.6 [95% CI, 0.1 to 54.2]).

Table 9 Health Outcomes for Orlistat at End of Treatment

Study | Followup, mos | Outcome | IG BL mean (SD) | CG BL mean (SD) | IG FU change mean (SD) | IG N | CG FU change mean (SD) | CG N | Stat | Between-group difference (95% CI) | Study-reported p-value
| | Quality of Life
Maahs, 2006^159^ | 6 | IWQOL, Total | NR | NR | NR | NR | NR | NR | MD in change | NR | NSD
| | Depression | | | IG n events (%) | | CG n events (%)
Chanoine, 2005^158^ | 12 | Depression incidence, % | N/A | N/A | 2 (0.6) | 352 | 0 (0) | 181 | RR | 2.59 (0.12 to 54.22) | NR

Abbreviations: BL = Baseline; CG = Control group; CI = Confidence interval; FU = Followup; IG = Intervention group; IWQOL = The Impact of Weight on Quality of Life; MD = Mean difference; Mos = Months; N/A = Not applicable; NSD = No significant difference; NR = Not reported; RR = Relative risk; SD = Standard deviation; Stat = Statistic; Tx = Treatment.

#### Phentermine/Topiramate

One study (n=227) reported quality of life and depression and found no between-group differences in either outcome (Table 10).^156^ Quality of life scores increased by 3.1 (SD, 12.8) to 4.3 (SD, 12.5) points with phentermine/topiramate and 2.9 (SD, 14.1) with placebo (MD, 0.2 [95% CI, −4.2 to 4.6]). Four percent (5/113) of participants taking the higher dose of phentermine/topiramate developed depression, compared with 2 percent (1/54) taking the lower dose and none (0/56) taking the placebo (RR of high dose vs. placebo, 5.7 [95% CI, 0.3 to 105.4]; low dose vs. placebo, 3.2 [95% CI, 0.1 to 79.5]). No group differences were found between phentermine/topiramate and placebo on heart rate (beats per minute).

Table 10 Health Outcomes for Phentermine/Topiramate at End of Treatment (13 Months Post-Baseline)^161^

Outcome, Daily Dose | IG BL mean (SD) | CG BL mean (SD) | IG FU change mean (SD) | IG N | CG FU change mean (SD) | CG N | Stat | Between-group difference (95% CI) | Study-reported p-value
Quality of life: IWQOL, Total; (range 0–100, higher is better)
IG1: PHEN (15 mg)/TOP (92 mg) | 82.7 (14.2) | 87.1 (10.2) | 3.1 (12.8) | 113 | 2.9 (14.1) | 56 | MD in change | 0.17 (−4.25 to 4.6) | NR
IG2: PHEN (7.5 mg)/TOP (46 mg) | 85.1 (13.1) | 87.1 (10.2) | 4.3 (12.5) | 54 | 2.9 (14.1) | 56 | MD in change | 1.37 (−3.64 to 6.39) | NR
Depression Incidence, % | | | IG n events (%) | | CG n events (%)
IG1: PHEN (15 mg)/TOP (92 mg) | N/A | N/A | 5 (4.4) | 113 | 0 (0) | 56 | RR | 5.73 (0.31 to 105.45) | NR
IG2: PHEN (7.5 mg)/TOP (46 mg) | N/A | N/A | 1 (1.9) | 54 | 0 (0) | 56 | RR | 3.17 (0.13 to 79.48) | NR

Abbreviations: BL = Baseline; CG = Control group; CI = Confidence interval; FU = Followup; IG = Intervention group; IWQOL = Impact of Weight on Quality of Life; MD = Mean difference; Mg = milligram; N/A = Not applicable; NR = Not reported; PHEN = Phentermine; RR = Relative risk; SD = Standard deviation; Stat = Statistic; TOP = Topiramate.

## KQ2 Do Primary Care–Relevant Behavioral, Pharmacotherapy, or Combined Weight Management Interventions for Children and Adolescents With Higher BMI Affect Weight Outcomes or Cardiometabolic Outcomes?

### Summary of Results

Behavioral weight management interventions were associated with small reductions in BMI and other weight-related outcomes after 6 to 12 months (MD, −0.7 kg/m^2^ [95% CI, −1.0 to −0.3]; 28 RCTs [n=4,494]; I^2^=86.8%, Figure 6, Table 11). Larger effects were seen in interventions with higher contact hours and that offered physical activity sessions as part of the intervention, rather than simply encouraging increased physical activity at home. We could not clearly disentangle the impact of contact hours from the impact of physical activity sessions, because many of the higher contact interventions included physical activity sessions. The clinical significance of the effect size is unclear, and evidence was sparse beyond 12 months. Lipid levels, blood pressure, and fasting plasma glucose were reported by a fairly small subset of trials. Pooled effects indicated no impact on measures of cholesterol but suggested small improvements in blood pressure and fasting plasma glucose in trials offering 26 or more hours of contact, again, most of which also offered physical activity sessions (Table 12). One study found that physical fitness was better maintained among participants of an intervention that included physical activity sessions compared with control participants.^151^

Figure 6 Pooled Analysis of Change in Body Mass Index (kg/m^2^) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; Kg/m^2^ = Kilograms per meters squared; MnChg = Mean change; Mos = Months; n = Number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment.

Figure 6 shows a pooled analysis of change in body mass index (kg/m2) in behavioral interventions compared with controls, by estimated contact hours

Table 11 Meta-Analysis Results for Weight-Related Outcomes for Behavioral Interventions

Outcome | All Studies in MA | | | <26 Contact hrs | | | ≥26 Contact hrs | | | P-value
| K (N) | I^2^, % | Mean Diff in Change (95% CI) | K (N) | I^2^, % | Mean Diff in Change (95% CI) | K (N) | I^2^, % | Mean Diff in Change (95% CI) | (diff b/t contact levels)
Weight
BMI, kg/m^2^ | 28 (4494) | 86.8 | −0.7; (−1.0 to −0.3) | 17 (3407) | 62.1 | −0.3 (−0.5 to −0.1) | 11 (1087) | 87.8 | −1.4 (−2.2 to −0.6) | 0.004
Weight, kg | 18 (1625) | 69.2 | −2.1; (−3.0 to −1.2) | 8 (718) | 69.5 | −1.5 (−3.0 to 0.1) | 10 (907) | 58.2 | −2.6 (−3.8 to −1.3) | 0.23
zBMI/BMI SDS | 34 (4995) | 67.0 | −0.09; (−0.13 to −0.05) | 19 (3527) | 0.01 | −0.05 (−0.08 to −0.03) | 15 (1468) | 83.1 | −0.17 (−0.27 to −0.07) | 0.009
Adiposity
Waist circumference, cm | 16 (2065) | 79.2 | −1.5 (−2.4 to −0.6) | 11 (1597) | 14.4 | −0.3 (−0.8 to 0.2) | 5 (468) | 77.6 | −3.0 (−5.5 to −0.4) | 0.005
% Body fat | 11 (1191) | 81.2 | −1.5 (−3.1 to 0.1) | 5 (583) | 0.0 | −0.2 (−1.1 to 0.8) | 6 (608) | 74.2 | −3.1 (−5.8 to −0.3) | 0.014

Abbreviations: BMI = Body mass index; BMI SDS = Standardized BMI; B/t = Between; CI = Confidence interval; Cm = centimeter; Diff = Difference; Hrs = Hours; K = Number of studies; Kg/m^2^ = kilograms per meters squared; MA = Meta-analysis.

Table 12 Meta-Analysis Results for Lipids, Blood Pressure, and Insulin Outcomes for Behavioral Interventions

Outcome | All Studies in MA | | | <26 Contact hrs | | | ≥26 Contact hrs | | | P-value
| K (N) | I^2^, % | Mean Diff in Change (95% CI) | K (N) | I^2^, % | Mean Diff in Change (95% CI) | K (N) | I^2^, % | Mean Diff in Change (95% CI) | (diff b/t contact levels)
Blood pressure
SBP, mm Hg | 12 (1189) | 63.5 | −2.0; (−4.1 to 0.2) | 4 (416) | 0.0 | 1.4; (−1.3 to 4.1) | 8 (773) | 47.3 | −3.6; (−5.7 to −1.5) | 0.001
DBP, mm Hg | 12 (1190) | 35.2 | −2.2; (−3.8 to −0.7) | 4 (417) | 0.0 | −0.8; (−2.3 to 0.7) | 8 (773) | 49.3 | −3.0; (−5.2 to −0.7) | 0.121
Lipids
LDL, mg/dL | 7 (648) | 56.9 | −3.2; (−9.0 to 2.6) | 4 (347) | 74.6 | −3.9; (−17.4 to 9.5) | 3 (301) | 0.0 | −2.4; (−9.7 to 4.8) | 0.765
HDL, mg/dL | 11 (916) | 0.0 | 0.7; (−0.0 to 1.4) | 7 (548) | 0.0 | 0.6; (-.2 to 1.3) | 4 (368) | 0.0 | 0.8; (−1.6 to 3.2) | 0.839
TC, mg/dL | 6 (534) | 46.5 | −4.3; (−12.1 to 3.4) | 3 (233) | 14.0 | −2.2; (−18.4 to 13.9) | 3 (301) | 63.0 | −5.9; (−28.2 to 16.4) | 0.567
TG, mg/dL | 9 (800) | 53.0 | −4.7; (−14.5 to 5.1) | 5 (433) | 0.0 | 5.5; (0.6 to 10.5) | 4 (367) | 0.0 | −16.9; (−29.7 to −4.0) | <0.001
Glucose
FPG, mg/dL | 9 (750) | 28.5 | −0.6; (−2.1 to 1.0) | 5 (383) | 5.0 | 1.0; (−1.4 to 3.4) | 4 (367) | 0.0 | −1.9; (−2.7 to −1.2) | .016

Abbreviations: B/t = Between; CI = Confidence Interval; DBP = Diastolic blood pressure; Diff = Difference; FPG = Fasting plasma glucose; HDL = High-density lipoprotein; Hrs = Hours; K = Number of studies; LDL = low-density lipoprotein; MA = Meta-analysis; Mg/dL = Milligrams per deciliter; mm Hg = Milligrams mercury; SBP = Systolic blood pressure; TC = Total cholesterol; TG = Triglycerides.

Intermediate outcomes were reported by two studies of orlistat^158,^ ^159^ and one study each of phentermine/topiramate,^161^ liraglutide,^156^ and semaglutide^162^ (Tables 13–18). Pharmacotherapy was associated with larger mean BMI reductions than placebo in all the studies except one small (n=40) study of orlistat.^159^ Liraglutide was associated with 1.6 kg/m^2^ greater reduction in BMI than placebo (MD, −1.6 kg/m^2^ [95% CI, −2.5 to −0.7] after 13 months),^156^ semaglutide with a 6.0 kg/m^2^ greater reduction in BMI (MD, −6.0 kg/m^2^ [95% CI, −7.3 to −4.6] after 16 months), orlistat with a 0.9 kg/m^2^ greater reduction (MD, −0.9 kg/m^2^ [95% CI not reported [NR]; p=0.001] after 12 months),^158^ and phentermine/topiramate with 3.7 to 5.4 kg/m^2^ greater reductions (15/92 mg dose MD, −5.4 kg/m^2^ [95% CI, −6.4 to −4.3]; 7.4/46 mg dose MD, −3.7 kg/m^2^ [95% CI, −5.0 to −2.5] after 13 months).^161^ Group differences were not maintained in the liraglutide study after 6 months without treatment and longer-term maintenance after medication withdrawal was not reported for any of the other medications. All medications showed increases in the likelihood of losing both 5 percent and 10 percent of baseline weight or BMI. The only medication that showed a clear benefit for blood pressure was phentermine/topiramate, and only at the higher dose level (MD, −4.0 [95% CI, −7.7 to −0.5]). Semaglutide use improved low-density lipoprotein (LDL) cholesterol (MD in percent change, −7.1 [95% CI, −11.9 to −1.8]), and phentermine/topiramate improved high-density lipoprotein (HDL) cholesterol (e.g., 15/92 mg/day dose: MD in percent change, 8.8 [95% CI, 2.2 to 15.4]) but other medications had minimal to no impact on lipid levels. None of the trials found improvements in glucose-related parameters.

Table 13 Weight-Related Outcomes for Glucagon-Like Peptide-1 Agonists

Study | Medication | Followup (months since tx ended) | Outcome | IG BL mean (SD) | CG BL mean (SD) | IG FU change mean (SD) | IG N | CG FU change mean (SD) | CG N | Between-group difference in mean change (95% CI) | Study-reported p-value
Kelly, 2020^156^ | Liraglutide | 13 (0) | BMI, kg/m^2^ | 35.3 (5.1) | 35.8 (5.7) | −1.4 (3.5) | 125 | 0.2 (3.7) | 126 | −1.6 (−2.5 to −0.7) | NR
Kelly, 2020^156^ | Liraglutide | 19 (6) | BMI, kg/m^2^ | 35.3 (5.1) | 35.8 (5.7) | −0.2 (3.5) | 112 | 0.8 (4) | 102 | −1.0 (−2.0 to 0.01) | NR
Kelly, 2020^156^ | Liraglutide | 13 (0) | Weight, kg | 99.3 (19.7) | 102.2 (21.6) | −2.3 (10.5) | 125 | 2.2 (11) | 126 | −4.5 (−7.2 to −1.8) | NR
Kelly, 2020^156^ | Liraglutide | 19 (6) | Weight, kg | 99.3 (19.7) | 102.2 (21.6) | 1.7 (10.1) | 112 | 4.4 (11.7) | 102 | −2.7 (−5.6 to 0.2) | NR
Weghuber, 2022^162^ | Semaglutide | 16 (0) | BMI, kg/m^2^ | 37.7 (6.7) | 35.7 (5.4) | −5.8 (NR) | 134 | 0.1 (NR) | 67 | −6 (−7.3 to −4.6) | NR
Weghuber, 2022^162^ | Semaglutide | 16 (0) | Weight, kg | 109.9 (25.2) | 102.6 (22.3) | 15.3 (NR) | 134 | 2.4 (NR) | 67 | −17.7 (−21.8 to −13.7) | NR
| | | | | | IG n events (%) | | CG n events (%) | | RR (95% CI)
Kelly, 2020^156^ | Liraglutide | 13 (0) | ≥5% BMI loss, % | -- | -- | 51 (45.1) | 113 | 20 (19) | 105 | 3.50 (1.78 to 6.16) | NR
Kelly, 2020^156^ | Liraglutide | 13 (0) | ≥10% BMI loss, % | -- | -- | 33 (29.2) | 113 | 9 (8.6) | 105 | 4.40 (1.81 to 8.83) | NR
Weghuber, 2022^162^ | Semaglutide | 16 (0) | ≥5% BMI loss, % | -- | -- | 95 (72.5) | 131 | 11 (17.7) | 62 | 12.2 (6.3 to 31) | <0.001
Weghuber, 2022^162^ | Semaglutide | 16 (0) | ≥10% weight loss, % | -- | -- | 81 (61.8) | 131 | 5 (8.1) | 62 | 18.5 (8.3 to 63.7) | NR

Abbreviations: BL = Baseline; BMI = Body mass index; CI = Confidence Interval; FU = Followup; IG = Intervention group; Kg/m^2^ = Kilograms per meters squared; NR = Not reported; RR = Relative risk; SD = Standard deviation; Tx = Treatment.

Table 14 Weight-Related Outcomes for Orlistat, Sorted By Outcome

Study | Followup (months since tx ended) | Outcome | IG BL mean (SD) | CG BL mean (SD) | IG FU change mean (SD) | IG N | CG FU change mean (SD) | CG N | Between-group difference in mean change (95% CI) | Study-reported p-value
Chanoine, 2005^158^ | 12 (0) | BMI, kg/m^2^ | 35.7 (4.2) | 35.4 (4.1) | −0.6 (NR) | 352 | 0.3 (NR) | 181 | −0.9 (NR) | 0.001
Maahs, 2006^159^ | 6 (0) | BMI, kg/m^2^ | 39.2 (5.3) | 41.7 (11.7) | −1.3 (7.2) | 16 | −0.8 (13.4) | 18 | −0.5 (−7.9 to 6.9) | 0.70
Chanoine, 2005^158^ | 12 (0) | Weight, kg | 97.7 (15) | 95.1 (14.2) | 0.5 (NR) | 352 | 3.1 (NR) | 181 | −2.6 (NR) | <0.001
Maahs, 2006^159^ | 6 (0) | Weight, kg | 111.1 (22.9) | 114.3 (38.4) | −5.5 (23.9) | 16 | −1.6 (39.4) | 18 | −3.9 (−26.2 to 18.3) | 0.76
| | | | | IG n events (%) | | CG n events (%) | | RR (95% CI)
Chanoine, 2005^158^ | 12 (0) | ≥5% BMI loss, % | -- | -- | 93 (26.4) | 352 | 29 (16.0) | 181 | 1.9 (1.2 to 3.0) | 0.005
Chanoine, 2005^158^ | 12 (0) | ≥10% BMI loss, % | -- | -- | 46 (13.1) | 352 | 8 (4.4) | 181 | 3.2 (1.5 to 7.0) | 0.002
Chanoine, 2005^158^ | 12 (0) | ≥5% Weight loss, % | | | 67 (19.0) | 352 | 21 (11.6) | 181 | 1.8 (1.1 to 3.0) | 0.03
Chanoine, 2005^158^ | 12 (0) | ≥10% Weight loss, % | | | 34 (9.7) | 352 | 6 (3.3) | 181 | 3.1 (1.3 to 7.6) | 0.01

Abbreviations: BL = Baseline; BMI = Body mass index; CG = Control group; CI = Confidence Interval; FU = Followup; IG = Intervention group; Kg/m^2^ = Kilograms per meters squared; NR = Not reported; SD = Standard deviation; Tx = Treatment.

Table 15 Weight-Related Outcomes for Phentermine/Topiramate at End of Treatment (13 Months Post-Baseline)^161^

Dose | Outcome | IG BL mean (SD) | CG BL mean (SD) | IG FU change mean (SD) | IG N | CG FU change mean (SD) | CG N | Between-group difference in mean change (95% CI) | Study-reported p-value
IG1: PHEN (15 mg)/TOP (92 mg) | BMI, kg/m^2^ | 39 (7.4) | 36.4 (6.4) | −4.2 (3.3) | 113 | 1.2 (3.4) | 56 | −5.4 (−6.4 to −4.3) | NR
IG2: PHEN (7.5 mg)/TOP (46 mg) | BMI, kg/m^2^ | 36.9 (6.8) | 36.4 (6.4) | −2.5 (3.2) | 54 | 1.2 (3.4) | 56 | −3.7 (−5.0 to −2.5) | NR
IG1: PHEN (15 mg)/TOP (92 mg) | Weight, kg | 108.5 (25) | 102.2 (21.8) | −9.2 (9.1) | 113 | 6.6 (9.6) | 56 | −15.8 (−18.8 to −12.8) | NR
IG2: PHEN (7.5 mg)/TOP (46 mg) | Weight, kg | 105.2 (22.4) | 102.2 (21.8) | −5.5 (9.0) | 54 | 6.6 (9.6) | 56 | −12.1 (−15.6 to −8.6) | NR
| | | | IG n events (%) | | CG n events (%) | | RR (95% CI)
IG1: PHEN (15 mg)/TOP (92 mg) | ≥5% BMI loss, % | -- | -- | 53 (46.9) | 113 | 3 (5.4) | 56 | 5.6 (2.2 to 14.4) | <0.001
IG2: PHEN (7.5 mg)/TOP (46 mg) | ≥5% BMI loss, % | | | 21 (38.9) | 54 | 3 (5.4) | 56 | 4.6 (1.7 to 12.7) | <0.001
IG1: PHEN (15 mg)/TOP (92 mg) | ≥10% BMI loss, % | -- | -- | 48 (42.5) | 113 | 0 (0) | 56 | 12.2 (3.1 to 48.3) | <0.001
IG2: PHEN (7.5 mg)/TOP (46 mg) | ≥10% BMI loss, % | | | 17 (31.5) | 54 | 0 (0) | 56 | 9.3 (2.3 to 38.0) | <0.001

Abbreviations: BL = Baseline; BMI = Body mass index; CI = Confidence Interval; FU = Followup; IG = Intervention group; Kg/m^2^ = Kilograms per meters squared; NR = Not reported; RR = Relative risk; SD = Standard deviation; Tx = Treatment.

Table 16 Blood Pressure, Lipids, and Insulin Outcomes for Glucagon-Like Peptide-1 Agonists

Study | Medication | FU mos | Outcome | IG BL mean (SD) | CG BL mean (SD) | IG FU change mean (SD) | IG N | CG FU change mean (SD) | CG N | Between-group difference in mean change (95% CI) | Study-reported p-value
Kelly, 2020^156^ | Liraglutide | 13 | SBP, mm Hg | 116 (10) | 117 (12) | −1.2 (10.1) | 125 | 0.8 (10.1) | 126 | −2.0 (−4.5 to 0.4) | NR
Kelly, 2020^156^ | Liraglutide | 13 | DBP, mm Hg | 72 (8) | 73 (8) | 0.8 (7.7) | 125 | −0.5 (7.7) | 126 | 1.2 (−0.7 to 3.1) | NR
Kelly, 2020^156^ | Liraglutide | 13 | LDL-C, mg/dL | 88.6 (24) | 86.6 (25.2) | 1 (0.2) | 125 | 1 (0.2) | 126 | 1.0 (0.9 to 1.0) | NR
Kelly, 2020^156^ | Liraglutide | 13 | HDL-C, mg/dL | 43.8 (10) | 43.8 (10.3) | 1 (0.2) | 125 | 1 (0.2) | 126 | 1.0 (1.0 to 1.07) | NR
Kelly, 2020^156^ | Liraglutide | 13 | TC, mg/dL | 156.4 (27) | 154.9 (29.6) | 1 (0.1) | 125 | 1 (0.1) | 126 | 1.0 (1.0 to 1.04) | NR
Kelly, 2020^156^ | Liraglutide | 13 | FPG, mg/dL | 94.1 (7.6) | 94.5 (11.1) | −2 (9.5) | 125 | −0.2 (9.7) | 126 | −1.8 (−4.1 to 0.5) | NR
Weghuber, 2022^162^ | Semaglutide | 16 | SBP, mm Hg | 120 (11) | 120 (12) | −2.7 (NR) | 134 | −0.8 (NR) | 67 | −1.9 (−5 to 1.1) | NR
Weghuber, 2022^162^ | Semaglutide | 16 | DBP, mm Hg | 73 (9) | 73 (9) | −1.4 (NR) | 134 | −0.8 (NR) | 67 | −0.6 (NR) | NR
Weghuber, 2022^162^ | Semaglutide | 16 | LDL-C, mg/dL | 89.8 (29.8) | 91.7 (26.9) | −10.2 (NR) | 134 | −3.4 (NR) | 67 | −7 (−11.9 to −1.8) | NR
Weghuber, 2022^162^ | Semaglutide | 16 | HDL-C, mg/dL | 43.7 (NR) | 43.3 (NR) | 8 (NR) | 134 | 3.2 (NR) | 67 | 4.7 (−1 to 10.7) | NR
Weghuber, 2022^162^ | Semaglutide | 16 | TC, mg/dL | 159.4 (19.3) | 160.1 (18.9) | −8.3 (NR) | 134 | −1.3 (NR) | 67 | −7.1 (−10.5 to −3.5) | NR

Abbreviations: BL = Baseline; CG = Control group; CI = Confidence Interval; DBP = Diastolic blood pressure; FPG = Fasting plasma glucose; FU = Followup; HDL-C = High-density lipoprotein cholesterol; IG = Intervention group; LDL-C = low-density lipoprotein cholesterol; Mg/dL = Milligrams per deciliter; mmHg = Milligrams mercury; Mos = Months; NR = Not reported; SBP = Systolic blood pressure; SD = Standard deviation; TC = Total cholesterol.

Table 17 Blood Pressure, Lipids, and Insulin Outcomes for Orlistat, Sorted by Outcome

Study | Followup (months since tx ended) | Outcome | IG BL mean (SD) | CG BL mean (SD) | IG FU change mean (SD) | IG N | CG FU change mean (SD) | CG N | Between-group difference in mean change (95% CI) | Study-reported p-value
Chanoine, 2005^158^ | 12 (0) | SBP, mm Hg | 114 (12) | 114 (12) | 1.1 (NR) | 347 | 1.3 (NR) | 180 | −0.2 (NR) | 0.84
Chanoine, 2005^158^ | 12 (0) | DBP, mm Hg | 68 (10) | 67 (10) | −0.5 (NR) | 347 | 1.3 (NR) | 180 | −1.8 (NR) | 0.04
Chanoine, 2005^158^ | 12 (0) | LDL-C, mg/dL | 97 (28) | 97 (27) | −1 (NR) | 322 | 0.9 (NR) | 162 | −1.9 (NR) | 0.29
Maahs, 2006^159^ | 6 (0) | LDL-C, mg/dL | 87.1 (34.9) | 89.6 (20.6) | 1.4 (31.6) | 16 | −4 (25.7) | 18 | 5.4 (−13.9 to 24.7) | 0.13
Chanoine, 2005^158^ | 12 (0) | HDL-C, mg/dL | 42 (10) | 42 (8) | 0.1 (NR) | 323 | −0.3 (NR) | 163 | 0.4 (NR) | 0.62
Maahs, 2006^159^ | 6 (0) | HDL-C, mg/dL | 42.2 (8.9) | 40 (7.6) | −0.2 (8.7) | 16 | 0.9 (8.6) | 18 | −1.1 (−6.9 to 4.7) | 0.47
Chanoine, 2005^158^ | 12 (0) | TC, mg/dL | 161 (32) | 163 (33) | 2.3 (NR) | 323 | 3.4 (NR) | 163 | −1.1 (NR) | 0.59
Maahs, 2006^159^ | 6 (0) | TC, mg/dL | 155.8 (43.8) | 159.3 (29.1) | −1.1 (39.7) | 16 | −3 (35.4) | 18 | 1.9 (−23.4 to 27.2) | 0.49
Chanoine, 2005^158^ | 12 (0) | FPG, mg/dL | 90 (11) | 92 (12) | −2.4 (NR) | 282 | −5.2 (NR) | 136 | 2.8 (NR) | 0.06
Maahs, 2006^159^ | 6 (0) | FPG, mg/dL | 87 (8.5) | 87.4 (8.9) | 2.8 (7.8) | 16 | 4.8 (8.2) | 18 | −2 (−7.4 to 3.4) | 0.12

Abbreviations: BL = Baseline; CG = Control group; CI = Confidence Interval; DBP = Diastolic blood pressure; FPG = Fasting plasma glucose; HDL-C = High-density lipoprotein cholesterol; IG = Intervention group; LDL-C = low-density lipoprotein cholesterol; Mg/dL = Milligrams per deciliter; mmHg = Milligrams mercury; NR = Not reported; SBP = Systolic blood pressure; SD = Standard deviation; TC = Total cholesterol; Tx = Treatment.

Table 18 Blood Pressure, Lipids, and Insulin Outcomes for Phentermine/Topiramate at End of Treatment (13 Months Post-Baseline)^161^

Dose | Outcome | IG BL mean (SD) | CG BL mean (SD) | IG FU change mean (SD) | IG N | CG FU change mean (SD) | CG N | Between-group difference in mean change (95% CI) | Study-reported p-value
IG1: PHEN (15 mg)/TOP (92 mg) | SBP, mm Hg | 117.4 (10.2) | 117.7 (10.4) | 1 (11.1) | 113 | 2.8 (12.1) | 56 | −1.80 (−5.58 to 1.97) | NR
IG2: PHEN (7.5 mg)/TOP (46 mg) | SBP, mm Hg | 121.4 (9.2) | 117.7 (10.4) | −1 (11) | 54 | 2.8 (12.1) | 56 | −3.76 (−8.09 to 0.56) | NR
IG1: PHEN (15 mg)/TOP (92 mg) | DBP, mm Hg | 72.9 (7.3) | 71.7 (8.3) | 0.1 (9) | 113 | 3.1 (10) | 56 | −2.97 (−6.07 to 0.12) | NR
IG2: PHEN (7.5 mg)/TOP (46 mg) | DBP, mm Hg | 75.8 (6.7) | 71.7 (8.3) | −0.9 (9) | 54 | 3.1 (10) | 56 | −3.99 (−7.53 to −0.45) | NR
IG1: PHEN (15 mg)/TOP (92 mg) | HDL-C, % change | -- | -- | 5.1 (18.7) | 113 | −3.7 (21.3) | 56 | 8.75 (2.15 to 15.35) | NR
IG2: PHEN (7.5 mg)/TOP (46 mg) | HDL-C, % change | -- | -- | 6.7 (18.0) | 54 | −3.7 (21.3) | 56 | 10.30 (2.91 to 17.7) | NR
IG1: PHEN (15 mg)/TOP (92 mg) | Insulin, mg/dL | 2.7 (2.1) | 2.5 (1.7) | 1.9 (4) | 113 | 1.1 (4.6) | 56 | 0.80 (−0.64 to 2.24) | NR
IG2: PHEN (7.5 mg)/TOP (46 mg) | Insulin, mg/dL | 3 (2.5) | 2.5 (1.7) | 1.2 (4) | 54 | 1.1 (4.6) | 56 | 0.19 (−1.45 to 1.82) | NR

Abbreviations: BL = Baseline; CG = Control group; CI = Confidence Interval; DBP = Diastolic blood pressure; FPG = Fasting plasma glucose; FU = Followup; HDL-C = High-density lipoprotein cholesterol; IG = Intervention group Mg/dL = Milligrams per deciliter; mmHg = Milligrams mercury; NR = Not reported; SBP = Systolic blood pressure; SD = Standard deviation.

### Detailed Results by Outcome

#### Behavioral Interventions

All 50 behavioral intervention trials reported a weight outcome, as specified in our inclusion criteria (N=8,798). Sixteen studies also reported blood pressure, one or more lipid measures, an insulin-related measure, or a measure of physical fitness (N=1,700).^110,^ ^114–120,^ ^127,^ ^131,^ ^133,^ ^135,^ ^136,^ ^150,^ ^151,^ ^154^ Detailed results for intermediate outcomes are shown in Appendix D Tables 7 and 8.

##### Weight

BMI was the primary outcome for this review, reported by 30 studies. Young people participating in behavioral interventions demonstrated a 0.7 kg/m^2^ greater reduction (or smaller increase) in BMI than those in control groups after 6 to 12 months (MD, −0.7 [95% CI, −1.0 to −0.3]; 28 RCTs [n=4,494]; I^2^=86.8%, Figure 6, Table 11). The effect was larger in trials with 26 or more hours of estimated contact (MD, −1.4 [95% CI, −2.2 to −0.6]; 11 RCTs [n=1,087]; I^2^=87.8%) than in trials with fewer than 26 hours of contact (MD, −0.3 [95% CI, −0.5 to −0.1]; 17 RCTs [n=3,407]; I^2^=62.1%; p=0.004 for difference between contact time levels). Meta-analysis results of other measures of weight generally showed similar patterns of results (Table 11, Appendix E Figures 4 and 5). The change in weight was 2.1 kg greater weight loss (or less weight gain) in the intervention groups than in the control groups (MD, −2.1 [95% CI, −3.0 to −1.2]; 18 RCTs [N=1,625]), but the effect on weight change did not differ between higher and lower contact interventions. While zBMI is not recommended as a measure of change,^100^ it is included in the table because it was the most widely reported outcome and was the primary outcome in the previous USPSTF report.^94^ Forest plots showing BMI and zBMI by four levels of estimated contact time are included in the Appendix, for comparison with findings of the previous review (Appendix E Figures 6 and 7).

Stratified analyses and meta-regression indicated that, in addition to contact time, a higher number of sessions (p<0.001) and the inclusion of physical activity sessions (p<0.001) during the intervention sessions were both associated with larger reductions in BMI (Figure 7, Appendix D Table 9). All of these measures are highly correlated, making it impossible to determine with certainty which features are driving the association. However, exploratory analyses suggested that the presence of physical activity sessions may have the strongest predictive utility. First, physical activity sessions were the only statistically significant predictor in a meta-regression that included both contact hours and an indicator for the presence of physical activity sessions. Second, a separate analysis found no association between effect size and contact hours among interventions that did not include physical activity sessions. On the other hand, the small number of calories burned during in-session activities seems unlikely to have a direct impact on weight.

Figure 7 Stratified Analyses of Body Mass Index (kg/m^2^) in Behavioral Interventions Compared With Controls

Abbreviations: BMI = Body mass index; CI = Confidence interval; Diff = Difference; Hrs = Hours; K = Number of studies; Kg/m^2 = Kilograms per meters squared; MnChg = Mean change; N = Number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SES = socioeconomic status.

Figure 7 is a stratified analyses of body mass index (kg/m2) in behavioral interventions compared with controls

Effect modification was not detected by any of the other characteristics we examined, including:

- Age category (preschool, elementary, adolescent, wide range)
- Months to followup
- Whether weight was measured immediately post-treatment versus delayed by 1 month or more
- Months’ gap between treatment completion and followup assessment
- Study quality rating (good vs. fair)
- Publication year
- Whether the study was conducted in the United States
- Whether the study was implemented in a primary care setting
- Whether the study was limited to young people with a BMI at or above the 95th percentile for age and sex (or similar criteria)
- Whether the study was limited to young people with a higher BMI but below the 95th percentile for age and sex (or similar criteria)
- Whether at least 50 percent of the study sample were comprised of Black or Hispanic/Latino young people

None of the alternative interventions with little to no counseling to change diet and physical activity levels showed an impact on weight. These included two trials examining interpersonal therapy as the treatment modality,^143,^ ^144^ specially calibrated plates and bowls for portion control,^115^ and a regulation of cues intervention.^106^

Seven studies reported subgroup analyses examining whether effect sizes for weight outcomes differed by socioeconomic indicators,^107,^ ^112,^ ^145^ gender,^112,^ ^114,^ ^127,^ ^136,^ ^145^ age,^107,^ ^145^ baseline BMI category,^123^ and race and ethnicity^145^ (Appendix D Table 7). Although none of them directly tested the interaction term, several found statistically significant effects in some subgroups but not their counterparts. All three studies that examined socioeconomic indicators found larger effects among participants with higher socioeconomic status, including those with higher maternal education levels,^107^ families categorized as having high socioeconomic status,^112^ and those with family income of $50,000 or less (published in 2011).^145^ The findings of effect size differences by gender were mixed, with some favoring girls^112,^ ^145^ and some favoring boys.^114,^ ^127,^ ^136^ The one trial that examined race and ethnicity found that effects were smaller among Hispanic/Latino youth than among those who were Black, White, or “Other.”^145^ No other analyses indicated effect modification.

We were unable to draw any conclusions about whether efforts to address social determinants of health improved the likelihood of improved weight outcomes. The approaches to addressing social determinants were highly heterogenous and interventions to address social determinants were confounded by effects of intervention dose. Ten trials (all behavioral intervention trials) reported an effort to mitigate one or more barriers to participation or social risk factors, such as difficulty with transportation, language barriers, help with accessing social services to address housing, financial strain, or food insecurity (Table 19).^111,^ ^123,^ ^125,^ ^132,^ ^133,^ ^136,^ ^138–140,^ ^147^ Four of these trials included a majority of participants who were Black, Hispanic/Latino, South Asian, or Native American.^123,^ ^133,^ ^136,^ ^138^

Table 19 Weight Outcomes for Studies That Address Potential Barriers to Participation or Mitigate Social Risk Factors, Sorted by Estimated Intervention Contact Hours

Estimated Intervention Contact Hrs | Study; Country | Key intervention components | Est hrs contact (Sessions) | Group Analyzed | Followup (months since tx ended) | Outcome | Between-group difference in mean change (95% CI) | Study-reported p-value
<26 | Love-Osborne, 2014^123^; US | Health Educator linked patients to existing resources for healthy eating and PA; facilitated applications for free parks and recreation memberships. | NR (5) | BL BMI 85%–95% | 8 (0) | zBMI, z-score | 0.14 (NR) | 0.65
<26 | Love-Osborne, 2014^123^; US | Health Educator linked patients to existing resources for healthy eating and PA; facilitated applications for free parks and recreation memberships. | NR (5) | BL BMI 95%–99% | 8 (0) | zBMI, z-score | 0.09 (NR) | 0.81
<26 | Love-Osborne, 2014^123^; US | Health Educator linked patients to existing resources for healthy eating and PA; facilitated applications for free parks and recreation memberships. | NR (5) | BL BMI >99% | 8 (0) | zBMI, z-score | 0 (NR) | 0.36
<26 | Mellin, 1987^125^; US | Content integrated ethnic, cultural, and economic differences and used examples of a broad range of family types. | 24 (16) | All | 6 (3) | Weight, kg | −0.35 (NR) | NSD
<26 | Resnicow, 2015^132^; US | Added RD sessions offered either in person or by telephone. | NR (10) | All | 24 (0) | BMI percentile | −3.1 (−6.32 to 0.12) | 0.02
≥26 | DeBar, 2012^111^; US | Offered option for telephone sessions in lieu of in-person sessions. | 36.5 (18) | All | 6 (1) | Weight, kg | −1.46 (−5.94 to 3.03) | 0.015
≥26 | Sacher, 2010^133^; UK | Free access to community swimming pool for 12 weeks. | 36 (18) | All | 6 (3.75) | BMI, kg/m^2^ | −1.2 (−1.8 to −0.6) | <0.001
≥26 | Savoye, 2014^136^; US | One of the two groups had Spanish bilingual instructors. | 78 (52) | All | 6 (0) | BMI, kg/m^2^ | −1.05 (−1.78 to −0.32) | 0.005
≥26 | Savoye, 2014^136^; US | One of the two groups had Spanish bilingual instructors. | 78 (52) | All | 6 (0) | Weight, kg | −3.1 (−5.3 to −0.9) | 0.006
≥26 | Smith, 2021^138^; US | Provided families with referrals to existing resources in collaboration with partner agencies (employment, food and housing insecurity, insurance coverage) | 53.79 (3) | All | 6 (0) | BMI, kg/m^2^ | 0.63 (−0.74 to 2) | 0.242
≥26 | Smith, 2021^138^; US | Provided families with referrals to existing resources in collaboration with partner agencies (employment, food and housing insecurity, insurance coverage) | 53.79 (3) | All | 12 (6) | BMI, kg/m^2^ | −0.26 (−1.66 to 1.14) | 0.833
≥26 | Stark, 2011^139^; US | Parents provided w/vegetables for 14 days’ worth of taste tests at each group session. Included in-home sessions; interventionist assisted family in setting up a safe place in the home for active play. | 38.25 (18) | All | 6 (0) | Weight, kg | −2.7 (−4.4 to −1) | 0.004
≥26 | Stark, 2011^139^; US | | 38.25 (18) | All | 12 (6) | Weight, kg | −4.3 (−7 to −1.5) | 0.005
≥26 | Stark, 2014^140^; US | Parents provided w/vegetables for 14 days’ worth of taste tests at each group session. Included in-home sessions; interventionist assisted family in setting up a safe place in the home for active play. | 30 (10) | All | 6 (0) | Weight, kg | −0.7 (−2.2 to 0.9) | 0.37
≥26 | Stark, 2014^140^; US | | 30 (10) | All | 12 (6) | Weight, kg | −3 (−5.5 to −0.4) | 0.03
≥26 | Stark, 2018^141^; US | Included in-home sessions; interventionist assisted family in setting up a safe place in the home for active play. | 38 (18) | All | 6 (0) | Weight, kg | −1.36 (−2.09 to −0.63) | <0.001
≥26 | Stark, 2018^141^; US | Included in-home sessions; interventionist assisted family in setting up a safe place in the home for active play. | 38 (18) | All | 12 (6) | Weight, kg | −1.1 (−2.08 to −0.12) | 0.02

Abbreviations: BL = Baseline; BMI = Body mass index; CI = Confidence interval; Est = Estimated Hrs = Hours; Kg = kilogram; NR = Not reported; NSD = No significant difference; PA = Physical activity; RD= Registered Dietician; Tx = Treatment; US = United States.

The efforts to address social determinants of health ranged from relatively minor accommodations such as flexibility with location or in-person versus telephone sessions,^111,^ ^132^ to providing free food samples or access to exercise facilities,^123,^ ^133,^ ^139,^ ^140^ bilingual instructors,^136^ or providing referrals to partner agencies to help address employment, food and housing insecurity, and insurance coverage.^138^ One trial did not provide material help, but described efforts to make the intervention materials inclusive and relevant to a wide range of families by integrating ethnic, cultural, and economic differences into the intervention content, including using a broad range of family types in the materials and examples.^125^ The pattern of effects in this subset of studies was similar to the overall findings: trials testing higher-contact interventions were likely to find greater relative reductions in weight-related outcomes, while lower-contact interventions were not. One trial that countered this pattern was a higher-contact trial that showed no group differences in weight, despite the fact that the intervention addressed social needs by providing families in need with referral to existing resources for help with employment, food and housing insecurity, and insurance coverage.^138^ Despite this trial’s results, we were not able to discern any pattern of effect modification with the integration of intervention components to address barriers to participation or social risk factors, and a meta-regression testing for effect modification was not statistically significant (p=0.61).

Data on the long-term effects of behavioral weight management interventions were extremely limited. Only 10 of the 50 trials reported results beyond 12 months after the baseline assessment (Appendix D Table 7).^107,^ ^117,^ ^118,^ ^124,^ ^132,^ ^137,^ ^141,^ ^145,^ ^148,^ ^149^ Only two trials found greater improvements in any weight outcome beyond 12 months, and both of these tested 24-month interventions and measured outcomes immediately after the intervention was completed.^132,^ ^148^ One of these two trials reported a 3.1-point greater reduction in BMI percentile (MD, −3.1 [95% CI, −6.3 to 0.1]; study-reported p=0.02). The other found larger reductions for both BMI (MD, −0.3 kg/m^2^ [95% CI, −0.6 to −0.0]) and waist circumference (MD, −1.5 cm [95% CI, −2.5 to −0.5]) after 24 months.^148^ Evidence was similarly very limited on how the trajectory of BMI over time is affected by weight management interventions, among studies providing multiple followup assessments. Figure 8 shows all studies reporting more than one post-baseline followup and illustrates both how limited the evidence is on longer-term trajectories and how group differences tend to attenuate over time among trials with group differences at any timepoint.

Figure 8 Mean Body Mass Index (kg/m^2^) Over Time Among Trials With Three Assessments

Abbreviations: BMI = Body mass index; CG= Control group; Est. = Estimated; IG = Intervention group; Kg/m^2^ = Kilograms per meters squared; Mo = Months.

Note: Gray sections of the graphs show followup after treatment ended. There were no group differences (p<0.05) beyond 12 months.

Figure 8 shows the mean body mass index (kg/m2) over time among trials with three followup assessments

Smaller subsets of trials reported waist circumference or percent body fat, which are more direct measures of adiposity. Similar to the other weight outcomes, these outcomes also showed larger effects in trials with higher contact hours, most of which included physical activity sessions (Table 11, Appendix E Figures 8 and 9). For both waist circumference and percent body fat, effects were statistically significant among trials offering 26 or more hours of contact and not significant among lower-contact trials. These results are limited by the small number of trials reporting these outcomes.

##### Blood Pressure

Thirteen studies reported either systolic blood pressure (SBP) or diastolic blood pressure (DBP).^114–118,^ ^127,^ ^131,^ ^133,^ ^135,^ ^136,^ ^150,^ ^151,^ ^154^ Only four studies found greater improvement in either SBP or DBP at any time point;^117,^ ^131,^ ^136,^ ^154^ all of these included more than 26 hours of contact, and three included physical activity sessions.^131,^ ^136,^ ^154^

Pooled analyses showed that weight management interventions were associated with improvements in DBP and that only higher-contact trials were associated with improvements in SBP after 6 to 12 months (SBP, ≥26 hours: MD, −3.6 mm Hg [95% CI, −5.7 to −1.5]; 8 RCTs [n=773]; I^2^=47.3%; DBP, all studies: MD, −2.2 mm Hg [95% CI, −3.8 to −0.7]; 12 RCTs [n=1,190]; I^2^=35.2%, Appendix E Figures 10 and 11, Table 12). All but one of the higher-contact trials included in the meta-analyses utilized physical activity sessions during the intervention sessions. No trials reported the percent of participants meeting criteria for hypertension. These results are limited by the small number of trials reporting these outcomes.

##### Lipid Levels

Fourteen studies reported either total cholesterol, HDL cholesterol, LDL cholesterol, or triglyceride levels.^110,^ ^114–116,^ ^118–120,^ ^123,^ ^127,^ ^135,^ ^136,^ ^150,^ ^151,^ ^154^ Only three studies reported any positive findings for any lipid outcome at any followup time point, finding larger improvements in total cholesterol,^135^ triglycerides,^136^ and LDL cholesterol levels only among female participants.^127^ All of these trials offered more than 26 hours of contact, two of them offered physical activity sessions, and none found group differences in other lipid levels.

None of the overall pooled analyses showed greater improvement in lipid outcomes for participants in weight management interventions than for those in control conditions after 6 to 12 months (Appendix E Figures 12–15, Table 12). For example, the overall effect for LDL cholesterol showed no group differences in change (MD, −3.2 mg/dL [95% CI, −9.0 to 2.6]; 7 RCTs [n=648]; I^2^=56.9%), and effect sizes were very similar for higher- and lower-contact trials (≥26 hours: MD, −2.4 mg/dL [95% CI, −9.7 to 4.8]; 3 RCTs [n=301]; I^2^=0%; <26 hours: MD, −3.9 mg/dL [95% CI, −17.4 to 9.5]; 4 RCTs [n=347]; I^2^=74.6%, Appendix E Figure 12). The only lipid outcome that showed improvement in any pooled analysis was triglycerides, which only showed improvement among participants of higher-contact trials (Table 12). One additional trial reported on the percent of participants meeting criteria for dyslipidemia at the end of an 8-month intervention, finding no difference between groups (1.2% of participants in each group met criteria).^123^ Lipid results are limited by the small number of trials reporting these outcomes.

##### Glucose Metabolism

Twelve studies reported an outcome related to glucose metabolism after 6 to 12 months.^110,^ ^114–116,^ ^118–120,^ ^123,^ ^127,^ ^135,^ ^136,^ ^150,^ ^151^ Four trials found group differences in improvement in outcomes related to glucose metabolism at any time point, including fasting plasma glucose^119,^ ^136^ or insulin levels.^135,^ ^136,^ ^151^ Diabetes incidence was reported in only two studies but there were too few cases to draw conclusions (two cases combined in both studies).^123,^ ^136^ In the pooled analysis, higher (but not lower) contact interventions were associated with a small decline in fasting plasma glucose level (≥26 hours: MD, −1.9 mg/dL [95% CI, −2.7 to −1.2]; 4 RCTs [n=367]; I^2^=0%; <26 hours: MD, 1.0 mg/dL [95% CI, −1.4 to 3.4]; 5 RCTs [n=383]; I^2^=5.0%; p=0.016 for difference between groups, Figure 9). All four interventions with 26 or more hours of contact also included physical activity sessions. These results are limited by the small number of trials reporting these outcomes.

Figure 9 Pooled Analysis of Change in Fasting Plasma Glucose (mg/dL) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; Mg/dL = Milligrams per deciliter; MnChg = Mean change; Mos = Months; n = Number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment.

Figure 9 shows a pooled analysis of change in fasting plasma glucose (mg/dL) in behavioral interventions compared with controls, by estimated contact hours

##### Physical Fitness

One study found that children participating in a multidisciplinary weight management intervention that included physical activity sessions maintained physical fitness after 12 months of participation in the intervention while fitness (measured by peak value of oxygen uptake, standardized for age and gender) declined in those in the control group (MD, 0.7 [95% CI, 0.3 to 1.1]; mean change from baseline, 0.0 [SD, 2.1] in the intervention group and −1.1 [SD, 2.0] in the control group).^151^

#### Glucagon-Like Peptide-1 Agonists

One study each reported intermediate outcomes for semaglutide (n=201)^162^ and liraglutide (n=251).^156^

##### Weight

After 13 months of daily injections of 3.0 mg of liraglutide, BMI was reduced by 1.6 kg/m^2^ more than for those taking placebo (MD, −1.6 [95% CI, −2.5 to −0.7], Table 13, Appendix D Table 10). This effect was no longer statistically significant 6 months later, in the absence of treatment (MD, −1.0 [95% CI, −2.0 to 0.01]). This amounted to a 4.5 kg greater reduction in weight than the placebo group after 13 months (MD, −4.5 [95% CI, −7.2 to −1.8]) and a statistically nonsignificant reduction of 2.7 more kilograms 6 months later (MD, −2.7 [95% CI, −5.6 to 0.2]). At the 13-month followup, participants taking liraglutide were more likely to have lost 5 percent of their baseline BMI (RR, 3.5 [95% CI, 1.8 to 6.2]) and 10 percent of their baseline BMI (RR, 4.4 [95% CI, 1.8 to 8.8]). Percent of BMI loss was not reported at the 19-month followup, 6 months after treatment had ended.

After 16 months of weekly injections of 2.4 mg of semaglutide, there was a 16.7 percentage point greater reduction in baseline BMI compared to those receiving placebo injections (MD, −16.7 [95% CI, −20.3 to −13.2], Table 13, Appendix D Table 10).^162^ Participants taking semaglutide lost a mean 15.3 kg compared to a mean 2.4 kg increase with placebo injections (MD, −17.7 [95% CI, −21.8 to −13.7]). In the 1 month after semaglutide was discontinued, those who had been taking semaglutide regained 3.1 percent of their original weight. After 16 months of treatment, those taking semaglutide showed a marked increased likelihood of 5 percent and 10 percent weight loss (5%: RR, 12.2 [95% CI, 6.3 to 31.0]; 10%: RR, 18.5 [95% CI, 8.3 to 63.7]). And, 25.4 percent of participants had a BMI below 25 kg/m^2^ after 16 months, compared with 1.7 percent receiving placebo injections (RR, 19.4 [95% CI, 2.6 to 146.5]). In this study, change in body weight did not differ by sex, age, or baseline body weight.

##### Blood Pressure

There were no group differences in either SBP or DBP for either medication at the end of the treatment period, with differences of 2.0 mm Hg or less in all cases (Table 16, Appendix D Table 11).

##### Lipid Levels

Liraglutide was associated with 1.0 mg/dL greater increases in all lipid measures after 13 months (e.g., LDL cholesterol MD, 1.0 [95% CI, 0.9 to 1.0]; HDL cholesterol MD, 1.0 [95% CI, 1.0 to 1.1], Table 16, Appendix D Table 11). Semaglutide was associated with greater percent reductions in LDL cholesterol, total cholesterol, and triglycerides from baseline levels (e.g., LDL cholesterol MD, −7.0% [95% CI, −11.9 to −1.8]) and a statistically nonsignificant increase in HDL cholesterol (MD, 4.7% [95% CI, −1 to 10.7]).

##### Glucose Metabolism

Liraglutide was not associated with a greater improvement in fasting plasma glucose (MD, −1.8 [95% CI, −4.1 to 0.5]) or HbA1c (MD, - 0.16 [95% CI, −0.1 to 0.0]) after 13 months (Table 16, Appendix D Table 11). Semaglutide also found no differences between groups in HbA1c (MD, −0.3 [95 % CI, NR]).

#### Orlistat

##### Weight Outcomes

In the larger study of orlistat (n= 539),^158^ BMI of participants treated with orlistat had decreased from baseline by 0.6 kg/m^2^ and increased by 0.3 kg/m^2^ in the placebo group after 12 months (p=0.001, Table 14, Appendix D Table 12). The difference in BMI change was slightly smaller and not statistically significant in the smaller study (n=40) after 6 months (MD, −0.5 kg/m^2^ [95% CI, −7.9 to 6.9]).^159^ After 12 months, participants taking orlistat in the larger study were more likely to have lost at least 5 percent of their baseline BMI (RR, 1.9 [95% CI, 1.2 to 3.0]) and at least 10 percent of their baseline BMI (RR, 3.2 [95 % CI, 1.5 to 7.0]).^158^

##### Blood Pressure

Blood pressure was only reported by the larger study, which found a small reduction in DBP with orlistat compared to placebo after 12 months, but no group differences in SBP (SBP: MD, −0.2 [95% CI NR], p=0.84; DBP: MD, −1.8 [95% CI NR], p=0.04, Table 17, Appendix D Table 13).

##### Lipid Levels

Neither study of orlistat found group differences in change in any lipid measures (Table 17, Appendix D Table 13).

##### Glucose Metabolism

Neither study of orlistat found group differences in change in any glucose-related measures (Table 17, Appendix D Table 13).

#### Phentermine/Topiramate

One study reported intermediate outcomes for phentermine/topiramate (n=227).^161^

##### Weight

After 13 months of treatment, participants taking the higher dose (15/92 mg) had reduced their BMI by 5.4 kg/m^2^ more than those taking placebo (MD, −5.4 [95% CI, −6.4 to −4.3]) and those taking the lower dose (7.5/46 mg) had reduced their BMI by 3.7 kg/m^2^ more than those taking placebo (MD, −3.7 [95% CI, −5.0 to −2.5], Table 15). This amounted to a 15.8 kg greater reduction in weight than the placebo group after 13 months in the higher-dose group (MD, −15.8 [95% CI, −18.8 to −12.8]) and a 12.1 kg reduction in the lower-dose group (MD, −12.1 [95% CI, −15.6 to 8.6]). At the 13-month followup, participants taking either dose of phentermine/topiramate were more likely to have lost 5 percent of their baseline BMI (RR, higher dose: 5.6 [95% CI, 2.2 to 14.4]; lower dose: 4.6 [95% CI, 1.7 to 21.7]) and 10 percent of their baseline BMI (RR, higher dose: 12.2 [95% CI, 3.1 to 48.3]; lower dose: 9.3 [95% CI, 2.3 to 38.0]).

##### Blood Pressure

There were no group differences for SBP after 13 months of treatment in either group; however, the lower dose group (but not the higher dose group) did show a statistically significant reduction in DBP (MD, −4.0 mm Hg [95% CI, −7.5 to −0.4], Table 18).

##### Lipid Levels

The phentermine/topiramate study reported only percent change in HDL cholesterol (Table 18).

##### Glucose Metabolism

Phentermine/topiramate was not associated with a greater improvement in insulin level (e.g., MD with the higher dose, 0.8 [95% CI, −0.6 to 2.2]) after 13 months (Table 18).

## KQ3 Do Primary Care–Relevant Behavioral, Pharmacotherapy, or Combined Weight Management Interventions for Children and Adolescents With Higher BMI Improve Behavioral Outcomes?

### Summary of Results

Twenty-three of the 50 behavioral intervention trials reported an eligible behavioral outcome (n=3,459).^107,^ ^111,^ ^113,^ ^114,^ ^119,^ ^122,^ ^124,^ ^126,^ ^128–131,^ ^133,^ ^134,^ ^137–141,^ ^145,^ ^148,^ ^152,^ ^153^ Although some individual trial findings were statistically significant, most evidence and the meta-analyses indicated no effect on minutes per day of physical activity or sedentary behavior (physical activity: MD, 5.2 [95% CI, −2.0 to 12.4]; 10 RCTs [n=1,533]; I^2^=85.5%, Figure 10, Table 20; sedentary behavior: MD, −13.3 [95% CI, −26.9 to 0.4]; 11 RCTs [n=1,366]; I^2^=41.4%, Figure 11, Table 20). Only five trials reported overall dietary pattern scores and findings were mixed (Figure 12). None of the pharmacotherapy studies reported relevant behavioral outcomes.

Figure 10 Pooled Analysis of Change in Physical Activity (minutes/day) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hr = Hour; Hrs = Hours; IG = Intervention group; MnChg = Mean change; Mos = Months; n = Number of participants; NR = Not reported; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment.

Figure 10 shows a pooled analysis of change in physical activity (minutes/day) in behavioral interventions compared with controls, by estimated contact hours

Table 20 Meta-Analysis Results for Minutes per Day of Physical Activity and Sedentary Behavior for Behavioral interventions

Outcome | All Studies in MA | | | <26 Contact hrs | | | ≥26 Contact hrs | | | P-value
| K (N) | I^2^, % | Mean Diff in Change (95% CI) | K (N) | I^2^, % | Mean Diff in Change (95% CI) | K (N) | I^2^, % | Mean Diff in Change (95% CI) | (diff b/t dose levels)
PA, Min/day | 10 (1533) | 85.5 | 5.2 (−2.0 to 12.4) | 4 (714) | 0 | 3.4 (−3.3 to 10.1) | 6 (819) | 88.6 | 7.8 (−4.7 to 20.2) | 0.007
Sedentary Min/day | 11 (1366) | 41.4 | −13.3 (−26.9 to 0.4) | 5 (610) | 0.0 | −23.9 (−34.4 to −13.3) | 6 (756) | 45.2 | −4.7 (−27.0 to 17.8) | 0.702

Abbreviations: B/t = Between; CI = Confidence Interval; Diff = Difference; Hrs = Hours; K = Number of studies; MA = Meta-analysis; Min = Minutes; PA = Physical activity.

Figure 11 Pooled Analysis of Change in Sedentary Behavior (minutes/day) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; MnChg = Mean change; Mos = Months; n = Number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment.

Figure 11 shows a pooled analysis of change in sedentary behavior (minutes/day) in behavioral interventions compared with controls, by estimated contact hours

Figure 12 Change in Dietary Outcomes in Behavioral Interventions Compared With Controls

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; HEI = Healthy Eating Index; Hrs = Hours; IG = Intervention group; MnChg = Mean change; Mos = Months; n = Number of participants; NHANES DSQ = National Health and Nutrition Examination Survey Dietary Screener Questionnaire; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Tx = Treatment.

Figure 12 examines the change in dietary outcomes in behavioral interventions compared with controls

### Detailed Results by Outcome

#### Behavioral Interventions

Twenty-three behavioral intervention trials reported an eligible behavioral outcome (n=3,459).^107,^ ^111,^ ^113,^ ^114,^ ^119,^ ^122,^ ^124,^ ^126,^ ^128–131,^ ^133,^ ^134,^ ^137–141,^ ^145,^ ^148,^ ^152,^ ^153^ Detailed results for all behavioral outcomes are shown in Appendix D Table 14. Thirteen of these trials were conducted in the United States.^111,^ ^119,^ ^122,^ ^128–130,^ ^134,^ ^137–141,^ ^145^ Four included a majority of participants who were Hispanic/Latino,^119,^ ^128,^ ^129,^ ^138^ and most or all participating families had low income levels in two of these trials, based on Medicaid or Children’s Health Insurance Program enrollment.^128,^ ^138^

##### Physical Activity

Seventeen trials reported a measure of moderate, moderate-to-vigorous, or overall physical activity (including MET unit measures).^111,^ ^113,^ ^114,^ ^119,^ ^122,^ ^128–130,^ ^133,^ ^137,^ ^139–141,^ ^145,^ ^148,^ ^152,^ ^153^ Physical activity was most commonly measured by accelerometer, but some trials used 24-hour or 7-day self-reported recall measures. Only one trial reported a statistically significant increase in physical activity at followup compared to the control group.^133^ Ten trials reported a measure of minutes per day (or one that could be converted to minutes/day) and provided sufficient data to be included in the meta-analysis. Change in minutes per day of physical activity did not differ between participants in weight management interventions and those in control conditions (MD, 5.2 [95% CI, −2.0 to 12.4]; 10 RCTs [n=1,533]; I^2^=85.5%, Figure 10, Table 20). Effects were statistically nonsignificant for both higher- and lower-contact interventions.

##### Sedentary Behavior

Eighteen trials reported a measure of sedentary behavior, screen time, or computer time, typically measured by self-report.^107,^ ^111,^ ^113,^ ^114,^ ^119,^ ^122,^ ^124,^ ^126,^ ^128–131,^ ^133,^ ^134,^ ^137,^ ^145,^ ^148,^ ^153^ Five trials found a greater improvement in the intervention participants than in the control participants at some time point, but in all cases, multiple time points, intervention groups, or specific outcomes were reported and differences were statistically significant for only one group, time point, or outcome.^119,^ ^128,^ ^129,^ ^133,^ ^145^ Eleven trials reported a measure of minutes per day (or one that could be converted to minutes/day) and provided sufficient data to include in the meta-analysis. Change in minutes per day of sedentary activity did not differ between participants in weight management interventions and those in control conditions (MD, −13.3 [95% CI, −26.9 to 0.4]; 11 RCTs [n=1,366]; I^2^=41.4%, Figure 11, Table 20). Effects were statistically nonsignificant for both higher- and lower-contact interventions.

##### Dietary Pattern

Only five trials reported an overall dietary pattern outcome (N=820).^124,^ ^138,^ ^141,^ ^152,^ ^153^ All available data are shown in Figure 12. Three of the trials reported an improvement in dietary pattern,^124,^ ^138,^ ^141^ one only for the higher-contact intervention arm.^141^ One of these trials reported a 2.1 (95% CI, 1.3 to 2.9) greater increase in dietary pattern score, measured on a 28-point scale, 6 months after treatment had ended, and a slightly smaller but still statistically significant effect 6 months later.^124^ The other trial found an 8.7-point difference (95% CI, 3.8 to 13.6), measured on a 100-point scale, for their higher-contact group, but no improvement over the control group for the lower-contact group (estimated contact hours were 38 and 7.5, respectively). In the third study, there was a decline in the control group’s mean dietary pattern score but no change for the intervention group (MD, 0.2 [95% CI, −0.06 to 0.4]; study-reported p=0.008).^138^

#### Pharmacotherapy

None of the included studies reported eligible behavioral outcomes.

## KQ4 Are There Harms Associated With Weight Management Interventions for Children and Adolescents?

### Summary of Results

None of the 18 trials (N=2,539) reporting potential harms of behavioral weight management interventions found an increase in the risk of any adverse event or serious adverse events, or decreases in self-esteem, body satisfaction, or disordered eating after 6 to 12 months (Table 21). Two trials of interpersonal therapy with limited counseling to change diet and physical activity found reductions in disordered eating,^143,^ ^144^ suggesting a benefit rather than a harm of behavioral interventions. No information was available on the risk of harm beyond 12 months.

Table 21 Adverse Events for Pharmacotherapy Trials, Sorted by Type of Medication

Medication | Author, Year | Serious Adverse Events, n/N (%) | | Any Adverse Events, n/N (%) | | Dropout due to Adverse Events, n/N (%) | | Most common non-serious AEs
- | - | Medication | Placebo | Medication | Placebo | Medication | Placebo | -
Liraglutide (3 mg/day) | Danne, 2017^155^ | 0/14 (0) | 0/7 (0) | 14/14 (100) | 4/7 (57) | 0/14 (0) | 0/7 (0) | GI, nervous system, infections or infestations, administration site irritation
Liraglutide (3 mg/day) | Kelly, 2020^156^ | 3/125 (2) | 5/126 (4) | 111/125 (89) | 107/126 (85) | 13/125 (10) | 0/126 (0) | GI, hypoglycemic episodes
Liraglutide (3 mg/day) | Mastrandrea, 2019^157^ | 0/16 (0) | 0/8 (0) | 9/16 (56) | 5/8 (62) | 0/16 (0) | 0/8 (0) | GI, hypoglycemic episodes
Semaglutide (2.4 mg/week) | Weghuber, 2022^162^ | 15/133 (11) | 6/67 (9) | 105/133 (79) | 55/67 (82) | 6/133 (4) | 3/67 (4) | GI
Orlistat (360 mg/day) | Chanoine, 2005^158^ | 11/352 (3) | 5/181 (3) | 341/352 (97) | 170/181 (94) | 12/352 (3) | 3/181 (2) | Abdominal pain, flatus with discharge, fecal urgency, fecal incontinence
Orlistat (360 mg/day) | Maahs, 2006^159^ | NR | NR | NR | NR | 2/20 (10) | 0/20 (0) | Flatus with discharge, fecal urgency
Phentermine/Topiramate (15/92 mg/day) | Hsia, 2019^160^ | NR | NR | 10/13 (77) | 7/14 (50) | 2/13 (15) | 0/14 (0) | Nervous system, GI
Phentermine/Topiramate (15/92 mg/day) | Kelly, 2022^161^ | 2/113 (2) | 0/56 (0) | 59/113 (52) | 29/56 (52) | 1/113 (1) | 2/56 (4) | Musculoskeletal, psychiatric
Phentermine/Topiramate (7.5/46 mg/day) | Hsia, 2019^160^ | NR | NR | 6/15 (40) | 7/14 (50) | 0/15 (0) | 0/14 (0) | None
Phentermine/Topiramate (7.5/46 mg/day) | Kelly, 2022^161^ | 0/54 (0) | 0/56 (0) | 20/54 (37) | 29/56 (52) | 0/54 (0) | 2/56 (4) | None

Abbreviations: AEs = Adverse events; GI = Gastrointestinal; Mg = Milligrams; n = Number; N = Total number; NR = Not reported.

Gastrointestinal side effects were common among patients taking GLP agonists and orlistat (Figure 13). Discontinuation due to adverse effects occurred in 10.4 percent in the larger trial of liraglutide compared with none in the group receiving placebo injections.^156^ Discontinuation due to adverse effects was relatively rare with semaglutide, orlistat, and phentermine/topiramate—less than 5 percent in all groups. Serious adverse effects were rare for all medications and did not differ between groups in any study, although five participants taking semaglutide (3.8%) developed gallstones, compared to none taking placebo (calculated RR, 5.8 [95% CI, 0.3 to 106.1]). The most common non-serious adverse events reported with phentermine/topiramate were musculoskeletal and psychiatric, when taken at doses of 15 mg/92 mg. No evidence was available beyond 13 to 17 months of medication administration.

Figure 13 Main Harms Outcomes in Pharmacotherapy Studies (KQ4)

Abbreviations: AE = Adverse event; CG= Control group; GI = gastrointestinal; IG1 = Intervention group one; KQ = Key question; PHEN = Phentermine; TPM = Topiramate

Figure 13 shows the main harms outcomes in pharmacotherapylogic treatment studies (KQ4)

### Detailed Results by Outcome

#### Behavioral Interventions

Eighteen of the behavioral intervention trials reported a potential harm (N=2,539).^109,^ ^111,^ ^112,^ ^115,^ ^116,^ ^124,^ ^129–131,^ ^133,^ ^134,^ ^141,^ ^143,^ ^144,^ ^150,^ ^152,^ ^153^ None of the trials measured potential harms beyond 12 months post-baseline. Detailed results can be found in Appendix D Table 15.

##### Any or Any Serious Adverse Events

Three trials reported that no participants experienced either any adverse events^115,^ ^131^ or any adverse events related to treatment.^133^ One trial each reported an adverse event judged to be probably related to treatment.^133,^ ^141^ In these studies, one person bumped their head during an intervention activity,^141^ and in the other, one person in the control group reduced their BMI by 4.2 kg/m^2^, which the authors viewed as a possible harm.^109^ One other trial reported that no participants in either group were underweight at followup.^112^ Four trials reported no serious adverse events among the study participants.^130,^ ^141,^ ^150^

##### Disordered Eating

Five trials reported an outcome related to disordered eating.^111,^ ^134,^ ^143,^ ^144,^ ^150^ All of these trials were limited to youth age 12 years or older, and three were limited to girls.^111,^ ^143,^ ^144^ Two of these trials (both limited to girls) examined interpersonal therapy, and focused on overeating and loss-of-control eating and their links to interpersonal functioning, rather than the more typical approach of encouraging changes in diet and physical activity.^143,^ ^144^ Both of these trials reported larger improvements with interpersonal therapy compared to a brief health education control. One found a reduction in the percent of girls with any binge eating (odds ratio [OR], 0.14 [95% CI, 0.03 to 0.64]) and fewer binge eating episodes during the year post-baseline among youth in the interpersonal therapy group (the control group had 0.28 [95% CI, 0.03 to 0.53] more episodes than those in the interpersonal therapy group).^144^ The other trial of interpersonal therapy also found a greater reduction in the number of disordered eating episodes with interpersonal therapy (MD in change, −0.32 episodes [95% CI NR]; p=0.04). Another study in adolescent girls found no difference between groups in the percent of participants with disordered eating, with very few events but trending in the direction of benefit (e.g., 2/104 [1.9%] in the intervention group vs. 5/102 [4.9%] in the control group; RR, 0.38 [95% CI, 0.07 to 2.01] after 6 months).^111^ Groups did not differ on continuous measures based on questionnaires assessing eating attitude,^134,^ ^150^ dieting,^150^ loss-of-control eating,^144^ eating restraint,^134^ or eating disinhibition.^134^

##### Self Esteem

Seven trials reported an outcome related to self-esteem.^111,^ ^124,^ ^129,^ ^133,^ ^150,^ ^152,^ ^153^ None found group differences at any time point on any measure. Effect sizes for rating scales ranged from 0 to 1.8-point differences in change between groups, on 30- to 36-point scales.

##### Body Satisfaction

Five trials reported an outcome related to body satisfaction.^111,^ ^116,^ ^124,^ ^152,^ ^153^ One study of adolescent girls found that Body Satisfaction Scores improved by 0.23 points after 12 months (MD, 0.23 [95% CI, 0.02 to 0.44]; range of the scale NR). The remaining studies found no group differences on the 7-point Collins Body Figure Perception scale, with differences in change between groups ranging from −0.3 to 0.2, or no differences on the weight satisfaction subscale of a body esteem scale (MD, 0.0 [95% CI, −0.2 to 0.2]), range of the scale NR).

#### Glucagon-Like Peptide-1 Agonists

One RCT (n=201) of semaglutide^162^ and three RCTs of liraglutide were included for examination of harms.^155–157^ Two of the liraglutide studies were small trials (n=21 and n=24) with only 1 to 2 months in duration, so they did not meet the 6-month minimum followup criteria for health outcomes, weight, and other intermediate outcomes.^155,^ ^157^ The other study evaluating liraglutide included 251 participants.^163^

##### Discontinuation Due to Adverse Effects and Serious Adverse Effects

In the largest trial of liraglutide, 10.4 percent of participants discontinued treatment due to adverse effects, compared with none receiving placebo injections (RR, 30.36 [95% CI, 1.78 to 516.57], Figure 13, Table 21, Appendix D Table 16). The rate of serious adverse effects in the largest trial did not differ between groups (2.4% with liraglutide, 4% with placebo; RR, 0.60 [95% CI, 0.14 to 2.55]) and no serious adverse events occurred in either of the smaller trials. The smaller trials reported that 14.3^155^ percent and 31.3^157^ percent of participants taking liraglutide experienced an adverse event of any level of severity that was probably related to the treatment. For semaglutide, groups showed similar proportions who discontinued the medication due to adverse effects (4% in each group), who had serious adverse effects (11% with semaglutide, 9% with placebo), and who had any adverse effects (79% with semaglutide, 82% with placebo). Although the difference between groups was not statistically significant, five individuals taking semaglutide developed gallstones (3.8%), compared to none taking placebo (calculated RR, 5.8 [95% CI, 0.3 to 106.1]).

##### Side Effects

Gastrointestinal complaints were the most common class of side effects (Appendix D Table 16). For example, in the largest trial, gastrointestinal complaints occurred in 65 percent of those receiving liraglutide and 36 percent of those receiving placebo injections over the course of treatment, and the difference was statistically significant (RR, 3.20 [95% CI, 1.91 to 5.36]). Similarly, 61.7 percent of those receiving semaglutide and 41.8 percent of those receiving placebo injections reported gastrointestinal complaints. No other side effects differed between groups for either medication.

#### Orlistat

The same two RCTs of orlistat included for other KQs also reported harms outcomes; one was substantially larger (n=537)^158^ than the other (n=40).^159^

##### Discontinuation Due to Adverse Effects and Serious Adverse Effects

Both orlistat studies reported discontinuation due to adverse effects. Combined, 14/372 (4.0%) of participants taking orlistat discontinued due to adverse effects, compared with 3/201 (1.5%) taking placebo (Figure 13, Table 21, Appendix D Table 17). In the larger orlistat trial, there were 11 serious adverse events in the orlistat group and five in the placebo group.^158^ In the orlistat group, only one serious adverse event was thought to be possibly study-related—asymptomatic cholelithiasis leading to cholecystectomy in a 15-year-old female who had lost 15.8 kg by the time of the event. In the smaller trial, one suicide occurred in the orlistat group; this patient was under a psychiatrist’s care.^159^ No deaths occurred in the placebo group.

##### Side Effects

Side effects were primarily gastrointestinal and were fairly common among patients taking orlistat (Appendix D Table 17). Abdominal pain was higher with orlistat (22%) than placebo (11%) in the larger study.^158^ In the smaller study, cramping was not statistically higher during the final month of treatment (orlistat, 13% vs. placebo, 22%); however, cramping was higher with orlistat during the first months of treatment (e.g., 65% with orlistat vs. 26% with placebo in month one).^159^ Across both studies, flatus with discharge was reported by 20 to 25 percent of those taking orlistat and 0 to 3 percent of those taking placebo (RR, 8.74 [95% CI, 3.46 to 22.07] in the larger study). Fecal incontinence was reported in 6 to 9 percent of orlistat participants and 0 to 1 percent of placebo participants (RR, 17.38 [95 % CI, 2.35 to 128.4] in the larger study). The smaller trial reported adverse effects over time.^159^ The prevalence of some but not all adverse effects decreased over time among those taking orlistat.

##### Vitamin Levels

Both orlistat trials measured vitamin A, D, and E levels and reported no differences between groups.^158,^ ^159^ Both trials, however, provided multivitamin supplementation for all participants.

#### Phentermine/Topiramate

In addition to the trial examined for efficacy of phentermine/topiramate,^161^ an additional small RCT (n=42) reported on harms of two dosing regimens (15 mg/92 mg and 7.5 mg/46 mg) after 2 months of use.^160^ This trial was not included for evaluation of health outcomes, weight, or other intermediate outcomes due to the short duration of followup.

##### Discontinuation Due to Adverse Effects and Serious Adverse Effects

Across all treatment arms in both studies, three of 126 persons taking phentermine/topiramate discontinued treatment (2.4%, all receiving the higher dose) and two of 70 persons taking placebo discontinued (2.8%, Figure 13, Table 21, Appendix D Table 18). Three serious adverse events among two individuals were reported across both trials among those assigned to the higher dose of topiramate/phentermine: a bile duct stone, depression, and suicidal ideation. Most types of side effects were experienced at comparable rates between groups.

##### Side Effects

In the larger study, the side effects that were slightly more common with higher-dose phentermine/topiramate were musculoskeletal (experienced by 10 persons [8.8%] with phentermine/topiramate vs. 1 [1.8%] with placebo) and psychiatric (10 persons [8.8%] with phentermine/topiramate vs. 1 [1.8%] with placebo), although group differences were not statistically significant (Appendix D Table 18).^161^ Side effects that were more common in the smaller trial included those related to the nervous system (7 persons [54%] taking the 15 mg/92 mg combination, 2 persons [13%] taking the 7.5 mg/46 mg combination, and 4 persons [29%] taking the placebo) and gastrointestinal system (1 person taking the 15 mg/92 mg combination, 3 persons taking the 7.5 mg/46 mg combination, and 0 taking the placebo).^160^

## Contextual Findings

### CQ1 What Is the Prevalence of BMI Assessment in Children and Adolescents in Primary Care Practice? Does the Prevalence of BMI Assessment Vary by Age?

Summary: Data regarding the contemporary assessment of BMI in children and adolescents in the United States shows a mixed picture. Overall, clinical practice appears to have changed dramatically over the past one to two decades. Survey data of pediatricians indicate that the assessment of BMI is very common and the standard of practice; however, the prevalence of BMI percentile documentation is smaller in other datasets. Further, the extent to which BMI results are discussed with patients or used for referral for weight management is much more uncertain. Much of the literature is over a decade old and may no longer be applicable.^164^

A 2017 survey of AAP members assessing BMI-related practices found that 96 percent of pediatricians reported calculating BMI at each well-child visit.^165^ This proportion represents a dramatic increase over time, rising from 37 percent in 2006. An analysis of NHANES data found that in 2014, just over one-third (34%) of children ages 2 to 18 years with a BMI at or above the 85th percentile were notified by their healthcare provider about “unhealthy weight.”^166^ This represented an increase over time, where 22 percent were notified in 1999. This analysis found that older children and teens were more likely to be notified of unhealthy weight than younger children, as were girls, Black and Hispanic/Latino children, and those with a BMI at or above the 95th percentile (compared to ≥85th percentile).

Another data source suggests that BMI measurement is less common. The current Healthcare Effectiveness Data and Information Set (HEDIS) measures include a metric for “Weight Assessment and Counseling for Nutrition and Physical Activity for Children/Adolescents.”^167,^ ^168^ This measure assesses the percentage of health plan members 3 to 17 years of age who had an outpatient visit with a primary care clinician or obstetrician/gynecologist and who had evidence of BMI percentile documentation during the measurement year. In 2021, 72 percent of Commercial Health Maintenance Organization (HMO) members, 61 percent of Commercial Preferred Provider Organization (PPO) members, and 76 percent of Medicaid HMO members had documentation of BMI percentile. These figures represent dramatic increases over 2009 data, where 35, 17, and 30 percent, respectively, had BMI percentile documentation. For both survey data and HEDIS measures, no data are available for BMI assessment by age.^168^

In addition to measuring BMI at well-child visits, pediatrician surveys also suggest that providers are discussing healthy behaviors with families. The 2017 survey of AAP members reported that 93 percent are discussing eating a variety of fruits and vegetables, 91 percent are discussing being physically active, and 89 percent are discussing screen time.^165^ Again, results from HEDIS measures are more conservative.^168^ HEDIS measures from 2020 showed that counseling for nutrition occurred in 60 percent of Commercial HMO members, 53 percent of Commercial PPO members, and 67 percent of Medicaid HMO members. For physical activity counseling, these numbers were 56 percent, 49 percent, and 63 percent, respectively, for 2020.

Some data suggest that an increasing proportion of pediatricians are referring children and adolescents to community-based weight management programs. Comparing 2017 to 2006 survey data, more pediatricians reported referring children with “overweight” (14.6% vs. 20.4%), “obesity” without complications (44% vs. 52.3%), and “obesity” with complications (60.1% vs. 68.2%) to community-based weight management programs.^165^ These estimates, however, are higher than those cited in other sources. For example, a 2018 U.S.-based quality improvement study found that at baseline, 22.3 percent of visits with children and adolescents with a BMI at or above the 95th percentile documented referral to a weight management program.^169^

While physicians responding to the 2017 AAP survey overwhelmingly felt that pediatricians should address obesity at well-child visits (98%) and that pediatricians can help prevent childhood obesity (88%), far fewer felt that there are effective means of treating pediatric obesity (56%).^165^ A similar proportion agreed that their counseling on obesity management was somewhat or very effective (55%).

### CQ2 How Well Does BMI Predict Adiposity and Overall Health? Does the Predictive Accuracy of BMI Differ by Race or Ethnicity?

Summary:The BMI is an imperfect measure of adiposity and is not an equivalent measure of adiposity across racial and ethnic groups. At a BMI at or above the 95th percentile, however, most young people have relatively high levels of adiposity (e.g., ≥75th percentile in normative samples). Despite limitations in this measure, it is important to understand how the BMI correlates with health outcomes given that its measurement is standard of practice.

Overall, the literature assessing the relationship between BMI and overall health is difficult to interpret because of complex etiology, a substantial potential for confounding, and long periods of followup required for evaluation. Longitudinal data show that higher BMI in childhood is associated with early CVD (mortality, early cancer mortality, diabetes, and dyslipidemia in adulthood). The degree of BMI tracking between childhood and adulthood may influence perspectives on when and how aggressively to attempt treatment in children with higher BMI. Overall, cohort studies suggest that BMI tracking is moderate from childhood to adulthood but high for adolescence to adulthood. At the same time, there is a substantial proportion of individuals for whom higher BMI emerges in adulthood. Association data from cohorts of adults have more uncertain findings with respect to the relationship between BMI and mortality. While a BMI of 35 kg/m^2^ or higher is consistently associated with increased overall mortality risk, associations in intermediate BMI ranges differ in prominent analyses and are sensitive to analytic procedures. In the adult literature, evidence suggests that lifestyle behaviors and cardiorespiratory fitness play an important role in the association between BMI and mortality. When these factors are taken into account, behavior appears to modify the association and vastly mitigates or eliminates the role of higher BMI in findings of higher mortality risk. Unfortunately, all of these data are from studies of associations. Trial data evaluating the effect of intentional weight loss on subsequent mortality are sparse and inconclusive.

Strong evidence that weight loss in children and adolescents at higher BMI is associated with health outcomes would support intervention to reduce higher BMI at younger ages. Evidence to connect BMI in childhood to health outcomes is difficult to obtain because of long followup periods between measurement in childhood and older ages at which health events and mortality would occur. In the absence of robust evidence between child BMI and adult health outcomes, an indirect evidence pathway can be assessed by the degree to which childhood BMI persists into adulthood, and how adult BMI is subsequently associated with adult health outcomes (Figure 14). Evaluation of these associations at all ages is complicated by a complex ecosystem of factors that are related to both BMI and health outcomes, including other cardiometabolic measures as well as behavioral, social, psychological, and environmental factors.

Figure 14 Linkages From Child BMI to Adult Health Outcomes With Model of BMI Influences

Abbreviations: ACEs = adverse childhood experiences; BMI = body mass index.

Figure 14 shows the linkages from child BMI to adult health outcomes with a model of BMI influences

#### Accuracy of the BMI

Obesity is presumed to have an impact on health through accumulation of adipose tissue, particularly subcutaneous adipose tissue, which may affect health by increasing inflammation, among other possible pathways.^170^ Although there is not an established cutoff for defining excess body fat that is associated with poor health,^171^ one study showed many young people with BMI percentile in the 85th to 95th percentile do not have high body fat, as measured using normative data for DEXA measures of body fat (i.e., ≥75th percentile body fat).^12^ For example, 43 percent of youth with BMI percentile between 85th and 95th percentile were above the 75th percentile for body fat, meaning 57 percent were below this threshold for high body fat. Misclassification declined as children’s BMI percentile increased; 81 percent of boys and 87 percent of girls with a BMI at or above the 95th percentile had high levels of body fat. Other investigators have evaluated the accuracy of the BMI to classify adults as cardiometabolically healthy or unhealthy using intermediate outcomes such as blood pressure, lipid levels, and glucose-related measures.^172^ An analysis using a sample of 40,020 adults in the United States showed that 47 percent of adults with a BMI of 25 to less than 30 kg/m^2^, 29 percent of adults with a BMI of 30 to less than 35 kg/m^2^, and 16 percent of adults with a BMI of 35 kg/m^2^ or higher were metabolically healthy; 69 percent of adults with a BMI of 18.5 to less than 25 kg/m^2^ were metabolically healthy.

Evidence further shows that BMI is not an equivalent measure of adiposity in different racial and ethnic groups. Overall, analyses suggest that at the same BMI, Black children and adolescents tend to have lower body fat compared to White children and adolescents, and Hispanic/Latino children and adolescents tend to have a higher body fat percent.^14,^ ^173,^ ^174^ Several analyses have suggested that these differences are more prominent in boys than girls.^14,^ ^174^ Others investigators have reported differences in body composition and stature across the lifespan between Black, Hispanic/Latino, and White adults that could give rise to differences in the BMI-adiposity relationship.^175^ The above analyses did not include Asian children and adolescents. A recent NHANES analysis using 2011–2018 data including Asian children and adolescents found that age-adjusted mean body fat percentage was similar for Asian and White boys, which were higher than Black boys, and lower than Latinos.^174^ For girls, body fat percentage was similar in Asian, White, and Black girls but higher in Latinas. This analysis further demonstrated that differences by race and ethnicity were not consistent by BMI category, with fewer significant differences at a BMI at or above the 95th percentile. Older studies have shown more consistently that at the same BMI, Asian populations have a higher body fat percentage than White populations, with some variation by sex and BMI-for-age.^176^ However, because of heterogeneity in body fatness within regions of Asia, findings for the broad population categorization of “Asian” should be interpreted with caution.^177,^ ^178^

Some analyses in adults have translated racial and ethnic differences in the BMI-adiposity relationship into specific BMI values. For example, a meta-analysis of 32 studies (N=11,924 adults) showed that at the same body fat percent, age, and gender, Black Americans had a 1.3 kg/m^2^ higher predicted BMI than White populations, meaning that Black adults had lower body fat for the same BMI as White adults.^179^ This analysis also included a small sample of 128 individuals in Polynesia, and found an even larger discrepancy compared to White adults; among adults at the same body fat, age, and gender, Polynesian individuals had a 4.5 kg/m^2^ higher predicted BMI than White populations at a given body fat percent.

Racial and ethnic differences are also present in the relationship between BMI and the incidence of type 2 diabetes in adults. Evidence from NHANES data (n=19,335) suggests that Black, Hispanic/Latino, and Asian adults all have increased risk for diabetes at lower BMI thresholds than White adults.^180^ This study found that, among adults in the United States age 35 years or older, offering diabetes screening to Black Americans and Hispanic/Latino Americans at a BMI of 18.5 kg/m^2^ and higher and 20 kg/m^2^ and higher for Asian Americans would be equivalent to screening White Americans with a BMI of 25 kg/m^2^ and higher.^180^ The American Diabetes Association’s 2020 guidelines recommend a lower screening threshold in Asian Americans (≥23 kg/m^2^) compared to a 25 kg/m^2^ and higher threshold in other groups, and further consider African Americans, Hispanic/Latino, Native Americans, and Pacific Islander individuals to have a “high risk race/ethnicity.”^181^ On the other hand, a separate study based on NHANES data (N=45,514) seems to contradict these findings, showing that the relationship between BMI and diabetes onset is weaker for Black adults (OR for the interaction term relative to White adults, 0.97 [95% CI, 0.95 to 0.98]).^182^ Taken together, these findings suggest some complexity to the association between BMI and diabetes.

#### BMI Prediction of Adiposity and Overall Health, Direct Evidence as Measured in Childhood

Robust assessment of the relationship between childhood BMI and overall health requires very long followup periods to observe health outcomes, overcoming difficulties of participant retention over a substantial time horizon, and the ability to control for confounders. Large, pooled analyses from the International Childhood Cardiovascular Cohort (i3c) Consortium represent 30- to 40-year prospective longitudinal followup for seven international cohorts, which offer adjudicated outcomes collected from registries that overcome some of these difficulties. Evidence from this robust dataset shows that higher BMI in childhood is consistently associated with early CVD mortality, early cancer mortality, diabetes, and dyslipidemia in adulthood^23–26^ (Appendix D Table 19). For example, for each unit of childhood zBMI, the hazard ratio (HR) for CVD mortality was 1.44 (95% CI, 1.33 to 1.57) when adjusted for sex, Black race, cohort, mean age, and parental education.^23^ Several features of these data, however, limit the certainty of conclusions for the independent predictive value of childhood BMI. These estimates were not adjusted for other cardiometabolic risk factors, physical activity, diet or other behaviors, adult BMI alone, and other potential confounders. When an adult CVD risk score combining several risk factors was added to an analysis of combined childhood CVD risk, the risk for fatal CVD events associated with childhood combined CVD risk was reduced and was no longer statistically significant, underscoring the prognostic importance of risk factors in adulthood. Cohort enrollment occurred 30 to 50 years ago and so may not be representative of contemporary populations. For example, advances in CVD treatment and changes in diet, physical activity, and sleep patterns, environmental contaminants, and myriad other environmental and lifestyle factors may affect these associations. Further, the mean age at death in this analysis was 47 years; thus, it reflects associations with premature CVD death, which may reflect a different risk profile than later death. Additionally, when analyses were conducted for categorical BMI, the reference category of “low-normal” is less than 50th percentile, which is a low and unconventional cutpoint for BMI. Analyses from the i3c Consortium specifically for cancer mortality offer several analytic advantages such as control for additional cardiometabolic risk factors and adult BMI; the more comprehensively adjusted HR for cancer mortality was 1.35 (95% CI, 1.12 to 1.63).^24^ The mean age of cancer death was 45 years.

In these analyses, the proportions of Black participants ranged from 13 to 29 percent and the proportion of participants who were Hispanic/Latino, Asian, or Native American was not reported but is presumably very low.^23–26^ In analyses for CVD and cancer mortality, there were no statistically significant interactions with Black race.^23,^ ^24^ In analyses for diabetes and dyslipidemia,^25,^ ^26^ associations with BMI were larger in White participants than in Black participants, but only statistically significant in selected analyses for dyslipidemia (association of dyslipidemia with adult BMI in females; White: 2.01 [95% CI, 1.83 to 2.22], Black: 1.61 [95% CI, 1.41 to 1.83]; p=0.003).

Other investigators have used alternate measures of predictive value. A systematic review by Llewellyn and colleagues^183^ estimated the accuracy of various BMI cutpoints in childhood to predict adult outcomes in terms of sensitivity, finding that the use of the BMI to predict adult morbidities is poor. At a childhood BMI cutpoint of at or above the 85th percentile, the pooled sensitivities for adult coronary heart disease (CHD) and stroke were 22 percent (95% CI, 19% to 26%) and 16 percent (95% CI, 16% to 17%) when BMI was measured between ages 12 and 18 years, with similar estimates for ages 7 to 11 years. Estimates were lower at a childhood BMI cutpoint of at or above the 95th percentile. For BMI measured between ages 12 and 18 years, sensitivities for adult CHD and stroke were 8 percent (95% CI, 7% to 10%) and 5 percent (95% CI, 5.36% to 5.84%). At each cutpoint, sensitivities for hypertension and diabetes outcomes were higher. The highest sensitivity was at or above the 85th percentile to predict diabetes, at 31 percent. This review included 37 total cohort studies; however, analyses for any one outcome for a specific age group and cutpoint included no more than four cohorts each and were limited to one cohort for stroke outcomes predicted from ages 12 to 18 years.

#### BMI Tracking From Childhood to Adulthood

In concert with evidence for direct associations between BMI at a particular age and mortality, evidence on the degree of BMI tracking throughout the lifespan may influence perspectives on when and how aggressively to attempt treatment in children with higher BMI. Overall, cohort studies suggest that BMI tracking is moderate from childhood to adulthood but high for adolescence to adulthood. At the same time, there is a substantial proportion of individuals for whom higher BMI emerges in adulthood. It is rare for BMI trajectory to improve over the lifespan, and factors associated with higher risk for increasing BMI over time are female sex and Black race.

A 2016 systematic review and meta-analysis of 15 prospective cohort studies (N=200,777) showed that while the persistence of BMI in the 95th or higher percentile from childhood to adolescence was moderate (55%), the persistence of BMI in the 95th or higher percentile from adolescence to adulthood was quite strong (80%).^27^ Taken together, children and adolescents with BMI in the 95th or higher percentile were five times more likely to have this BMI percentile in adulthood (RR, 5.21 [95% CI, 4.50 to 6.02]) than children and adolescents below this threshold. However, 70 percent of adults with BMI at or above the 95th percentile did not have a BMI at or above the 95th percentile in childhood or adolescence, suggesting that BMI at this threshold emerges principally in adulthood.

This finding parallels an analysis from the i3c Consortium (N=12,142) focusing on the higher BMI threshold of 35 kg/m^2^ or higher in adulthood.^28^ An adult BMI of 35 kg/m^2^ or higher occurred in 6 percent of children with “normal weight”; 29 percent of children with “overweight”; 56 percent of children with “obesity”; and 80 percent of children with “severe obesity.” On the other hand, 38 percent of the 1,440 adults with a BMI of 35 kg/m^2^ or higher were “normal weight” as children. Another i3C Consortium analysis shows that less than 5 percent of individuals in included cohorts had decreasing BMI trajectories.^184^ Nearly half (47%) demonstrated increasing BMI trajectories. Factors associated with a higher risk of increasing BMI trajectory were female gender, lower parental education level, and Black race.

#### BMI Prediction of Adiposity and Overall Health, Evidence From BMI Measured in Adulthood

Although the applicability to children of evidence among adults is not well understood, given the limited information among children, it may nevertheless be informative to explore the evidence among adults for potential extrapolation. Very large meta-analyses and individual-patient-data (IPD) meta-analyses of observational studies have evaluated the association between BMI and all-cause mortality in adult populations.^29–31^ These studies have consistently shown that a BMI of 35 kg/m^2^ or higher is positively associated with all-cause mortality; however, there are mixed findings for a BMI in the range of 25 to 35 kg/m^2^. One prominent analysis shows that a BMI of 25 to less than 30 kg/m^2^ is statistically significantly protective for all-cause mortality^30^ and another analysis shows that this BMI category is associated with statistically significant excess risk.^29^ For example, an IPD meta-analysis by the Global BMI Collaboration reported an HR of 1.11 (95% CI, 1.10 to 1.11) for the association of BMI in the 25 to less than 30 kg/m^2^ range with all-cause mortality in its primary analysis.^29^ In contrast, a systematic review and meta-analysis by Flegal and colleagues found an HR of 0.94 (95% CI, 0.91 to 0.96) for this same comparison.^30^ These analyses have several analytic differences such as varied sample size constraints as well as differential methods for handling smoking and pre-existing disease. Further, these analyses identified data using different procedures: a study-level meta-analysis based on systematic review in one case and an IPD analysis with opportunity for selection bias in the other.^185^ Other investigators have empirically studied the potential for uncontrolled confounding in both analyses, suggesting caution in the interpretation of protective or detrimental effects of overweight on all-cause mortality.^186^

Cardiorespiratory fitness is rarely reported in the studies underlying the above meta-analyses and may have a meaningful joint association with BMI in examining the risk of mortality. A systematic review of prospective studies (k=10, N=92,986) examined the joint association of cardiorespiratory fitness and BMI and found that unfit adults have roughly twice the all-cause mortality risk as fit adults, regardless of BMI, and that fit “overweight and obese” adults had similar mortality risk to fit adults at “normal weight” (Figure 15).^32^ These findings, however, are from a subset of the literature, as few studies report objectively measured cardiorespiratory fitness. This analysis should be confirmed with additional research incorporating new studies.

Figure 15 Joint Association of Cardiorespiratory Fitness, BMI, and All-Cause Mortality^32^

Abbreviation: BMI = body mass index.

Lower cardiorespiratory fitness: 1st quintile of objectively measured cardiorespiratory fitness (7 of 10 included studies) or study-specific criteria; Higher cardiorespiratory fitness: 2nd–5th quintile of objectively measured cardiorespiratory fitness (7 of 10 included studies) or study-specific criteria.

Figure 15 shows the joint association of cardiorespiratory fitness, BMI, and all-cause mortality

Studies including a broader array of healthy behaviors when investigating the association of BMI with mortality have similarly found important joint associations between these factors. An analysis of 11,761 adults from NHANES evaluated mortality by BMI category and the number of healthy behaviors: eating 5 or more fruits or vegetables per day, regular exercise more than 12 times per month, moderate alcohol use (up to one drink per day for women and two per day for men), and not smoking.^33^ Mortality risks were similar among adults with all four healthy behaviors, regardless of BMI category. Further, mortality was similar between adults with a BMI of 30 kg/m^2^ or higher with all four healthy behaviors and adults with a BMI of 18.5 to less than 25 kg/m^2^ with none of these healthy behaviors. Such evidence challenges a common perception that BMI is synonymous with health (Figure 16).

Figure 16 Risk of All-Cause Mortality for Adults by Adherence to Health Habits, Stratified by BMI^33^

Abbreviations: BMI = body mass index; CI = Confidence interval; HR = hazard ratio.

Healthy habits: eating ≥5 fruits or vegetables per day, regular exercise >12 times per month, moderate alcohol use (up to 1 drink per day for women and 2 per day for men), not smoking.

Figure 16 shows the risk of all-cause mortality for adults by adherence to health habits, stratified by BMI

The above studies address the association between BMI at the baseline period of observational studies and subsequent mortality after prospective followup. More relevant to this review, however, may be the association of intentional weight loss with subsequent mortality and other health outcomes. Mortality has been traditionally hard to assess because of the limited followup periods in RCTs of weight loss and low event rates. A meta-analysis of 32 studies and 19,463 participants showed that weight loss interventions were associated with a lower but nonsignificant risk of all-cause mortality (OR, 0.86 [95% CI, 0.73 to 1.02]).^22^ The average followup in this analysis was 9.2 years; 593 deaths occurred, which is equivalent to an annual mortality rate of 0.3 percent. A 2018 systematic review by LeBlanc and colleagues that focused more directly on general population samples (e.g., without diabetes) identified only four RCTs of intentional weight loss in adults that reported all-cause mortality. Results were too sparse to be quantitatively pooled; none of the four trials found significant differences in weight loss versus control groups over 2 to 16 years of followup.^21^ This review also reported that only two studies reported on cardiovascular outcomes, and neither found a reduction in cardiovascular events.^21^ This review also reported that weight management interventions were associated with a reduction in type 2 diabetes incidence, with an estimated absolute risk reduction of approximately 14.5 percent over 3 to 9 years.^21^ Similarly, the Look AHEAD trial, which was limited to adults with type 2 diabetes ages 45 to 75 years, found no group differences in CVD events after 9 years’ followup (HR for the primary composite outcome, 0.95 [95% CI, 0.83 to 1.09]), despite the mean 3.5 percent reduction in weight at the end of the intervention and sustained improvements in glycated hemoglobin level and SBP.^187–190^

### CQ3 Are There Harms Associated With Diagnosing Children and Adolescents as Being Overweight or Having Obesity in the Healthcare Setting (e.g., Harms Associated With Labeling)? Does the Risk of Harm Differ Across Racial and Ethnic Groups or Contribute to Health Inequities?

Summary: Labeling children and adolescents as having overweight or obesity is associated with poorer psychosocial outcomes, higher rates of unhealthy weight control behaviors, and appears to have either no impact on weight or is associated with greater future weight gain. Weight labeling may undermine health-promoting behaviors associated with body satisfaction among youth with higher BMI, and children who misperceive their weight as being lower than it is may experience less future weight gain, fewer depressive symptoms, and improved blood pressure.

Accurate weight perception has historically been a focus of public health efforts to reduce obesity, founded on the belief that motivation to engage in healthy behaviors requires individuals to acknowledge that they have an elevated BMI.^44^ However, this belief is not based on empirical findings, and some observational studies have reported the opposite effect. Specifically, research has shown that under-perception of one’s weight may be associated with lower future weight gain and improved blood pressure.^44^ For example, the National Heart, Lung, and Blood Institute (NHLBI) Growth and Health Study reported that youth with overweight or obesity who under-perceived their weight had lower blood pressure in adulthood than those who perceived themselves to be overweight.^45^ In a 2020 editorial, Tracy Richmond, MD, of Boston Children’s Hospital stated, “because body satisfaction is protective against so many adverse health outcomes, the continued push to correct weight misperception ignores these protective effects and may actually cause harm by inadvertently promoting weight stigma and weight discrimination.”^44^ The harms of stigma and weight bias are discussed in more depth in Contextual Question 7.

#### Association of Labeling With Future Weight

Prior studies have demonstrated that labeling of children as “overweight” or “obese” is associated with either no change in BMI or increased BMI in both the short and long term. For example, Madsen and colleagues (2021) reported on the impact of school-based BMI reporting on weight status and adverse outcomes among a diverse student population. Children in 79 California schools were cluster randomized to annual BMI screening and reporting results to parents, BMI screening only, or control (no screening or reporting).^34^ They found that BMI reporting had no effect on BMI z score change at 1- or 2- years’ followup. Furthermore, they found increased weight dissatisfaction among students having BMI screened at school compared to control participants. Likewise, the longitudinal NHLBI Growth and Health Study (2018) followed 2,379 girls ages 10 to 19 years to evaluate the effect of being labeled “too fat” by a family member, friend, or teacher on future obesity.^35,^ ^36^ At baseline, 58 percent of girls reported being labeled and Black girls reported more weight labeling than white girls. The results indicated that girls who experienced weight-based labeling at age 10 years were more likely to experience obesity at age 19 years, adjusting for baseline BMI, household income, parental education, race, and age at menarche. This effect was not modulated by race. Relatedly, the National Longitudinal Study of Adolescent Health (N=6,523; mean age at baseline, 16 years; 58% female) found that adolescents who misperceived themselves as being overweight had greater odds of developing obesity over the 12-year followup period than adolescents who perceived their weight accurately (OR, 1.41 [95% CI, 1.22 to 1.64]).^191^ Taken together, these findings suggest that labeling may be associated with no changes in weight in the short term and possibly increased weight in the longer term, at least in the context of the school and home. We did not find information on the impact of labeling in the medical context, but these findings suggest the need to discuss children’s weight in a sensitive manner. Further, clinicians may have a valuable role to play in helping parents avoid harmful labeling of their children.

#### Association of Labeling With Unhealthy Weight Control Behaviors

Increasing child BMI over time is correlated strongly with parental concerns about their child’s weight and perceived overweight or obesity.^192^ Parental concern about child overweight or obesity is associated with an increased likelihood of restricting children’s food intake.^193^ In turn, parental feeding restriction has been linked to increased child food intake and higher child body weight.^194^

Weight-labeling has been consistently linked to disordered eating and unhealthy weight control behaviors in adolescence. The NHLBI Growth and Health Study (2018) found that girls who were told they were “too fat” by family member, friends, or teachers at age 14 years demonstrated an increase in unhealthy weight control behaviors over the subsequent 5 years, including not eating for a day or more, vomiting, taking diet pills, and using laxatives.^37^ These effects were independent of baseline levels of disordered eating, BMI, and demographic factors such as race, parental income, and education levels. Neumark-Sztainer and colleagues (2011) published 5- and 10-year results of a longitudinal study examining the prevalence and patterns of unhealthy dieting and weight control behaviors, including binge eating, from adolescents to young adulthood.^38,^ ^195^ They found that weight concerns, importance of weight and shape, and parent weight concerns predicted the onset of unhealthy weight loss behaviors, among other factors (e.g., peer dieting, depression, reading articles about weight loss).^195^ Further, disordered eating behaviors that began during adolescence often continued into young adulthood. They concluded that there is a need for both early prevention efforts before the onset of harmful behavioral patterns as well as ongoing prevention and treatment interventions to address the high prevalence of disordered eating throughout adolescence and young adulthood.^38^

Solmi and colleagues (2020) examined consequences of the focus on obesity in a study of teenagers from three U.K.-based birth cohorts spanning three decades.^39^ They reported that the percentage of youths reporting intentions to lose weight increased substantially from 2005 to 2015 and they also reported an increase in the perception of excess weight across the actual weight spectrum from 1986 to 2015, as well as an increase in percentage of youths who reported using diet or exercise to lose weight over the same time period. Evidence suggests similar trends in the United States; it has been estimated that at least two-thirds of adolescents restrict their food intake with the intent of losing weight, and the use of diet and exercise behaviors to lose weight has increased over time.^44,^ ^196^ Such weight loss behaviors (whether unhealthy or not) are likely to be counterproductive, as evidence suggests that adolescents who diet (i.e., changed the way they eat to lose weight) tend to have higher BMI 5 years later, compared with adolescents who do not diet.^40^ We discuss potential harms of weight loss attempts in childhood and adolescence in more depth in Contextual Question 8.

#### Association of Labeling With Psychosocial Well-Being

Prior research has suggested that the use of weight-based labels or terminology is associated with children’s physical self-perception and emotional well-being. For example, children labeled as having overweight or obesity may feel less smart, less physically capable, and less positive about themselves in general.^41,^ ^42^ Children report that weight-based labels contribute to feelings of embarrassment and sadness, and youth who perceive themselves to be overweight are more likely to experience depressive symptoms than children who do not perceive themselves to be overweight, even when controlling for actual BMI.^43,^ ^44^ Internalization of thin-body ideal and body dissatisfaction are both associated with an increased risk of onset of binge- and purge-spectrum eating disorders.^197^

A systematic review by Gillison and colleagues^198^ examined the association of parent-child weight-talk and child well-being. Weight-talk was categorized into four communication types: encouragement to lose weight; encouragement to exercise/eat a healthy diet without reference to weight; weight criticism (including teasing); and impersonal weight comment/discussion. They found that encouraging children to lose weight and criticizing weight were associated with poorer physical self-perceptions and greater dieting and dysfunctional eating (effect sizes, 0.20 to 0.47). However, parental encouragement of healthy lifestyles without explicit reference to weight was associated with better well-being, but this was only measured in two studies. They found no effect of child age on the strength of associations, but they did report differences by gender. Specifically, dysfunctional eating was more strongly associated with parent communication for girls than boys. They were unable to draw conclusions about impersonal weight comments due to limited and heterogeneous evidence. The findings suggest that certain types of parent-child weight-talk may be linked with poorer child well-being; however, encouraging healthy behaviors without reference to weight may help offset such effects.

Limited research has evaluated the impact of race and ethnicity on the psychological correlates of weight labeling in children and adolescents; however, studies in adult populations may be relevant. One such study used data from the National Health Measurement Study (NHMS), a national sample of English-speaking adults.^199^ Those findings suggest that the effect of weight-based discrimination on mental health is highly dependent upon social status. Specifically, the psychological consequences of discrimination on Hispanic women and women in the lowest household income group were significantly greater relative to White women and women with higher household income, controlling for obesity status and self-rated health. These results indicate that higher social status may have a protective effect on mental health with regard to weight-related stigma.

### CQ4 What Level of Weight or Relative Weight Decrease in Children or Adolescents With Obesity Reduces the Likelihood of Obesity in Adulthood or Health Outcomes Associated With Obesity?

Summary: Empiric evidence to support any particular cutoff of weight loss that confers health benefit is limited in both pediatric and adult populations. The most robust evidence in pediatric populations is from a meta-regression study that suggested zBMI reductions of at least 0.7 are needed to confer benefit for cardiometabolic measures. Mean reductions in zBMI found in the behavioral intervention trials included in our review were far smaller, generally ranging from 0.2 to 0.4 with higher-contact interventions and 0 to 0.2 in lower-contact interventions. Semaglutide was associated with a zBMI reduction of 1.1, however, which is consistent with the range needed to expect an impact on cardiometabolic parameters. Conclusions about clinically important differences in weight change are difficult to draw because most evidence does not attempt to disentangle potential benefits from improved diet and physical activity from potential benefits of weight loss alone.

The clinical importance of small reductions in BMI or BMI percentile in children or adolescents, such as those found in our review, is difficult to understand and disentangle from potential benefits associated with behavioral change alone. All evidence we identified exploring thresholds for clinically important weight change in young people examined change in zBMI. This outcome has important limitations as a measure of weight change among young people with a zBMI above the 97th percentile for age and sex.^100^ Nevertheless, it is used because it may be applied across the age spectrum of growing children, in whom the goal may be slowing the trajectory of weight growth rather than weight reduction.

A 2020 meta-regression of 71 studies reported various cardiovascular measurements associated with mean change in BMI standard deviation scores (BMI-SDS, equivalent to zBMI) in children and adolescents.^200^ They concluded that BMI-SDS reductions of 1, 1.2, and 0.7 were associated with consistent mean reductions in SBP, LDL cholesterol, and triglyceride levels, respectively. These values are substantially higher than the mean improvements in zBMI with the behavioral interventions in our review, where zBMI change generally ranged from mean reductions of 0.2 to 0.4 with higher-contact interventions and 0 to 0.2 in lower-contact interventions. In contrast, mean changes in the control groups generally ranged from −0.1 to +0.1 (Appendix E Figure 5). Baseline zBMI scores were heterogeneous across studies, however, and the importance in zBMI change magnitude may vary by baseline zBMI. This level of weight reduction was seen in the included study of semaglutide, however. This study also found greater improvement in LDL cholesterol level, triglyceride level, waist circumference, and blood pressure among participants taking semaglutide who achieved 2 category BMI reduction versus less than 2 category BMI reduction.

Several prospective studies of children with weight categorized as “obese” have reported larger improvements in cardiometabolic measures among those who reduced their zBMI over time compared to those who did not reduce their zBMI.^201–205^ These studies typically found a greater likelihood of statistically detectable change in cardiometabolic risk factors with zBMI reductions of 0.125 to 0.500.^201–205^ Statistical significance was the determinant of benefit in all of these studies, however, which is partially a function of sample size and may not reflect clinically meaningful change. However, in many trials, children in the control groups were more likely to show a continued trajectory of increasing levels of high weight, on average, so simply arresting the gain in excess weight may constitute a clinically important benefit for many of these interventions, assuming the changes in weight trajectory are maintained in the long term.

Given limited evidence in children, it may be helpful to explore what is known about the clinical significance of weight loss in adults, for potential extrapolation. In the literature focusing on adult populations, weight loss amounts of both 5 and 10 percent or more of baseline weight are commonly cited as thresholds of clinical significance to confer cardiovascular benefit.^206^ These thresholds appear to be based largely on evidence that adults participating in lifestyle-based weight management interventions have shown reductions of 0.6 to 1.0 percent in HbA1c and a reduced need for diabetes medications among adults with type 2 diabetes; approximately 3 and 2 mm Hg for SBP and DBP, respectively, among adults with elevated CVD risk (e.g., diabetes or hypertension); and longitudinal studies showing a dose-response relationship between weight loss and lipid levels. However, a systematic review of long-term (≥2 years) dietary-focused interventions for weight loss found that weight loss of at least 5 percent was not consistently associated with significant improvements in cardiovascular risk factors in an unselected adult population with overweight or obesity.^207^ Instead, substantial changes in risk factors occurred principally among those at increased cardiovascular risk, such as participants with impaired glucose tolerance. The FDA set efficacy benchmarks of mean weight loss of 5 percent or more to guide industry about developing products for weight management, subsequently citing the Diabetes Prevention Program (DPP) and a narrative review of obesity epidemiology.^94,^ ^208–211^

However, the association between particular cutoffs of weight loss and reduction in CVD events is less clear. The Look AHEAD trial, a large weight loss trial conducted in adults with type 2 diabetes, was stopped for futility after a mean 9.6 years of followup.^187^ This trial found that its primary composite cardiovascular event outcome occurred in 403 patients in the intervention group and in 418 in the control group (1.83 and 1.92 events per 100 person-years, respectively; HR, 0.95 [95% CI, 0.83 to 1.09]). The results were very similar for its broader secondary CVD outcome. This finding of no difference in cardiovascular events was despite greater weight loss in the intervention group (8.6% vs. 0.7% at 1 year; 6.0% vs. 3.5% at study end) as well as greater improvements in measures of several CVD risk factors and cardiorespiratory fitness.

We found limited direct evidence to justify any specific threshold for percent weight reduction or percent BMI reduction for children or adolescents. In the pediatric literature, we found one study showing a statistically greater increase in insulin sensitivity with an 8 percent reduction in BMI; however, it did not provide compelling data showing this level of BMI change to be an important threshold (e.g., compared with 6% or 10%), nor whether the amount of improvement in insulin sensitivity reported was clinically significant.^212^

A limitation of the literature showing the association between weight loss and cardiometabolic risk factors is the potential confounding by accompanying behavioral changes such as improved fitness, eating habits, and engagement with the healthcare system; few studies have adjusted for these factors (see Contextual Question 2). Interestingly, the Look AHEAD study did attempt to disentangle the effects of weight loss from the effects of improved fitness among adults with type 2 diabetes.^188^ While results were not conclusive, they suggested that fitness may have a comparable or possibly stronger association with improved CVD events, particularly with smaller changes in fitness or weight (Figure 17). At all levels of fitness improvement (small, medium, or large gain), the risk of CVD events trended in the direction of benefits (13% to 22% relative reduction in the risk of a CVD event), but a comparable effect size was only seen at the highest level of weight loss (≥10%).^187–190^ Weight loss of less than 10 percent was associated with statistically nonsignificant relative increases in CVD events of 8 to 16 percent. However, the degree to which the findings apply to children and adolescents is unknown.

Figure 17 CVD Outcomes Associated With Changes in Weight or Fitness From the Look AHEAD Study^188^

Abbreviations: AHEAD = Action for Health in Diabetes; CVD = cardiovascular disease; CI = Confidence interval; HR = hazard ratio.

Primary outcome = composite of the first occurrence of death from cardiovascular causes, nonfatal acute myocardial infarction, stroke, or admission to hospital for angina.

Secondary outcome = primary outcome plus coronary artery bypass grafting, carotid endartectomy, percutaneous coronary intervention, admission to hospital for congestive heart failure, peripheral vascular disease, and total mortality.

HRs are adjusted for sex, age, baseline weight (from weight-change models), baseline fitness (from fitness-change models), history of cardiovascular disease, insulin use, diabetes duration, smoking status, low-density lipoprotein cholesterol, systolic blood pressure, and diastolic blood pressure.

Figure 17 shows the CVD outcomes associated with changes in weight or fitness from the Look AHEAD study

### CQ5 What Are the Inequities in Factors That Support Healthy Eating and Physical Activity in Youth (e.g., Food Insecurity, Financial Security, or Neighborhood-Level Factors)?

Summary: Diet and physical activity are heavily influenced by the local community environment and by family-level economics, which are also shaped by larger structural forces that have systematically disadvantaged communities that have experienced discrimination, such as Black, Hispanic/Latino, and Native American communities.^213,^ ^214,215^ For example, neighborhood environment has an impact on physical activity.^213^ Further, financial insecurity is an important driver of dietary behaviors; families with limited financial resources must spend a higher proportion of their household income on food, and insufficient food budgets can drive families to prioritize cost-effectiveness over healthfulness in order to help reduce financial strain.^214^ Additionally, stress, uncertainty, and long work hours for parents constrain their ability to prepare and serve healthy foods, and are associated with haphazard meal planning, emotional eating, and snacking on sweets among adults with higher BMI.^213^

Encouraging families with higher-weight children to change their diet and physical activity forms the foundation of most weight management interventions. However, diet and physical activity are heavily influenced by the local community environment and by family-level economics, which are also shaped by larger structural forces.^213,^ ^214^ In the United States, numerous local and national-level policies have systematically disadvantaged communities that have historically experienced substantial discrimination.^215^ Not surprisingly, such policies have contributed to higher proportions of Black, Hispanic/Latino, and Native American families living below the poverty line than White families.^213^ In the United States, rates of children meeting BMI criteria for obesity are also highest in the Black, Hispanic/Latino, and Native American communities (Figure 1),^216^ and also higher for people with limited financial resources. Food insecurity is associated with higher zBMI as young as age 2 years.^217^ Cross-sectional economic evidence is strengthened by studies looking at changes over time, associated with larger economic trends. There is also evidence that economic recession has a larger deleterious effect on BMI in young children among families living at or below the federal poverty level; a study conducted in Los Angeles County found that average BMI increased more in these children after the 2008 recession than in children in families with higher income levels.^218^

Sawyer and colleagues published an umbrella review of 43 different reviews examining systems that influence consumption of healthier versus unhealthier diets. They identified geographic accessibility, household finances and resources, social and cultural influences, and individual influences as all being important determinants of food consumption.^214^ With regard to geographic accessibility, these authors note that healthy food is generally less accessible in low-income neighborhoods. Residents then must take the time to seek healthy food in other areas, but many residents in low-income neighborhoods also have limited access to private vehicles, which makes acquisition of healthy foods more costly and unreliable than simply shopping in local stores. These time and travel barriers are heightened if childcare is limited or unaffordable and young children must accompany parents on shopping expeditions. These barriers also may affect food selection, such as through discouraging purchase of perishable (e.g., fresh fruits and vegetables) and heavy items (e.g., grains) that are more difficult to transport via public transportation.

A review by Soltero and colleagues highlights the impact of the immigration policies on the Hispanic/Latino community, and notes that immigration policies may limit employment opportunities, limit access to public services, and cause fear and stress related to immigration law enforcement.^219^ The authors point out that the risk of food insecurity is increased when families in need cannot access assistance programs. They report evidence that food insecurity is associated with high BMI in Hispanic youth. These authors also describe a study among immigrant Mexican American households that found a 10 percent increase in food insecurity after the passage of restrictive immigration-related legislation.

The impact of distance to retail outlets with abundant and appealing healthy food options was borne out in an RCT of a weight management intervention for children.^220^ This study found that distance to supermarkets was an effect modifier of 1-year change in fruit and vegetable intake.

With each 1-mile shorter distance to a supermarket, intervention participants increased their fruit and vegetable intake by 0.29 servings per day relative to those in the control group (95% CI, 0.01 to 0.57). Distance to a supermarket was also associated with 1-year change in zBMI: each 1-mile reduction in distance was associated with a greater decrease in BMI z-score (differences in zBMI change, −0.05 units [95% CI, −0.01 to −0.10])

Families with limited financial resources must spend a higher proportion of their household income on food, and insufficient food budgets can drive families to prioritize cost-effectiveness over healthfulness in order to help reduce financial strain.^214^ Sawyer and colleagues found evidence that energy-dense, low-nutrient foods (e.g., foods high in refined grains, added sugars, and saturated fats) are often cheaper to purchase than healthier foods. In addition, a limited food budget encourages a diet with little variety, as families seek to minimize food waste by choosing foods that are familiar and known to be palatable for all family members. These shopping patterns can reduce demand for healthy foods in low-income neighborhoods, leading to higher cost for healthier items and lower quality stock due to low turnover.

Sawyer and colleagues noted that research shows that social aspects of food consumption are important for people at all income levels.^214^ Sharing food is an important social activity, food provision can be seen as a marker of parenting, and purchasing certain brands or shopping at some specific locations can signify social or cultural status. Preference for specific brands or products can increase the acceptability of energy-dense, low-nutrient snack foods, processed ready-meals, and fast-food restaurant meals.

Limited financial means also increases stress levels for parents. Interviews with low-income parents indicated that long work hours constrain the ability to prepare and serve healthy foods, and that high stress levels are associated with haphazard meal planning, emotional eating, and snacking on sweets among adults with higher BMI.^213^ Stress among children and adolescents may also influence eating. A systematic review found that stress was associated with unhealthy eating behaviors in both younger (Hedge’s g=0.283; p <0.001) and older (Hedge’s g=0.274; p=0.001) children.^221^

Beyond the challenges of purchasing food with limited financial resources, uncertainty in important social determinants of health such as housing, employment, and finances puts additional strain on families’ ability to eat a healthy diet. A review by Thompson and colleagues noted that insecure work and requirements of social services agencies can create multiple and conflicting constraints on families; securing a basic level of income can be very labor intensive and at times social service agencies can ask parents to be in different places at the same time and provide “evidence” to support program requirements at short notice.^222^ To mitigate challenges related to uncertainty in meeting basic needs, parents in these households tend to prefer foods with easy preparation and a long shelf-life. Unfortunately, these foods tend to be high in fat, salt, and sugar and lower in fruit and vegetables. Similarly, housing insecurity can mean limited or uncertain access to adequate facilities to store and cook food, inadequate space to eat together, and inability to maintain mealtime routines. A study among children in Head Start preschool illustrates that food insecurity may affect BMI, particularly in young girls.^223^ There were no associations between changes in household food insecurity and changes in zBMI or dietary quality among boys in this study. On the other hand, this study found that girls from households that became food insecure over the year of the study had a 0.21-unit higher gain in zBMI than girls from households that were persistently food secure, after adjustment for potential confounders (95% CI, 0.02 to 0.39; p=0.03).

This is similar to the 0.20 mean difference in zBMI change found in the current review among behavioral interventions with 26 or more hours of estimated contact time (MD, −0.20 [95% CI, −0.32 to −0.08]), and substantially higher than that of interventions with less than 26 hours of contact time (MD, −0.05 [95% CI, −0.07 to −0.03)]. Girls from households that became food secure had improvements in dietary quality over the year compared to girls from persistently food insecure households (adjusted difference in HEI score change, 9.1 points [95% CI, 3.0 to 15.0]; p=0.003). One study included in our review reported on change in the HEI.^141^ This study, among families with a 2- to 5-year-old child with a BMI at or above the 95th percentile for age and sex, found an 8.7-point greater increase in HEI in the intervention group with an estimated 23 hours of contact (95% CI, 3.75 to 13.65), but no group differences between a lower-contact intervention group and the control group (MD, 1.2 points, [95% CI, −3.6 to 6]).

Neighborhood environment also has an impact on physical activity. Young people are less likely to walk to the store or play outside if they live in neighborhoods with high crime rates.^213^ Neighborhoods with a greater proportion of Black, Hispanic/Latino, Native American, or lower income families also tend to have higher crime rates.^224^ Individuals in neighborhoods with a high proportion of low-income families or Black, Hispanic/Latino, and Native American families also have less access to recreational facilities.^213^ In addition, a recent survey found that there was a higher likelihood of having no nearby park for children in families with incomes below the federal poverty level (OR, 1.48 [95% CI, 1.38 to 1.58]).^225^ This study also found that children who did not have a nearby park were more likely to be physically inactive (OR, 1.36 [95% CI, 1.24 to 1.48]) and have excessive screen time (OR, 1.19 [95% CI, 1.14 to 1.25]).^225^ Other features are also associated with amount of physical activity: one study found girls living in neighborhoods with more traffic lights for street crossing had higher activity levels, as did boys living on cul-de-sacs and on streets with speed bumps.^213^ A review of bike lanes found that bike lane access was associated with higher levels of physical activity in children and adolescents.^226^ Environment may affect young children too. Accelerometer data have shown than toddlers in low-income families are less likely to have at least 60 minutes per day of physical activity.^227^

This literature is primarily derived from correlational studies, where causal mechanisms cannot be clearly identified. The impact of environmental factors would be reinforced by evidence showing that diet and physical activity change when the environment is changed. Among the included studies in this review, we found no pattern indicating smaller or larger effects in studies that included intervention components that addressed barriers to participation, including social risk factors. Beyond the studies included in our review, one cluster randomized trial implemented a year-long multilevel intervention in public housing developments that included components to change the dietary and physical activity-related environments of the developments.^228^ Surveys at baseline and 1-year followup found that participants living in the intervention housing developments changed their eating and activity behaviors and body weight from baseline to 1-year followup (p’s <0.05) while participants in control group housing developments reported no changes in study outcomes. Intervention components included a weekly mobile market that provided healthy affordable groceries, weekly group walks led by lay health advisors, cooking demonstrations of culturally and economically tailored healthy meals, and resource maps of local health-related resources such as local gyms, walking parks, and places with healthful eating options.

### CQ6 What Are the Inequities in Access to or Participation in Weight Management Interventions?

Summary: The literature suggests that there are several contributing factors that could lead to downstream inequities in access to and participation in weight management interventions within the healthcare setting. There is strong evidence documenting important barriers to healthcare for families with lower income that could lead to lower participation in weight management interventions in healthcare settings. Further, differences in intervention attendance in specific groups could modify the success of weight management programs. The evidence is sparse and inconclusive regarding whether there are differences in intervention efficacy among specific groups. Finally, evidence suggests substantial inconsistency in perceptions about barriers to weight loss between patients and their providers.

One important source of inequity in access to and participation in professionally supported weight management interventions is inequities in access to healthcare in general. Health insurance coverage, and type of coverage, affects access to care. According to the 2019 National Health Interview Survey (NHIS), Hispanic/Latino children were more likely to be uninsured (7%) compared with White (4%) and Black (3%) children. In addition, White children were more likely to have private health insurance (69%) compared with Black (36%) and Hispanic (36%) children. Black (59%) and Hispanic (55%) children were more likely to have public health insurance compared with White children (23%).^229^

Insurance coverage is important because children are less likely to attend well-child visits if they lack health insurance; one study found that children without insurance attended 31 percent of recommended well-child visits, compared with 59 percent of recommended visits for children with public insurance coverage and 66 percent of recommended visits for children with private insurance coverage.^230^ Well-child visits present opportunities to measure height and weight and determine weight status. Other factors that are associated with a lower likelihood of attending well-child visits include:

- Lower income (56% of recommended visits attended among children in families <200% of the federal poverty line vs. 73% among >400% of the federal poverty line)
- Lower parental educational attainment (50% among children of parents with no high school degree vs. 68% among children of parents who had at least attended some college)
- Race (Black, 53%; Hispanic/Latino, 58%; non-Hispanic White, 68% of recommended visits)^230^

Relatedly, low income levels are also associated with a lack of a usual source of healthcare. Children in families with incomes at or below 200 percent of the federal poverty level were more likely to lack a usual source of care (4%) compared with children in families with incomes at 200 percent of the poverty level and above (2%) in 2019.”^231^

Although we found no information directly related to weight stigma and children in the U.S. healthcare setting, evidence in adults suggests that weight stigma may be another source of inequity in receiving high quality healthcare.^232^ For example, studies have found that clinicians are not immune to weight bias, and are more likely to perceive patients with high BMI as lazy, weak-willed, and noncompliant.^54^ In turn, patients with high BMI are more likely to cancel appointments or delay care.^233^ Parents’ experience with weight stigma in the healthcare setting may affect higher BMI children as well, particularly those whose parents have directly experienced stigma due to their own weight. Concern about weight-based stigma may be compounded for families in other communities who have experienced widespread discrimination, such as Black, Hispanic/Latino, and Native American communities, whose intersection of weight and race or ethnicity may put them at even higher risk of negative, stigmatizing experiences. For further discussion on the harms of weight stigma, see Contextual Question 7.

Inequities may arise in the identification of patients with high BMI as assessed in healthcare settings. While reported rates of identification of high BMI by social determinants of health among children are not available, NHANES data showed that Black American adults were less likely to report being told that they are overweight by a clinician than White Americans regardless of clinical weight status and weight-associated comorbidities, especially when their BMI was close to the 30 kg/m^2^ threshold.^234^ While this may reflect inequities in identification of higher BMI (and treatment that may flow from the diagnosis), it may also reflect clinicians’ acknowledgement of evidence that BMI may not track with adiposity as well in Black persons compared with White persons.^14,^ ^173,^ ^174^ Another study found that adult women with a BMI of 30 kg/m^2^ or higher were more than twice as likely to be diagnosed with obesity than adult men with a BMI of 30 kg/m^2^ or higher.^235^

There may also be inequities in the likelihood of being advised to lose weight among people with high BMI. Again, we did not find evidence on patterns of advice among children, but evidence among adults suggests differences based on social factors. Among a representative sample of 1,109 adult residents of New Jersey with overweight or obesity who completed a telephone survey in 2009–2010, multivariate models showed that a number of factors were associated with a lower likelihood of being advised by a healthcare provider to lose weight in the prior 12 months: lower income, Hispanic ethnicity (vs. White and Black race), lower educational attainment, lacking health insurance, male sex, and not having diabetes.^236^ A smaller study (n=282) found a very similar pattern of results among patients recruited from a primary care setting in South Carolina.^237^ As with identification of high weight, some discrepancies in advice might not reflect inequities, but instead reflect an effort to minimize burden for patients facing significant barriers to weight loss, or setting a higher priority on building trust and respecting patient preferences than on weight loss.

A survey of 5,275 teens across 10 (non-U.S.) countries and their caregivers and healthcare clinicians suggests potentially important differences between adolescents and their parents or caregivers and their healthcare clinicians concerning motivation and barriers to weight loss and healthy lifestyle.^238^ This study found that 72 percent of the teens reported feeling that obesity had a strong or very strong impact on their life, compared to 89 percent of healthcare clinicians assuming a strong or very strong impact on the teens’ lives. Caregivers tended to underestimate how worried their teenager was about their own weight and were often unaware of their teenager’s recent attempts to lose weight. As a group, the healthcare clinicians did not know the main reasons why teenagers want to lose weight. They also did not know the main reasons preventing teenagers from losing weight.

We found no information on inequities in the likelihood of being referred to or initiating behavioral weight management treatment among children. For pharmacotherapy, one study found that, among youth seen in a pediatric weight management clinic, prescription medication use was lower in Hispanic/Latino individuals compared to non-Hispanic White patients, and use of interpreters was associated with higher prescription incidence rates among non-primary English speakers.^239^ In addition, there may be unequal access to weight loss medication based on insurance status and income. Weight loss medications can be expensive; according to the GoodRx website, the monthly costs of medications approved for weight loss in children and adolescents are $198 for phentermine/topiramate, $746 for orlistat, and $1,334 to $1,345 for liraglutide and semaglutide (costs shown to be “as low as” the listed costs).^240^ These costs represent substantial barriers for lower-income households. One study found that, as of 2016, only eight states covered weight management medications for Medicaid beneficiaries: Alabama, North Dakota, South Carolina, South Dakota, Texas, Virginia, Wisconsin, and Delaware.^241^

Some reviews have examined factors that predict the likelihood of remaining in treatment and high attendance of intervention sessions in weight management studies among children and adolescents.^242,^ ^243^ One review found that lower socioeconomic status was associated with lower attendance rates, reported in six studies.^242^ This review also found four studies that examined the association of treatment attendance and psychological factors. Three of the four studies reporting such exploration did find associations with lower attendance among young people with high levels of psychological distress, bulimia, depressed mood, lower emotional regulation, higher anorexic symptoms, and poorer health-related quality of life.^242^ The other review found that Black race was associated with higher intervention dropout, and that low family income was associated with lower attendance.^243^ These findings raise questions as to whether the interventions were feasible and relevant to participants with higher dropout and lower attendance.

Finally, disparities could be exacerbated if young people across different groups and social determinants of health do not benefit equally from interventions. We found no studies examining differences in benefit for weight loss medications, but one systematic review looked at social factors as potential effect modifiers of benefit in behavioral weight management interventions for children ages 3 to 10 years.^244^ Similar to our review, they found very limited evidence on the impact of social risk factors on intervention effects. Specifically, they examined 81 studies of child weight management interventions and found that only five examined effect modification by any of the following: ethnicity, migrant status, educational status, household income, health insurance status, or other related socioeconomic measure, such as area deprivation index. Three of these studies were included in our review.^107,^ ^114,^ ^145^ Of these five studies, findings were mixed. One study found no association between socioeconomic status and intervention effect, two found larger intervention effects among children with lower income or socioeconomic status, and two studies found larger intervention effects among children whose mothers had higher education levels.

### CQ7 What Are the Harms of Stigma and Weight Bias? What Is the Extent of Weight Bias in Healthcare?

Summary: Weight stigma and bias are pervasive and harmful. Youth with high BMI commonly experience weight-based victimization, teasing, and bullying by peers, parents, or teachers. The impact of stigma is even felt in young children, prior to age 11, who already evaluate their own bodies and may feel anxious about their weight. These experiences put youth with high BMI at an increased risk for psychological distress, including low self-esteem, anxiety, depression, and suicidal ideation; substance abuse; poor social and academic outcomes; avoidance of healthcare services; and adverse physical health consequences, including increased unhealthy behaviors (e.g., binge eating) and decreased healthy behaviors (e.g., dietary, physical activity), and weight gain. Weight bias has been documented among healthcare clinicians, which can have deleterious effects on patients, leading to substandard care and avoidance of care.^245^

#### Harms of Stigma and Weight Bias

According to both the recent AAP clinical practice guideline and a 2017 AAP policy statement on stigma experienced by children and adolescents with obesity, the stigmatization of people with overweight or obesity in our society is both pervasive and harmful.^46,4^ Weight stigma is defined as the societal devaluation of individuals with overweight or obesity and is frequently associated with stereotypes suggesting that these individuals are lazy, sloppy, sedentary, unmotivated, or lacking in willpower or discipline.^43,^ ^246^ These stereotypes may lead to individuals with higher BMI being subjected to social rejection, prejudice, or overt discrimination (i.e., “anti-fat bias”).

In youth, weight stigma tends to be experienced primarily as weight-based victimization, teasing, and bullying by peers, parents, or teachers.^47^ A systematic review of attitudes toward people with high BMI among children ages 4 to 11 years found that children were primarily aware of the social impact of body size, describing experiences and awareness of abuse and isolation for children with a greater weight.^245^ This review further found that body size was seen as under the individual’s control and children attributed negative characteristics to people with high BMI. Children actively assessed their own size; many wished their bodies were different and some were anxious about their shape.

Weight stigma may be tolerated in society due to the false belief that stigma and shame can motivate people with higher BMI to lose weight.^247^ Indeed, news coverage and entertainment media overwhelmingly reinforce the message that both the cause and the solution for high BMI reside within the individual.^248^ However, rather than motivating positive change, weight stigma may put youth at an increased risk for psychological distress, including low self-esteem, anxiety, depression, and suicidal ideation; substance abuse; poor social and academic outcomes; avoidance of healthcare services; and adverse physical health consequences, including increased unhealthy behaviors (e.g., binge eating) and decreased healthy behaviors (e.g., dietary, physical activity), and weight gain.^49–51^ Furthermore, experiences of weight stigma also impact overall quality of life, especially for children and adolescents. For example, one study reported that children and adolescents with severe obesity had quality-of-life scores that were worse than age-matched children who had cancer.^249^

In the school environment, weight-based bullying is one of the most common types of bullying reported by students. As early as preschool, children attribute negative characteristics and stereotypes to peers with larger body sizes.^250,^ ^251^ By elementary school, youth with higher BMI commonly experience negative weight-based stereotypes and weight bias. For example, children with higher BMI are less likely to receive help from their peers and are more likely to be bullied than are students with lower BMI.^252,^ ^253^ Longitudinal evidence suggests that weight status significantly predicts future victimization, and youth with higher BMI are the most likely to be bullied.^254^ Recent evidence also demonstrates that the primary reason that adolescents are teased or bullied at school is because of their weight.^255^ Among racially diverse samples of adolescents, weight-based harassment was the most common form of harassment self-reported by girls and the second-most common form of harassment reported among boys.^256^ Such harassment is linked to future attempts to lose weight. A study of adolescents seeking weight loss treatment reported that 71 percent had been bullied about their weight within the past year, and more than one-third reported that the bullying had persisted for 5 years or more.^255^

Beyond bullying, there is also evidence that weight bias affects educational outcomes. Students with high BMI show no statistically significant differences in intelligence or achievement test scores, yet receive lower grades in middle school, community college, and university, after controlling for demographic variables, intelligence, personality, and well-being.^257^ And, students with high BMI are less likely to attend college, irrespective of their level of competence to do so,^258^ and get less financial support from their parents.^259^

#### Stigma and Weight Bias in Healthcare

According to a 2020 joint international consensus statement of experts, the quality of healthcare is known to be adversely affected by weight-based stigma.^50^ Prior studies have found that healthcare professionals regularly express weight stigma toward patients meeting criteria for obesity, and patients meeting criteria for obesity commonly feel stigmatized in healthcare settings.^43,^ ^50,^ ^52^ Healthcare providers may hold assumptions that body weight is entirely under their patients’ personal control. However, the belief that voluntarily improving diet and/or increasing exercise can entirely prevent or reverse obesity is not well supported by biological or clinical evidence. Furthermore, healthcare providers’ causal attributions of personal responsibility for higher BMI are associated with stronger weight bias, whereas beliefs in genetic, physiological, or environmental causes of higher BMI are associated with lower levels of weight bias.^50^ Health promotion strategies for weight loss that solely target the individual may therefore perpetuate weight stigma and also avoid addressing societal inequities that may be associated with health and weight disparities.^44^

One study reported that more than two-thirds of women meeting criteria for overweight or obesity have experienced stigma about their weight perpetuated by healthcare providers.^260^ Prior research has demonstrated that a variety of healthcare professionals (including medical students, physicians, nurses, dietitians, mental health providers, and obesity specialists) exhibit bias and prejudice toward patients with higher BMI.^54,^ ^261,^ ^262^ For example, one survey of over 4,000 medical students reported that nearly 75 percent of the students displayed implicit bias and roughly two-thirds exhibited explicit bias toward patients with overweight and obesity.^263^ Other research has demonstrated that physicians associate obesity with treatment noncompliance, decreased medication adherence, and poor self-control. They may also attribute other negative characteristics to these patients, including hostility, dishonesty, laziness, lower intelligence, and poor hygiene.^55^ These biases, in turn, can negatively affect quality of care. For example, prior research suggests that physicians spend less time in office visits with patients with higher BMI than they do with patients with a lower BMI, and are more hesitant to perform or recommend preventive health screenings, such as pelvic examinations or cancer screenings.^52^ Patients with high BMI have also reported not being provided with appropriate-sized medical equipment, such as blood pressure cuffs and patient gowns, resulting in a less hospitable medical experience that may affect the quality of the healthcare received.^50,^ ^54–56^ These experiences may result in patients with obesity being less likely to seek future preventive care, delaying treatment, or canceling appointments.^57–59,^ ^264^ For example, a systematic review of 10 studies found that adults with high BMI are more likely to report delaying or avoiding care and that women with high BMI have lower likelihood of completing colorectal cancer, breast, and cervical cancer screening.^264^

For children and adolescents, subtleties in the terminology healthcare providers utilize to discuss weight-related issues with patients or their parents can contribute to stigma and avoidance of future healthcare. Parents may experience feelings of isolation, a sense of blame for their child’s weight issues (especially for parents who themselves have experienced weight issues), and fear regarding their child’s future health.^35^ However, limited research has assessed how healthcare providers can sensitively and effectively discuss weight with patients and families.^265,^ ^266^ One national study of parents of children 2 to 18 years old examined parental perceptions of words commonly used to describe higher body weight.^267^ Parents were asked to rate whether 10 commonly used words were stigmatizing, blaming, desirable, or motivating for weight loss. The terms “fat,” “obese,” and “extremely obese” were rated as the most undesirable, stigmatizing, blaming, and least motivating. Terms like “weight” or “unhealthy weight” were rated as the most desirable and motivating for weight loss. Furthermore, parents were asked how they would respond if a healthcare provider referred to their child’s weight using stigmatizing terminology. A substantial proportion of parents indicated that they would switch doctors (35%) or avoid future medical appointments for their children (24%). These findings warrant further research and highlight the importance of how healthcare providers discuss weight-related health with their patients and with patients’ families.

Historically, medical schools and residencies have offered limited training about effective strategies for promoting positive health behavior change (e.g., motivational interviewing) and discussing weight-related issues with patients and families. Therefore, many healthcare providers report that they do not feel competent or comfortable discussing weight with their patients.^268–270^ There are various techniques for educating medical students and healthcare providers about weight stigma, including educational strategies that highlight biological, genetic, and environmental contributors to higher BMI beyond personal control; communication skills training; role-playing with virtual patients; and educational films, in addition to traditional lecture-style learning.^271–276^ More training is needed for healthcare providers and trainees to empower children and families to make healthy changes that do not contribute to weight stigma or weight bias.

In addition to recommendations surrounding sensitive handling of weight-related discussions, current National Institute for Health and Care Excellence guidelines highlight the importance of informed consent before embarking on discussions related to weight, recommending that healthcare clinicians ask the person’s permission before talking about the degree of overweight, obesity, and central adiposity.^277^ The 2017 AAP policy statement provides multiple clinical practice and advocacy recommendations for pediatricians in addressing weight stigma.^46^ These recommendations include modeling best practices for nonbiased behaviors and language;^278^ using empathetic and empowering counseling techniques (e.g., motivational interviewing); inquiring about experiences with weight stigma and bullying during clinic visits; and advocating for inclusion of training and education about weight stigma in medical schools, residency programs, and continuing medical education programs. Finally, the policy statement recommends empowering families to advocate for confronting weight stigma in both the home and school environments.

### CQ8 Are There Long-Term Harms of Weight Loss Attempts During Childhood or Adolescence?

Summary: Studies show that weight loss is typically followed by weight gain. This is consistent with physiologic adaptations in hormonal signaling and energy expenditure in response to weight loss and calorie restriction that promote weight regain. Evidence among adults suggests that multiple cycles of weight loss and regain increase the risk of higher ultimate weight and may also increase the likelihood of diabetes incidence. While studies of weight management interventions in healthcare settings among children and adolescents do not demonstrate psychosocial harms in the short term, evidence on the etiology of eating disorders suggests that dieting combined with body dissatisfaction is an important risk factor for binging- and purging-spectrum eating disorders. We found no studies of adults reflecting on the psychosocial impact of weight management interventions during childhood or adolescence, which may be an important perspective for fully understanding the psychosocial impact of weight management interventions.

The RCTs of weight interventions included in our systematic review were of short duration, and therefore could not report on potential longer-term harms such as hormonal or metabolic adaptations that may promote weight regain, disordered eating tendencies, or psychological harms that appeared in the longer term or after weight regain. Therefore, we sought information on longer-term harms from the broader literature.

#### Future Weight Gain

Weight regain after weight loss is the norm among adults with intentional weight loss, commonly overshooting baseline weight, even among participants who are well supported by thoughtfully constructed, evidence-based weight loss interventions.^279–281^ In our systematic review, we found very limited evidence on weight maintenance beyond 12 months for children and adolescents, but the limited evidence we found suggests that weight regain was common. This could be purely due to the natural history of weight to increase over time, or this effect could be exacerbated by the impact of weight loss. Indeed, prospective observational studies in adolescents and college-aged adults have found that greater weight suppression (i.e., discrepancy between current and highest weight) is associated with greater weight gain.^282–284^ Among members of the National Weight Control Registry, comprised of people who lost at least 30 pounds and maintained it for at least 1 year, researchers identified a cluster of participants who were vulnerable to weight regain, characterized as people who had struggled with weight since childhood, noting that they employed the greatest number of resources and strategies to lose and maintain weight, and reported higher levels of stress and depression.^285^

There are several mechanisms known to promote weight regain among adults who have lost weight, presumed to have conferred evolutionary advantage by improving survival when food was scarce. These mechanisms are two-fold, increasing the drive to eat and decreasing energy expenditure.^286^ Calorie restriction induces reductions in the body’s energy expenditure that exceed what would be expected based on the mechanics of reduced mass.^287^ For adults, this amounts to approximately 300 to 400 kcal/day that must be compensated for by eating even less.^286^ Physiologic compensatory reactions include changes in in the neuroendocrine system (reduced triiodothyronine, thyroxine, leptin, and thyroid stimulating hormone levels; increased reverse triiodothyronine level), autonomic systems (decreased sympathetic nervous system tone, increased parasympathetic nervous system tone), and muscles (increased efficiency). While energy expenditure is reduced, hormonal adaptations result in delayed satiation, reduced perception of amount eaten, heightened positive response to food, and reduced restraint in response to food.^286^ Mathematical models have estimated that, for each kilogram of lost weight, calorie expenditure decreases by approximately 25 kcal/day and appetite increases by approximately 95 kcal/day above baseline levels prior to weight loss.^288^ Collectively, these findings explain why weight regain is common among adults, and suggest that there may be limits on the amount of weight loss that individuals can sustain. We did not find studies examining these compensatory mechanisms in children and adolescents.

#### Impact of Weight Regain and Weight Cycling

If weight regain is benign, cycles of weight loss and weight regain would not be problematic. We found no research on the physiologic impacts of repeated cycles of weight loss followed by weight gain in children and adolescents. The evidence in adults is mixed but suggests that these cycles may lead to greater ultimate weight gain. Eleven of 19 studies in a systematic review found that a history of weight cycling was correlated with increased body fat and central adiposity, and four of eight studies found that weight cycling increased the likelihood of future weight gain.^289^ These studies were observational and often cross-sectional, however, and there may be confounding factors behind these associations and cannot demonstrate causality. A study of 4,129 twins found that twins who had a higher number of episodes of intentional weight loss (of ≥5 kg) gained more weight than their paired twin over the course of 25 years. The effect was smaller for monozygotic twins (0.4 kg/m^2^) than dizygotic twins (2.2 kg/m^2^).^290^

We were unable to find information on the association between weight cycling and glucose metabolism in children or adolescents. The systematic review of weight cycling in adults also looked at its impact on diabetes and glucose parameters.^289^ This review found that most included studies (13/17 [76%]) showed no association between weight cycling and blood glucose measures. However, four of eight studies reporting on type 2 diabetes incidence found an increased risk of type 2 diabetes with higher levels of weight cycling. Although not all findings were statistically significant, the best available evidence of these studies (the large prospective studies and a prospective analysis of the Diabetes Prevention Project participants) consistently found higher type 2 diabetes incidence associated with more weight cycling (Table 22). None of the studies found that weight cycling was associated with any improved weight or cardiometabolic outcome at followup. Again, however, the observational nature of these studies limits our understanding of whether weight cycling is causing the increased risk or if there are other confounding factors.

Table 22 The Association Between Weight Cycling and Type 2 Diabetes Incidence Reported in Mackie et al Review^289^

Study | N | Effect (95% CI) (higher number corresponds to increased risk of type 2 diabetes)
Nurses’ Health Study II^345^ | 46,634 women | RR, 1.11 (95% CI, 0.89 to 1.37) for mild weight cycling;; RR, 1.39 (95% CI, 0.90 to 2.13) for severe weight cycling
Iowa Women’s Health Study^346^ | 33,834 women | RR, 1.72 (95% CI, 1.29 to 2.30)
Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study^347^ | 20,952 male smokers | RR, 1.64 (95% CI, 1.24 to 2.17)
European Prospective Investigation into Cancer and Nutrition^348^ | 26,010 women | HR, 1.36 (95% CI, 1.09 to 1.68)
Framingham Heart Study^349^ | 1476 | Crude HR = 1.6 (95% CI, 1.2 to 2.1), but no effect after adjustment for BMI (details NR)
Diabetes Prevention Project^350^ | 1000 | HR, 1.33 (95% CI, 1.12 to 1.58)
“Obesity Day” participant cross-sectional survey^351^ | 914 | No association (details NR)
Longitudinal study of Pima Indians^352^ | 584 | IRR comparing 75th percentile vs. 25th percentile in weight fluctuation, 1.03 (95% CI, 0.85 to 1.25).

Abbreviations: BMI = Body mass index; CI = Confidence interval; HR = Hazard ratio; IRR = incidence rate ratio; NR = Not reported; RR = Relative risk.

#### Psychosocial Impact of Intentional Weight Loss

We found very limited evidence on young people’s experiences with weight loss or weight management programs beyond the initial period of involvement, typically lasting 6 to 24 months. Psychosocial impact immediately after weight management interventions generally indicated no increased risk of psychosocial harm in the trials included in this review. A separate longitudinal cohort study among 1,291 children and adolescents who participated in a multidisciplinary childhood obesity treatment program in clinical practice in Denmark found improvements in the domains of quality of life, mood, appetite, and body image satisfaction after a median of 14 months of participation.^291^ A systematic review of studies of treatment-seeking young people participating in weight management programs confirms these findings, where most included studies followed participants for 6 to 24 months.^292^

However, there may be a subset of young people who are vulnerable to eating disorders. A number of studies have indicated that self-reported efforts to lose weight, not necessarily associated with a formal program, are associated with future eating disorders. Prospective data from three eating disorder prevention trials of young women with body dissatisfaction (mean age, 18 years) followed for 3 years found that a history of weight loss efforts was associated with future onset of binge- and purge-spectrum eating disorders.^197^ A history of weight loss efforts was the strongest predictor of purging disorder, and negative affect and strong desire for thinness amplified this association.^293^ Further, a separate study found that weight suppression predicted future onset of anorexia nervosa (OR, 1.36 [95% CI, 1.03 to 1.80]), bulimia nervosa (OR, 1.34 [95% CI, 1.11 to 1.62]), and purging disorder (OR, 1.46 [95% CI, 1.23 to 1.74]).^294^ In this sample, women with the largest difference between their highest past weight and current weight were at greatest risk of eating disorders. Another study of people with binge eating disorder found that 65 percent of participants reported that dieting preceded binge eating.^295^ While formal, sensitively delivered weight management programs appear not to show associations with disordered eating in the short term, and may even reduce it with interpersonal therapy as a treatment modality,^143,^ ^144^ it is unknown whether such experiences would inoculate young people from developing eating disorders who continue to receive messages that they should lose weight over many years.

Psychosocial impacts may become more pronounced over the years, as people continue to struggle with their weight in the longer term. We found no qualitative studies of adults reflecting on their experiences with weight management programs during their childhood or adolescence, but anecdotal first-person accounts among people with lived experience suggest that weight loss interventions during childhood, in the context of the larger culture of weight stigma, were damaging to their psychosocial health.

Further research is needed to understand the longer-term psychosocial impact of weight management interventions for children and adolescents.