# Chapter 2 Methods

## Scope and Purpose

This systematic review updates a review to support the 2017 USPSTF recommendation on screening and interventions for overweight and obesity in children and adolescents.^1,^ ^94^ While most of the scope from the prior review was maintained, there are a few notable changes that were made for consistency with the USPSTF systematic reviews on obesity in adult populations and behavioral counseling in adults with cardiovascular risk factors.^21,^ ^95^ First, this update addresses weight management interventions but does not examine the evidence related to screening. Second, the medications that are in scope for the current review have changed since the previous review. Two glucagon-like peptide agonists (liraglutide and semaglutide) and combination phentermine/topiramate have been approved for use in youth age 12 years or older with obesity since the previous review and are included in this update; metformin was excluded from the current review because it is not FDA-approved for a weight loss indication in any population. Third, a selected set of behavioral physical activity and dietary outcomes were newly included for systematic review.

## Key Questions and Analytic Framework

We followed USPSTF procedures and methods to define study inclusion and exclusion criteria (Appendix A Table 1) and developed an Analytic Framework (Figure 3) and four KQs to guide the literature search, data abstraction, and data synthesis.

Figure 3 Analytic Framework

Abbreviations: BMI = Body mass index; KQ = Key Question; MET = Metabolic equivalent; Mins = Minutes; MVPA = Moderate to vigorous physical activity; PA = Physical activity.

Figure 3 is an analytic framework that depicts four Key Questions to be addressed in the systematic review. The figure illustrates how primary care–relevant behavioral and/or pharmacotherapy weight management interventions for children and adolescents with higher body mass index (BMI) (e.g., >85th percentile for age and sex) improve health outcomes (Key Question 1), and whether primary care–relevant behavioral and/or pharmacotherapy weight management interventions for children and adolescents with higher BMI affect weight outcomes or cardiometabolic outcomes (Key Question 2). Additionally, the figure addresses whether primary care–relevant behavioral and/or pharmacotherapy weight management interventions for children and adolescents with higher BMI improve behavioral outcomes (Key Question 3), and if weight management interventions for children and adolescents may result in any harms (Key Question 4).

1. Do primary care–relevant behavioral, pharmacotherapy, or combined weight management interventions for children and adolescents with higher BMI improve health outcomes?
2. Do primary care–relevant behavioral, pharmacotherapy, or combined weight management interventions for children and adolescents with higher BMI affect weight outcomes or cardiometabolic outcomes?
3. Do primary care–relevant behavioral, pharmacotherapy, or combined weight management interventions for children and adolescents with higher BMI improve behavioral outcomes?
4. Are there harms associated with weight management interventions for children and adolescents?

## Data Sources and Searches

We considered all studies from the previous review on this topic for inclusion in the current review and performed a comprehensive search for new literature. We searched MEDLINE via Ovid, PsycINFO via Ovid, and the Cochrane Central Registry of Controlled Trials for relevant studies published between January 1, 2016, and January 12, 2023, building upon the most recent full search for this topic. For the MEDLINE search, we used a modified Cochrane sensitivity- and precision-maximizing RCT filter for identifying randomized trials.^96,^ ^97^ A research librarian developed and executed the search, which was peer-reviewed by a second research librarian (Appendix A). All searches were limited to articles published in English. Additionally, due to updates in the eligibility criteria for control groups and study settings, we performed a targeted review of studies that were previously excluded for these reasons. Further, previously included studies were evaluated to determine whether they reported behavioral outcomes, which were a newly included outcome in this review.

In addition to these database searches, we also examined the reference lists of previously published reviews, meta-analyses, and primary studies to identify potential studies for inclusion. We supplemented our searches with news and table-of-content alerts such as those produced by the USPSTF Scientific Resource Center LitWatch activity.^20^ We conducted ongoing surveillance for relevant literature through August 2, 2023. One new study was identified; however, it did not substantively change the review’s interpretation of findings or conclusions and is not addressed further.^98^ We managed literature search results using version X9 of Endnote® (Thomson Reuters, New York, NY), a bibliographic management software database.

## Study Selection

Detailed inclusion and exclusion criteria were developed to guide study selection (Appendix A Table 1). Two reviewers independently reviewed the title and abstract of all identified articles using DistillerSR (Evidence Partners, Ottawa, Canada) to determine if the study met our a priori inclusion and exclusion criteria for aim, population, intervention, comparator, outcomes, setting, and study design. Two reviewers then independently evaluated the full-text article(s) of all potentially relevant studies against the complete inclusion and exclusion criteria. Disagreements about the abstract and/or full-text review were resolved by discussion. A list of included studies is available in Appendix B and excluded studies can be found in Appendix C.

### Study Design, Population, and Aim

For all KQs we included RCTs, including cluster randomized trials, of weight management interventions in children ages 2 to18 years who were identified as having a higher BMI, as defined by the study. The inclusion criteria for individual studies most commonly were children with BMI at or above the 85th or 95th percentile for age and sex; however, other definitions of higher BMI were also eligible, such as those based on the percent of ideal weight, or with cutoffs other than the 85th or 95th percentiles. We did require overall cutoffs to be no lower than the 75th percentile. We also included trials of weight maintenance in youth who had previously participated in a weight management program. Studies that were limited to young people with an eating disorder, who were pregnant or postpartum, had developmental disabilities, chronic medical conditions, or who were taking medications that may affect weight were excluded. Included trials had to have a primary aim of promoting weight reduction or stabilization, or maintenance of previous weight reduction or stabilization. Thus, studies with a primary aim of preventing overweight in youth with BMI below the overweight range were excluded, as were studies designed to improve diet or physical activity without a weight management aim. Studies included for KQ1 to KQ3 had to report weight or adiposity change at least 6 months following the start of the intervention to be included. For KQ4, evaluating the potential harms of weight management interventions, we included large cohort or case-control studies examining harms of medications in addition to RCTs. No minimum followup for KQ4 was required.

### Interventions

We included behavioral counseling interventions, health system–level interventions (e.g., stepped care or collaborative care), pharmacotherapy approved by the FDA for long-term weight loss/management in children or adolescents (i.e., orlistat, liraglutide, semaglutide, phentermine/topiramate), and combinations of these interventions. The original research plan did not include phentermine/topiramate or semaglutide; however, these medications received FDA approval during the conduct of this review and were added as an included intervention. We excluded studies with components that could not be implemented in typical primary care settings, such as changes to the built environment, and interventions providing most or all the participants’ food. We excluded studies of surgical procedures, medications not approved by the FDA for long-term weight loss in children or adolescents, complementary and alternative treatments, and dietary supplements.

### Settings

We included interventions that were either conducted in a primary care setting, feasible in “usual” primary care, or referrable from primary care. This was operationalized by requiring that studies were either conducted in or recruited from a healthcare system. Interventions that relied upon existing social networks that could not be replicated in primary care, such as schools or churches, were excluded. Moreover, for the greatest applicability to U.S.-based primary care practice, we included only studies from countries classified as “very high” on the 2019 Human Development Index.^99^

### Comparators

For studies of behavioral counseling interventions, the following control groups were eligible: no intervention (e.g., wait list, usual care, assessment only), minimal intervention (e.g., one to two sessions delivering information typically in a primary care setting, generic print materials, links to widely available website), or attention controls (e.g., similar format and contact time but different content). We excluded studies that evaluated the comparative effectiveness of two active interventions unless there was also a true control group as described above. We considered control groups with the following components too intensive to be considered usual care and these were excluded for comparative effectiveness: personalized prescription for weight loss and exercise based on standardized dietary assessment; homework, such as study-provided self-help workbooks with a weight loss focus; or more than two annual intervention contacts, unless the content was not related to weight loss. For studies of pharmacotherapy, we included both placebo-controlled studies and studies with non-medication control groups; ancillary behavioral intervention components were allowed as long as they were consistent across groups.

### Outcomes

We did not abstract any outcome with less than 60 percent followup; studies in which followup for all outcomes was below 60 percent were excluded for quality as described further below. A weight-related outcome reported at least 6 months following the start of the study was required to be included for KQ1 to KQ3. In addition to weight-related outcomes, we also extracted health outcomes, cardiometabolic measures, selected diet and physical activity outcomes, and harms. Health outcomes included mortality, medical events or conditions that may be associated with high weight (e.g., cardiovascular events; onset or resolution of asthma, sleep apnea, or orthopedic pain), quality of life, functioning, and depression.

Intermediate outcomes included weight or adiposity, cardiometabolic measures (i.e., blood pressure, lipid levels, measures of glucose metabolism), measures of liver dysfunction (e.g., nonalcoholic fatty liver disease), and physical fitness. Acceptable weight-related measures included weight (kilograms or pounds), age- and sex-normative weight (BMI percentile, percent of the median BMI, percent of the 95th percentile BMI, or zBMI/BMI-SDS for age and sex), relative weight (BMI or percent overweight), total adiposity (e.g., dual-energy x-ray absorptiometry, underwater weight, or comparable), or other similar measures. The z-score for BMI was considered a secondary weight measure because of limitations of this measure above the 97th percentile.^100^

A focused set of behavioral outcomes were newly included in this updated review and included dietary pattern score, minutes per week of moderate-to-vigorous physical activity or metabolic-equivalent (MET)-minutes per week, percent meeting physical activity goals, and sedentary behavior or screen time. We acknowledge that there are numerous individual dietary intake components that are reported in the literature (e.g., fruits and vegetables, sugar, fiber). Our selection of a dietary pattern score as the sole included dietary outcome was based on feasibility as well as the stated emphasis in the 2020 to 2025 Dietary Guidelines for Americans on the importance of a healthy dietary pattern as a whole rather than on individual nutrients or foods in isolation.^72^

Adverse events included treatment-related harms and discontinuation of medication due to adverse effects at any time point during intervention. We also included harms associated with labeling; stigma or increased body image concerns or negative mental health effects; negative impacts on provider-patient relationship (e.g., care avoidance or dissatisfaction with care); unhealthy weight management efforts (e.g., using laxatives or self-induced vomiting) or eating patterns (excessive fasting, overly restrictive eating, or binging); suppressed growth; exercise-induced injury; other serious treatment-related harms at any time after initiation of intervention (i.e., death or medical issue requiring hospitalization or urgent medical treatment), or other treatment-related harms reported in trials meeting inclusion criteria for intermediate or health outcomes. For self-esteem and body satisfaction outcomes, we acknowledge that these are problematic because improvement would represent a benefit and decline would represent a harm. We captured these under KQ4 for consistency but acknowledge this complexity.

## Quality Assessment and Data Abstraction

Two reviewers independently assessed the methodological quality of each study using predefined study-design specific criteria developed by the USPSTF.^20^ Disagreements about quality were resolved by discussion. Each study was given a final quality rating of good, fair, or poor. Good-quality studies were those that met nearly all of the specified quality criteria (e.g., comparable groups were assembled initially and maintained throughout the study, followup was approximately ≥85%, conservative data substitution methods were used in cases of missing data, no evidence of selective outcome or analysis reporting) (Appendix A Table 2). Fair-quality studies did not meet these criteria but did not have serious threats to their internal validity related to the design or execution of the study. Studies we rated as poor quality had several important limitations, including at least one of the following risks of bias: very high attrition (generally >40%), differential attrition between intervention arms (generally >20%); lack of baseline comparability between groups without adjustment; methods for ascertainment of weight outcomes were unclear or differed between groups (e.g., self-report or objective measurement and not reported by group); or issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting, inappropriate exclusion of participants from analyses, and questionable validity of randomization and allocation concealment procedures). Studies rated as poor quality were excluded from the review. In studies of pharmacotherapy, most dropout is due to adverse events or lack of effectiveness, and not loss to followup. We allowed studies with more than 40 percent attrition to be rated as fair quality if they used adequate data substitution methods with sensitivity analyses using different methods (e.g., baseline observation carried forward, multiple imputation, estimation from a mixed-effects model using all available followup data). Because this review was an update of our own work, we did not repeat critical appraisal of the original studies through full dual-quality rating; rather, we confirmed the quality rating during data abstraction. One previously included study was excluded in the update because followup for the weight-related outcome was less than 60 percent.^101^

For all included studies, one reviewer extracted key elements into standardized abstraction forms in Microsoft Access® 2010 (Microsoft, Redmond, WA). A second reviewer checked the data for accuracy. For each study, we abstracted general characteristics of the study (e.g., author, year, study design), clinical and demographic characteristics of the sample and setting (e.g., age, race and ethnicity, baseline clinical characteristics, setting, country), analytic methods, and results. For intervention characteristics, we abstracted detailed information about specific components: duration, number, and length of sessions; group or individual delivery of counseling; mode of delivery (i.e., in person, telephone, electronic, or print); providers and provider training; setting; and adherence to the intervention. We abstracted the number of sessions and length of sessions according to what was planned (and not necessarily what was implemented).

## Data Synthesis and Analysis

Evidence was synthesized separately for behavioral interventions and for each medication. Tables were developed to show study, population, intervention characteristics, and outcomes for each of these interventions. We examined population characteristics to understand whether the evidence included traditionally marginalized or underrepresented groups who have a higher prevalence of higher BMI, such as Black, Latino/Hispanic, and Native American/Alaska Native populations, and those with low income. We also sought to understand whether interventions were effective in these populations, or if interventions tailored to these populations may have improved effectiveness.

We only conducted meta-analysis for behavioral interventions, since only one to three medication trials were included for all KQs. Among behavioral interventions, random-effects meta-analysis was conducted using the restricted maximum likelihood method with the Knapp-Hartung correction for all outcomes with comparable measures and sufficient evidence for pooling.^102,^ ^103^ Study-reported between-group effects were used in the meta-analysis if they were reported, with adjusted analyses selected over unadjusted results. Crude between-group effect estimates were calculated if they were not reported. The followup time point closest to 12 months was used in the meta-analysis if multiple time points were reported. Results that were not included in meta-analyses are presented in Appendix D. If a trial had more than one active intervention arm, we plotted the arm with the most comprehensive or highest contact (all denoted as Intervention Group 1 [IG1]). Results for other intervention arms are also presented in Appendix D. For continuous measures, we preferentially analyzed between-group difference in change from baseline if available and substituted between-group post-test differences if differences in change were not available. In both cases, a negative number represents either greater weight loss or smaller weight gain in the intervention group. For dichotomous outcomes, crude risk ratios comparing post-treatment proportions were calculated if they were not reported by the studies. Egger’s test was used to examine the risk of small study effects for the behavioral weight loss trials, both with and without estimated contact hours in the model to account for between-study heterogeneity due to contact hours.

The primary outcome for this review was BMI, selected because it was the most widely-reported outcome among those recommended for measuring weight outcomes in children.^100^ Secondary weight- or adiposity-related outcomes are weight, BMI percentile, zBMI, proportion exceeding BMI cutoffs, waist circumference, and percent body fat. BMI was used to explore effect modification and for sensitivity analysis. A sensitivity analysis was conducted to determine whether effects would have been similar using the longest followup, rather than the followup closest to 12 months. This approach had minimal effect on the results and is not discussed further. We used meta-regression to explore whether effect size was associated with the following study or intervention characteristics:

- Publication year
- Study quality rating
- Whether the study was conducted in the United States
- Months’ followup
- Months between the end of treatment and the followup assessment
- Whether the study was limited to young people with higher weight but who did not meet BMI criteria for obesity (e.g., above the 75th or 85th percentile but below the 95th percentile for age and sex)
- Contact dose (number of sessions, estimated contact hours, and duration of the intervention)
- Setting (primary care vs. other setting)
- Whether group sessions were provided
- Whether the intervention included physical activity sessions during the intervention sessions (vs. encouragement and instruction for physical activity at home)

Hours of contact were estimated based on number of planned treatment sessions and the length of each session, or average contact time if that was reported. If no information on session length was provided, we estimated only the broad category of contact hours: 0 to 5.9 hours, 6 to 25.9 hours, 26 to 51.9 hours, or 52 or more hours. If session length was provided for some parts of the intervention but not others, we used a priori–developed assumptions to estimate contact hours; for example, assigning phone sessions described as “brief” to be 5 minutes in length, phone sessions not described as “brief” as 15 minutes, individual sessions as 30 minutes, and group sessions as 60 minutes. Concurrent parent and child sessions were counted separately, so concurrent 1-hour parent and child sessions were calculated as 2 hours of contact. Our primary analyses present studies stratified by whether the intervention involved fewer than 26 contact hours versus 26 or more contact hours. This cutpoint was based both on the logic that this corresponds to weekly 1-hour meetings for 6 months, and because the current USPSTF recommendation recommends referral to weight management interventions that include at least 26 hours of contact. Estimated hours of contact in the first 12 months only are shown on the forest plots because the primary outcome was weight change at 12 months (or closest followup available).

We used Stata 16.1 (StataCorp LLC, College Station, TX). All significance testing was 2-sided, and results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach,^104^ which is based on a system developed by the Grading of Recommendations Assessment,^105^ Development and Evaluation (GRADE) Working Group. Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

The domain of consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). The domain of precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body-of-evidence limitations field highlights important restrictions in answering the overall KQ (e.g., evidence of reporting bias, lack of replication of interventions, nonreporting of outcomes important to patients).

At least two independent reviewers rated the overall strength of evidence for each intervention type. We resolved discrepancies through consensus discussion with the full review team, consulting with outside reviewers as needed. We graded the overall strength of evidence as high, moderate, low, or insufficient. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit an estimate of an effect.

## Contextual Questions

In addition to the systematically reviewed questions (KQs 1–4), we also addressed contextual questions (CQs) to aid with the broader interpretation of the evidence. CQs are important considerations that may not be readily answerable from the available RCT literature. Eight CQs were prespecified in our research plan:

1. What is the prevalence of BMI assessment in children and adolescents in primary care practice? Does the prevalence of BMI assessment vary by age?
2. How well does BMI predict adiposity and overall health? Does the predictive accuracy of BMI differ by race or ethnicity?
3. Are there harms associated with diagnosing children and adolescents as being overweight or having obesity in the healthcare setting (e.g., harms associated with labeling)? Does the risk of harm differ across racial and ethnic groups or contribute to health inequities?
4. What level of weight or relative weight decrease in children or adolescents with obesity reduces the likelihood of obesity in adulthood or health outcomes associated with obesity?
5. What are the inequities in factors that support healthy eating and physical activity in youth (e.g., food insecurity, financial security, or neighborhood-level factors)?
6. What are the inequities in access to or participation in weight management interventions?
7. What are the harms of stigma and weight bias? What is the extent of weight bias in healthcare?
8. Are there long-term harms of weight loss attempts during childhood or adolescence?

CQs are not systematically reviewed. Evidence for CQs was identified based on literature retrieved for the systematic search for KQs as well as targeted searches and scanning bibliographies of relevant articles. A best evidence approach was used to identify most recent, applicable, and robust evidence. CQs are available in the Results section under “Contextual Findings.”

## Expert Review and Public Comment

The draft Research Plan was posted on the USPSTF website from February 10, 2022, to March 9, 2022. Most comments received by the USPSTF pertained to which outcomes should be included. Based on public comments and key informant interviews, the USPSTF removed the outcomes of self-esteem/body satisfaction (due to cultural differences in beauty and body standards that make these data difficult to interpret at the study level), BMI z-score (due to lack of sensitivity to change at the highest BMI levels; however, the USPSTF will accept this outcome if it is the only weight outcome reported by a study), and sugar-sweetened beverage consumption (to maintain the focus on overall diet pattern). The USPSTF added outcomes reflecting sedentary behavior, including both sedentary time and screen time. Other changes that were made based on public comments include: adding text to clarify that a BMI exceeding the 85th percentile for age and sex serves as an acceptable definition of higher BMI; allowing weight-neutral healthy lifestyle counseling as a control group; and including studies with 6 to 11 months of followup. A final Research Plan was posted on the USPSTF website on June 23, 2022.

The draft version of this report was reviewed by invited experts and individuals at USPSTF federal partner agencies. Experts were selected based on their expertise with both methodologic and content aspects of the review and were selected to obtain diverse informed perspectives. The revised draft of the report was posted for public comment on the USPSTF Website from December 12, 2023, through January 17, 2024. The draft received numerous public comments, leading to minor editorial changes but no updates to the included evidence or the report conclusions.

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and KQs and to resolve issues around scope for the final evidence synthesis.

AHRQ staff provided oversight for the project, coordinated the systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.