# Chapter 1 Introduction

## Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2017 recommendation on Screening for Obesity in Children and Adolescents.^1^ The systematic review supporting the 2017 recommendation sought evidence on the benefits and harms of both screening as well as weight management interventions. Consistent with the parallel topic in adults,^2^ the current review does not address questions related to screening for high weight. No evidence was found on the benefits or harms of screening in the prior review, and future studies are unlikely, since height and weight measurement are the standard of care for children and adolescents, making it difficult to create a non-screened comparison group. The current review focuses exclusively on updated evidence for the benefits and harms of weight management interventions (Results Chapter) together with important contextual information to aid in the interpretation of the evidence (Contextual Findings Chapter).

## Terminology and Measures

Childhood and adolescent weight status is usually determined by the body mass index (BMI), which is calculated by dividing weight in kilograms by the square of height in meters. For children and adolescents in the United States, BMI is measured relative to other children of the same age and sex using the Centers for Disease Control and Prevention (CDC) 2000 growth charts.^3^ Children and adolescents weight are categorized as having “overweight” when their BMI is between the 85th and 95th percentile, and as having “obesity” when their BMI is at or above the 95th percentile on these charts.^3^ Additional stratifications for “severe obesity” have also been proposed.^4^ These percentiles are calculated from CDC growth charts, which were derived from U.S. population-based survey data collected between the 1960s and 1990s, with the primary aim to monitor children’s growth in the clinical setting.^5,^ ^6^ In children and adolescents, a BMI standard deviation score (BMI-SDS) or a z-score for BMI (zBMI) can also be calculated, showing the BMI in terms of standard deviation units on a normal or z-distribution. So, a zBMI or BMI-SDS of 1.0 would indicate one standard deviation above the median BMI for age and sex. The CDC has recently published new methods for zBMI calculation to improve the performance of zBMI for children with weight above the 98th percentile for age and sex.^7^

We will use the general term “high BMI” when referring to people considered to be above “normal” or “healthy” body weight according to CDC standards, in keeping with the preferences of people with lived experience,^8^ and will refer to specific BMI cutoffs whenever possible. For example, “at or above the 95th percentile for age and sex” rather than “obese” and “85th to 95th percentile for age and sex” rather than “overweight.”^3^ These percentile cutoffs represent statistical definitions rather than empirical risk-based criteria,^6^ and definitions have changed over time. For example, prior to 2007, a BMI at or above the 95th percentile in children and adolescents was considered “overweight,” where it was recommended that this screening BMI value would generate an in-depth medical assessment; BMIs in the 85th to 95th percentile were defined as “at risk for overweight.”^9,^ ^10^ Alternative definitions and reference criteria have been developed and are used internationally, such as the International Obesity Task Force (IOTF) standards, which use six worldwide datasets to construct BMI percentile curves that identify cutoff values corresponding to the BMI thresholds of 25 kg/m^2^ and 30 kg/m^2^ used in adult populations.^11^

Being comprised only of height and weight, BMI is a crude measure that does not account for different distributions in fat or fat-free mass.^12^ On the other hand, the convenience of BMI measurement makes it suitable for use in a variety of settings, and BMI is the accepted clinical standard measure of excess fat in the United States^13^ (see Contextual Question 1, Contextual Findings Chapter). While data show that the BMI is an imperfect measure of adiposity and is not an equivalent measure of adiposity across racial and ethnic groups, most children with BMI-for-age at or above the 95th percentile have high adiposity, and few children with BMI-for-age less than the 85th percentile have high adiposity. Misclassification as having high body fat is fairly common among those with BMI-for-age between the 85th and 95th percentile.^12–14^ We found no widely-accepted threshold of body fat that confers adverse impact on health, however. (See Contextual Question 2, Contextual Findings Chapter).

## Prevalence

National Health and Nutrition Examination Survey (NHANES) data from 2017 to 2020 (pre-pandemic) show that 19.7 percent of children and adolescents in the United States have a BMI at or above the 95th percentile for age and sex, based on the 2000 CDC growth charts.^15^ There are statistically significant differences in the prevalence of BMI at or above the 95th percentile by age, race and ethnicity, and socioeconomic status (Figure 1). The prevalence of high BMI increases with age, decreases with higher income, and is the highest in Hispanic/Latino and non-Hispanic Black children and adolescents. Differences in high BMI prevalence by sex are significant only for the 6- to 11-year-old age group, where prevalence is higher in boys than girls (22.9% vs. 18.5%). NHANES data are also available for the prevalence of BMI between the 85th and 95th percentile from the 2017–2018 survey, which was estimated to be 16.1 percent among children 2 to 19 years of age.^16^

Figure 1 Prevalence of Children and Adolescents Ages 2–19 years With BMI ≥95th Percentile for Age and Sex, by Demographic Characteristics: United States, 2017 to March 2020 (NHANES)^15^

Abbreviations: BMI = body mass index; NHANES = National Health and Nutrition Examination Survey; % of FPL = percent of the federal poverty line.

*Differences in high BMI prevalence by sex are significant for the 6- to 11-year-old age group, where prevalence is higher in boys than girls (22.9% vs 18.5%).

Figure 1 shows the prevalence of children and adolescents aged 2-19 years with BMI ?95th percentile for age and sex, by demographic characteristics in the United States, 2017 to March 2020 (using NHANES).

Overall, there has been an upward trend over time in the prevalence of BMI at or above the 95th percentile among children and adolescents in the United States, with some periodic variation in trends in particular age groups (Figure 2).

Figure 2 Trends in Prevalence of BMI ≥95th Percentile for Age and Sex Among Children and Adolescents Ages 2–19 Years, by Age: United States, 1963–1965 Through 2017–2018

Abbreviation: BMI = body mass index.

Figure 2 shows trends in prevalence of BMI ?95th percentile for age and sex among children and adolescents aged 2-19 years, by age in the United States, 1963-1965 through 2017-2018.

Source: National Center for Health Statistics, National Health Examination Surveys II (ages 6–11), III (ages 12–17); and National Health and Nutrition Examination Surveys (NHANES) I–III, and NHANES 1999–2000, 2001–2002, 2003–2004, 2005–2006, 2007–2008, 2009–2010, 2011–2012, 2013–2014, 2015–2016, and 2017–2018.

Data from the Youth Risk Factor Behavior Surveillance System show that 48.3 percent of U.S.-based ninth to 12th graders were trying to lose weight in 2019, with dramatically higher rates among females (59.8%) than males (37.0%).^17^ The proportion of high school students attempting to lose weight has increased since these data began being monitored in 1991. This figure is similar to the proportion of adults age 20 years or older attempting weight loss, estimated at 49.1 percent between 2013 and 2016.^18^ Investigators have observed concurrent parallel increases in both measured BMI and weight loss attempts among adults.^19^

## Association of Weight Loss and BMI With Health Outcomes

According to USPSTF methodology, health outcomes are symptoms, functional levels, and conditions that patients can feel or experience and are defined by measures of physical or psychological well-being, such as cardiovascular events, pain, breathing difficulties, quality of life, and mortality.^20^ There are no randomized, controlled trials (RCTs) of weight loss interventions in children and adolescents with sufficient followup length to provide direct evidence about whether weight loss is potentially associated with outcomes such as cardiovascular disease (CVD) events or mortality. In the absence of evidence in children and adolescents, studies in adults may inform the evidence landscape. However, evidence about the association between weight loss and health outcomes from RCTs in adults are inconclusive and limited by short followup and low event rates.^21,^ ^22^ Given the lack of robust RCT evidence in either pediatric or adult populations, observational literature has been used to assess the relationship between BMI and health outcomes more broadly.

Overall, the literature assessing the relationship between BMI and health outcomes is difficult to interpret because of the complex etiology of adverse health outcomes, a substantial potential for confounding, and long periods of followup required for evaluation. Longitudinal data show that higher BMI in childhood is associated with early CVD mortality, early cancer mortality, diabetes, and dyslipidemia in adulthood.^23–26^ However, it is generally unclear from these epidemiological data whether cardiometabolic risk factors in childhood have a direct impact on long-term health, or whether risk is elevated primarily because risk factors often track into adulthood.^23^ Overall, cohort studies suggest that BMI tracking is moderate from childhood to adulthood but high for adolescence to adulthood.^27^ At the same time, there is a substantial proportion of individuals for whom higher BMI emerges in adulthood.^27,^ ^28^

Association data from cohorts of adults have even more uncertain findings with respect to the relationship between BMI and mortality. While a BMI of 35 kg/m^2^ or higher is consistently associated with increased overall mortality risk, associations in intermediate BMI ranges differ in prominent analyses and are sensitive to analytic procedures.^29–31^ In the adult literature, evidence suggests that lifestyle behaviors and cardiorespiratory fitness play an important role in the association between BMI and mortality.^32,^ ^33^ When these factors are taken into account, behavior appears to modify the association and vastly mitigates or eliminates the role of higher BMI in findings of higher mortality risk. Unfortunately, all of these data are from studies of associations, so they cannot demonstrate that weight loss will result in similar effects. A detailed discussion of the association of BMI with health outcomes is available in Contextual Question 2, Contextual Findings Chapter.

## Harms Associated With Diagnosing Children as Being Overweight or Having Obesity and the Harms of Weight Stigma and Weight Bias

Labeling children and adolescents as having overweight or obesity is associated with poorer psychosocial outcomes, higher rates of unhealthy weight control behaviors, and appears to have either no impact on weight or is associated with greater future weight gain, at least in the context of school and the home.^34–44^ Weight labeling may undermine health-promoting behaviors associated with body satisfaction among youth with higher BMI, as under-perception of weight is associated with positive outcomes such as lower future weight gain, fewer depressive symptoms, and improved blood pressure.^44,^ ^45^ A detailed discussion of harms associated with diagnosis is available in Contextual Question 3, Contextual Findings Chapter.

Weight stigma is pervasive and harmful.^46^ Youth with high BMI commonly experience weight-based victimization, teasing, and bullying by peers, parents, or teachers.^47^ For example, in one study of treatment-seeking youth with high BMI, 73 percent reported weight-based teasing.^48^ These experiences put youth at an increased risk for psychological distress, even after controlling for BMI, including low self-esteem, anxiety, depression, and suicidal ideation; substance abuse; poor social and academic outcomes; avoidance of healthcare services; and adverse physical health consequences, including increased unhealthy behaviors (e.g., binge eating) and decreased healthy behaviors (e.g., dietary, physical activity), and weight gain.^49–51^ Weight bias has been documented among healthcare clinicians, which can have deleterious effects on patients, leading to substandard care and avoidance of care.^43,^ ^50,^ ^52–59^ A detailed discussion of harms of stigma and weight bias is available in Contextual Question 7, Contextual Findings Chapter.

## Etiology and Risk Factors

Childhood BMI has highly complex, interacting determinants that include individual, family, school, community, societal, and structural components.^60–64^ Further, genetic components contributing to high BMI are well documented.^65,^ ^66^ Within the individual, complex metabolic and hormonal systems are working to promote homeostasis. These systems appear to be sensitive to physiological adaptations, can counter the effects of weight loss, and are primed to help the body maintain or return to their previous higher weight (Contextual Question 8, Contextual Findings).^67^

Diet, physical activity, and screen time are the most commonly cited behavioral factors leading to high BMI in children and adolescents. There are well documented inequities in factors that support healthy eating and physical activity in children and adolescents, with financial status showing an important impact on these behaviors (Contextual Question 5, Contextual Findings). In addition to the behavioral components of diet and physical activity, sleep habits, mental stress, and use of certain medications have also been documented to modify BMI.^13,^ ^62,^ ^63^ Parental weight and maternal characteristics such as smoking during pregnancy,^68^ prepregnancy BMI, and to a lesser degree, gestational weight gain, have been cited as additional risk factors for high BMI in childhood.^68,^ ^69^ Further, evidence suggests that adverse childhood experiences increase the risk for childhood high BMI.^70^ The evidence to support many of these risk factors, however, is almost entirely observational in nature, and cannot establish causality. The role of the microbiome in high BMI is an active area of research and may have the potential to uncover some causal mechanisms.^71^

## Prevalence of Potentially Weight-Related Behaviors in Children and Adolescents

Data suggest that children in the United States are generally not meeting recommendations for healthy diet and activity behaviors.

### Diet

The Dietary Guidelines for Americans emphasize a healthy dietary pattern that consists of nutrient-dense forms of foods and beverages across all food groups, within calorie limits.^72^ Further, added sugars should be kept to less than 10 percent of calories per day starting at age 2, saturated fat less than 10 percent of calories per day, and sodium less than 2,300 mg/day, and even less for children younger than 14 years. NHANES data suggest that overall diet quality among children and adolescents is poor.^72^ Among children ages 2 to 4 years, the estimated Healthy Eating Index (HEI) score is 61 out of 100. This score progressively declines throughout childhood and adolescence, with scores for adolescents ages 14 through 18 being estimated at 51 out of 100.

### Physical Activity

The Physical Activity Guidelines for Americans recommend that children and adolescents 6 to 17 years of age should get 60 or more minutes per day of moderate to vigorous physical activity.^73^ Most of this physical activity should be moderate or vigorous intensity aerobic activity, but should also include muscle- and bone-strengthening activity at least 3 days per week. Survey data broadly suggest that children and adolescents in the United States are not achieving these recommended levels. Data from the 2019 Youth Risk Factor Behavior Surveillance System show that 23.3 percent of adolescents (grades nine to 12) achieved 60 or more minutes of moderate to vigorous physical activity daily; this represents a statistically significant gradual decline over time (28.7% of this population was achieving this level of physical activity in 2011).^74^ This survey also estimated that one-half of U.S.-based ninth through 12th graders engaged in strengthening or toning exercises 3 or more days per week. A 2016 pooled analysis similarly estimated that 72.0 percent (95% CI, 68.8% to 75.1%) of U.S. adolescents ages 11 to 17 years had insufficient physical activity (60 minutes of physical activity per day).^75^ This analysis further found a large difference by sex; boys were more likely to get recommended levels of physical activity (percent with insufficient physical activity, 64.0% for boys vs. 80.5% for girls).

### Sleep

Many children and adolescents across the age span are getting less sleep than recommended,^76^ with the highest prevalence of short sleep duration occurring in high school students.

- 3- to 5-year-olds (<10 hours per 24-hr period, including naps): 35 percent^77^
- 6- to 12-year-olds (<9 hours per 24-hr period): 38 percent^77^
- 13- to 14-year-olds (<8 hours per 24-hr period): 20 percent^77^
- High school students (<8 hours of sleep per 24-hr period): 78 percent^78^

### Screen Time

The American Academy of Pediatrics (AAP) recommends that children ages 2 to 5 years should get 1 hour or less of screen time per day. For children and adolescents 5 through 18 years of age, the AAP recommends that families develop a Family Media Use Plan for each child or teenager that specifies consistent limits on hours per day of media as well as types of media used, but does not specify a general time recommendation.^79^ Further, the AAP promotes meeting physical activity and sleep recommendations. The 2019 Youth Risk Behavior Survey reports that 19.8 percent of U.S.-based ninth through 12th graders are watching 3 or more hours of television per day on an average school day.^74^ Further, 46.1 percent of this population played video or computer games or used a computer 3 or more hours per school day for activities that were not schoolwork.^74^

## Recommended Interventions

Major organizations have developed guidelines for screening and interventions related to reducing high BMI in children and adolescents as well as encouraging healthy diet and physical activity behaviors more generally (Table 1). In January 2023, the AAP issued its first clinical practice guideline on the evaluation and treatment of children and adolescents with high BMI.^4^ This guideline includes 13 “Key Action Statements” for pediatricians and other pediatric healthcare professionals on diagnosis and measurement, evaluation, comorbidity assessment, and treatment related to overweight and obesity. Regarding treatment, the AAP states that “Pediatricians and other primary healthcare practitioners should treat overweight (BMI ≥85th percentile to <95th percentile) and obesity (BMI ≥95th percentile) in children and adolescents, following the principles of the medical home and the chronic care model, using a family-centered and nonstigmatizing approach that acknowledges obesity’s biologic, social, and structural drivers.” The guideline additionally offers implementation recommendations that are further aimed at the policy, community, and practice level that acknowledge the numerous barriers to healthy lifestyle and treatment of high BMI. The AAP guideline is a comprehensive report that addresses health equity considerations, racism, weight bias and stigma, and adverse childhood experiences as important factors in the complex and multifactorial etiology of childhood BMI. The guideline is based on technical reports addressing two overarching key questions (KQs). KQ1 was “What are effective clinically based treatments for pediatric obesity?” and KQ2 was “What is the risk of comorbidities among children with obesity?” Harms of interventions were not directly addressed as KQs.

Table 1 BMI Screening and Weight Management Intervention Recommendations From Other Organizations

Organization; (Year) | Recommendation
American Academy of Pediatrics (2023)^4^ | Measure height and weight, calculate BMI, and assess BMI percentile using age- and sex-specific CDC growth charts or growth charts for children with severe obesity at least annually for all children 2 to 18 years of age to screen for overweight (BMI ≥85th percentile to <95th percentile), obesity (BMI ≥95th percentile), and severe obesity (BMI ≥120% of the 95th percentile for age and sex).; Evaluate children 2 to 18 years of age with overweight (BMI ≥85th percentile to <95th percentile) and obesity (BMI ≥95th percentile) for obesity-related comorbidities by using a comprehensive patient history, mental and behavioral health screening, social determinants of health evaluation, physical examination, and diagnostic studies.; In children 10 years and older, evaluate for lipid abnormalities, abnormal glucose metabolism, and abnormal liver function in children and adolescents with obesity (BMI ≥95th percentile) and for lipid abnormalities in children and adolescents with overweight (BMI ≥85th percentile to <95th percentile).; In children 10 years and older with overweight (BMI ≥85th percentile to <95th percentile), pediatricians and pediatric providers may evaluate for abnormal glucose metabolism and liver function in the presence of risk factors for type 2 diabetes or nonalcoholic fatty liver disease. In children 2 to 9 years of age with obesity (BMI ≥95th percentile), pediatricians and other pediatric providers may evaluate for lipid abnormalities.; Treat children and adolescents for overweight (BMI ≥85th percentile to <95th percentile) or obesity (BMI ≥95th percentile) and comorbidities concurrently.; Evaluate for dyslipidemia by obtaining a fasting lipid panel in children 10 years and older with overweight (BMI ≥85th percentile to <95th percentile) and obesity (BMI ≥95th percentile); pediatricians and pediatric providers may evaluate for dyslipidemia in children 2 through 9 years of age with obesity.; Evaluate for prediabetes and/or diabetes mellitus with fasting plasma glucose, 2-h plasma glucose after 75-g oral glucose tolerance test (OGTT), or glycosylated hemoglobin (HbA1c).; Evaluate for nonalcoholic fatty liver disease by obtaining an alanine transaminase test.; Evaluate for hypertension by measuring blood pressure at every visit starting at 3 years of age in children and adolescents with overweight (BMI ≥85 to <95th percentile) and obesity (BMI ≥95th percentile).; Treat overweight (BMI ≥85th percentile to <95th percentile) and obesity (BMI ≥95th percentile) in children and adolescents, following the principles of the medical home and the chronic care model, using a family-centered and nonstigmatizing approach that acknowledges obesity’s biologic, social, and structural drivers.; Use motivational interviewing to engage patients and families in treating overweight (BMI ≥85th percentile to <95th percentile) and obesity (BMI ≥95th percentile).; Pediatricians and other pediatric care providers should provide or refer children 6 years and older (Grade B) and may provide or refer children 2 through 5 years of age (Grade C) with overweight (BMI ≥85th percentile to <95th percentile) and obesity (BMI ≥95th percentile) to intensive health behavior and lifestyle treatment. Health behavior and lifestyle treatment is more effective with greater contact hours; the most effective treatment includes 26 or more hours of face-to-face, family-based, multicomponent treatment over a 3- to 12-mo period.; Offer adolescents 12 years and older with obesity (BMI ≥95th percentile) weight loss pharmacotherapy, according to medication indications, risks, and benefits, as an adjunct to health behavior and lifestyle treatment.; Offer referral for adolescents 13 years and older with severe obesity (BMI ≥120% of the 95th percentile for age and sex) for evaluation for metabolic and bariatric surgery to local or regional comprehensive multidisciplinary pediatric metabolic and bariatric surgery centers.
Academy of Nutrition and Dietetics (2021)^317^ | (Position statement) Prevention of pediatric overweight and obesity requires multilevel, multicomponent, and culturally appropriate interventions with family involvement to improve and sustain intake of healthy dietary patterns and physical activity in a developmentally appropriate manner throughout childhood and adolescence.
Academy of Nutrition and Dietetics (2022)^335^ | (Position statement) Children and adolescents with overweight or obesity should receive multicomponent, culturally appropriate interventions with family involvement and nutrition counseling from a registered dietitian nutritionist (RDN). RDNs should use appropriate screening and assessment methods that address weight and mental health status; use inclusive language; and work within their scope of practice to provide nutrition assessment and tailored interventions that leverage new technology to improve health outcomes.
American Psychological Association (2018)^336^ | Strongly recommends providing family-based multicomponent behavioral interventions with a minimum of 26 contact hours initiated at an early age for children and adolescents with overweight or obesity.
American Academy of Pediatrics (2022)^337^ | Recommends BMI measurement and charting at all pediatric visits for all patients 2 years and older.
The Endocrine Society (2017)^338^ | Recommends using BMI to screen children for overweight or obesity and also recommends age-appropriate lifestyle interventions for treating obesity. It additionally recommends that use of weight loss medications during childhood and adolescence should be restricted to clinical trials, and that bariatric surgery should be considered only in exceptional circumstances.
The American College of Obstetricians and Gynecologists (2017)^339^ | Recommends screening for adolescent overweight and obesity, and additionally that overweight or obese adolescents should been screened for depression, bullying, and peer victimization and appropriately referred. Recommends that providers initiate behavioral counseling or other multidisciplinary management as necessary. Metformin is not recommended for adolescent weight loss alone, clinicians should caution against the use of weight loss supplements, and bariatric surgery should only be considered after careful candidate selection by a multidisciplinary team.
The Canadian Task Force on Preventive Health Care (2015)^340^ | Recommends growth monitoring in all children and adolescents 17 years and younger at all primary care visits. Also recommends structured behavioral interventions focused on weight management for children and adolescents with overweight or obesity. The Task Force recommends against routinely offering orlistat for healthy weight management in children 12 to 17 years and against routine referral of obese children and adolescents 2 to 17 years for surgical interventions.
The National Association of Pediatric Nurse Practitioners (2021)^341,^ ^342^ | Recommends measuring BMI in children 2 years and older and evaluating family eating and physical activity patterns and amount of daily screen time and sedentary time in all children. Recommends evaluating children or adolescents with BMI ≥85th percentile for obesity-related comorbidities. Encourage healthy nutrition, activity, and sleep practices for prevention of high BMI and management. Use motivational interviewing techniques to encourage behavior change and highlight the role of parental and family modeling. Weight loss programs should be multicomponent and considered within a clinical setting or in schools or community settings. Recognize adolescents with severe obesity may require tertiary care and refer early to a Metabolic and Bariatric Surgery Center (direct readers to American Society for Metabolic and Bariatric Surgery guidelines).
The National Heart, Lung, and Blood Institute (2011)^343^ | Recommends charting height, weight, and BMI and classifying weight by BMI in children and adolescents 2 years and older. If BMI ≥85th percentile, intensify focus on diet and physical activity for 6 months and refer to dietician if no change.; If BMI ≥95th percentile, specifically assess for comorbidities (hypertension, dyslipidemia, diabetes), encourage family-based weight gain prevention with parents as focus, dietician counseling and followup for energy-balanced diet, physical activity prescription, and limit sedentary time with followup in 3 months for ages 2 to 5 years and 6 months for 6 to 11 years. For those 6 years and older, refer to comprehensive multidisciplinary lifestyle weight loss program if no reduction in BMI percentile, further consideration of orlistat in those 12 years and older if no further change.; If BMI ≥95th percentile with comorbidities or >97th percentile or progressive rise in BMI despite therapy, refer to comprehensive multidisciplinary weight loss program for intensive management for 6 months if 6 years and older. If older than 12 years, consider orlistat, and further consider bariatric surgery if BMI far above 35 kg/m^2^ with comorbidities if unresponsive to lifestyle therapy for >1 year.
The National Institute for Health and Care Excellence (UK; 2022)^277^ | Use BMI as a practical estimate of overweight and obesity and ensure that charts are appropriate for children and young people and are adjusted for age and sex. Interpret BMI with caution because it is not a direct measure of central adiposity. Consider using waist-to-height ratio in those 5 years and older to assess and predict health risks associated with central adiposity.; Recommend the following BMI classifications:; Overweight: BMI 91st centile + 1.34 standard deviations (SDs); Clinical obesity: BMI 98th centile + 2.05 SDs; Severe obesity: BMI 99.6th centile + 2.68 SDs; Define the degree of central adiposity based on waist-to-height ratio in children and young people as follows:; - Healthy central adiposity: waist-to-height ratio 0.4 to 0.49, indicating no increased health risk; - Increased central adiposity: waist-to-height ratio 0.5 to 0.59, indicating increased health risk; - High central adiposity: waist-to-height ratio 0.6 or more, indicating further increased health risk.; When talking to a child, young person, and their families and carers, explain that they should try and keep their waist to half their height (so a waist-to-height-ratio of under 0.5).; Recommend asking permission from children, young people, and their families and carers, before talking about the degree of overweight, obesity, and central adiposity, and discussing in a sensitive and age-appropriate manner.; Recommend considering tailored interventions for children and young people who are living with overweight or obesity or have increased health risk based on their waist-to-height ratio. Take into account their individual needs and preferences, and factors such as weight-related comorbidities, ethnicity, socioeconomic status, social complexity (for example, looked-after children and young people), family medical history, mental and emotional health and wellbeing, developmental age, and special educational needs and disabilities (SEND).; Multicomponent interventions are the treatment of choice. Ensure weight management programs include behavior change strategies to increase people’s physical activity levels or decrease inactivity, improve eating behavior and the quality of the person’s diet, and reduce energy intake. Encourage people to increase physical activity and improve their diet even if they do not lose weight, because there can be other health benefits.; Additional details recommended in the full guideline.; Drug treatment is not generally recommended for children younger than 12 years. In children age 12 years and older, treatment with orlistat is recommended only if physical comorbidities (such as orthopedic problems or sleep apnea) or severe psychological comorbidities are present. If orlistat is prescribed for children, a 6- to 12-month trial is recommended, with regular review to assess effectiveness, adverse effects, and adherence.; Surgical intervention is not generally recommended in children or young people. Bariatric surgery may be considered for young people only in exceptional circumstances, and if they have achieved or nearly achieved physiological maturity.
The Society for Adolescent Health and Medicine (2016)^344^ | Recommends calculating BMI and identifying BMI percentile for age and sex for all adolescents. Assessing for medical complications and screening for behaviors, including physical activity, and family history, that increase the risk of, or worsen, obesity. Reinforce healthy behaviors and, when appropriate, counsel adolescents regarding body-image, inappropriate dieting, and weight stigmatization. Once a diagnosis of obesity has been established, providers should work with dietitians, behavioral health providers, and exercise specialists to guide the patient through an evaluation for comorbidities, deliver evidence-based lifestyle counseling, and if indicated, refer to more intensive treatment options such as weight loss surgery, monitored diets, or residential care.

Abbreviations: BMI = Body mass index; UK = United Kingdom.

Recommended treatments for children and adolescents with higher BMI typically focus on behavioral interventions designed to modify dietary habits (e.g., increasing healthy grains, fruits, and vegetables and decreasing sugars, fats, and processed foods), increasing physical activity, and decreasing sedentary behaviors.^80^ Interventions tend to be multicomponent, behavioral, or cognitive-behavioral in approach, and often involve the family in addition to the child or adolescent.^1^ Behavioral components may include strategies such as goal setting, food diaries, making changes to the environment to avoid overeating, and problem-solving. Cognitive strategies may focus on identifying and reframing unhealthy thought patterns linked to overeating or poor body image. Most information on intervention approaches and outcomes are derived from RCTs of weight management interventions, and translation to clinical settings is not well understood.

Pharmacotherapy interventions are additional treatment options that may be recommended for young people when BMI is at or above the 95th percentile for age and sex or other higher thresholds. When recommended, pharmacotherapy is usually offered only after lifestyle modifications have been attempted. Four medications are U.S. Food and Drug Administration (FDA)-approved for weight management as an adjunct to lifestyle modification in pediatric populations meeting various criteria for “obesity.” Orlistat was approved in 2003 for adolescents age 12 years or older and functions by decreasing the absorption of dietary fat in the intestines.^81^ Two glucagon-like peptide-1 (GLP-1) receptor agonists are approved for individuals age 12 years or older: liraglutide (approved in 2020) and semaglutide (approved in 2022). These medications function by appetite suppression and delayed gastric emptying.^82–84^ In 2022, the FDA approved Qsymia (phentermine and topiramate extended-release capsules) for individuals 12 years or older; phentermine is presumed to support weight loss through appetite suppression and increase of metabolism, and topiramate may be associated with appetite suppression and enhancement of satiety.^85,^ ^86^ Metformin is prescribed off-label for weight loss in the presence of abnormal insulin or glucose metabolism; however, it is not FDA-approved for weight management in either children or adults.

Bariatric surgery is another weight loss intervention available for adolescents under stringent criteria. The American Society for Metabolic and Bariatric Surgery and the AAP recommend consideration of surgical intervention in adolescents with a BMI greater than 120 percent of the 95th percentile or a BMI of 35 kg/m^2^ or higher and major comorbidity, or a BMI greater than 140 percent of the 95th percentile or a BMI of 40 kg/m^2^ or higher.^4,^ ^87–89^ Major comorbidities include but are not limited to obstructive sleep apnea, diabetes, idiopathic intracranial hypertension, nonalcoholic steatohepatitis, or selected orthopedic complications. Indications for surgery include consideration from a multidisciplinary team about long-term adherence to recommended pre- and postoperative treatments. Several professional organizations have advised against routine referral for bariatric surgery in adolescent populations; when recommended, bariatric surgery is considered for highly selected populations (Table 1).

## Previous USPSTF Recommendation

In 2017, the USPSTF concluded with moderate certainty that screening for obesity in children and adolescents 6 years or older and offering or referring them to comprehensive, intensive behavioral interventions to promote improvements in weight status is of moderate net benefit (B recommendation).^1^

The USPSTF has also published several additional recommendations related to pediatric cardiometabolic health and eating behaviors:

- Screening for prediabetes and type 2 diabetes in children and adolescents^90^ (I statement)
- Screening for eating disorders in adolescents and adults^91^ (I statement)
- Screening for high blood pressure in children and adolescents^92^ (I statement)
- Screening for lipid disorders in children and adolescents^93^ (I statement)