# Appendix F Ongoing Studies

Trial | Location | N | Duration (Months) | Intervention | Relevant outcomes | Trial registry no. | Est. completion date
Behavioral Studies
Dyad Plus Effectiveness | US | 90 | 6 | A coordinated program (Dyad Plus) that aims to facilitate self-monitoring, positive communication, joint problem-solving, and social support to increase physical activity, healthy eating, and weight loss. Participants of the Brenner FIT (Families In Training) pediatric weight management program and their parent/guardian will co-enroll in weight loss programs. Parents/guardians will receive the components of By Design Essentials. Youth 2-18 years old are referred by a physician for overweight or obesity. | zBMI, PA, FBG, fasting insulin, TC | NCT04036331 | June 2023
Guided self-help Obesity Treatment in the primary care setting (GOTDoc) | US | 200 | 12 | Parent-child dyads will be randomized to receive health coaching focused on healthy diet and PA behaviors or usual care. The overall goal of this program is to help children improve their weight status by losing ½ to 1 lb per week. Parents interested in losing weight are also encouraged to do so since parent weight loss is highly correlated with child weight loss. | zBMI, PA, diet scores | NR | NR
Executive Function Training in Childhood Obesity: Food Choice, Quality of Life, and Brain Connectivity (TOuCH) | Spain | 46 | 12 | This study aims to explore the impact of executive function training on food-related choices, cognitive and neuroimaging outcomes, but also on the psychological and physical status and quality of life measures. Obese children in the intervention group will complete home-based executive function training by iPad. At the same time, they will be asked to learn basic psychoeducational contents and send pictures of their daily meals. Education around learning healthy habits will also be a part of the program. | BMI, WC, food choices, PedsQL, PA | NCT03615274 | January 2021
TEXT message Behavioral Intervention for Teens on Eating, physical activity, and Social wellbeing (TEXTBITES) | Australia | 150 | 12 | An RCT comparing a two-way text message intervention, with optional telephone health counseling, to usual care in adolescents (13-18 years old) who are overweight (recruited from a pediatric weight management clinic and the broader community in Sydney, Australia). | zBMI, dietary intake, PA, sedentary behavior, QoL, eating disorder symptoms, depression symptoms | ACTRN12619000389101 | December 2021
Adaptando Dieta y Acción Para Todos (ADAPT+) | US | 48 – 60 dyads | 2 | Focus groups targeting Latino families, followed by a small quasi-RCT. The RCT will include an 8-session, culturally sensitive multi-family behavioral obesity intervention targeting families with pre-adolescents, to increase healthy eating and physical activity lifestyle behaviors in both parents and their children. | zBMI, BP, PA, dietary intake | NR | NR
FITLINE | US | 501 | 12 | Two practice-based interventions on improving diet and physical activity and reducing BMI among overweight and obese 8- to 12-year-olds seen in pediatric practice: (1) Fitline-Coaching, consisting of a pediatric practice-based component plus Fitline counseling and workbook, or (2) Fitline-Workbook, consisting of the same practice-based component, but only the family workbook materials mailed over 8 weeks, with no referral to Fitline coaching. | BMI, zBMI, dietary intake, PA | NCT03143660 | January 2022
eatNplay | US | 44 families | 6 | A RCT pilot trial of a rural, family-based, telehealth intervention that aims to improve weight-related behaviors among children, compared to monthly newsletter. | BMI, zBMI, QoL, dietary intake, sedentary behavior, PA | NR | NR
Primary care pediatrics, Learning, Activity, and Nutrition (PLAN) with Families study | US | 528 families | 24 | Family-based behavioral treatment that targets diet, activity, behavioral skills, parenting, and social facilitation in children and their parents. The treatment includes: 1) the Traffic Light Eating Plan, which utilizes RED, YELLOW, and GREEN labels for food to guide families toward the goal of consuming healthy low energy dense, high nutrient dense foods; 2) the Traffic Light Activity Program, also utilizes RED, YELLOW, and GREEN labels for different levels of caloric expenditure to increase physical activity and reduce sedentary behaviors; 3) a variety of behavioral techniques, including stimulus control, self-monitoring, goal setting, problem-solving, finding behavioral substitutes for highly reinforcing food, improving positive parenting, providing reinforcers for behavior change and weight loss; and 4) facilitation of support in the family and peer environments to optimize the durability and generalizability of improved eating and activity habits across multiple social and environmental contexts (e.g., home, school, with friends). | BMI, zBMI, PA, sedentary behavior | NR | NR
Hearts & Parks | US | 327 | 12 | A two-arm, randomized crossover-controlled trial comparing routine primary care management of childhood obesity vs. a novel clinic/family/community partnership program to treat childhood obesity. The goal is to evaluate how different types of physical activity and nutrition education and support (in addition to normal clinical care) through attendance and participation in the Duke Healthy Lifestyles/Bull City Fit clinic/community program affect children’s health. | zBMI, PA, QOL, FPG, Lipids | NCT03339440 | June 2021
Population Effects of MI on Pediatric Obesity in Primary Care (BMI2+) | US | 329 | 24 | A cluster randomized effectiveness trial, pediatric primary care practices will be recruited (18 in total). Intervention arm practices will select 1-2 pediatric clinicians, including pediatricians and nurse practitioners, to receive in-person training in motivational Interviewing (MI), behavioral therapy, billing and coding, and study procedures. Over 24 months, parents in the IG may receive up to 4 in-person, MI-based counseling sessions with a trained pediatric clinician and up to 6 telephone counseling sessions with an MI-trained Registered Dietician. | BMI, % distance from the sex-age-specific 95% percentile | NCT03177148 (https://clinicaltrials.gov/show/NCT03177148) | August 2021
Implementation and effectiveness of a network approach (de Laat, et. al) | The Netherlands | 180 | 12 | An integrated network approach of preventive care for children with overweight and obesity in designated neighborhoods, in which nurses fulfill the role of central care providers. The theory behind the integrated network approach is supporting overweight children and their families is based on patient and family empowerment and self-management. | BMI, PedsQL, IWQOL, dietary behaviors, PA | NTR6813 | January 2020
The More and Less Study Europe | Multisite (Romania, Spain, Sweden) | 300 | 9 | A 10-week parent training group session (More and Less Program) followed by a 6-month mobile phone-based intervention. Both components aim to develop healthy lifestyle behaviors regarding dietary habits and physical activity in 2- to 6-year-olds. The intervention is delivered toward the parents. | zBMI, WC, CEBQ, PA, sedentary behavior | NCT03800823 | December 2023
Gamification-based smartphone application for weight loss in overweight and obese adolescents (Timpel, et. al) | US | 108 | 6 | A gamification-based smartphone application for weight loss in overweight and obese adolescents. The application combines tracking (monitoring) and gamification to develop a healthy lifestyle and can be a tool in the management of obesity in children and teenagers. | zBMI, WC, BP, Lipids, FPG, IWQOL, PA | NR | NR
Family-based behavioral treatment of childhood obesity (FABO) study | Norway | 120 | 24 | Seventeen weekly family-based treatment sessions at the hospital obesity clinic followed by monthly followup sessions with their local nurse and followup sessions at the hospital every third month for 2 years. The treatment targets both child and parent lifestyle; eating habits, physical activity, sedentary activity, and sleep habits. Behavior modification techniques are systematically employed; such as self-monitoring, goal setting, reward systems, problem-solving. and stimulus control. In addition, FBSFT focuses on facilitating lifestyle change across different settings (family, friends, school, and community) and harnessing social support for healthy habits, which is considered important for long-term weight control. | BMI, BMI SDS, % above the IOTF cut-off for OW, WC, % body fat, BP, dietary intake, PA | NCT02687516 | May 2021
Study for using Technology to Reach Individual Excellence (STRIVE) | US | 68 | 6 | An RCT that will test the feasibility of using mHealth to reduce cardiometabolic risk in children by collecting longitudinal patient-generated health behavior data and providing clinical recommendations in a closed-loop feedback system. | zBMI, dietary intake, PA, sedentary behavior | NCT 02659163 | October 2018
Pharmacology studies
Lifestyle Counseling and Medication for Adolescent Weight Management (QUEST) | US | 120 | 12 | One year of semaglutide plus relatively low-intensity behavioral counseling (12 contact hours) compared to 1 year of intensive (52 contact hours) behavioral counseling in adolescents with severe obesity. | BMI | NCT04873245 | January 2025
Brain Activation and Satiety in Children 2 (BASIC2) | US | 64 | 6 | 24 weekly sessions of family-based behavioral treatment with weekly injections of 2 mg exenatide (IG) or matching placebo (CG). | zBMI, body composition assessed with bioelectrical impedance, insulin resistance | NCT04520490 | August 2024
SMART Use of Medication for the Treatment of Adolescent Severe Obesity (SMART) | US | 150 | 11 | Individual lifestyle counseling for 12 or 24 weeks with stepped therapy to phentermine and topiramate; groups are randomized to timing and sequence of adding pharmacotherapy as an adjunct to lifestyle counseling in adolescents with BMI ≥1.2 times the 95th percentile or ≥35 kg/m^2^ who do not achieve 5% BMI loss with lifestyle counseling alone. | BMI | NCT04007393 | August 2025