# Appendix E Additional Figures

Appendix E Figure 1 Pooled Analysis of Change in Physical Quality of Life in Behavioral Interventions Compared With Controls, by Estimated Hours of Contact

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; PedsQL = Pediatric Quality of Life Inventory; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in physical quality of life in behavioral interventions compared with controls, by estimated hours of contact

Appendix E Figure 2 Pooled Analysis of Change in Total or Global Quality of Life (Standardized Mean Difference) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CHQ = Child Health Questionnaire; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; PedsQL = Pediatric Quality of Life Inventory; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in total or global quality of life (standardized mean difference) in behavioral interventions compared with controls, by estimated contact hours

Appendix E Figure 3 Pooled Analysis of Change in Psychosocial Quality of Life in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; PedsQL = Pediatric Quality of Life Inventory; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in psychosocial quality of life in behavioral interventions compared with controls, by estimated contact hours

Appendix E Figure 4 Pooled Analysis of Change in Weight (kg) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; Kg = Kilograms; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in weight (kg) in behavioral interventions compared with controls, by estimated contact hours

Appendix E Figure 5 Pooled Analysis of Change in zBMI (z-score) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment; zBMI = Standardized body mass index

This figure shows a pooled analysis of change in zBMI (z-score) in behavioral interventions compared with controls, by estimated contact hours

Appendix E Figure 6 Pooled Analysis of Change in Body Mass Index (kg/m^2^) in Behavioral Interventions Compared With Controls, by Four Levels of Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; Kg/m^2^ = Kilograms per meters squared; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in body mass index (kg/m2) in behavioral interventions compared with controls, by four levels of estimated contact hours

Appendix E Figure 7 Pooled Analysis of Change in zBMI (z-score) in Behavioral Interventions Compared With Controls, by Four Levels of Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment; zBMI = Standardized body mass index

This figure shows a pooled analysis of change in zBMI (z-score) in behavioral interventions compared with controls, by four levels of estimated contact hours

Appendix E Figure 8 Pooled Analysis of Change in Waist Circumference (cm) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; cm = cemtimeters; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in waist circumference (cm) in behavioral interventions compared with controls, by estimated contact hours

Appendix E Figure 9 Pooled Analysis of Change in Percent Body Fat in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in percent body fat in behavioral interventions compared with controls, by estimated contact hours

Appendix E Figure 10 Pooled Analysis of Change in Systolic Blood Pressure (mm Hg) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; Mm Hg = Millimeters of mercury; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in systolic blood pressure (mm Hg) in behavioral interventions compared with controls, by estimated contact Hours

Appendix E Figure 11 Pooled Analysis of Change in Diastolic Blood Pressure (mm Hg) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; Mm Hg = Millimeters of mercury; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in diastolic blood pressure (mm Hg) in behavioral interventions compared with controls, by estimated contact hours

Appendix E Figure 12 Pooled Analysis of Change in Low-Density Lipoprotein Cholesterol (mg/dL) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; Mg/dL = Milligrams per deciliter; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in low-density lipoprotein cholesterol (mg/dL) in behavioral interventions compared with controls, by estimated contact hours

Appendix E Figure 13 Pooled Analysis of Change in High-Density Lipoprotein Cholesterol (mg/dL) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; Mg/dL = Milligrams per deciliter; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in high-density lipoprotein cholesterol (mg/dL) in behavioral interventions compared with controls, by estimated contact hours

Appendix E Figure 14 Pooled Analysis of Change in Total Cholesterol (mg/dL) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; Mg/dL = Milligrams per deciliter; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in total cholesterol (mg/dL) in behavioral interventions compared with controls, by estimated contact hours

Appendix E Figure 15 Pooled Analysis of Change in Triglycerides (mg/dL) in Behavioral Interventions Compared With Controls, by Estimated Contact Hours

Abbreviations: CG= Control group; CI = Confidence interval; Diff = Difference; Est. = Estimated; Hrs = Hours; IG = Intervention group; Mg/dL = Milligrams per deciliter; MnChg = Mean change; Mos = Months; n = number of participants; PA = Physical activity; REML = Restricted maximum likelihood; SD = Standard deviation; Sess = Session; Tx = Treatment

This figure shows a pooled analysis of change in triglycerides (mg/dL) in behavioral interventions compared with controls, by estimated contact hours