# Appendix D Evidence Tables

Appendix D Table 1 Population Characteristics of Trials of Behavioral Interventions

Appendix D Table 2 Intervention Characteristics of Trials of Behavioral Interventions

Appendix D Table 3 Detailed Intervention Characteristics of Behavioral Interventions

Appendix D Table 4 Population Characteristics of Trials of Medications, Sorted by Type of Medication

Appendix D Table 5 Intervention Characteristics of Trials of Medications, Sorted by Type of Medication

Appendix D Table 6 Health Outcomes Results for Behavioral Interventions (Key Question 1)

Appendix D Table 7 Weight-Related Outcomes Results for Behavioral Interventions (Key Question 2), Sorted by Outcome

Appendix D Table 8 Other Intermediate Outcomes for Behavioral Interventions (Key Question 2), Sorted by Outcome

Appendix D Table 9 Stratified Analyses of Change in Body Mass Index (kg/m^2^) in Behavioral Interventions Compared With Controls

Appendix D Table 10 Weight-Related Outcomes Results for Glucagon-Like Peptide-1 Agonists (Key Question 2)

Appendix D Table 11 Other Intermediate Outcomes Results for Glucagon-Like Peptide-1 Agonists (Key Question 2)

Appendix D Table 12 Weight-Related Outcomes for Orlistat (Key Question 2), Sorted by Outcome

Appendix D Table 13 Other Intermediate Outcomes for Orlistat, Sorted by Outcome

Appendix D Table 14 Diet, Physical Activity, and Sedentary Behavior Outcomes Results for Behavioral Interventions (Key Question 3), Sorted by Outcome

Appendix D Table 15 Harms Outcomes Results for Behavioral Interventions, Sorted by Outcome (Key Question 4)

Appendix D Table 16 Harms Outcomes Results for Glucagon-Like Peptide-1 Agonists (Key Question 4)

Appendix D Table 17 Harms Outcomes Results for Orlistat (Key Question 4), Sorted by Outcome

Appendix D Table 18 Harms Outcomes Results for Phentermine/Topiramate (Key Question 4)

Appendix D Table 19 Associations of Childhood BMI With Outcomes in Adulthood in the International Childhood Cardiovascular Cohort (i3c) Consortium

Appendix D Table 20 Behavioral Intervention Implementation Table: Summary and Examples of Included Interventions