# Appendix C Excluded Studies

Reason for Exclusion
E1. Study relevance
E2. Setting (not in a very high HDI country)
E2a. Insufficient connection to health care
E3. Population (other than age or listed below)
E3a. Limited to average age younger than 2 yrs old or older than 18 yrs
E3b. Limited exclusively to youth who have an active eating disorder, are pregnant or postpartum, have overweight or obesity secondary to a genetic or medical condition, are in college
E4. Study design
E5. Intervention
E5a. Primary prevention in children who are normal weight
E5b. Intervention: Metformin
E5c. Surgical interventions
E5d. Complementary and alternative medicine approaches
E5e. Study provides all or most of participants’ food
E6. Comparator
E7. No relevant outcomes
E7a. Timing of outcome assessment <6 mo after baseline
E8. Study quality
E9. Language
E10. Conference abstract only/study on-going with no results published yet

1 Aagaard, L, Hallgreen, CE, . Serious adverse events reported for antiobesity medicines: postmarketing experiences from the EU adverse event reporting system EudraVigilance. Int J Obes. 40(11): 1742–1747. 2016. PMID: 27478924. 10.1038/ijo.2016.135 KQ1E4, KQ2E4, KQ3E4, KQ4E427478924
2 Adams, E. L., . (2022). “Home Food Environment Changes and Dietary Intake during an Adolescent Behavioral Weight Loss Intervention Differ by Food Security Status.” [underlined: Nutrients] 14(5): 25. KQ1E6, KQ2E6, KQ3E6, KQ4E6
3 Adeyemo, MA, McDuffie, JR, . Effects of metformin on energy intake and satiety in obese children. Diabetes Obes Metab. 17(4): 363–70. 2015. PMID: 25483291. 10.1111/dom.12426 KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b25483291
4 Aguilar-Cordero, MJ, Leon Rios, XA, . Effects of physical activity on quality of life in overweight and obese children. Nutr Hosp. 38(4): 736–741. 2021. PMID: 34092077. 10.20960/nh.03373 KQ1E6, KQ2E6, KQ3E6, KQ4E634092077
5 Aguilar-Cordero, MJ, Rodriguez-Blanque, R, . Influence of Physical Activity on Blood Pressure in Children With Overweight/Obesity: A Randomized Clinical Trial. Am J Hypertens. 33(2): 131–136. 2020. PMID: 31678988. 10.1093/ajh/hpz174 KQ1E6, KQ2E6, KQ3E6, KQ4E631678988
6 Aguilar-Cordero, Mj, Rodríguez-Blanque, R, . Influence of physical activity on the quality of life of overweight or obese children. Salud Publica Mex. 61(4): 550–551. 2019. PMID: Pubmed 31430089. 10.21149/10013 KQ1E9, KQ2E9, KQ3E9, KQ4E931430089
7 Ahmad, N, Shariff, ZM, . Effect of Family-Based REDUCE Intervention Program on Children Eating Behavior and Dietary Intake: Randomized Controlled Field Trial. Nutrients. 12(10): 08. 2020. PMID: 33049909. 10.3390/nu12103065 KQ1E2, KQ2E2, KQ3E2, KQ4E233049909
8 Akgul Gundogdu, N, Sevig, EU, . The effect of the solution-focused approach on nutrition-exercise attitudes and behaviours of overweight and obese adolescents: Randomised controlled trial. J Clin Nurs. 27(7–8): e1660–e1672. 2018. PMID: 29278443. 10.1111/jocn.14246 KQ1E6, KQ2E6, KQ3E6, KQ4E629278443
9 Alberga, AS, Prud’homme, D, . Effects of aerobic training, resistance training, or both on cardiorespiratory and musculoskeletal fitness in adolescents with obesity: the HEARTY trial. Appl Physiol Nutr Metab. 41(3): 255–65. 2016. PMID: 26881317. 10.1139/apnm-2015-0413 KQ1E6, KQ2E6, KQ3E6, KQ4E626881317
10 Alberga, A., . (2022) Effects of the HEARTY exercise randomized controlled trial on eating behaviors in adolescents with obesity. [underlined: Obesity science and practice] DOI: 10.1002/osp4.620. KQ1E6, KQ2E6, KQ3E6, KQ4E6
11 Alustiza, E, Perales, A, . Tackling risk factors for type 2 diabetes in adolescents: PRE-STARt study in Euskadi. Anales de pediatria. 95(3): 186–196. 2021. PMID: 34384737. 10.1016/j.anpede.2020.11.005 KQ1E7, KQ2E8, KQ3E8, KQ4E834384737
12 Amiri, P, Jalali-Farahani, S, . Behavioral Interventions for Weight Management in Overweight and Obese Adolescents: A Comparison Between a Motivation-based Educational Program and Conventional Dietary Counseling. Int J Endocrinol Metab. 18(1): e88192. 2020. PMID: 32308694. 10.5812/ijem.88192 KQ1E2, KQ2E2, KQ3E2, KQ4E232308694
13 Anderson, YC, Kirkpatrick, K, . Do changes in weight status affect cognitive function in children and adolescents with obesity? A secondary analysis of a clinical trial. BMJ Open. 9(2): e021586. 2019. PMID: 30782863. 10.1136/bmjopen-2018-021586 KQ1E7, KQ2E7, KQ3E7, KQ4E730782863
14 Anderson, YC, Leung, W, . Economic evaluation of a multi-disciplinary community-based intervention programme for New Zealand children and adolescents with obesity. Obes Res Clin Pract. 12(3): 293–298. 2018. PMID: 29779834. 10.1016/j.orcp.2018.04.001 KQ1E6, KQ2E6, KQ3E6, KQ4E629779834
15 Anderson, YC, Wynter, LE, . A Novel Home-Based Intervention for Child and Adolescent Obesity: The Results of the Whanau Pakari Randomized Controlled Trial. Obesity. 25(11): 1965–1973. 2017. PMID: 29049868. 10.1002/oby.21967 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a29049868
16 Anderson, YC, Wynter, LE, . Two-year outcomes of Whanau Pakari, a multi-disciplinary assessment and intervention for children and adolescents with weight issues: A randomized clinical trial. Pediatr Obes. 16(1): e12693. 2021. PMID: 32959996. 10.1111/ijpo.12693 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a32959996
17 Azad, A, Gharakhanlou, R, . Effects of aerobic exercise on lung function in overweight and obese students. Tanaffus. 10(3): 24–31. 2011. PMID: 25191372 KQ1E2, KQ2E2, KQ3E2, KQ4E225191372
18 Barkin, ShariL, Gesell, SabinaB, . “Culturally tailored, family-centered, behavioral obesity intervention for Latino-American preschool-aged children”: Errata. Pediatrics Vol 143(6), 2019, ArtID e20190813. 143(6). 2019. KQ1E3, KQ2E3, KQ3E3, KQ4E3
19 Barlow, SE, Durand, C, . Who benefits from the intervention? Correlates of successful BMI reduction in the Texas Childhood Obesity Demonstration Project (TX-CORD). Pediatr Obes. 15(5): e12609. 2020. PMID: 31944617. 10.1111/ijpo.12609 KQ1E6, KQ2E6, KQ3E6, KQ4E631944617
20 Berkel, C, Mauricio, Am, . Motivational Interviewing and Caregiver Engagement in the Family Check-Up 4 Health. Prevention science. 22(6): 737–746. 2021. PMID: Pubmed 32488687. 10.1007/s11121-020-01112-8 KQ1E7, KQ2E7, KQ3E7, KQ4E732488687
21 Berry, DC, McMurray, RG, . A cluster randomized controlled trial for child and parent weight management: children and parents randomized to the intervention group have correlated changes in adiposity. BMC Obesity. 4. 39. 2017. PMID: 29225899. 10.1186/s40608-017-0175-z KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a29225899
22 Berry, DC, McMurray, RG, . Benefits for African American and white low-income 7-10-year-old children and their parents taught together in a community-based weight management program in the rural southeastern United States. BMC Public Health. 18(1): 1107. 2018. PMID: 30200925. 10.1186/s12889-018-6006-4 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a30200925
23 Bharath, Lp, Choi, Ww, . Erratum: correction to: combined resistance and aerobic exercise training reduces insulin resistance and central adiposity in adolescent girls who are obese: randomized clinical trial (European journal of applied physiology (2018) 118 8 (1653-1660)). Eur J Appl Physiol. 2021. PMID: Pubmed 33399912. 10.1007/s00421-020-04579-z KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a33399912
24 Bocca, G, Corpeleijn, E, . Results of a multidisciplinary treatment program in 3-year-old to 5-year-old overweight or obese children: a randomized controlled clinical trial. Arch Pediatr Adolesc Med. 166(12): 1109–1115. 2012. PMID: 23108941. 10.1001/archpediatrics.2012.1638 KQ1E6, KQ2E6, KQ3E6, KQ4E623108941
25 Bocca, G, Corpeleijn, E, . Three-year follow-up of 3-year-old to 5-year-old children after participation in a multidisciplinary or a usual-care obesity treatment program. Clin Nutr. 33(6): 1095–100. 2014. PMID: 24377413. 10.1016/j.clnu.2013.12.002 KQ1E6, KQ2E6, KQ3E6, KQ4E624377413
26 Bocca, G, Kuitert, MW, . A multidisciplinary intervention programme has positive effects on quality of life in overweight and obese preschool children. Acta Paediatr. 103(9): 962–7. 2014. PMID: 24862085. 10.1111/apa.12701 KQ1E6, KQ2E6, KQ3E6, KQ4E624862085
27 Bocca, G, Kuitert, MWB, . Effect of a multidisciplinary treatment program on eating behavior in overweight and obese preschool children. Journal of Pediatric Endocrinology & Metabolism. 31(5): 507–513. 2018. PMID: 29652666. 10.1515/jpem-2017-0390 KQ1E6, KQ2E6, KQ3E6, KQ4E629652666
28 Bohlin, A, Hagman, E, . Childhood obesity treatment: telephone coaching is as good as usual care in maintaining weight loss - a randomized controlled trial. Clin Obes. 7(4): 199–205. 2017. PMID: 28508579. 10.1111/cob.12194 KQ1E6, KQ2E6, KQ3E6, KQ4E628508579
29 Boudreau, AD, Kurowski, DS, . Latino families, primary care, and childhood obesity: a randomized controlled trial. Am J Prev Med. 44(3 Suppl 3): S247–57. 2013. PMID: 23415190. 10.1016/j.amepre.2012.11.026 KQ1E8, KQ2E8, KQ3E8, KQ4E723415190
30 Brady, C, Shaikh, MG. Liraglutide does not provide sustainable results for weight improvement in adolescents with obesity. Archives of Disease in Childhood Education & Practice. 28. 28. 2020. PMID: 32988963. 10.1136/archdischild-2020-319807 KQ1E4, KQ2E4, KQ3E4, KQ4E432988963
31 Bruno, A, Escobar, P, . Home-exercise Childhood Obesity Intervention: A Randomized Clinical Trial Comparing Print Versus Web-based (Move It) Platforms. J Pediatr Nurs. 42. e79–e84. 2018. PMID: 29747957. 10.1016/j.pedn.2018.04.008 KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a29747957
32 Burgert, TS, Duran, EJ, . Short-term metabolic and cardiovascular effects of metformin in markedly obese adolescents with normal glucose tolerance. Pediatr Diabetes. 9(6): 567–76. 2008. PMID: 18761646. 10.1111/j.1399-5448.2008.00434.x KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b18761646
33 Byrd-Bredbenner, C, Martin-Biggers, J, . Promoting healthy home environments and lifestyles in families with preschool children: HomeStyles, a randomized controlled trial. Contemp Clin Trials. 64. 139–151. 2018. PMID: 29079392. 10.1016/j.cct.2017.10.012 KQ1E3, KQ2E3, KQ3E3, KQ4E329079392
34 Calvo-Malvar, M, Benitez-Estevez, Aj, . Changes in dietary patterns through a nutritional intervention with a traditional Atlantic diet: the galiat randomized controlled trial. Nutrients. 13(12): . 2021. 10.3390/nu13124233 KQ1E3, KQ2E3, KQ3E3, KQ4E3
35 Campos, J., . (2022) Culturally sensitive nutrition intervention for children of dominican heritage with obesity. [underlined: Journal of Investigative Medicine] 70, 1019–1020 . KQ1E10, KQ2E10, KQ3E10, KQ4E10
36 Chen, E, Miller, GE, . Unsupportive parenting moderates the effects of family psychosocial intervention on metabolic syndrome in African American youth. Int J Obes. 42(4): 634–640. 2018. PMID: 28984843. 10.1038/ijo.2017.246 KQ1E3, KQ2E3, KQ3E3, KQ4E328984843
37 Chen, JL, Guedes, CM, . Smartphone-based Healthy Weight Management Intervention for Chinese American Adolescents: Short-term Efficacy and Factors Associated With Decreased Weight. J Adolesc Health. 64(4): 443–449. 2019. PMID: 30409751. 10.1016/j.jadohealth.2018.08.022 KQ1E6, KQ2E6, KQ3E6, KQ4E630409751
38 Chew, CSE, Oh, JY, . Evaluation of a group family-based intervention programme for adolescent obesity: the LITE randomised controlled pilot trial. Singapore Med J. 62(1): 39–47. 2021. PMID: 33619579. 10.11622/smedj.2019122 KQ1E6, KQ2E6, KQ3E6, KQ4E633619579
39 Chongviriyaphan, N, Sangthien, N, . The nutrition counselling with a behavior modification is effective in obese school-aged children. 11th International Congress on Obesity. 11. 292–3. 2010. PMID: None. KQ1E10, KQ2E10, KQ3E10, KQ4E10
40 Christie, D, Hudson, L, . Assessing the efficacy of the Healthy Eating and Lifestyle Programme (HELP) compared with enhanced standard care of the obese adolescent in the community: study protocol for a randomized controlled trial. Trials. 12. 242. 2011. 10.1186/1745-6215-12-242 KQ1E7, KQ2E7, KQ3E7, KQ4E722088133
41 Clarson, CL, Brown, H, . Structured lifestyle intervention with metformin extended release or placebo in obese adolescents. Diabetes. 62. A337–A338. 2013. PMID: None. 10.2337/db13-859-1394 KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b
42 Clarson, CL, Brown, HK, . Effects of a comprehensive, intensive lifestyle intervention combined with metformin extended release in obese adolescents. International Scholarly Research Notices. 2014(659410): 1. 2014. PMID: 27433488. 10.1155/2014/659410 KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b27433488
43 Cohen, TR, Hazell, TJ, . A family-centered lifestyle intervention for obese six- to eight-year-old children: Results from a one-year randomized controlled trial conducted in Montreal, Canada. Can J Public Health. 107(4–5): e453–e460. 2016. PMID: 28026713. 10.17269/cjph.107.5470 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a28026713
44 Cohen, T. R., . (2022). “Changes in Adiposity without Impacting Bone Health in Nine- to Twelve-Year-Old Children with Overweight and Obesity after a One-Year Family-Centered Lifestyle Behavior Intervention.” [underlined: Childhood Obesity] 05: 05. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a
45 Cohen, TR, Hazell, TJ, . Changes in eating behavior and plasma leptin in children with obesity participating in a family-centered lifestyle intervention. Appetite. 125. 81–89. 2018. PMID: 29410008. 10.1016/j.appet.2018.01.017 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a29410008
46 Comeras-Chueca, C., . (2022). “Effect of an Active Video Game Intervention Combined With Multicomponent Exercise for Cardiorespiratory Fitness in Children With Overweight and Obesity: Randomized Controlled Trial.” [underlined: JMIR Serious Games] 10(2): e33782. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a35471240
47 Condarco, TA, Sherafat-Kazemzadeh, R, . Long-term follow-up of a randomized, placebo-controlled trial of orlistat in African-American and caucasian adolescents with obesity-related comorbid conditions. The Endocrine Society’s 95th Annual Meeting and Expo. 34(3 Suppl 1): SAT-666. 2013. PMID: None. KQ1E10, KQ2E10, KQ3E10, KQ4E10
48 Crespo, NC, Talavera, GA, . A randomized controlled trial to prevent obesity among Latino paediatric patients. Pediatr Obes. 13(11): 697–704. 2018. PMID: 30257069. 10.1111/ijpo.12466 KQ1E7, KQ2E8, KQ3E7, KQ4E730257069
49 Davis, AnnM, Stough, Cathleen Odar, . Outcomes of a weight management program conjointly addressing parent and child health. Children’s Health Care. 45(2): 227–240. 2016. 10.1080/02739615.2014.979923 KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a
50 Davis, CL, Litwin, SE, . Exercise effects on arterial stiffness and heart health in children with excess weight: The SMART RCT. Int J Obes. 44(5): 1152–1163. 2020. PMID: 31754238. 10.1038/s41366-019-0482-1 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a31754238
51 de Laat, S, de Vos, I, . The evaluation of an integrated network approach of preventive care for children with overweight and obesity; study protocol for an implementation and effectiveness study. BMC Public Health. 19(1): 979. 2019. PMID: 31337365. 10.1186/s12889-019-7304-1 KQ1E7, KQ2E7, KQ3E7, KQ4E731337365
52 Demir, D. and M. Bektas (2021) The Effect of an Obesity Prevention Program on Children’s Eating Behaviors, Food Addiction, Physical Activity, and Obesity Status. [underlined: Journal of pediatric nursing] 61, 355–363 DOI: 10.1016/j.pedn.2021.09.001. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a34563806
53 de Niet, J, Timman, R, . Short message service reduces dropout in childhood obesity treatment: a randomized controlled trial. Health Psychol. 31(6): 797–805. 2012. PMID: 22468714. 10.1037/a0027498 KQ1E6, KQ2E6, KQ3E6, KQ4E622468714
54 de Niet, J, Timman, R, . The effect of a short message service maintenance treatment on body mass index and psychological well-being in overweight and obese children: a randomized controlled trial. Pediatr Obes. 7(3): 205–19. 2012. PMID: 22492669. 10.1111/j.2047-6310.2012.00048.x KQ1E6, KQ2E6, KQ3E6, KQ4E622492669
55 Diao, H, Wang, H, . The impacts of multiple obesity-related interventions on quality of life in children and adolescents: a randomized controlled trial. Health Qual Life Outcomes. 18(1): 213. 2020. PMID: 32631401. 10.1186/s12955-020-01459-0 KQ1E2, KQ2E2, KQ3E2, KQ4E232631401
56 Dorenbos, E, Drummen, M, . Effect of a high protein/low glycaemic index diet on insulin resistance in adolescents with overweight/obesity-A PREVIEW randomized clinical trial. Pediatr Obes. 16(1): e12702. 2021. PMID: 32681547. 10.1111/ijpo.12702 KQ1E1, KQ2E1, KQ3E1, KQ4E132681547
57 Eichen, DM, Rhee, KE, . Impact of Race and Ethnicity on Weight-Loss Outcomes in Pediatric Family-Based Obesity Treatment. Journal of Racial & Ethnic Health Disparities. 7(4): 643–649. 2020. PMID: 31919695. 10.1007/s40615-019-00694-6 KQ1E6, KQ2E6, KQ3E6, KQ4E631919695
58 Eiffener, E, Eli, K, . The influence of preschoolers’ emotional and behavioural problems on obesity treatment outcomes: Secondary findings from a randomized controlled trial. Pediatr Obes. 14(11): e12556. 2019. PMID: 31290278. 10.1111/ijpo.12556 KQ1E6, KQ2E6, KQ3E6, KQ4E631290278
59 Ek, A, Lewis Chamberlain, K, . A Parent Treatment Program for Preschoolers With Obesity: A Randomized Controlled Trial. Pediatrics. 144(2): 08. 2019. PMID: 31300528. 10.1542/peds.2018-3457 KQ1E6, KQ2E6, KQ3E6, KQ4E631300528
60 Ek, A. (2022). “Early obesity : Family-based risk factors and treatment interventions.” [underlined: Dissertation abstracts international: section B: the sciences and engineering] 83(5-B): No Pagination Specified. KQ1E6, KQ2E6, KQ3E6, KQ4E6
61 Eldridge, G, Paul, L, . Effects of parent-only childhood obesity prevention programs on BMIz and body image in rural preteens. Body Image. 16. 143–53. 2016. PMID: 26851605. 10.1016/j.bodyim.2015.12.003 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a26851605
62 Elkind-Hirsch, KE, Chappell, N, . Exenatide, Dapagliflozin, or Phentermine/Topiramate Differentially Affect Metabolic Profiles in Polycystic Ovary Syndrome. J Clin Endocrinol Metab. 106(10): 3019–3033. 2021. PMID: 34097062. 10.1210/clinem/dgab408 KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a34097062
63 Enright, G, Gyani, A, . What Motivates Engagement in a Community-Based Behavior Change Strategy for Overweight Children?. Health Promot Pract. 23(1): 174–184. 2022. PMID: 32713213. 10.1177/1524839920944859 KQ1E6, KQ2E6, KQ3E6, KQ4E632713213
64 Erratum: effect of a home-visiting intervention to reduce early childhood obesity among Native American children: a randomized clinical trial (JAMA Pediatr. (2020) DOI: 10.1001/jamapediatrics.2020.3557). JAMA Pediatr. 2020. PMID: Pubmed 33315081. 10.1001/jamapediatrics.2020.6053 KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a33315081
65 Evia-Viscarra, ML, Rodea-Montero, ER, . The effects of metformin on inflammatory mediators in obese adolescents with insulin resistance: controlled randomized clinical trial. J Pediatr Endocrinol. 25(1–2): 41–9. 2012. PMID: 22570949. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b22570949
66 Falbe, J, Friedman, LE, . “She Gave Me the Confidence to Open Up”: Bridging Communication by Promotoras in a Childhood Obesity Intervention for Latino Families. Health Education & Behavior. 44(5): 728–737. 2017. PMID: 28851237. 10.1177/1090198117727323 KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a28851237
67 Fenner, AA, Howie, EK, . Relationships between psychosocial outcomes in adolescents who are obese and their parents during a multi-disciplinary family-based healthy lifestyle intervention: One-year follow-up of a waitlist controlled trial (Curtin University’s Activity, Food and Attitudes Program). Health Qual Life Outcomes. 14(1): 100. 2016. PMID: 27389034. 10.1186/s12955-016-0501-z KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a27389034
68 Fernandez-Ruiz, VE, Sole-Agusti, M, . Weight Loss and Improvement of Metabolic Alterations in Overweight and Obese Children Through the I2AO2 Family Program: A Randomized Controlled Clinical Trial. Biol Res Nurs. 23(3): 488–503. 2021. PMID: 33517762. 10.1177/1099800420987303 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a33517762
69 Fleischman, A, Hourigan, SE, . Creating an integrated care model for childhood obesity: a randomized pilot study utilizing telehealth in a community primary care setting. Clin Obes. 6(6): 380–388. 2016. PMID: 27863024. 10.1111/cob.12166 KQ1E6, KQ2E6, KQ3E6, KQ4E627863024
70 Foley, L, Ni Mhurchu, C, . Screen Time Weight-loss Intervention Targeting Children at Home (SWITCH): process evaluation of a randomised controlled trial intervention. BMC Public Health. 16. 439. 2016. PMID: 27230770. 10.1186/s12889-016-3124-8 KQ1E3, KQ2E3, KQ3E3, KQ4E327230770
71 Fonseca, H, Prioste, A, . Effectiveness analysis of an internet-based intervention for overweight adolescents: next steps for researchers and clinicians. BMC obesity. 3(1) (no pagination): . 2016. 10.1186/S40608-016-0094-4 KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a
72 Foster, BA, Weinstein, K, . Growing Healthy Together: A Randomized Clinical Trial Using Parent Mentors for Early Childhood Obesity in Low-Income, Latino Families. Childhood Obesity. 05. 05. 2021. PMID: 34613828. 10.1089/chi.2021.0165 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a34613828
73 Fowler, LA, Grammer, AC, . Examining the interdependence of parent-child dyads: Effects on weight loss and maintenance. Pediatr Obes. 16(1): e12697. 2021. PMID: 32720457. 10.1111/ijpo.12697 KQ1E6, KQ2E6, KQ3E6, KQ4E632720457
74 Freemark, M, Bursey, D. The effects of metformin on body mass index and glucose tolerance in obese adolescents with fasting hyperinsulinemia and a family history of type 2 diabetes. Pediatrics. 107(4): E55. 2001. PMID: 11335776. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b11335776
75 Freemark, M. Liver dysfunction in paediatric obesity: a randomized, controlled trial of metformin. Acta Paediatr. 96(9): 1326–32. 2007. PMID: 17718786. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b17718786
76 French, SA, Sherwood, NE, . Multicomponent Obesity Prevention Intervention in Low-Income Preschoolers: Primary and Subgroup Analyses of the NET-Works Randomized Clinical Trial, 2012-2017. Am J Public Health. 108(12): 1695–1706. 2018. PMID: 30403521. 10.2105/AJPH.2018.304696 KQ1E3, KQ2E3, KQ3E3, KQ4E330403521
77 French, SA, Sherwood, NE, . Physical changes in the home environment to reduce television viewing and sugar-sweetened beverage consumption among 5- to 12-year-old children: a randomized pilot study. Pediatr Obes. 11(5): e12–5. 2016. PMID: 26317968. 10.1111/ijpo.12067 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a26317968
78 Fulkerson, JA, Horning, M, . Weight outcomes of NU-HOME: a randomized controlled trial to prevent obesity among rural children. Int J Behav Nutr Phys Act. 19(1): 29. 2022. 10.1186/s12966-022-01260-w KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a35305674
79 Fulkerson, JA, Horning, ML, . Universal childhood obesity prevention in a rural community: Study design, methods and baseline participant characteristics of the NU-HOME randomized controlled trial. Contemp Clin Trials. 100. 106160. 2021. PMID: 33002598. 10.1016/j.cct.2020.106160 KQ1E3, KQ2E3, KQ3E3, KQ4E333002598
80 Gance-Cleveland, B, Ford, LC, . Technology to Support Motivational Interviewing. J Pediatr Nurs. 35. 120–128. 2017. PMID: 28728762. 10.1016/j.pedn.2017.03.014 KQ1E7, KQ2E7, KQ3E7, KQ4E728728762
81 Garza, C, Martinez, DA, . Effects of Telephone Aftercare Intervention for Obese Hispanic Children on Body Fat Percentage, Physical Fitness, and Blood Lipid Profiles. International Journal of Environmental Research & Public Health [Electronic Resource]. 16(24): 16. 2019. PMID: 31888169. 10.3390/ijerph16245133 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a31888169
82 Gomez, SF, Casas Esteve, R, . Effect of a community-based childhood obesity intervention program on changes in anthropometric variables, incidence of obesity, and lifestyle choices in Spanish children aged 8 to 10 years. Eur J Pediatr. 177(10): 1531–1539. 2018. PMID: 30027297. 10.1007/s00431-018-3207-x KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a30027297
83 Gonzalez-Ruiz, K, Correa-Bautista, Je, . Exercise dose on hepatic fat and cardiovascular health in adolescents with excess of adiposity. Pediatr Obes. 2021. 10.1111/ijpo.12869 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a
84 Gorin, AA, Wiley, J, . Steps to Growing Up Healthy: a pediatric primary care based obesity prevention program for young children. BMC Public Health. 14. 72. 2014. PMID: 24456698. 10.1186/1471-2458-14-72 KQ1E3, KQ2E3, KQ3E3, KQ4E324456698
85 Gulley, LD, Shomaker, LB, . Indirect Effects of a Cognitive-Behavioral Intervention on Adolescent Weight and Insulin Resistance Through Decreasing Depression in a Randomized Controlled Trial. J Pediatr Psychol. 44(10): 1163–1173. 2019. PMID: 31393981. 10.1093/jpepsy/jsz064 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a31393981
86 Grammer, A. C., . (2023). “Change in parent and child psychopathology following obesity treatment and maintenance: A secondary data analysis.” [underlined: Pediatric obesity] 18(1): e12971. KQ1E6, KQ2E6, KQ3E6, KQ4E635971859
87 Gross, A., . (2021) Urge to eat predicts weight loss maintenance in youth with severe obesity treated with exenatide. [underlined: Obesity (Silver Spring, Md.)] 29, 185- DOI: 10.1002/oby.23329. KQ1E5, KQ2E5, KQ3E5, KQ4E5
88 Gulley, L. D., . (2022). “Examining cognitive-behavioral therapy change mechanisms for decreasing depression, weight, and insulin resistance in adolescent girls at risk for type 2 diabetes.” [underlined: Journal of Psychosomatic Research] 157: 110781. KQ1E1, KQ2E1, KQ3E1, KQ4E135367918
89 Gyu-Young, Lee, Yun-Jung, Choi. Effects of an obesity management mentoring program for Korean children. Applied nursing research. 31. 160–164. 2016. 10.1016/j.apnr.2016.03.001 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a27397835
90 Hagman, E., . (2022). “Effect of an interactive mobile health support system and daily weight measurements for pediatric obesity treatment, a 1-year pragmatical clinical trial.” [underlined: International journal of obesity] 46(8): 1527–1533. KQ1E4, KQ2E4, KQ3E4, KQ4E435641569
91 Haines, J, Rifas-Shiman, SL, . Randomized trial of a prevention intervention that embeds weight-related messages within a general parenting program. Obesity. 24(1): 191–9. 2016. PMID: 26638185. 10.1002/oby.21314 KQ1E3, KQ2E3, KQ3E3, KQ4E326638185
92 Harshman, S. G., . (2022). “Pediatric weight management interventions improve prevalence of overeating behaviors.” [underlined: International journal of obesity] 46(3): 630–636. KQ1E6, KQ2E6, KQ3E6, KQ4E634862470
93 Hawkins, KR, Apolzan, JW, . Efficacy of a Home-Based Parent Training-Focused Weight Management Intervention for Preschool Children: The DRIVE Randomized Controlled Pilot Trial. J Nutr Educ Behav. 51(6): 740–748. 2019. PMID: 31178009. 10.1016/j.jneb.2019.04.002 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a31178009
94 Hay, J, Wittmeier, K, . Physical activity intensity and adiposity in overweight youth: A randomized controlled trial. 3rd National Obesity Summit. 37. S228. 2013. PMID: None. KQ1E6, KQ2E6, KQ3E6, KQ4E6
95 Hay, J, Wittmeier, K, . Physical activity intensity and type 2 diabetes risk in overweight youth: a randomized trial. Int J Obes (Lond). 2015. 10.1038/ijo.2015.241 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a
96 Heerman, WJ, Cole, J, . Qualitative analysis of COACH: A community-based behavioral intervention to reduce obesity health disparities within a marginalized community. Contemporary Clinical Trials Communications. 16. 100452. 2019. PMID: 31650072. 10.1016/j.conctc.2019.100452 KQ1E3, KQ2E3, KQ3E3, KQ4E331650072
97 Herbst, RB, Khalsa, AS, . Effective Implementation of Culturally Appropriate Tools in Addressing Overweight and Obesity in an Urban Underserved Early Childhood Population in Pediatric Primary Care. Clin Pediatr (Phila). 58(5): 511–520. 2019. PMID: 30841719. 10.1177/0009922819832088 KQ1E4, KQ2E4, KQ3E4, KQ4E430841719
98 Hrubeniuk, TJ, Hay, JL, . Interindividual variation in cardiometabolic health outcomes following 6 months of endurance training in youth at risk of type 2 diabetes mellitus. Appl Physiol Nutr Metab. 46(7): 727–734. 2021. PMID: 33544653. 10.1139/apnm-2020-0707 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a33544653
99 Hruska, V, Darlington, G, . Parent Stress as a Consideration in Childhood Obesity Prevention: Results from the Guelph Family Health Study, a Pilot Randomized Controlled Trial. Nutrients. 12(6): 19. 2020. PMID: 32575660. 10.3390/nu12061835 KQ1E3, KQ2E3, KQ3E3, KQ4E332575660
100 Hughes, AR, Stewart, L, . Randomized, controlled trial of a best-practice individualized behavioral program for treatment of childhood overweight: Scottish Childhood Overweight Treatment Trial (SCOTT). Pediatrics. 121(3): e539–46. 2008. PMID: 18310175. 10.1542/peds.2007-1786 KQ1E6, KQ2E6, KQ3E6, KQ4E618310175
101 Hystad, HT, Steinsbekk, S, . A randomised study on the effectiveness of therapist-led v. self-help parental intervention for treating childhood obesity. Br J Nutr. 110(6): 1143–50. 2013. PMID: 23388524. 10.1017/S0007114513000056 KQ1E6, KQ2E6, KQ3E6, KQ4E623388524
102 Jain, V., . (2022). “A comprehensive yoga programme for weight reduction in children & adolescents with obesity: A randomized controlled trial.” [underlined: Indian Journal of Medical Research] 155(3&4): 387–396. KQ1E2, KQ2E2, KQ3E2, KQ4E236124513
103 Janicke, DavidM, Gray, WendyN, . A pilot study examining a group-based behavioral family intervention for obese children enrolled in Medicaid: Differential outcomes by race. Children’s Health Care. 40(3): 212–231. 2011. 10.1080/02739615.2011.590394 KQ1E6, KQ2E6, KQ3E6, KQ4E6
104 Janicke, DM, Lim, CS, . Featured Article: Behavior Interventions Addressing Obesity in Rural Settings: The E-FLIP for Kids Trial. J Pediatr Psychol. 44(8): 889–901. 2019. PMID: 31039250. 10.1093/jpepsy/jsz029 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a31039250
105 Jelalian, E, Jandasek, B, . Cognitive-behavioral therapy plus healthy lifestyle enhancement for depressed, overweight/obese adolescents: results of a pilot trial. Journal of clinical child and adolescent psychology. 1–10. 2016. KQ1E3, KQ2E3, KQ3E3, KQ4E326743331
106 Johansson, L, Hagman, E, . A novel interactive mobile health support system for pediatric obesity treatment: a randomized controlled feasibility trial. BMC Pediatr. 20(1): 447. 2020. PMID: 32967638. 10.1186/s12887-020-02338-9 KQ1E6, KQ2E6, KQ3E6, KQ4E632967638
107 John, J., . (2021) Effectiveness of Parent Focused Group Program on Obesity-Related Behavior & Anthropometric Measurements among 6-12-Year-old Obese Children-A Pilot Study. [underlined: Medico-legal update] 21, 669–675 DOI: 10.37506/mlu.v21i2.2760. KQ1E2, KQ2E2, KQ3E2, KQ4E2
108 Johnson, WG, Hinkle, LK, . Dietary and exercise interventions for juvenile obesity: long-term effect of behavioral and public health models. Obes Res. 5(3): 257–61. 1997. PMID: 9192400. KQ1E6, KQ2E6, KQ3E6, KQ4E69192400
109 Jones, RA, Warren, JM, . Process evaluation of the Hunter Illawarra Kids Challenge Using Parent Support study: a multisite randomized controlled trial for the management of child obesity. Health Promot Pract. 11(6): 917–27. 2010. PMID: 19158237. 10.1177/1524839908328994 KQ1E6, KQ2E6, KQ3E6, KQ4E619158237
110 Kahhan, N, Hossain, MJ, . Durability of Changes in Biomarkers of Cardiometabolic Disease: 1-Year Family-Based Intervention in Children with Obesity. Metab Syndr Relat Disord. 19(5): 264–271. 2021. PMID: 33650888. 10.1089/met.2020.0097 KQ1E7, KQ2E2a, KQ3E7, KQ4E733650888
111 Kay, JP, Alemzadeh, R, . Beneficial effects of metformin in normoglycemic morbidly obese adolescents. Metabolism. 50(12): 1457–61. 2001. PMID: 11735093. 10.1053/meta.2001.28078 KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b11735093
112 Kelishadi, R. Liraglutide for management of adolescent obesity. Nature Reviews Endocrinology. 16(8): 405–406. 2020. PMID: 32514092. 10.1038/s41574-020-0371-7 KQ1E4, KQ2E4, KQ3E4, KQ4E432514092
113 Kelley, JC, Stettler-Davis, N, . Effects of a Randomized Weight Loss Intervention Trial in Obese Adolescents on Tibia and Radius Bone Geometry and Volumetric Density. J Bone Miner Res. 33(1): 42–53. 2018. PMID: 28884881. 10.1002/jbmr.3288 KQ1E6, KQ2E6, KQ3E6, KQ4E628884881
114 Kendall, D, Vail, A, . Metformin in obese children and adolescents: the MOCA trial. J Clin Endocrinol Metab. 98(1): 322–9. 2013. PMID: 23175691. 10.1210/jc.2012-2710 KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b23175691
115 Kittiya, Rattanamanee, Chintana, Wacharasin. Effectiveness of a Family-Based Behavioral Counseling Program among School-aged Children with Obesity: a Quasi-Experimental Study. Pacific rim international journal of nursing research. 25(3): 466–480. 2021. KQ1E2, KQ2E2, KQ3E2, KQ4E2
116 Kong, AP, Choi, KC, . A randomized controlled trial to investigate the impact of a low glycemic index (GI) diet on body mass index in obese adolescents. BMC Public Health. 14. 180. 2014. PMID: 24552366. 10.1186/1471-2458-14-180 KQ1E6, KQ2E6, KQ3E6, KQ4E624552366
117 Krystia, O, Ambrose, T, . A randomized home-based childhood obesity prevention pilot intervention has favourable effects on parental body composition: preliminary evidence from the Guelph Family Health Study. BMC Obesity. 6. 10. 2019. PMID: 30873285. 10.1186/s40608-019-0231-y KQ1E3, KQ2E3, KQ3E3, KQ4E330873285
118 Kumar, S, Croghan, IT, . Family-Based Mindful Eating Intervention in Adolescents with Obesity: A Pilot Randomized Clinical Trial. Children. 5(7): 06. 2018. PMID: 29986459. 10.3390/children5070093 KQ1E6, KQ2E6, KQ3E6, KQ4E629986459
119 Larruy-Garcia, A., . (2022) Changes in body composition after one year of lifestyle intervention in children at risk of obesity: preliminary results. Melipop study. [underlined: Annals of Nutrition & Metabolism] 78, 13- DOI: 10.1159/000526374. KQ1E10, KQ2E10, KQ3E10, KQ4E10
120 Larsen, KT, Huang, T, . The effect of a multi-component camp-based weight-loss program on children’s motor skills and physical fitness: a randomized controlled trial. BMC Pediatr. 16. 91. 2016. PMID: 27416906. 10.1186/s12887-016-0627-5 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a27416906
121 Larsen, LM, Hertel, NT, . Early intervention for childhood overweight: a randomized trial in general practice. Scand J Prim Health Care. 33(3): 184–90. 2015. PMID: 26194172. 10.3109/02813432.2015.1067511 KQ1E6, KQ2E6, KQ3E6, KQ4E626194172
122 Law, LH, Wilson, DK, . Families Improving Together (FIT) for weight loss: a resource for translation of a positive climate-based intervention into community settings. Transl Behav Med. 10(4): 1064–1069. 2020. PMID: 31167022. 10.1093/tbm/ibz020 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a31167022
123 Lee, SY, Kim, J, . A 24-week intervention based on nutrition care process improves diet quality, body mass index, and motivation in children and adolescents with obesity. Nutr Res. 84. 53–62. 2020. PMID: 33218692. 10.1016/j.nutres.2020.09.005 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a33218692
124 Lochrie, Amanda, Wysocki, Tim, . The effects of a family-based intervention (FBI) for overweight/obese children on health and psychological functioning. Clin Pract Pediatr Psychol. 1. 159. 2013. 10.1037/cpp0000020 KQ1E8, KQ2E8, KQ3E7, KQ4E7
125 Loeb, KL, Le Grange, D, . Adapting family-based treatment for paediatric obesity: A randomized controlled pilot trial. European Eating Disorders Review. 27(5): 521–530. 2019. PMID: 31344751. 10.1002/erv.2699 KQ1E6, KQ2E6, KQ3E6, KQ4E631344751
126 Logan, N. E. (2023). “Obesity, physical activity, cognition and brain function in preadolescent children.” [underlined: Dissertation abstracts international: section B: the sciences and engineering] 84(1-B): No Pagination Specified. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a
127 Lopez, KE, Salvy, SJ, . Executive Functioning, Depressive Symptoms, and Intervention Engagement in a Sample of Adolescents Enrolled in a Weight Management Program. Childhood Obesity. 17(4): 281–290. 2021. PMID: 33826861. 10.1089/chi.2020.0334 KQ1E6, KQ2E6, KQ3E6, KQ4E633826861
128 Love-Osborne, K, Sheeder, J, . Addition of metformin to a lifestyle modification program in adolescents with insulin resistance. J Pediatr. 152(6): 817–822. 2008. PMID: 18492523. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b18492523
129 Luque, V, Feliu, A, . The Obemat2.0 Study: A Clinical Trial of a Motivational Intervention for Childhood Obesity Treatment. Nutrients. 11(2): 16. 2019. PMID: 30781525. 10.3390/nu11020419 KQ1E6, KQ2E6, KQ3E6, KQ4E630781525
130 Magarey, AM, Perry, RA, . A parent-led family-focused treatment program for overweight children aged 5 to 9 years: the PEACH RCT. Pediatrics. 127(2): 214–22. 2011. PMID: 21262890. 10.1542/peds.2009-1432 KQ1E6, KQ2E6, KQ3E6, KQ4E621262890
131 Mani, S, Joseph, LH, . Feasibility of telemedicine or telephone-based family intervention for rural paediatric obesity: Cluster randomized control trial. J Telemed Telecare. 22(4): 264–5. 2016. PMID: 26362563. 10.1177/1357633X15601524 KQ1E4, KQ2E4, KQ3E4, KQ4E426362563
132 Matthan, NR, Wylie-Rosett, J, . Effect of a Family-Based Intervention on Nutrient Biomarkers, Desaturase Enzyme Activities, and Cardiometabolic Risk Factors in Children with Overweight and Obesity. Current Developments in Nutrition. 4(1): nzz138. 2020. PMID: 31922084. 10.1093/cdn/nzz138 KQ1E6, KQ2E6, KQ3E6, KQ4E631922084
133 McDuffie, JR, Calis, KA, . Efficacy of orlistat as an adjunct to behavioral treatment in overweight African American and Caucasian adolescents with obesity-related co-morbid conditions. J Pediatr Endocrinol Metab. 17(3): 307–19. 2004. PMID: 15112907 KQ1E4, KQ2E4, KQ3E4, KQ4E415112907
134 Md Yusop, NB, Mohd Shariff, Z, . The effectiveness of a stage-based lifestyle modification intervention for obese children. BMC Public Health. 18(1): 299. 2018. PMID: 29490648. 10.1186/s12889-018-5206-2 KQ1E2, KQ2E2, KQ3E2, KQ4E229490648
135 Minossi, V, Cecchetto, FH, . Healthy habits education for overweight children impacts both children and caregivers: A randomized clinical trial. Glob Heart. 9(Suppl 1): e226–e227. 2014. 10.1016/j.gheart.2014.03.2044 KQ1E10, KQ2E10, KQ3E10, KQ4E10
136 Miri, SF, Javadi, M, . Effectiveness of cognitive-behavioral therapy on nutrition improvement and weight of overweight and obese adolescents: A randomized controlled trial. Diabetes Metab Syndr. 13(3): 2190–2197. 2019. PMID: 31235156. 10.1016/j.dsx.2019.05.010 KQ1E2, KQ2E2, KQ3E2, KQ4E231235156
137 Moore, SM, Borawski, EA, . Two Family Interventions to Reduce BMI in Low-Income Urban Youth: A Randomized Trial. Pediatrics. 143(6): 06. 2019. PMID: 31126971. 10.1542/peds.2018-2185 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a31126971
138 Naguib, MonicaN, Hegedus, Elizabeth, . Continuous Glucose Monitoring in Adolescents With Obesity: Monitoring of Glucose Profiles, Glycemic Excursions, and Adherence to Time Restricted Eating Programs. Front Endocrinol (Lausanne). 13. 2022. 10.3389/fendo.2022.841838 KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a
139 Nambi, G., . (2022). “Clinical (BMI and MRI) and Biochemical (Adiponectin, Leptin, TNF-alpha, and IL-6) Effects of High-Intensity Aerobic Training with High-Protein Diet in Children with Obesity Following COVID-19 Infection.” [underlined: International Journal of Environmental Research & Public Health] [underlined: [Electronic Resource]] 19(12): 11. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a
140 Nct (2022) Expanding Health System Intervention Through The Women, Infants and Children (WIC) Program Partnership. https://clinicaltrials.gov/show/NCT05356338 KQ1E3, KQ2E3, KQ3E3, KQ4E3
141 Newsome, F. A., . (2022). “Wellness Achieved through Changing Habits: A Randomized Controlled Trial of an Acceptance-Based Intervention for Adolescent Girls with Overweight or Obesity.” [underlined: Childhood Obesity] 17: 17. KQ1E6, KQ2E6, KQ3E6, KQ4E6
142 Nguyen, B, Shrewsbury, V, . Adolescent and parent views of an adolescent weight management program: Lessons from the Loozit randomised controlled trial. Obes Res Clin Pract. 6. 56. 2012. 10.1016/j.orcp.2012.08.114 KQ1E6, KQ2E6, KQ3E6, KQ4E6
143 Nguyen, B, Shrewsbury, VA, . A process evaluation of an adolescent weight management intervention: findings and recommendations. Health Promot Int. 30(2): 201–12. 2015. PMID: 25550288. 10.1093/heapro/dau110 KQ1E6, KQ2E6, KQ3E6, KQ4E625550288
144 Nowicka, P, Hoglund, P, . Family Weight School treatment: 1-year results in obese adolescents. Int J Pediatr Obes. 3(3): 141–7. 2008. PMID: 18608623. 10.1080/17477160802102475 KQ1E4, KQ2E4, KQ3E4, KQ4E418608623
145 Ojeda-Rodriguez, A, Zazpe, I, . Improved Diet Quality and Nutrient Adequacy in Children and Adolescents with Abdominal Obesity after a Lifestyle Intervention. Nutrients. 10(10): 13. 2018. PMID: 30322156. 10.3390/nu10101500 KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a30322156
146 Ozkan, B, Bereket, A, . Addition of orlistat to conventional treatment in adolescents with severe obesity. Eur J Pediatr. 163(12): 738–41. 2004. PMID: 15378354. 10.1007/s00431-004-1534-6 KQ1E7, KQ2E8, KQ3E7, KQ4E715378354
147 Papageorgiou, AL, Efthymiou, V, . Comparison of Hospital Consultation and Summer Camp Lifestyle Intervention Programs for Sustained Body Weight Loss in Overweight/Obese Greek Children. Children. 9(1): 08. 2022. PMID: 35053711. 10.3390/children9010086 KQ1E5, KQ2E5, KQ3E5, KQ4E535053711
148 Pasquale, E, Neshteruk, CD, . An Integrated Clinic-Community Model to Treat Childhood Obesity: Revisiting 2 Years Later. Clin Pediatr (Phila). 59(12): 1092–1096. 2020. PMID: 32506928. 10.1177/0009922820930368 KQ1E6, KQ2E6, KQ3E6, KQ4E632506928
149 Patsopoulou, A, Tsimtsiou, Z, . Evaluating the Efficacy of the Feeding Exercise Randomized Trial in Overweight and Obese Adolescents. Childhood Obesity. 13(2): 128–137. 2017. PMID: 28075147. 10.1089/chi.2016.0192 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a28075147
150 Pena, A, McNeish, D, . Response heterogeneity to lifestyle intervention among Latino adolescents. Pediatr Diabetes. 21(8): 1430–1436. 2020. PMID: 32939893. 10.1111/pedi.13120 KQ1E7, KQ2E7, KQ3E7, KQ4E732939893
151 Perry, RA, Daniels, L, . Impact of a 6-month family-based weight management programme on child food and activity behaviours: short-term and long-term outcomes of the PEACH TM intervention. Pediatr Obes. 13(11): 744–751. 2018. PMID: 30280513. 10.1111/ijpo.12460 KQ1E6, KQ2E6, KQ3E6, KQ4E630280513
152 Perry, RA, Daniels, LA, . Facilitators and Barriers to the Achievement of Healthy Lifestyle Goals: Qualitative Findings From Australian Parents Enrolled in the PEACH Child Weight Management Program. J Nutr Educ Behav. 49(1): 43–52.e1. 2017. PMID: 27780669. 10.1016/j.jneb.2016.08.018 KQ1E6, KQ2E6, KQ3E6, KQ4E627780669
153 Persson, J. E. (2022). “Family-based prevention of childhood obesity: Long-term outcomes, challenges and implications for future research.” [underlined: Dissertation abstracts international: section B: the sciences and engineering] 83(5-B): No Pagination Specified. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a
154 Pine, AE, Schvey, NA, . A Pilot Feasibility Study of Interpersonal Psychotherapy for the Prevention of Excess Weight Gain Among Adolescent Military-dependent Girls. Mil Med. 186(3–4): 344–350. 2021. PMID: 33241297. 10.1093/milmed/usaa514 KQ1E6, KQ2E6, KQ3E6, KQ4E633241297
155 Prado, G, Fernandez, A, . Results of a Family-Based Intervention Promoting Healthy Weight Strategies in Overweight Hispanic Adolescents and Parents: An RCT. Am J Prev Med. 59(5): 658–668. 2020. PMID: 33011010. 10.1016/j.amepre.2020.06.010 KQ1E7, KQ2E2a, KQ3E2a, KQ4E733011010
156 Quattrin, T, Cao, Y, . Cost-effectiveness of Family-Based Obesity Treatment. Pediatrics. 140(3): . 2017. PMID: 28842402. 10.1542/peds.2016-2755 KQ1E6, KQ2E6, KQ3E6, KQ4E628842402
157 Quattrin, T, Roemmich, JN, . Efficacy of family-based weight control program for preschool children in primary care. Pediatrics. 130(4): 660–6. 2012. PMID: 22987879. 10.1542/peds.2012-0701 KQ1E6, KQ2E6, KQ3E6, KQ4E622987879
158 Racil, G, Coquart, JB, . Greater effects of high- compared with moderate-intensity interval training on cardio-metabolic variables, blood leptin concentration and ratings of perceived exertion in obese adolescent females. Biology of Sport. 33(2): 145–52. 2016. PMID: 27274107. 10.5604/20831862.1198633 KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a27274107
159 Raine, LB, Khan, NA, . Obesity, Visceral Adipose Tissue, and Cognitive Function in Childhood. J Pediatr. 187. 134–140.e3. 2017. PMID: 28622956. 10.1016/j.jpeds.2017.05.023 KQ1E3, KQ2E3, KQ3E3, KQ4E328622956
160 Randhawa, S, Randhawa, N, . Pilot evaluation of obesity-specific health-related quality of life following a 12-week non-randomized lifestyle intervention in youth. Obesity Science & Practice. 7(6): 803–807. 2021. PMID: 34877016. 10.1002/osp4.535 KQ1E4, KQ2E4, KQ3E4, KQ4E434877016
161 Raynor, HA, Propst, S, . Implementing Prevention Plus with Underserved Families in an Integrated Primary Care Setting. Childhood Obesity. 12. 12. 2021. PMID: 34767729. 10.1089/chi.2021.0071 KQ1E6, KQ2E6, KQ3E6, KQ4E634767729
162 Reilly, K. C. (2023). “Parents as agents of change in the treatment of childhood obesity and the promotion of children’s health behaviours.” [underlined: Dissertation Abstracts International Section A: Humanities and Social Sciences] 84(3-A): No Pagination Specified. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a
163 Reinehr, T, Bucksch, J, . 7-Year follow-up of a lifestyle intervention in overweight children: Comparison to an untreated control group. Clinical Nutrition. 37(5): 1558–1562. 2018. PMID: 28882396. 10.1016/j.clnu.2017.08.017 KQ1E4, KQ2E4, KQ3E4, KQ4E428882396
164 Reinehr, T, de Sousa, G, . Long-term follow-up of cardiovascular disease risk factors in children after an obesity intervention. Am J Clin Nutr. 84(3): 490–496. 2006. PMID: 16960161. KQ1E4, KQ2E4, KQ3E4, KQ4E416960161
165 Reinehr, T, Kleber, M, . Lifestyle intervention in obese children is associated with a decrease of the metabolic syndrome prevalence. Atherosclerosis. 207(1): 174–80. 2009. PMID: 19442975. 10.1016/j.atherosclerosis.2009.03.041 KQ1E4, KQ2E4, KQ3E4, KQ4E419442975
166 Reinehr, T, Temmesfeld, M, . Four-year follow-up of children and adolescents participating in an obesity intervention program. Int J Obes (Lond). 31(7): 1074–1077. 2007. PMID: 17471300. KQ1E4, KQ2E4, KQ3E4, KQ4E417471300
167 Riddiford-Harland, DL, Steele, JR, . Does participation in a physical activity program impact upon the feet of overweight and obese children?. Journal of Science & Medicine in Sport. 19(1): 51–5. 2016. PMID: 25499915. 10.1016/j.jsams.2014.11.008 KQ1E6, KQ2E6, KQ3E6, KQ4E625499915
168 Robertson, W, Fleming, J, . Randomised controlled trial and economic evaluation of the ‘Families for Health’ programme to reduce obesity in children. Arch Dis Child. 102(5): 416–426. 2017. PMID: 28003178. 10.1136/archdischild-2016-311514 KQ1E6, KQ2E6, KQ3E6, KQ4E628003178
169 Robertson, W, Fleming, J, . Randomised controlled trial evaluating the effectiveness and cost-effectiveness of ‘Families for Health’, a family-based childhood obesity treatment intervention delivered in a community setting for ages 6 to 11 years. Health Technol Assess. 21(1): 1–180. 2017. PMID: 28059054. 10.3310/hta21010 KQ1E6, KQ2E6, KQ3E6, KQ4E628059054
170 Robinson, TN, Matheson, D, . A community-based, multi-level, multi-setting, multi-component intervention to reduce weight gain among low socioeconomic status Latinx children with overweight or obesity: The Stanford GOALS randomised controlled trial. The Lancet Diabetes & Endocrinology. 9(6): 336–349. 2021. PMID: 33933181. 10.1016/S2213-8587(21)00084-X KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a33933181
171 Roh, HT, Cho, SY, . Effects of Regular Taekwondo Intervention on Oxidative Stress Biomarkers and Myokines in Overweight and Obese Adolescents. International Journal of Environmental Research & Public Health [Electronic Resource]. 17(7): 06. 2020. PMID: 32268592. 10.3390/ijerph17072505 KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a32268592
172 Rojo, M., . (2022). “Family-reported barriers and predictors of short-term attendance in a multidisciplinary intervention for managing childhood obesity: A psycho-family-system based randomised controlled trial (ENTREN-F).” [underlined: European eating disorders review] 30(6): 746–759. KQ1E6, KQ2E6, KQ3E6, KQ4E635644038
173 Rolin, J., . (2022). “Supplementary drug treatment to reduce weight in adolescents with severe obesity.” [underlined: Tidsskrift for Den Norske Laegeforening] 142(14): 11. KQ1E4, KQ2E4, KQ3E4, KQ4E4
174 Rosenkranz, RR, Cull, BJ, . Home-Based Health Coaching for Girls With Overweight and Obesity: A Randomized Clinical Trial. JAMA Netw Open. 5(6): e2216720. 2022. 10.1001/jamanetworkopen.2022.16720 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a35696168
175 Rubin, DA, Wilson, KS, . Effectiveness of a Parent-led Physical Activity Intervention in Youth with Obesity. Med Sci Sports Exerc. 51(4): 805–813. 2019. PMID: 30407275. 10.1249/MSS.0000000000001835 KQ1E1, KQ2E1, KQ3E1, KQ4E130407275
176 Sanchez-Lopez, AM, Menor-Rodriguez, MJ, . Play as a Method to Reduce Overweight and Obesity in Children: An RCT. International Journal of Environmental Research & Public Health [Electronic Resource]. 17(1): 03. 2020. PMID: 31947884. 10.3390/ijerph17010346 KQ1E6, KQ2E6, KQ3E6, KQ4E631947884
177 Salahshoornezhad, S., . (2022). “Effect of a multi-disciplinary program on anthropometric and biochemical parameters in obese and overweight elementary school girls: A randomized clinical trial.” [underlined: Nutrition Metabolism & Cardiovascular Diseases] 32(8): 1982–1989. KQ1E2, KQ2E2, KQ3E2, KQ4E2
178 Samuels, S., . (2022) Real-world effectiveness of the Bright Bodies healthy lifestyle intervention for childhood obesity. [underlined: Obesity (Silver Spring, Md.)] DOI: 10.1002/oby.23627. KQ1E4, KQ2E4, KQ3E4, KQ4E4
179 Sauder, KA, Dabelea, D, . Targeting risk factors for type 2 diabetes in American Indian youth: the Tribal Turning Point pilot study. Pediatr Obes. 13(5): 321–329. 2018. PMID: 28635082. 10.1111/ijpo.12223 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a28635082
180 Schaefer, A, Winkel, K, . An effective lifestyle intervention in overweight children: one-year follow-up after the randomized controlled trial on “Obeldicks light”. Clin Nutr. 30(5): 629–33. 2011. PMID: 21514017. 10.1016/j.clnu.2011.03.012 KQ1E4, KQ2E4, KQ3E4, KQ4E421514017
181 Schneiders, LB, Brand, C, . A Multicomponent Intervention Program With Overweight and Obese Adolescents Improves Body Composition and Cardiorespiratory Fitness, but Not Insulin Biomarkers. Frontiers in Sports & Active Living. 3. 621055. 2021. PMID: 33693430. 10.3389/fspor.2021.621055 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a33693430
182 Seo, YG, Lim, H, . Effects of circuit training or a nutritional intervention on body mass index and other cardiometabolic outcomes in children and adolescents with overweight or obesity. PLoS ONE [Electronic Resource]. 16(1): e0245875. 2021. PMID: 33507953. 10.1371/journal.pone.0245875 KQ1E6, KQ2E6, KQ3E6, KQ4E633507953
183 Serra-Paya, N, Ensenyat, A, . Effectiveness of a multi-component intervention for overweight and obese children (Nereu Program): a randomized controlled trial. PLoS One. 10(12): e0144502. 2015. PMID: 26658988. 10.1371/journal.pone.0144502 KQ1E6, KQ2E6, KQ3E6, KQ4E626658988
184 Shah, NB, Fenick, AM, . A Healthy Weight for Toddlers? Two-Year Follow-up of a Randomized Controlled Trial of Group Well-Child Care. Clin Pediatr (Phila). 55(14): 1354–1357. 2016. PMID: 26823557. 10.1177/0009922815623230 KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a26823557
185 Sharifi, M, Franz, C, . Cost-Effectiveness of a Clinical Childhood Obesity Intervention. Pediatrics. 140(5). 2017. PMID: 29089403. 10.1542/peds.2016-2998 KQ1E4, KQ2E4, KQ3E4, KQ4E429089403
186 Sherwood, NE, JaKa, MM, . Pediatric primary care-based obesity prevention for parents of preschool children: a pilot study. Child Obes. 11(6): 674–82. 2015. PMID: 26478951. 10.1089/chi.2015.0009 KQ1E3, KQ2E3, KQ3E3, KQ4E326478951
187 Shomaker, LB, Tanofsky-Kraff, M, . A randomized, comparative pilot trial of family-based interpersonal psychotherapy for reducing psychosocial symptoms, disordered-eating, and excess weight gain in at-risk preadolescents with loss-of-control-eating. International Journal of Eating Disorders. 50(9): 1084–1094. 2017. PMID: 28714097. 10.1002/eat.22741 KQ1E6, KQ2E6, KQ3E6, KQ4E628714097
188 Siegrist, M, Heitkamp, M, . Changes of omentin-1 and chemerin during 4 weeks of lifestyle intervention and 1 year follow-up in children with obesity. Clinical Nutrition. 40(11): 5648–5654. 2021. PMID: 34666255. 10.1016/j.clnu.2021.09.042 KQ1E4, KQ2E4, KQ3E4, KQ4E434666255
189 Sierra Velez, D., . (2022). “Effects of a Pediatric Weight Management Intervention on Parental Stress.” [underlined: Childhood Obesity] 18(3): 160–167. KQ1E6, KQ2E6, KQ3E6, KQ4E634619054
190 Silveira, Ds, Lemos, Lfgbf, . Effect of a pilot multi-component intervention on motor performance and metabolic risks in overweight/obese youth. J Sports Sci. 36(20): 2317–2326. 2018. 10.1080/02640414.2018.1452142 KQ1E2, KQ2E2, KQ3E2, KQ4E229558321
191 Skjåkødegård, H., . (2022) Family-based treatment of children with severe obesity in a public healthcare setting: results from a randomized controlled trial. [underlined: Clinical obesity] 12, e12513 DOI: 10.1111/cob.12513 KQ1E6, KQ2E6, KQ3E6, KQ4E635218145
192 Small, L, Thacker, L, . A Pilot Intervention Designed to Address Behavioral Factors That Place Overweight/Obese Young Children at Risk for Later-Life Obesity. West J Nurs Res. 39(8): 1192–1212. 2017. PMID: 28511584. 10.1177/0193945917708316 KQ1E8, KQ2E8, KQ3E8, KQ4E828511584
193 Soltero, EG, Ayers, SL, . Theoretical Mediators of Diabetes Risk and Quality of Life Following a Diabetes Prevention Program for Latino Youth With Obesity. American Journal of Health Promotion. 35(7): 939–947. 2021. PMID: 33949215. 10.1177/08901171211012951 KQ1E5, KQ2E5, KQ3E7, KQ4E733949215
194 Soltero, EG, Olson, ML, . Effects of a Community-Based Diabetes Prevention Program for Latino Youth with Obesity: A Randomized Controlled Trial. Obesity. 26(12): 1856–1865. 2018. PMID: 30426694. 10.1002/oby.22300 KQ1E5, KQ2E5, KQ3E5, KQ4E530426694
195 Song, W. Effects of a training program on lifestyle modification for adolescents identified with overweight. Neuroquantology. 15(4): 174–179. 2017. 10.14704/nq.2017.15.4.1147 KQ1E2, KQ2E2, KQ3E2, KQ4E2
196 Srinivasan, S, Ambler, GR, . Randomized, controlled trial of metformin for obesity and insulin resistance in children and adolescents: improvement in body composition and fasting insulin. J Clin Endocrinol Metab. 91(6): 2074–2080. 2006. PMID: 16595599. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b16595599
197 Staiano, AE, Beyl, RA, . Home-based exergaming among children with overweight and obesity: a randomized clinical trial. Pediatr Obes. 13(11): 724–733. 2018. PMID: 30027607. 10.1111/ijpo.12438 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a30027607
198 Steele, RG, Aylward, BS, . Comparison of a family-based group intervention for youths with obesity to a brief individual family intervention: a practical clinical trial of positively fit. J Pediatr Psychol. 37(1): 53–63. 2012. PMID: 21852343. 10.1093/jpepsy/jsr057 KQ1E6, KQ2E6, KQ3E6, KQ4E621852343
199 Stewart, L, Houghton, J, . Dietetic management of pediatric overweight: development and description of a practical and evidence-based behavioral approach. J Am Diet Assoc. 105(11): 1810–5. 2005. PMID: 16256768. 10.1016/j.jada.2005.08.006 KQ1E4, KQ2E4, KQ3E4, KQ4E416256768
200 Sundar, TKB, Londal, K, . Overweight adolescents’ views on physical activity - experiences of participants in an internet-based intervention: a qualitative study. BMC Public Health. 18(1): 448. 2018. PMID: 29618327. 10.1186/s12889-018-5324-x KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a29618327
201 Topham, GL, Washburn, IJ, . The Families and Schools for Health Project: A Longitudinal Cluster Randomized Controlled Trial Targeting Children with Overweight and Obesity. International Journal of Environmental Research & Public Health [Electronic Resource]. 18(16): 19. 2021. PMID: 34444492. 10.3390/ijerph18168744 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a34444492
202 Towner, EK, Kapur, G, . Physical Activity as a Predictor of Changes in Systolic Blood Pressure for African-American Adolescents Seeking Treatment for Obesity. J Adolesc Health. 65(3): 430–432. 2019. PMID: 31227385. 10.1016/j.jadohealth.2019.04.001 KQ1E6, KQ2E6, KQ3E6, KQ4E631227385
203 Trajkovic, N, Lazic, A, . Effects of After-School Volleyball Program on Body Composition in Overweight Adolescent Girls. Children. 9(1): 29. 2021. PMID: 35053646. 10.3390/children9010021 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a35053654
204 Tucker, JM, DeFrang, R, . Evaluation of a Primary Care Weight Management Program in Children Aged 2-5 years: Changes in Feeding Practices, Health Behaviors, and Body Mass Index. Nutrients. 11(3): 27. 2019. PMID: 30818772. 10.3390/nu11030498 KQ1E4, KQ2E4, KQ3E4, KQ4E430818772
205 Tyler, DO, Horner, SD. A primary care intervention to improve weight in obese children: A feasibility study. J Am Assoc Nurse Pract. 28(2): 98–106. 2016. 10.1002/2327-6924.12246 KQ1E8, KQ2E8, KQ3E7, KQ4E725782163
206 van Leeuwen, Janneke, Andrinopoulou, Eleni-Rosalina, . The effect of a multidisciplinary intervention program for overweight and obese children on cardiorespiratory fitness and blood pressure. Fam Pract. 36(2): 147–153. 2019. 10.1093/fampra/cmy061 KQ1E4, KQ2E4, KQ3E4, KQ4E429939242
207 Vander Wyst, KB, Olson, ML, . Yields and costs of recruitment methods with participant phenotypic characteristics for a diabetes prevention research study in an underrepresented pediatric population. Trials [Electronic Resource]. 21(1): 716. 2020. PMID: 32799920. 10.1186/s13063-020-04658-8 KQ1E7, KQ2E7, KQ3E7, KQ4E732799920
208 Vermeiren, E, Naets, T, . Improving Treatment Outcome in Children With Obesity by an Online Self-Control Training: A Randomized Controlled Trial. Frontiers in Pediatrics. 9. 794256. 2021. PMID: 35004547. 10.3389/fped.2021.794256 KQ1E6, KQ2E6, KQ3E6, KQ4E635004547
209 Vidmar, AP, Goran, MI, . Time limited eating in adolescents with obesity (time LEAd): Study protocol. Contemp Clin Trials. 95. 106082. 2020. PMID: 32682994. 10.1016/j.cct.2020.106082 KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a32682994
210 Vidmar, A., . (2021) Changes in food addiction scores over the course of weight management interventions in a diverse sample of adolescents with overweight and obesity. [underlined: Hormone research in paediatrics] 94, 94–95 KQ1E6, KQ2E6, KQ3E6, KQ4E6
211 Vidmar, A. P., . (2022). “An addiction-based digital weight loss intervention: A multi-centre randomized controlled trial.” [underlined: Pediatric obesity]: e12990. KQ1E6, KQ2E6, KQ3E6, KQ4E636484235
212 Visuthranukul, C, Hurst, C, . Effects of low-glycemic index diet on plasma adipokines in obese children. Pediatr Res. 90(5): 1009–1015. 2021. PMID: 33753893. 10.1038/s41390-021-01463-0 KQ1E2, KQ2E2, KQ3E2, KQ4E233753893
213 Walpole, B, Dettmer, E, . Motivational interviewing to enhance self-efficacy and promote weight loss in overweight and obese adolescents: a randomized controlled trial. J Pediatr Psychol. 38(9): 944–53. 2013. PMID: 23671058. 10.1093/jpepsy/jst023 KQ1E6, KQ2E6, KQ3E6, KQ4E623671058
214 Wen, L., . (2022) Effectiveness of a combined telephone and SMS support to mothers with children between 2 and 3 years in reducing children’s BMI at 3 years: a randomized controlled trial. [underlined: Obesity reviews] 23, DOI: 10.1111/obr.13502. KQ1E10, KQ2E10, KQ3E10, KQ4E10
215 Wiegand, S, l’Allemand, D, . Metformin and placebo therapy both improve weight management and fasting insulin in obese insulin-resistant adolescents: a prospective, placebo-controlled, randomized study. Eur J Endocrinol. 163(4): 585–92. 2010. PMID: 20639355. 10.1530/EJE-10-0570 KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b20639355
216 Wild, CEK, Wynter, LE, . Five-year follow-up of a family-based multidisciplinary program for children with obesity. Obesity. 29(9): 1458–1468. 2021. PMID: 34370401. 10.1002/oby.23225 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a34370401
217 Wilfley, DE, Saelens, BE, . Dose, Content, and Mediators of Family-Based Treatment for Childhood Obesity: A Multisite Randomized Clinical Trial. JAMA Pediatr. 171(12): 1151–1159. 2017. PMID: 29084318. 10.1001/jamapediatrics.2017.2960 KQ1E6, KQ2E6, KQ3E6, KQ4E629084318
218 Williams, CF, Bustamante, EE, . Exercise effects on quality of life, mood, and self-worth in overweight children: the SMART randomized controlled trial. Transl Behav Med. 9(3): 451–459. 2019. PMID: 31094443. 10.1093/tbm/ibz015 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a31094443
219 Williamson, DA, Martin, PD, . Efficacy of an internet-based behavioral weight loss program for overweight adolescent African-American girls. Eat Weight Disord. 10(3): 193–203. 2005. PMID: 16277142. KQ1E6, KQ2E6, KQ3E6, KQ4E616277142
220 Williamson, DA, Walden, HM, . Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring). 14(7): 1231–43. 2006. PMID: 1689980. 10.1038/oby.2006.140 KQ1E6, KQ2E6, KQ3E6, KQ4E616899804
221 Wilson, AJ, Prapavessis, H, . Lifestyle modification and metformin as long-term treatment options for obese adolescents: study protocol. BMC Public Health. 9. 434. 2009. PMID: 19943971. 10.1186/1471-2458-9-434 KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b19943971
222 Wilson, DK, Kitzman-Ulrich, H, . An overview of the Families Improving Together (FIT) for weight loss randomized controlled trial in African American families. Contemp Clin Trials. 42. 145–57. 2015. 10.1016/j.cct.2015.03.009 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a25835731
223 Wilson, DK, Sweeney, AM, . Web-Based Program Exposure and Retention in the Families Improving Together for Weight Loss Trial. Annals of Behavioral Medicine. 53(4): 399–404. 2019. PMID: 30892641. 10.1093/abm/kay047 KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a30892641
224 Wilson, DM, Abrams, SH, . Metformin extended release treatment of adolescent obesity: a 48-week randomized, double-blind, placebo-controlled trial with 48-week follow-up. Arch Pediatr Adolesc Med. 164(2): 116–23. 2010. PMID: 20124139. 10.1001/archpediatrics.2009.264 KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b20124139
225 Wolff, Maren Mae. Facilitating lifestyle behavior change in the primary care setting with a staged approach to childhood obesity treatment. Dissertation Abstracts International: Section B: The Sciences and Engineering. 80(2-B(E)): No Pagination Specified. 2019. KQ1E1, KQ2E1, KQ3E1, KQ4E1
226 Woo, S., . (2022) Additive Effects of Exercise or Nutrition Intervention in a 24-Month Multidisciplinary Treatment with a Booster Intervention for Children and Adolescents with Overweight or Obesity: the ICAAN Study. Nutrients 14, DOI: 10.3390/nu14020387. KQ1E4, KQ2E4, KQ3E4, KQ4E4
227 Wright, JA, Phillips, BD, . Randomized trial of a family-based, automated, conversational obesity treatment program for underserved populations. Obesity (Silver Spring). 21(9): E369–78. 2013. 10.1002/oby.20388 KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a23512915
228 Wylie-Rosett, J, Groisman-Perelstein, AE, . Embedding weight management into safety-net pediatric primary care: randomized controlled trial. International Journal of Behavioral Nutrition & Physical Activity. 15(1): 12. 2018. PMID: 29357894. 10.1186/s12966-017-0639-z KQ1E6, KQ2E6, KQ3E6, KQ4E629357894
229 Xiang, MQ, Liao, JW, . Effect of a Combined Exercise and Dietary Intervention on Self-Control in Obese Adolescents. Front Psychol. 10. 1385. 2019. PMID: 31316417. 10.3389/fpsyg.2019.01385 KQ1E2, KQ2E2, KQ3E2, KQ4E231316417
230 Yackobovitch-Gavan, M, Wolf Linhard, D, . Intervention for childhood obesity based on parents only or parents and child compared with follow-up alone. Pediatr Obes. 13(11): 647–655. 2018. PMID: 29345113. 10.1111/ijpo.12263 KQ1E7, KQ2E8, KQ3E8, KQ4E729345113
231 Yanovski, J. Safety and efficacy of xenical in children and adolescents with obesity-related diseases. NCT00001723. 2017(02/05/2016): . 2012. PMID: None. KQ1E10, KQ2E10, KQ3E10, KQ4E10
232 Yanovski, JA, Krakoff, J, . Effects of metformin on body weight and body composition in obese insulin-resistant children: a randomized clinical trial. Diabetes. 60(2): 477–85. 2011. PMID: 21228310. 10.2337/db10-1185 KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b21228310
233 Zanatta, LB, Heinzmann-Filho, JP, . Effect of an interdisciplinary intervention with motivational approach on exercise capacity in obese adolescents: a randomized controlled clinical trial. Einstein. 18. eAO5268. 2020. PMID: 32428066. 10.31744/einstein_journal/2020ao5268 KQ1E2, KQ2E2, KQ3E2, KQ4E232428066