# Appendix B Included Studies

- Boutelle, Kerrin, Zucker, Nancy, . An intervention based on Schachter’s externality theory for overweight children: The Regulation of Cues pilot. J Pediatr Psychol. 39(4): 405–417. 2014. PMID: 24459240. 10.1093/jpepsy/jst142 24459240
- Broccoli, S, Davoli, AM, . Motivational interviewing to treat overweight children: 24-month follow-up of a randomized controlled trial. Pediatrics. 137(1): 1–10. 2016. PMID: 26702030. 10.1542/peds.2015-1979 26702030
  - Broccoli, S, Bonvicini, L, . Understanding the association between mother’s education level and effectiveness of a child obesity prevention intervention: a secondary analysis of an RCT. Epidemiol Prev. 44(5-6 Suppl 1): 153–162. 2020. PMID: 33415958. 10.19191/EP20.5-6.S1.P153.085 33415958
  - Davoli, AM, Broccoli, S, . Pediatrician-led motivational interviewing to treat overweight children: an RCT. Pediatrics. 132(5): e1236–46. 2013. PMID: 24144717. 10.1542/peds.2013-1738 24144717
- Bryant, M, Farrin, A, . Results of a feasibility randomised controlled trial (RCT) for WATCH IT: a programme for obese children and adolescents. Clin Trials. 8(6): 755–64. 2011. PMID: 22024104. 10.1177/1740774511424766 22024104
  - Rudolf, M, Christie, D, . WATCH IT: a community based programme for obese children and adolescents. Arch Dis Child. 91(9): 736–9. 2006. PMID: 16531453. 10.1136/adc.2005.089896 16531453
- Chanoine, JP, Hampl, S, . Effect of orlistat on weight and body composition in obese adolescents: a randomized controlled trial. JAMA. 293(23): 2873–2883. 2005. PMID: 15956632.15956632
  - Chanoine, JP, Richard, M. Early weight loss and outcome at one year in obese adolescents treated with orlistat or placebo. Int J Pediatr Obes. 6(2): 95–101. 2011. PMID: 20858149. 10.3109/17477166.2010.519387 20858149
- Croker, H, Viner, RM, . Family-based behavioural treatment of childhood obesity in a UK National Health Service setting: randomized controlled trial. Int J Obes (Lond). 36(1): 16–26. 2012. PMID: 21931327. 10.1038/ijo.2011.182 21931327
- Danne, T, Biester, T, . Liraglutide in an Adolescent Population with Obesity: A Randomized, Double-Blind, Placebo-Controlled 5-Week Trial to Assess Safety, Tolerability, and Pharmacokinetics of Liraglutide in Adolescents Aged 12-17 Years. J Pediatr. 181. 146–153.e3. 2017. PMID: 27979579. 10.1016/j.jpeds.2016.10.076 27979579
- Davis, JN, Ventura, EE, . Effects of a randomized maintenance intervention on adiposity and metabolic risk factors in overweight minority adolescents. Pediatr Obes. 7(1): 16–27. 2012. PMID: 22434736. 10.1111/j.2047-6310.2011.00002.x 22434736
- DeBar, LL, Stevens, VJ, . A primary care-based, multicomponent lifestyle intervention for overweight adolescent females. Pediatrics. 129(3): e611–20. 2012. PMID: 22331335. 10.1542/peds.2011-0863 22331335
- Derwig, M, Tiberg, I, . A child-centered health dialogue for the prevention of obesity in child health services in Sweden - A randomized controlled trial including an economic evaluation. Obesity Science & Practice. 8(1): 77–90. 2022. PMID: 35127124. 10.1002/osp4.547 35127124
- Gerards, SM, Dagnelie, PC, . The effectiveness of lifestyle triple p in the Netherlands: a randomized controlled trial. PLoS One. 10(4): e0122240. 2015. PMID: 25849523. 10.1371/journal.pone.0122240 25849523
  - Gerards, SM, Dagnelie, PC, . Lifestyle Triple P: a parenting intervention for childhood obesity. BMC Public Health. 12. 267. 2012. PMID: 22471971. 10.1186/1471-2458-12-267 22471971
- Golley, RK, Magarey, AM, . Twelve-month effectiveness of a parent-led, family-focused weight-management program for prepubertal children: a randomized, controlled trial. Pediatrics. 119(3): 517–525. 2007. PMID: 17332205. 10.1542/peds.2006-1746 17332205
  - Golley, RebeccaK, Perry, RebeccaA, . Family-focused weight management program for five- to nine-year-olds incorporating parenting skills training with healthy lifestyle information to support behaviour modification. Nutr Diet. 64(3): 144–150. 2007. PMID: 24843434. 10.1111/j.1747-0080.2007.00106.x 24843434
  - Golley, RK, Magarey, AM, . Children’s food and activity patterns following a six-month child weight management program. Int J Pediatr Obes. 6(5–6): 409–14. 2011. PMID: 21838569. 10.3109/17477166.2011.605894 21838569
  - Golley, RK, Magarey, AM, . Comparison of metabolic syndrome prevalence using six different definitions in overweight pre-pubertal children enrolled in a weight management study. Int J Obes (Lond). 30(5): 853–60. 2006. PMID: 16404409.16404409
  - Sanders, MR. Triple P-Positive Parenting Program: towards an empirically validated multilevel parenting and family support strategy for the prevention of behavior and emotional problems in children. Clin Child Fam Psychol Rev. 2(2): 71–90. 1999. PMID: 11225933.11225933
- Ho, J, Pedersen, SD, . Family Intervention for Obese/Overweight Children Using Portion Control Strategy (FOCUS) for Weight Control: A Randomized Controlled Trial. Lobal Pediatric Health. 3. 2333794X16669014. 2016. PMID: 27699184.27699184
- Hofsteenge, GH, Chinapaw, MJ, . Long-term effect of the Go4it group treatment for obese adolescents: a randomised controlled trial. Clin Nutr. 33(3): 385–91. 2014. PMID: 23810626. 10.1016/j.clnu.2013.06.002 23810626
  - Hofsteenge, GH, Chinapaw, MJ, . Go4it; study design of a randomised controlled trial and economic evaluation of a multidisciplinary group intervention for obese adolescents for prevention of diabetes mellitus type 2. BMC Public Health. 8. 410. 2008. PMID: 19087330. 10.1186/1471-2458-8-410 19087330
  - Hofsteenge, GH, Weijs, PJ, . Effect of the Go4it multidisciplinary group treatment for obese adolescents on health related quality of life: a randomised controlled trial. BMC Public Health. 13. 939. 2013. PMID: 24103472. 10.1186/1471-2458-13-939 24103472
  - Weijs, PJ, Hofsteenge, AG, . Long-term effect of the Go4it group treatment for obese adolescents: A randomised controlled trial. Clinical Nutrition. 7(1 Suppl): 130. 2012. PMID: 23810626. 10.1016/S1744-1161%2812%2970317-4 23810626
- Hsia, DS, Gosselin, NH, . A randomized, double-blind, placebo-controlled, pharmacokinetic and pharmacodynamic study of a fixed-dose combination of phentermine/topiramate in adolescents with obesity. Diabetes Obes Metab. 22(4): 480–491. 2020. PMID: 31696603. 10.1111/dom.13910 31696603
- Kalarchian, MA, Levine, MD, . Family-based treatment of severe pediatric obesity: randomized, controlled trial. Pediatrics. 124(4): 1060–8. 2009. PMID: 19786444. 10.1542/peds.2008-3727 19786444
  - Wildes, JE, Marcus, MD, . Self-reported binge eating in severe pediatric obesity: impact on weight change in a randomized controlled trial of family-based treatment. Int J Obes (Lond). 34(7): 1143–8. 2010. PMID: 20157322. 10.1038/ijo.2010.35 20157322
- Kalavainen, MP, Korppi, MO, . Clinical efficacy of group-based treatment for childhood obesity compared with routinely given individual counseling. Int J Obes (Lond). 31(10): 1500–8. 2007. PMID: 17438555. 10.1038/sj.ijo.0803628 17438555
  - Kalavainen, M, Korppi, M, . Long-term efficacy of group-based treatment for childhood obesity compared with routinely given individual counselling. Int J Obes. 35(4): 530–3. 2011. PMID: 21285943. 10.1038/ijo.2011.1 21285943
  - Kalavainen, M, Utriainen, P, . Impact of childhood obesity treatment on body composition and metabolic profile. World J Pediatr. 8(1): 31–7. 2012. PMID: 22105574. 10.1007/s12519-011-0324-2 22105574
- Kelly, AS, Auerbach, P, . A Randomized, Controlled Trial of Liraglutide for Adolescents with Obesity. N Engl J Med. 382(22): 2117–2128. 2020. PMID: 32233338. 10.1056/NEJMoa1916038 32233338
  - Kelly, AS, Hale, PM. Liraglutide for Adolescents with Obesity. Reply. N Engl J Med. 383(12): 1193–1194. 2020. PMID: 32937058. 10.1056/NEJMc2023284 32937058
  - Maljaei, MB, Bahreini, A. Liraglutide for Adolescents with Obesity. N Engl J Med. 383(12): 1193. 2020. PMID: 32937057. 10.1056/NEJMc2023284 32937057
- Kelly, AS, Bensignor, MO, . Phentermine/Topiramate for the Treatment of Adolescent Obesity. N Engl J Med Evid. 1(6). 2022. PMID: None. DOI:10.1056/EVIDoa2200014
- Kong, AS, Sussman, AL, . School-based health center intervention improves body mass index in overweight and obese adolescents. J Obes. 2013. 575016. 2013. PMID: 23589771. 10.1155/2013/575016 23589771
- Kose, S, Yildiz, S. Motivational support programme to enhance health and well-being and promote weight loss in overweight and obese adolescents: A randomized controlled trial in Turkey. Int J Nurs Pract. 27(1): e12878. 2021. PMID: 32808423. 10.1111/ijn.12878 32808423
- Lison, JF, Real-Montes, JM, . Exercise intervention in childhood obesity: a randomized controlled trial comparing hospital-versus home-based groups. Acad Pediatr. 12(4): 319–25. 2012. PMID: 22634075. 10.1016/j.acap.2012.03.003 22634075
- Looney, SM, Raynor, HA. Examining the effect of three low-intensity pediatric obesity interventions: a pilot randomized controlled trial. Clin Pediatr (Phila). 53(14): 1367–74. 2014. PMID: 25006118. 10.1177/0009922814541803 25006118
- Love-Osborne, K, Fortune, R, . School-based health center-based treatment for obese adolescents: feasibility and body mass index effects. Child Obes. 10(5): 424–31. 2014. PMID: 25259781. 10.1089/chi.2013.0165 25259781
  - Fortune, R, Love-Osborne, K, . Use of text messaging as an adjunct to obesity prevention and treatment in school-based health clinics. J Adolesc Health. 50(2 suppl. 1): S33. 2012. PMID: None. 10.1016/j.jadohealth.2011.10.094
- Maahs, D, de Serna, DG, . Randomized, double-blind, placebo-controlled trial of orlistat for weight loss in adolescents. Endocr Pract. 12(1): 18–28. 2006. PMID: 16524859.16524859
- Mastrandrea, LD, Witten, L, . Liraglutide effects in a paediatric (7-11 y) population with obesity: A randomized, double-blind, placebo-controlled, short-term trial to assess safety, tolerability, pharmacokinetics, and pharmacodynamics. Pediatr Obes. 14(5): e12495. 2019. PMID: 30653847. 10.1111/ijpo.12495 30653847
- McCallum, Z, Wake, M, . Outcome data from the LEAP (Live, Eat and Play) trial: a randomized controlled trial of a primary care intervention for childhood overweight/mild obesity. Int J Obes (Lond). 31(4): 630–636. 2007. PMID: 17160087. 10.1038/sj.ijo.0803509 17160087
  - McCallum, Z, Wake, M, . Can Australian general practitioners tackle childhood overweight/obesity? Methods and processes from the LEAP (Live, Eat and Play) randomized controlled trial. J Paediatr Child Health. 41(9–10): 488–494. 2005. PMID: 16150065.16150065
  - Wake, M, Gold, L, . Economic evaluation of a primary care trial to reduce weight gain in overweight/obese children: the LEAP trial. Ambul Pediatr. 8(5): 336–41. 2008. PMID: 18922508. 10.1016/j.ambp.2008.06.006 18922508
- Mellin, LM, Slinkard, LA, . Adolescent obesity intervention: validation of the SHAPEDOWN program. J Am Diet Assoc. 87(3): 333–338. 1987. PMID: 3819254.3819254
- Nemet, D, Barkan, S, . Short- and long-term beneficial effects of a combined dietary-behavioral-physical activity intervention for the treatment of childhood obesity. Pediatrics. 115(4): e443–e449. 2005. PMID: 15805347. 10.1542/peds.2004-2172 15805347
- Norman, G, Huang, J, . Outcomes of a 1-year randomized controlled trial to evaluate a behavioral ‘stepped-down’ weight loss intervention for adolescent patients with obesity. Pediatr Obes. 11(1): 18–25. 2016. PMID: 25702630. 10.1111/ijpo.12013 25702630
- O’Connor, TM, Hilmers, A, . Feasibility of an obesity intervention for paediatric primary care targeting parenting and children: Helping HAND. Child Care Health Dev. 39(1): 141–9. 2013. PMID: 22066521. 10.1111/j.1365-2214.2011.01344.x 22066521
- Patrick, K, Norman, GJ, . Outcomes of a 12-month technology-based intervention to promote weight loss in adolescents at risk for type 2 diabetes. J Diabetes Sci Technol. 7(3): 759–70. 2013. PMID: 2375941023759410
- Raynor, HA, Osterholt, KM, . Efficacy of U.S. paediatric obesity primary care guidelines: two randomized trials. Pediatr Obes. 7(1): 28–38. 2012. PMID: 22434737. 10.1111/j.2047-6310.2011.00005.x 22434737
- Reinehr, T, Schaefer, A, . An effective lifestyle intervention in overweight children: findings from a randomized controlled trial on “Obeldicks light”. Clin Nutr. 29(3): 331–6. 2010. PMID: 20106567. 10.1016/j.clnu.2009.12.010 20106567
  - Reinehr, T, Schaefer, A, . Development and evaluation of the lifestyle intervention “obeldicks light” for overweight children and adolescents. J Public Health (Oxf). 19(4): 377–384. 2011. PMID: 26811110. 10.1007/s10389-011-0410-x 26811110
- Resnicow, K, McMaster, F, . Motivational interviewing and dietary counseling for obesity in primary care: an RCT. Pediatrics. 135(4): 649–57. 2015. PMID: 25825539. 10.1542/peds.2014-1880 25825539
  - Resnicow, K, Harris, D, . Advances in Motivational Interviewing for Pediatric Obesity: Results of the Brief Motivational Interviewing to Reduce Body Mass Index Trial and Future Directions. Pediatr Clin North Am. 63(3): 539–62. 2016. PMID: 27261549. 10.1016/j.pcl.2016.02.008 27261549
  - Resnicow, K, McMaster, F, . Study design and baseline description of the BMI2 trial: reducing paediatric obesity in primary care practices. Pediatr Obes. 7(1): 3–15. 2012. PMID: 22434735. 10.1111/j.2047-6310.2011.00001.x 22434735
- Sacher, PM, Kolotourou, M, . Randomized controlled trial of the MEND program: a family-based community intervention for childhood obesity. Obesity (Silver Spring). 18 Suppl 1. 2010. PMID: 20107463.20107463
- Saelens, BE, Sallis, JF, . Behavioral weight control for overweight adolescents initiated in primary care. Obes Res. 10(1): 22–32. 2002. PMID: 11786598.11786598
- Savoye, M, Caprio, S, . Reversal of early abnormalities in glucose metabolism in obese youth: results of an intensive lifestyle randomized controlled trial. Diabetes Care. 37(2): 317–24. 2014. PMID: 24062325. 10.2337/dc13-1571 24062325
  - Savoye, M, Caprio, S, . A community-based intervention for diabetes risk reduction in innercity obese adolescents. Diabetologia. 56(Suppl 1): S342. 2013. PMID: None. 10.1007/s00125-013-3012-z
- Savoye, M, Shaw, M, . Effects of a weight management program on body composition and metabolic parameters in overweight children: a randomized controlled trial. JAMA. 297(24): 2697–2704. 2007. PMID: 17595270. 10.1001/jama.297.24.2697 17595270
  - Savoye, M, Nowicka, P, . Long-term results of an obesity program in an ethnically diverse pediatric population. Pediatrics. 127(3): 402–10. 2011. PMID: 21300674. 10.1542/peds.2010-0697 21300674
  - Shaw, M, Savoye, M, . Effect of a successful intensive lifestyle program on insulin sensitivity and glucose tolerance in obese youth. Diabetes Care. 32(1): 45–7. 2009. PMID: 18840769. 10.2337/dc08-0808 18840769
  - Taylor, JH, Xu, Y, . Psychosocial predictors and moderators of weight management programme outcomes in ethnically diverse obese youth. Pediatr Obes. 12(6): 453–461. 2017. PMID: 27384496. 10.1111/ijpo.12165 27384496
- Sherwood, NE, Levy, RL, . The Healthy Homes/Healthy Kids 5-10 Obesity Prevention Trial: 12 and 24-month outcomes. Pediatr Obes. 14(8): e12523. 2019. PMID: 30873752. 10.1111/ijpo.12523 30873752
- Smith, JD, Berkel, C, . Health behaviour outcomes of a family based intervention for paediatric obesity in primary care: A randomized type II hybrid effectiveness-implementation trial. Pediatr Obes. 16(9): e12780. 2021. PMID: 33783104. 10.1111/ijpo.12780 33783104
  - Berkel, C, Fu, E, . Effects of the Family Check-Up 4 Health on Parenting and Child Behavioral Health: A Randomized Clinical Trial in Primary Care. Prev Sci. 22(4): 464–474. 2021. 10.1007/s11121-021-01213-y 33715136
  - Smith, JD, Berkel, C, . An individually tailored family-centered intervention for pediatric obesity in primary care: study protocol of a randomized type II hybrid effectiveness-implementation trial (Raising Healthy Children study). Implementation Science. 13(1): 11. 2018. PMID: 29334983. 10.1186/s13012-017-0697-2 29334983
  - Smith, JD, Carroll, AJ, . Baseline Targeted Moderation in a Trial of the Family Check-Up 4 Health: Potential Explanations for Finding Few Practical Effects. Prevention Science. 22. 22. 2021. PMID: 34159507. 10.1007/s11121-021-01266-z 34159507
- Stark, LJ, Clifford, LM, . A pilot randomized controlled trial of a behavioral family-based intervention with and without home visits to decrease obesity in preschoolers. J Pediatr Psychol. 39(9): 1001–12. 2014. PMID: 25080605. 10.1093/jpepsy/jsu059 25080605
  - Van Allen, J, Kuhl, ES, . Changes in parent motivation predicts changes in body mass index z-score (zBMI) and dietary intake among preschoolers enrolled in a family-based obesity intervention. J Pediatr Psychol. 39(9): 1028–37. 2014. PMID: 25016604. 10.1093/jpepsy/jsu052 25016604
- Stark, LJ, Spear Filigno, S, . Clinic and Home-Based Behavioral Intervention for Obesity in Preschoolers: A Randomized Trial. J Pediatr. 192. 115–121.e1. 2018. PMID: 29150147. 10.1016/j.jpeds.2017.09.063 29150147
  - Robson, Sm, Ziegler, Ml, . Changes in diet quality and home food environment in preschool children following weight management. International journal of behavioral nutrition and physical activity. 16(1). 2019. PMID: Pubmed 30717746. 10.1186/s12966-019-0777-6 30717746
  - Stark, LJ, Filigno, SS, . Learning about Activity and Understanding Nutrition for Child Health (LAUNCH): Rationale, design, and implementation of a randomized clinical trial of a family-based pediatric weight management program for preschoolers. Contemp Clin Trials. 52. 10–19. 2017. PMID: 27777128. 10.1016/j.cct.2016.10.007 27777128
  - Stark, LJ, Filigno, SS, . Maintenance Following a Randomized Trial of a Clinic and Home-based Behavioral Intervention of Obesity in Preschoolers. J Pediatr. 213. 128–136.e3. 2019. PMID: 31230889. 10.1016/j.jpeds.2019.05.004 31230889
- Stark, LJ, Spear, S, . A pilot randomized controlled trial of a clinic and home-based behavioral intervention to decrease obesity in preschoolers. Obesity (Silver Spring). 19(1): 134–41. 2011. PMID: 20395948. 10.1038/oby.2010.87 20395948
- Stettler, N, Wrotniak, BH, . Prevention of excess weight gain in paediatric primary care: beverages only or multiple lifestyle factors. The Smart Step Study, a cluster-randomized clinical trial. Pediatr Obes. 2014. PMID: 25251166. 10.1111/ijpo.260 25251166
- Tanofsky-Kraff, M, Shomaker, LB, . Targeted prevention of excess weight gain and eating disorders in high-risk adolescent girls: a randomized controlled trial. Am J Clin Nutr. 100(4): 1010–8. 2014. 10.3945/ajcn.114.092536 25240070
  - Tanofsky-Kraff, M, Shomaker, LB, . Excess weight gain prevention in adolescents: Three-year outcome following a randomized controlled trial. J Consult Clin Psychol. 85(3): 218–227. 2017. PMID: 27808536. 10.1037/ccp0000153 27808536
- Tanofsky-Kraff, M, Wilfley, DE, . A pilot study of interpersonal psychotherapy for preventing excess weight gain in adolescent girls at-risk for obesity. Int J Eat Disord. 43(8): 701–6. 2010. PMID: 19882739. 10.1002/eat.20773 19882739
  - Etu, SarahF. A test of the compensation and capitalization models in group interpersonal psychotherapy for adolescent girls at risk for obesity. Dissertation Abstracts International: Section B: The Sciences and Engineering. 72(10-B): 6412. 2012.
  - Glasofer, Deborah Rose. Self-efficacy in adolescent girls at risk for overweight during an obesity prevention program. Dissertation Abstracts International: Section B: The Sciences and Engineering. 69(7-B): 4420. 2009.
- Taveras, EM, Gortmaker, SL, . Randomized controlled trial to improve primary care to prevent and manage childhood obesity: the High Five for Kids study. Arch Pediatr Adolesc Med. 165(8): 714–722. 2011. PMID: 21464376. 10.1001/archpediatrics.2011.44 21464376
  - Rifas-Shiman, SL, Taveras, EM, . Two-year follow-up of a primary care-based intervention to prevent and manage childhood obesity: the High Five for Kids study. Pediatr Obes. 12(3): e24–e27. 2017. PMID: 27231236. 10.1111/ijpo.12141 27231236
  - Sonneville, KR, Rifas-Shiman, SL, . Associations of obesogenic behaviors in mothers and obese children participating in a randomized trial. Obesity (Silver Spring). 20(7): 1449–54. 2012. PMID: 22349735. 10.1038/oby.2012.43 22349735
  - Taveras, EM, Hohman, KH, . Correlates of participation in a pediatric primary care-based obesity prevention intervention. Obesity (Silver Spring). 19(2): 449–52. 2011. PMID: 20847735. 10.1038/oby.2010.207 20847735
  - Woo Baidal, JA, Price, SN, . Parental perceptions of a motivational interviewing-based pediatric obesity prevention intervention. Clin Pediatr (Phila). 52(6): 540–8. 2013. PMID: 23564304. 10.1177/0009922813483170 23564304
- Taveras, EM, Marshall, R, . Comparative effectiveness of childhood obesity interventions in pediatric primary care: a cluster-randomized clinical trial. JAMA Pediatr. 169(6): 535–42. 2015. PMID: 25895016. 10.1001/jamapediatrics.2015.0182 25895016
  - Taveras, EM, Marshall, R, . Improving children’s obesity-related health care quality: process outcomes of a cluster-randomized controlled trial. Obesity (Silver Spring). 22(1): 27–31. 2014. PMID: 23983130. 10.1002/oby.20612 23983130
  - Taveras, EM, Marshall, R, . Rationale and design of the STAR randomized controlled trial to accelerate adoption of childhood obesity comparative effectiveness research. Contemp Clin Trials. 34(1): 101–8. 2013. PMID: 23099100. 10.1016/j.cct.2012.10.005 23099100
- Taveras, EM, Marshall, R, . Comparative Effectiveness of Clinical-Community Childhood Obesity Interventions: A Randomized Clinical Trial. JAMA Pediatr. 171(8): e171325. 2017. PMID: 28586856. 10.1001/jamapediatrics.2017.1325 28586856
  - Bala, N, Price, SN, . Use of Telehealth to Enhance Care in a Family-Centered Childhood Obesity Intervention. Clin Pediatr (Phila). 58(7): 789–797. 2019. PMID: 30894004. 10.1177/0009922819837371 30894004
  - Fiechtner, L, Puente, GC, . A Community Resource Map to Support Clinical-Community Linkages in a Randomized Controlled Trial of Childhood Obesity, Eastern Massachusetts, 2014-2016. Prev Chronic Dis. 14. E53. 2017. PMID: 28682745. 10.5888/pcd14.160577 28682745
- Taylor, RW, Cox, A, . A tailored family-based obesity intervention: a randomized trial. Pediatrics. 136(2): 281–9. 2015. PMID: 26195541. 10.1542/peds.2015-0595 26195541
  - Taylor, RW, Brown, D, . Motivational interviewing for screening and feedback and encouraging lifestyle changes to reduce relative weight in 4-8 year old children: design of the MInT study. BMC Public Health. 10. 271. 2010. PMID: 20497522. 10.1186/1471-2458-10-271 20497522
- van Grieken, A, Veldhuis, L, . Population-based childhood overweight prevention: outcomes of the ‘Be active, eat right’ study. PLoS One. 8(5): e65376. 2013. PMID: 23741491. 10.1371/journal.pone.0065376 23741491
  - van Grieken, A, Renders, CM, . Promotion of a healthy lifestyle among 5-year-old overweight children: health behavior outcomes of the ‘Be active, eat right’ study. BMC Public Health. 14. 59. 2014. PMID: 24447459. 10.1186/1471-2458-14-59 24447459
  - Veldhuis, L, Struijk, MK, . ‘Be active, eat right’, evaluation of an overweight prevention protocol among 5-year-old children: design of a cluster randomised controlled trial. BMC Public Health. 9. 177. 2009. PMID: 19505297. 10.1186/1471-2458-9-177 19505297
- Viner, RM, Kinra, S, . Improving the assessment and management of obesity in UK children and adolescents: the PROMISE research programme including a RCT. NIHR Journals Library. Programme Grants for Applied Research. 3. 3. 2020. PMID: 32250582. 10.3310/pgfar08030 32250582
  - Christie, D, Hudson, LD, . A community-based motivational personalised lifestyle intervention to reduce BMI in obese adolescents: results from the Healthy Eating and Lifestyle Programme (HELP) randomised controlled trial. Arch Dis Child. 102(8): 695–701. 2017. PMID: 28687677. 10.1136/archdischild-2016-311586 28687677
  - Panca, M, Christie, D, . Cost-effectiveness of a community-delivered multicomponent intervention compared with enhanced standard care of obese adolescents: cost-utility analysis alongside a randomised controlled trial (the HELP trial). BMJ Open. 8(2): e018640. 2018. PMID: 29449292. 10.1136/bmjopen-2017-018640 29449292
- Vos, RC, Wit, JM, . Long-term effect of lifestyle intervention on adiposity, metabolic parameters, inflammation and physical fitness in obese children: a randomized controlled trial. Nutr Diabetes. 1. e9. 2011. PMID: 23455021. 10.1038/nutd.2011.5 23455021
  - Vos, RC, Huisman, SD, . The effect of family-based multidisciplinary cognitive behavioral treatment on health-related quality of life in childhood obesity. Qual Life Res. 21(9): 1587–94. 2012. PMID: 22161746. 10.1007/s11136-011-0079-1 22161746
  - Vos, RC, Wit, JM, . The effect of family-based multidisciplinary cognitive behavioral treatment in children with obesity: study protocol for a randomized controlled trial. Trials. 12. 110. 2011. PMID: 21548919. 10.1186/1745-6215-12-110 21548919
- Wake, M, Baur, LA, . Outcomes and costs of primary care surveillance and intervention for overweight or obese children: the LEAP 2 randomised controlled trial. BMJ. 339. b3308. 2009. PMID: 19729418. 10.1136/bmj.b3308 19729418
  - Incledon, E, Gerner, B, . Psychosocial predictors of 4-year BMI change in overweight and obese children in primary care. Obesity (Silver Spring). 21(3): E262–70. 2013. PMID: 23404919. 10.1002/oby.20050 23404919
  - McCallum, Z, Wake, M, . Can Australian general practitioners tackle childhood overweight/obesity? Methods and processes from the LEAP (Live, Eat and Play) randomized controlled trial. J Paediatr Child Health. 41(9–10): 488–494. 2005. PMID: 16150065.16150065
- Wake, M, Lycett, K, . Shared care obesity management in 3-10 year old children: 12 month outcomes of HopSCOTCH randomised trial. BMJ. 346. f3092. 2013. PMID: 23751902. 10.1136/bmj.f3092 23751902
  - Wake, M, Lycett, K, . A shared-care model of obesity treatment for 3-10 year old children: protocol for the HopSCOTCH randomised controlled trial. BMC Pediatr. 12. 39. 2012. PMID: 22455381. 10.1186/1471-2431-12-39 22455381
- Weghuber D, Barrett T, . Once-Weekly Semaglutide in Adolescents with Obesity. N Engl J Med. 387(24):2245–2257. 2022. PMID: 36322838. 10.1056/NEJMoa2208601 36322838
  - Kelly, AS, Arslanian, S, . Reducing BMI below the obesity threshold in adolescents treated with once-weekly subcutaneous semaglutide 2.4 mg. Obesity. 2023 (epub ahead of print). PMID: 37196421.37196421
- Weigel, C, Kokocinski, K, . Childhood obesity: concept, feasibility, and interim results of a local group-based, long-term treatment program. J Nutr Educ Behav. 40(6): 369–73. 2008. PMID: 18984493. 10.1016/j.jneb.2007.07.009 18984493