# Appendix A Detailed Methods

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- pt = publication type
- * = truncation
- kw = keyword

Bridge Searches

Medline via Ovid

Ovid MEDLINE(R) ALL <1946 to January 12, 2023>

1. Obesity/ 210460
2. Obesity, Morbid/ 25365
3. Obesity, Abdominal/ 4942
4. Overweight/ 31984
5. Weight Gain/ 34937
6. Weight Loss/ 42637
7. Weight Cycling/ 10
8. obesity.ti,ab,kf. 310125
9. obese.ti,ab,kf. 146676
10. overweight.ti,ab,kf. 85422
11. over weight.ti,ab,kf. 544
12. (weight adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,kf. 208887
13. ((bmi or body mass ind$) adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,kf. 11474
14. weight maintenance.ti,ab,kf. 2445
15. weight control.ti,ab,kf. 7079
16. weight manag$.ti,ab,kf. 8295
17. or/1-16 599637
18. Child/ or Child, Preschool/ or Adolescent/ or Young Adult/ or Minors/ 3774002
19. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,kf. 1386171
20. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,ab,kf. 2151548
21. limit 20 to (“in data review” or in process or “pubmed not medline”) 208901
22. 17 and (18 or 19 or 21) 132262
23. Pediatric Obesity/ 13126
24. 22 or 23 133266
25. Counseling/ 39225
26. Directive Counseling/ 2429
27. Behavior therapy/ 30006
28. Aversive therapy/ 821
29. Biofeedback, Psychology/ 7694
30. Feedback, Psychological/ 3733
31. Cognitive therapy/ 29660
32. “Acceptance and commitment therapy”/ 798
33. Mindfulness/ 5839
34. Desensitization, psychologic/ 1581
35. Relaxation therapy/ 6542
36. Meditation/ 3658
37. Social Support/ 77959
38. Psychotherapy, Group/ 14449
39. Family Therapy/ 9150
40. Persuasive Communication/ 4002
41. Risk Reduction Behavior/ 14201
42. Health Education/ 63330
43. Health Promotion/ 80523
44. Patient Education as Topic/ 88171
45. “Early Intervention (Education)”/ 3469
46. ((psychological or behavio?r$) adj (therap$ or modif$ or chang$ or strateg$ or intervention$)).ti,ab,kf. 105180
47. (group therap$ or family therap$ or cognitive therap$).ti,ab,kf. 13341
48. (cbt or dcbt).ti,ab,kf. 14254
49. ((lifestyle or life style) adj (chang$ or interven$ or modif$)).ti,ab,kf. 28302
50. counsel?ing.ti,ab,kf. 113861
51. social$ support$.ti,ab,kf. 52640
52. (peer$ adj2 support$).ti,ab,kf. 8340
53. ((child$ adj3 parent$) and therap$).ti,ab,kf. 5834
54. (family intervention$ or parent$ intervention$).ti,ab,kf. 3438
55. (parent$ adj2 (behavio?r$ or involv$ or control$ or attitude$ or educat$)).ti,ab,kf. 33284
56. health education.ti,ab,kf. 41094
57. health promotion.ti,ab,kf. 40733
58. patient education.ti,ab,kf. 23284
59. nonpharmacologic intervention$.ti,ab,kf. 974
60. non pharmacologic intervention$.ti,ab,kf. 330
61. self regulat$.ti,ab,kf. 15711
62. (school$ adj5 (intervention$ or program$)).ti,ab,kf. 27739
63. or/25-62 752201
64. Exercise/ 137564
65. Physical Conditioning, Human/ 2878
66. (exercise or physical activity).ti,kf. 203885
67. aerobic$.ti,kf. 26830
68. (fitness adj (class$ or regime$ or program$)).ti,kf. 316
69. (physical training or physical education).ti,kf. 5855
70. (sedentary behavio?r$ adj3 reduc$).ti,ab,kf. 1019
71. ((exercise or physical activity) adj5 (intervention$ or promot$)).ti,ab,kf. 36048
72. telerehabilitation/ 890
73. or/64-72 289519
74. diet, fat-restricted/ 3979
75. diet, reducing/ 11497
76. Diet, Carbohydrate-Restricted/ 2045
77. diet therapy/ 10914
78. Caloric Restriction/ 7087
79. Food Habits/ 91711
80. (diet or diets or dieting or dietary).ti,kf. 228742
81. (diet$ adj (modif$ or therap$ or intervention$ or strateg$)).ti,ab,kf. 23185
82. (low calorie or calori$ control$ or healthy eating).ti,ab,kf. 13790
83. formula diet$.ti,ab,kf. 722
84. (weightwatcher$ or weight watcher$).ti,ab,kf. 161
85. or/74-84 338885
86. Case management/ 10566
87. Patient care team/ 69189
88. Cooperative behavior/ 45836
89. Interprofessional Relations/ 53140
90. Continuity of patient care/ 20521
91. Patient-centered care/ 22559
92. Patient care management/ 4742
93. Delivery of Health Care, Integrated/ 14139
94. collaborat$.ti,ab,kf. 190454
95. (interdisciplinary or inter disciplinary).ti,ab,kf. 47558
96. (multidisciplinary or multi disciplinary).ti,ab,kf. 120023
97. (integrated adj5 (healthcare or care)).ti,ab,kf. 20442
98. care manag$.ti,ab,kf. 12737
99. case manag$.ti,ab,kf. 15096
100. cooperative care.ti,ab,kf. 105
101. coordinated care.ti,ab,kf. 1618
102. patient centered care.ti,ab,kf. 7236
103. stepped care.ti,ab,kf. 1614
104. telemedicine/ 35834
105. or/86-104 570476
106. Anti-Obesity Agents/ 5695
107. pharmacotherap$.ti,kf. 12701
108. Lactones/ 19723
109. Orlistat/ 1355
110. Orlistat.ti,ab,kf. 1890
111. tetrahydrolipstatin.ti,ab,kf. 213
112. Xenical.ti,ab,kf. 105
113. Alli.ti,ab,kf. 111
114. glucagon-like peptide 1/ 9231
115. liraglutide/ 2373
116. liraglutide.ti,ab,kf. 3592
117. Saxenda.ti,ab,kf. 41
118. (setmelanotide or imcivree).ti,ab,kf. 67
119. (Phentermine/ or (Phentermine or adipex-p or Lomaira or Suprenza or sentis).ti,ab,kf.) and (Topiramate/ or (Topiramate or Trokendi XR or Qudexy XR or Topamax or eprontia or Topiramic acid).ti,ab,kf.) 305
120. “PHEN/TPM”.ti,ab,kf. 16
121. or/106-120 49633
122. Weight Reduction Programs/ 2782
123. ((weight loss or weight reduction) adj3 (intervention$ or promot$ or program$)).ti,ab,kf. 9191
124. 24 and (63 or 73 or 85 or 105 or 121 or 122 or 123) 42527
125. Pediatric Obesity/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy] 5173
126. Obesity/dh, dt, pc, rh, th 52758
127. Obesity, Morbid/dh, dt, pc, rh, th 1924
128. Obesity, Abdominal/dh, dt, pc, rh, th 524
129. Overweight/dh, dt, pc, rh, th 7012
130. or/126-129 58113
131. 130 and (18 or 19 or 21) 15440
132. 124 or 125 or 131 48070
133. (randomized controlled trial or controlled clinical trial or clinical trial or meta analysis).pt. or clinical trials as topic.sh. or exp Randomized Controlled Trials as Topic/ or (randomized or randomised or placebo or randomly or phase iii or phase 3 or clinical trial or controlled trial).ti,ab,kf. or trial.ti,kf. 1982975
134. control groups/ or double-blind method/ or single-blind method/ or random allocation/ or placebos/ 324427
135. (RCT or placebo or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or random$).ti,ab,kf. not medline.st. 235216
136. or/133-135 2134569
137. 132 and 136 10601
138. limit 137 to (english language and yr="2016 -Current") 4847
139. 24 and 121 942
140. Pediatric Obesity/dt 111
141. Obesity/dt or Obesity, Morbid/dt or Obesity, Abdominal/dt or Overweight/dt 12569
142. 141 and (18 or 19 or 21) 1345
143. 139 or 140 or 142 2073
144. limit 143 to (english language and yr="2016 -Current") 689
145. 138 or 144 5159
146. 145 not (animals/ not humans/) 5149
147. (202201* or 202202* or 202203* or 202204* or 202205* or 202206* or 202207* or 202208* or 202209* or 202210* or 202211* or 202212* or 2023*).dt,da,ez. 2003086
148. 146 and 147 703

Bridge PsycInfo via Ovid

APA PsycInfo <1806 to January Week 2 2023>

1. obesity/ 27902
2. overweight/ 5205
3. weight gain/ 3484
4. weight control/ 5364
5. weight loss/ 4435
6. (Obesity or Obesity, Morbid or Obesity, Abdominal or Overweight).mh. 18058
7. Weight Cycling.mh. 1
8. obesity.ti,ab,id. 40033
9. obese.ti,ab,id. 17344
10. overweight.ti,ab,id. 17203
11. over weight.ti,ab,id. 124
12. (weight adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,id. 27329
13. ((bmi or body mass ind$) adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,id. 1936
14. weight maintenance.ti,ab,id. 602
15. weight control.ti,ab,id. 3004
16. weight manag$.ti,ab,id. 2728
17. or/1-16 70905
18. limit 17 to (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>) 17300
19. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,ab,id. 1043844
20. 17 and 19 21497
21. 18 or 20 23929
22. Behavior Therapy/ 15610
23. Cognitive Behavior Therapy/ 23211
24. Cognitive Therapy/ 13954
25. Cognitive Techniques/ 1723
26. Behavior Modification/ 10693
27. Behavior Change/ 13410
28. Lifestyle Changes/ 1486
29. Lifestyle/ 11903
30. School Counseling/ 6472
31. Psychotherapeutic Counseling/ 1621
32. Peer Counseling/ 1212
33. Group Counseling/ 5149
34. Community Counseling/ 117
35. Motivational Interviewing/ 2958
36. Feedback/ 21041
37. Biofeedback/ 2567
38. Health Education/ 14518
39. Health Promotion/ 27904
40. Client Education/ 4505
41. Self Regulation/ 11599
42. Intervention/ 83110
43. School Based Intervention/ 21736
44. Family Intervention/ or Family Therapy/ 26018
45. Early Intervention/ 12203
46. aversion therapy/ 588
47. “Acceptance and commitment therapy”/ 2450
48. Mindfulness/ 12093
49. Social Support/ 42049
50. support groups/ 4549
51. ((psychological or behavio?r$) adj (therap$ or modif$ or chang$ or strateg$ or intervention$)).ti,ab,id. 103049
52. (group therap$ or family therap$ or cognitive therap$).ti,ab,id. 42113
53. cbt.ti,ab,id. 16803
54. ((lifestyle or life style) adj (chang$ or interven$ or modifi$)).ti,ab,id. 5380
55. counsel$.ti,ab,id. 120553
56. social$ support$.ti,ab,id. 59330
57. (peer adj2 support).ti,ab,id. 6606
58. ((child$ adj3 parent$) and therapy).ti,ab,id. 6082
59. (family intervention$ or parent$ intervention$).ti,ab,id. 5565
60. (parent$ adj2 (behavio?r$ or involv$ or control$ or attitude$ or educat$)).ti,ab. 46180
61. health education.ti,ab,id. 12195
62. health promotion.ti,ab,id. 22260
63. patient education.ti,ab,id. 4260
64. nonpharmacologic intervention$.ti,ab,id. 253
65. non pharmacologic intervention$.ti,ab,id. 110
66. self regulat$.ti,ab,id. 25786
67. (school$ adj5 (intervention$ or program$)).ti,ab,id. 44095
68. or/22-67 624627
69. Physical Activity/ 25136
70. Physical Fitness/ 4783
71. Exercise/ 26718
72. Aerobic Exercise/ 2265
73. Active Living/ 275
74. (exercise or physical activity).ti,id. 46482
75. aerobic$.ti,id. 2611
76. (fitness adj (class$ or regime$ or program$)).ti,id. 228
77. (physical training or physical education).ti,id. 4815
78. (sedentary behavio?r$ adj3 reduc$).ti,ab,id. 376
79. ((exercise or physical activity) adj5 (intervention$ or promot$)).ti,ab,id. 11861
80. or/69-79 62268
81. Diets/ 14955
82. Dietary Restraint/ 1860
83. Food Intake/ 15487
84. Eating Behavior/ 16013
85. Healthy Eating/ 161
86. “obesity (attitudes toward)”/ 476
87. (diet or diets or dieting or dietary).ti. 11361
88. (diet$ adj (modif$ or therapy or intervention$ or strateg$)).ti,ab,id. 1661
89. (low calorie or calori$ control$ or healthy eating or formula diet$).ti,ab,id. 4398
90. (weightwatcher$ or weight watcher$).ti,ab,id. 71
91. or/81-90 47415
92. Interdisciplinary Treatment Approach/ 7854
93. Collaboration/ 14393
94. Cooperation/ 16167
95. Case Management/ 3443
96. Work Teams/ 5869
97. Community Mental Health Services/ 8030
98. Health Care Delivery/ 22200
99. Community Psychology/ 2525
100. Community Psychiatry/ 906
101. client centered therapy/ 3587
102. “continuum of care”/ 2218
103. collaborat$.ti,ab,id. 99407
104. (interdisciplinary or inter disciplinary).ti,ab,id. 27449
105. (multidisciplinary or multi disciplinary).ti,ab,id. 24114
106. (integrated adj5 (healthcare or care)).ti,ab,id. 6492
107. care manag$.ti,ab,id. 3093
108. case manag$.ti,ab,id. 7387
109. cooperative care.ti,ab,id. 45
110. coordinated care.ti,ab,id. 448
111. patient centered care.ti,ab,id. 2045
112. or/92-111 210605
113. ((weight loss or weight reduction or weight control or weight maintenance or weight management) adj3 (intervention$ or promot$ or program$)).ti,ab,id. 3970
114. 21 and (68 or 80 or 91 or 112 or 113) 12796
115. random$.ti,ab,id,hw. 233976
116. placebo$.ti,ab,hw,id. 43783
117. (controlled trial$ or control group$).ti,ab,id,hw,md. 135129
118. clinical trial$.ti,ab,id,hw. 44636
119. meta analy$.ti,ab,hw,id. 48648
120. treatment outcome.md. 23075
121. (sham or dummy).ti,ab,id. 15750
122. (single blind$ or double blind$ or triple blind$ or treble blind$).ti,ab,id. 28441
123. (allocated or allocation).ti,ab,id. 30851
124. (phase iii or phase 3).ti,ab,id. 3850
125. or/115-124 425050
126. 114 and 125 2268
127. (exp Overweight/ or weight loss/ or weight control/) and exp Drug Therapy/ 1018
128. Orlistat.ti,ab,id. 105
129. tetrahydrolipstatin.ti,ab,id. 16
130. Xenical.ti,ab,id. 3
131. Alli.ti,ab,id. 42
132. liraglutide.ti,ab,id. 111
133. Saxenda.ti,ab,id. 1
134. (setmelanotide or imcivree).ti,ab,id. 2
135. ((Phentermine or adipex-p or Lomaira or Suprenza or sentis) and (Topiramate or Trokendi XR or Qudexy XR or Topamax or eprontia or Topiramic acid)).ti,ab,id. 25
136. “PHEN/TPM”.ti,ab,id. 2
137. or/127-136 1231
138. 21 and 137 155
139. 126 or 138 2403
140. limit 139 to (english language and yr="2016 -Current") 960
141. (202201* or 202202* or 202203* or 202204* or 202205* or 202206* or 202207* or 202208* or 202209* or 202210* or 202211* or 202212* or 2023*).up. 189553
142. 140 and 141 122

Bridge Cochrane via Wiley

Date Run: 13/01/2023 17:54:35

ID Search Hits
#1 (child* or teen or teens or teenage* or adolescen* or youth or youths or young people or (young next adult*) or pediatric* or paediatric* or schoolchildren or school children or preschool* or (pre next school*) or toddler*):ti,ab,kw 344849
#2 (obese or obesity or overweight or “over weight”):ti,ab,kw 54014
#3 (weight next gain*):ti,ab,kw or (weight next loss*):ti,ab,kw 35513
#4 ((weight next change*) or (weight next reduc*)):ti,ab,kw 11278
#5 (bmi or body mass index):ti,ab,kw near/2 (gain* or loss* or change* or reduc*):ti,ab,kw 25964
#6 “weight maintenance”:ti,ab,kw 1333
#7 “weight control”:ti,ab,kw 1877
#8 “weight management”:ti,ab,kw 2791
#9 {or #2-#8} 84479
#10 (psychological or behavior* or behaviour*):ti,ab,kw next (therap* or modif* or chang* or strateg* or intervention*):ti,ab,kw 46259
#11 psychotherapy:ti,ab,kw 14232
#12 (group or family or cognitive):ti,ab,kw next therap*:ti,ab,kw 11822
#13 cbt:ti,ab,kw 9974
#14 (lifestyle or “life style”):ti,ab,kw next (chang* or interven* or modif*):ti,ab,kw 11227
#15 counsel*:ti,ab,kw 27093
#16 (social* next support*):ti,ab,kw 9585
#17 (peer* near/2 support*):ti,ab,kw 1927
#18 (child* near/3 parent*):ti,ab,kw and therap*:ti,ab,kw 4972
#19 (family or parent*):ti,ab,kw next intervention*:ti,ab,kw 1955
#20 parent*:ti,ab,kw near/2 (behavior* or behaviour* or involv* or control* or attitude* or educat*):ti,ab,kw 6777
#21 health:ti,ab,kw next (education or promotion):ti,ab,kw 22106
#22 “patient education”:ti,ab,kw 14852
#23 (nonpharmacologic or “non pharmacologic”):ti,ab,kw next intervention*:ti,ab,kw 312
#24 (self next regulat*):ti,ab,kw 2734
#25 school*:ti,ab,kw near/5 (intervention* or program*):ti,ab,kw 8482
#26 {or #10-#25} 136617
#27 (exercise or “physical activity”):ti 53259
#28 fitness:ti,ab,kw next (class* or regime* or program*):ti 319
#29 (“physical training” or “physical education”):ti 1025
#30 (sedentary next (behavior* or behaviour*)):ti,ab,kw near/3 (reduc* or mimim* or less*):ti,ab,kw 469
#31 (exercise or “physical activity”):ti,ab,kw near/5 (intervention* or promot*):ti,ab,kw 22770
#32 {or #27-#31} 63279
#33 (diet or diets or dieting or dietary):ti 23487
#34 diet*:ti,ab,kw next (modif* or therap* or intervention* or strateg*):ti,ab,kw 17683
#35 (“low calorie” or (calori* next control*) or “healthy eating”):ti,ab,kw 4637
#36 (formula next diet*):ti,ab,kw 247
#37 weightwatcher*:ti,ab,kw or (weight next watcher*):ti,ab,kw 139
#38 {or #33-#37} 36728
#39 collaborat*:ti,ab,kw 14184
#40 (interdisciplinary or “inter disciplinary”):ti,ab,kw 2498
#41 (multidisciplinary or multi-disciplinary):ti,ab,kw 7630
#42 integrated:ti,ab,kw near/5 (healthcare or care):ti,ab,kw 3026
#43 (care or case):ti,ab,kw next manag*:ti,ab,kw 5410
#44 “cooperative care”:ti,ab,kw 4
#45 “patient centered care”:ti,ab,kw 1259
#46 “stepped care”:ti,ab,kw 930
#47 “coordinated care”:ti,ab,kw 165
#48 ^335–^#^47^ 31580
#49 Orlistat:ti,ab,kw 577
#50 tetrahydrolipstatin:ti,ab,kw 93
#51 Xenical:ti,ab,kw 43
#52 Alli:ti,ab,kw 33
#53 liraglutide:ti,ab,kw 2186
#54 Saxenda:ti,ab,kw 28
#55 (setmelanotide or imcivree):ti,ab,kw 26
#56 (Phentermine or adipex-p or Lomaira or Suprenza or sentis) AND (Topiramate or “Trokendi XR” or “Qudexy XR” or Topamax or eprontia or “Topiramic acid”):ti,ab,kw 110
#57 “PHEN/TPM”:ti,ab,kw 47
#58 pharmacotherap*:ti,kw 3078
#59 ^336–^#^58^ 5960
#60 ((“weight loss” or “weight reduction” or “weight control” or “weight maintenance” or “weight management”) near/3 (intervention* or promot* or program*)):ti,ab,kw 6495
#61 #26 or #32 or #38 or #48 or #59 or #60 244977
#62 #1 and #9 and #61 with Publication Year from 2016 to present, with Cochrane Library publication date from Jan 2022 to present, in Trials 730

Original Searches

MEDLINE

Database: Ovid MEDLINE(R) ALL <1946 to February 15, 2022>

Search Strategy:

------------------------------------------------------------

1. Obesity/ (199295)
2. Obesity, Morbid/ (23494)
3. Obesity, Abdominal/ (4451)
4. Overweight/ (29183)
5. Weight Gain/ (33615)
6. Weight Loss/ (40391)
7. Weight Cycling/ (4)
8. obesity.ti,ab,kf. (288333)
9. obese.ti,ab,kf. (139651)
10. overweight.ti,ab,kf. (79612)
11. over weight.ti,ab,kf. (512)
12. (weight adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,kf. (196865)
13. ((bmi or body mass ind$) adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,kf. (10724)
14. weight maintenance.ti,ab,kf. (2329)
15. weight control.ti,ab,kf. (6765)
16. weight manag$.ti,ab,kf. (7606)
17. or/1-16 (564853)
18. Child/ or Child, Preschool/ or Adolescent/ or Young Adult/ or Minors/ (3671966)
19. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,kf. (1314801)
20. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,ab,kf. (2042844)
21. limit 20 to (“in data review” or in process or “pubmed not medline”) (192036)
22. 17 and (18 or 19 or 21) (126129)
23. Pediatric Obesity/ (11751)
24. 22 or 23 (127096)
25. Counseling/ (38203)
26. Directive Counseling/ (2424)
27. Behavior therapy/ (29432)
28. Aversive therapy/ (820)
29. Biofeedback, Psychology/ (7554)
30. Feedback, Psychological/ (3697)
31. Cognitive therapy/ (28431)
32. “Acceptance and commitment therapy”/ (648)
33. Mindfulness/ (4983)
34. Desensitization, psychologic/ (1581)
35. Relaxation therapy/ (6511)
36. Meditation/ (3380)
37. Social Support/ (76093)
38. Psychotherapy, Group/ (14353)
39. Family Therapy/ (9079)
40. Persuasive Communication/ (3915)
41. Risk Reduction Behavior/ (13994)
42. Health Education/ (62655)
43. Health Promotion/ (78732)
44. Patient Education as Topic/ (87897)
45. “Early Intervention (Education)”/ (3342)
46. ((psychological or behavio?r$) adj (therap$ or modif$ or chang$ or strateg$ or intervention$)).ti,ab,kf. (96952)
47. (group therap$ or family therap$ or cognitive therap$).ti,ab,kf. (12812)
48. (cbt or dcbt).ti,ab,kf. (13069)
49. ((lifestyle or life style) adj (chang$ or interven$ or modif$)).ti,ab,kf. (25942)
50. counsel?ing.ti,ab,kf. (106933)
51. social$ support$.ti,ab,kf. (47918)
52. (peer$ adj2 support$).ti,ab,kf. (7289)
53. ((child$ adj3 parent$) and therap$).ti,ab,kf. (5441)
54. (family intervention$ or parent$ intervention$).ti,ab,kf. (3171)
55. (parent$ adj2 (behavio?r$ or involv$ or control$ or attitude$ or educat$)).ti,ab,kf. (31015)
56. health education.ti,ab,kf. (38536)
57. health promotion.ti,ab,kf. (37776)
58. patient education.ti,ab,kf. (21784)
59. nonpharmacologic intervention$.ti,ab,kf. (927)
60. non pharmacologic intervention$.ti,ab,kf. (292)
61. self regulat$.ti,ab,kf. (14483)
62. (school$ adj5 (intervention$ or program$)).ti,ab,kf. (25979)
63. or/25-62 (715551)
64. Exercise/ (128647)
65. Physical Conditioning, Human/ (2826)
66. (exercise or physical activity).ti,kf. (189850)
67. aerobic$.ti,kf. (24976)
68. (fitness adj (class$ or regime$ or program$)).ti,kf. (310)
69. (physical training or physical education).ti,kf. (5422)
70. (sedentary behavio?r$ adj3 reduc$).ti,ab,kf. (912)
71. ((exercise or physical activity) adj5 (intervention$ or promot$)).ti,ab,kf. (32646)
72. telerehabilitation/ (721)
73. or/64-72 (271353)
74. diet, fat-restricted/ (3901)
75. diet, reducing/ (11403)
76. Diet, Carbohydrate-Restricted/ (1902)
77. diet therapy/ (10896)
78. Caloric Restriction/ (6862)
79. Food Habits/ (89545)
80. (diet or diets or dieting or dietary).ti,kf. (214538)
81. (diet$ adj (modif$ or therap$ or intervention$ or strateg$)).ti,ab,kf. (21422)
82. (low calorie or calori$ control$ or healthy eating).ti,ab,kf. (12637)
83. formula diet$.ti,ab,kf. (707)
84. (weightwatcher$ or weight watcher$).ti,ab,kf. (150)
85. or/74-84 (321815)
86. Case management/ (10415)
87. Patient care team/ (68523)
88. Cooperative behavior/ (45443)
89. Interprofessional Relations/ (52701)
90. Continuity of patient care/ (20259)
91. Patient-centered care/ (21813)
92. Patient care management/ (4728)
93. Delivery of Health Care, Integrated/ (13829)
94. collaborat$.ti,ab,kf. (174063)
95. (interdisciplinary or inter disciplinary).ti,ab,kf. (43783)
96. (multidisciplinary or multi disciplinary).ti,ab,kf. (109197)
97. (integrated adj5 (healthcare or care)).ti,ab,kf. (18536)
98. care manag$.ti,ab,kf. (11831)
99. case manag$.ti,ab,kf. (14483)
100. cooperative care.ti,ab,kf. (102)
101. coordinated care.ti,ab,kf. (1503)
102. patient centered care.ti,ab,kf. (6473)
103. stepped care.ti,ab,kf. (1483)
104. telemedicine/ (32355)
105. or/86-104 (533605)
106. Anti-Obesity Agents/ (5541)
107. pharmacotherap$.ti,kf. (11879)
108. Lactones/ (19170)
109. Orlistat/ (1304)
110. Orlistat.ti,ab,kf. (1790)
111. tetrahydrolipstatin.ti,ab,kf. (212)
112. Xenical.ti,ab,kf. (103)
113. Alli.ti,ab,kf. (103)
114. glucagon-like peptide 1/ (8591)
115. liraglutide/ (2125)
116. liraglutide.ti,ab,kf. (3280)
117. Saxenda.ti,ab,kf. (31)
118. (setmelanotide or imcivree).ti,ab,kf. (49)
119. or/106-118 (47122)
120. Weight Reduction Programs/ (2676)
121. ((weight loss or weight reduction) adj3 (intervention$ or promot$ or program$)).ti,ab,kf. (8575)
122. 24 and (63 or 73 or 85 or 105 or 119 or 120 or 121) (40552)
123. Pediatric Obesity/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy] (4760)
124. Obesity/dh, dt, pc, rh, th (50725)
125. Obesity, Morbid/dh, dt, pc, rh, th (1892)
126. Obesity, Abdominal/dh, dt, pc, rh, th (511)
127. Overweight/dh, dt, pc, rh, th (6542)
128. or/124-127 (55856)
129. 128 and (18 or 19 or 21) (15144)
130. 122 or 123 or 129 (45906)
131. (randomized controlled trial or controlled clinical trial or clinical trial or meta analysis).pt. or clinical trials as topic.sh. or exp Randomized Controlled Trials as Topic/ or (randomized or randomised or placebo or randomly or phase iii or phase 3 or clinical trial or controlled trial).ti,ab,kf. or trial.ti,kf. (1886631)
132. control groups/ or double-blind method/ or single-blind method/ or random allocation/ or placebos/ (319325)
133. (RCT or placebo or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or random$).ti,ab,kf. not medline.st. (217682)
134. or/131-133 (2030116)
135. 130 and 134 (10101)
136. limit 135 to (english language and yr="2016 -Current") (4352)
137. 24 and 119 (897)
138. Pediatric Obesity/dt (95)
139. Obesity/dt or Obesity, Morbid/dt or Obesity, Abdominal/dt or Overweight/dt (11677)
140. 139 and (18 or 19 or 21) (1301)
141. 137 or 138 or 140 (1985)
142. limit 141 to (english language and yr="2016 -Current") (604)
143. 136 or 142 (4617)
144. 143 not (animals/ not humans/) (4608)

Original PsycInfo via Ovid

Database: APA PsycInfo <1806 to February Week 1 2022>

Search Strategy:

------------------------------------------------------------

1. obesity/ (26739)
2. overweight/ (4921)
3. weight gain/ (3365)
4. weight control/ (5218)
5. weight loss/ (4225)
6. (Obesity or Obesity, Morbid or Obesity, Abdominal or Overweight).mh. (17813)
7. Weight Cycling.mh. (0)
8. obesity.ti,ab,id. (38333)
9. obese.ti,ab,id. (16959)
10. overweight.ti,ab,id. (16509)
11. over weight.ti,ab,id. (121)
12. (weight adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,id. (26448)
13. ((bmi or body mass ind$) adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,id. (1857)
14. weight maintenance.ti,ab,id. (585)
15. weight control.ti,ab,id. (2915)
16. weight manag$.ti,ab,id. (2573)
17. or/1-16 (68359)
18. limit 17 to (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>) (16674)
19. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,ab,id. (1007163)
20. 17 and 19 (20601)
21. 18 or 20 (22971)
22. Behavior Therapy/ (14969)
23. Cognitive Behavior Therapy/ (22006)
24. Cognitive Therapy/ (13758)
25. Cognitive Techniques/ (1714)
26. Behavior Modification/ (10616)
27. Behavior Change/ (12862)
28. Lifestyle Changes/ (1430)
29. Lifestyle/ (11356)
30. School Counseling/ (6249)
31. Psychotherapeutic Counseling/ (1582)
32. Peer Counseling/ (1193)
33. Group Counseling/ (5095)
34. Community Counseling/ (100)
35. Motivational Interviewing/ (2791)
36. Feedback/ (19799)
37. Biofeedback/ (2516)
38. Health Education/ (14055)
39. Health Promotion/ (26814)
40. Client Education/ (4324)
41. Self Regulation/ (11030)
42. Intervention/ (76044)
43. School Based Intervention/ (20729)
44. Family Intervention/ or Family Therapy/ (25344)
45. Early Intervention/ (11728)
46. aversion therapy/ (579)
47. “Acceptance and commitment therapy”/ (2199)
48. Mindfulness/ (11311)
49. Social Support/ (40010)
50. support groups/ (4452)
51. ((psychological or behavio?r$) adj (therap$ or modif$ or chang$ or strateg$ or intervention$)).ti,ab,id. (98049)
52. (group therap$ or family therap$ or cognitive therap$).ti,ab,id. (41148)
53. cbt.ti,ab,id. (15767)
54. ((lifestyle or life style) adj (chang$ or interven$ or modifi$)).ti,ab,id. (5015)
55. counsel$.ti,ab,id. (117155)
56. social$ support$.ti,ab,id. (56247)
57. (peer adj2 support).ti,ab,id. (6007)
58. ((child$ adj3 parent$) and therapy).ti,ab,id. (5834)
59. (family intervention$ or parent$ intervention$).ti,ab,id. (5311)
60. (parent$ adj2 (behavio?r$ or involv$ or control$ or attitude$ or educat$)).ti,ab. (44322)
61. health education.ti,ab,id. (11617)
62. health promotion.ti,ab,id. (21338)
63. patient education.ti,ab,id. (4030)
64. nonpharmacologic intervention$.ti,ab,id. (241)
65. non pharmacologic intervention$.ti,ab,id. (101)
66. self regulat$.ti,ab,id. (24357)
67. (school$ adj5 (intervention$ or program$)).ti,ab,id. (42385)
68. or/22-67 (596742)
69. Physical Activity/ (23149)
70. Physical Fitness/ (4617)
71. Exercise/ (25329)
72. Aerobic Exercise/ (2115)
73. Active Living/ (272)
74. (exercise or physical activity).ti,id. (43563)
75. aerobic$.ti,id. (2484)
76. (fitness adj (class$ or regime$ or program$)).ti,id. (221)
77. (physical training or physical education).ti,id. (4587)
78. (sedentary behavio?r$ adj3 reduc$).ti,ab,id. (327)
79. ((exercise or physical activity) adj5 (intervention$ or promot$)).ti,ab,id. (10999)
80. or/69-79 (58400)
81. Diets/ (14215)
82. Dietary Restraint/ (1810)
83. Food Intake/ (15257)
84. Eating Behavior/ (15100)
85. Healthy Eating/ (17)
86. “obesity (attitudes toward)”/ (423)
87. (diet or diets or dieting or dietary).ti. (10909)
88. (diet$ adj (modif$ or therapy or intervention$ or strateg$)).ti,ab,id. (1562)
89. (low calorie or calori$ control$ or healthy eating or formula diet$).ti,ab,id. (4115)
90. (weightwatcher$ or weight watcher$).ti,ab,id. (66)
91. or/81-90 (45405)
92. Interdisciplinary Treatment Approach/ (7627)
93. Collaboration/ (12978)
94. Cooperation/ (15681)
95. Case Management/ (3341)
96. Work Teams/ (5619)
97. Community Mental Health Services/ (7911)
98. Health Care Delivery/ (21685)
99. Community Psychology/ (2406)
100. Community Psychiatry/ (893)
101. client centered therapy/ (3517)
102. “continuum of care”/ (2074)
103. collaborat$.ti,ab,id. (93626)
104. (interdisciplinary or inter disciplinary).ti,ab,id. (26086)
105. (multidisciplinary or multi disciplinary).ti,ab,id. (22840)
106. (integrated adj5 (healthcare or care)).ti,ab,id. (6002)
107. care manag$.ti,ab,id. (2940)
108. case manag$.ti,ab,id. (7158)
109. cooperative care.ti,ab,id. (43)
110. coordinated care.ti,ab,id. (419)
111. patient centered care.ti,ab,id. (1878)
112. or/92-111 (200393)
113. ((weight loss or weight reduction or weight control or weight maintenance or weight management) adj3 (intervention$ or promot$ or program$)).ti,ab,id. (3796)
114. 21 and (68 or 80 or 91 or 112 or 113) (12236)
115. random$.ti,ab,id,hw. (222452)
116. placebo$.ti,ab,hw,id. (42734)
117. (controlled trial$ or control group$).ti,ab,id,hw,md. (128455)
118. clinical trial$.ti,ab,id,hw. (42444)
119. meta analy$.ti,ab,hw,id. (44562)
120. treatment outcome.md. (22302)
121. (sham or dummy).ti,ab,id. (15073)
122. (single blind$ or double blind$ or triple blind$ or treble blind$).ti,ab,id. (27654)
123. (allocated or allocation).ti,ab,id. (29340)
124. (phase iii or phase 3).ti,ab,id. (3665)
125. or/115-124 (405727)
126. 114 and 125 (2144)
127. (exp Overweight/ or weight loss/ or weight control/) and exp Drug Therapy/ (993)
128. Orlistat.ti,ab,id. (105)
129. tetrahydrolipstatin.ti,ab,id. (16)
130. Xenical.ti,ab,id. (3)
131. Alli.ti,ab,id. (39)
132. liraglutide.ti,ab,id. (99)
133. Saxenda.ti,ab,id. (1)
134. (setmelanotide or imcivree).ti,ab,id. (2)
135. or/127-134 (1186)
136. 21 and 135 (152)
137. 126 or 136 (2276)
138. limit 137 to (english language and yr="2016 -Current") (844)

Original Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL) via Wiley

Date Run: 17/02/2022 01:04:16

ID Search Hits
#1 (child* or teen or teens or teenage* or adolescen* or youth or youths or young people or (young next adult*) or pediatric* or paediatric* or schoolchildren or school children or preschool* or (pre next school*) or toddler*):ti,ab,kw 327523
#2 (obese or obesity or overweight or “over weight”):ti,ab,kw 50546
#3 (weight next gain*):ti,ab,kw or (weight next loss*):ti,ab,kw 33810
#4 ((weight next change*) or (weight next reduc*)):ti,ab,kw 11144
#5 (bmi or body mass index):ti,ab,kw near/2 (gain* or loss* or change* or reduc*):ti,ab,kw 24183
#6 “weight maintenance”:ti,ab,kw 1276
#7 “weight control”:ti,ab,kw 1811
#8 “weight management”:ti,ab,kw 2590
#9 {or #2-#8} 79480
#10 (psychological or behavior* or behaviour*):ti,ab,kw next (therap* or modif* or chang* or strateg* or intervention*):ti,ab,kw 43072
#11 psychotherapy:ti,ab,kw 13553
#12 (group or family or cognitive):ti,ab,kw next therap*:ti,ab,kw 11434
#13 cbt:ti,ab,kw 9270
#14 (lifestyle or “life style”):ti,ab,kw next (chang* or interven* or modif*):ti,ab,kw 10281
#15 counsel*:ti,ab,kw 25377
#16 (social* next support*):ti,ab,kw 8910
#17 (peer* near/2 support*):ti,ab,kw 1723
#18 (child* near/3 parent*):ti,ab,kw and therap*:ti,ab,kw 4569
#19 (family or parent*):ti,ab,kw next intervention*:ti,ab,kw 1797
#20 parent*:ti,ab,kw near/2 (behavior* or behaviour* or involv* or control* or attitude* or educat*):ti,ab,kw 6234
#21 health:ti,ab,kw next (education or promotion):ti,ab,kw 20436
#22 “patient education”:ti,ab,kw 14323
#23 (nonpharmacologic or “non pharmacologic”):ti,ab,kw next intervention*:ti,ab,kw 298
#24 (self next regulat*):ti,ab,kw 2490
#25 school*:ti,ab,kw near/5 (intervention* or program*):ti,ab,kw 7916
#26 {or #10-#25} 127173
#27 (exercise or “physical activity”):ti 49281
#28 fitness:ti,ab,kw next (class* or regime* or program*):ti 301
#29 (“physical training” or “physical education”):ti 949
#30 (sedentary next (behavior* or behaviour*)):ti,ab,kw near/3 (reduc* or mimim* or less*):ti,ab,kw 424
#31 (exercise or “physical activity”):ti,ab,kw near/5 (intervention* or promot*):ti,ab,kw 20432
#32 {or #27-#31} 58252
#33 (diet or diets or dieting or dietary):ti 22266
#34 diet*:ti,ab,kw next (modif* or therap* or intervention* or strateg*):ti,ab,kw 17057
#35 (“low calorie” or (calori* next control*) or “healthy eating”):ti,ab,kw 4284
#36 (formula next diet*):ti,ab,kw 240
#37 weightwatcher*:ti,ab,kw or (weight next watcher*):ti,ab,kw 138
#38 {or #33-#37} 34957
#39 collaborat*:ti,ab,kw 13212
#40 (interdisciplinary or “inter disciplinary”):ti,ab,kw 2302
#41 (multidisciplinary or multi-disciplinary):ti,ab,kw 6970
#42 integrated:ti,ab,kw near/5 (healthcare or care):ti,ab,kw 2777
#43 (care or case):ti,ab,kw next manag*:ti,ab,kw 5134
#44 “cooperative care”:ti,ab,kw 4
#45 “patient centered care”:ti,ab,kw 1153
#46 “stepped care”:ti,ab,kw 885
#47 “coordinated care”:ti,ab,kw 154
#48 ^335–^#^47^ 29336
#49 Orlistat:ti,ab,kw 564
#50 tetrahydrolipstatin:ti,ab,kw 95
#51 Xenical:ti,ab,kw 41
#52 Alli:ti,ab,kw 33
#53 liraglutide:ti,ab,kw 2081
#54 Saxenda:ti,ab,kw 26
#55 (setmelanotide or imcivree):ti,ab,kw 14
#56 pharmacotherap*:ti,kw 3050
#57 ^336–^#^56^ 5715
#58 ((“weight loss” or “weight reduction” or “weight control” or “weight maintenance” or “weight management”) near/3 (intervention* or promot* or program*)):ti,ab,kw 6204
#59 #26 or #32 or #38 or #48 or #57 or #58 228422
#60 #1 and #9 and #59 with Publication Year from 2016 to present, in Trials 4378

Phen/TPM

Ovid MEDLINE(R) ALL <1946 to August 04, 2022>

1. Obesity/ 205894
2. Obesity, Morbid/ 24797
3. Obesity, Abdominal/ 4716
4. Overweight/ 30788
5. Weight Gain/ 34388
6. Weight Loss/ 41804
7. Weight Cycling/ 7
8. obesity.ti,ab,kf. 299932
9. obese.ti,ab,kf. 143414
10. overweight.ti,ab,kf. 82625
11. over weight.ti,ab,kf. 529
12. (weight adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,kf. 203138
13. ((bmi or body mass ind$) adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,kf. 11138
14. weight maintenance.ti,ab,kf. 2398
15. weight control.ti,ab,kf. 6928
16. weight manag$.ti,ab,kf. 7962
17. or/1-16 583323
18. Child/ or Child, Preschool/ or Adolescent/ or Young Adult/ or Minors/ 3735743
19. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,kf. 1352057
20. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,ab,kf. 2099675
21. limit 20 to (“in data review” or in process or “pubmed not medline”) 193816
22. 17 and (18 or 19 or 21) 129454
23. Pediatric Obesity/ 12582
24. 22 or 23 130446
25. Counseling/ 38848
26. Directive Counseling/ 2429
27. Behavior therapy/ 29784
28. Aversive therapy/ 821
29. Biofeedback, Psychology/ 7632
30. Feedback, Psychological/ 3722
31. Cognitive therapy/ 29194
32. “Acceptance and commitment therapy”/ 739
33. Mindfulness/ 5476
34. Desensitization, psychologic/ 1581
35. Relaxation therapy/ 6530
36. Meditation/ 3553
37. Social Support/ 77185
38. Psychotherapy, Group/ 14412
39. Family Therapy/ 9124
40. Persuasive Communication/ 3965
41. Risk Reduction Behavior/ 14130
42. Health Education/ 63044
43. Health Promotion/ 79829
44. Patient Education as Topic/ 88112
45. “Early Intervention (Education)”/ 3422
46. ((psychological or behavio?r$) adj (therap$ or modif$ or chang$ or strateg$ or intervention$)).ti,ab,kf. 101199
47. (group therap$ or family therap$ or cognitive therap$).ti,ab,kf. 13080
48. (cbt or dcbt).ti,ab,kf. 13692
49. ((lifestyle or life style) adj (chang$ or interven$ or modif$)).ti,ab,kf. 27185
50. counsel?ing.ti,ab,kf. 110510
51. social$ support$.ti,ab,kf. 50358
52. (peer$ adj2 support$).ti,ab,kf. 7845
53. ((child$ adj3 parent$) and therap$).ti,ab,kf. 5645
54. (family intervention$ or parent$ intervention$).ti,ab,kf. 3324
55. (parent$ adj2 (behavio?r$ or involv$ or control$ or attitude$ or educat$)).ti,ab,kf. 32199
56. health education.ti,ab,kf. 39799
57. health promotion.ti,ab,kf. 39269
58. patient education.ti,ab,kf. 22608
59. nonpharmacologic intervention$.ti,ab,kf. 952
60. non pharmacologic intervention$.ti,ab,kf. 317
61. self regulat$.ti,ab,kf. 15108
62. (school$ adj5 (intervention$ or program$)).ti,ab,kf. 26858
63. or/25-62 734721
64. Exercise/ 134123
65. Physical Conditioning, Human/ 2869
66. (exercise or physical activity).ti,kf. 197107
67. aerobic$.ti,kf. 25953
68. (fitness adj (class$ or regime$ or program$)).ti,kf. 313
69. (physical training or physical education).ti,kf. 5633
70. (sedentary behavio?r$ adj3 reduc$).ti,ab,kf. 980
71. ((exercise or physical activity) adj5 (intervention$ or promot$)).ti,ab,kf. 34377
72. telerehabilitation/ 836
73. or/64-72 280908
74. diet, fat-restricted/ 3957
75. diet, reducing/ 11464
76. Diet, Carbohydrate-Restricted/ 1987
77. diet therapy/ 10915
78. Caloric Restriction/ 7024
79. Food Habits/ 90878
80. (diet or diets or dieting or dietary).ti,kf. 221781
81. (diet$ adj (modif$ or therap$ or intervention$ or strateg$)).ti,ab,kf. 22350
82. (low calorie or calori$ control$ or healthy eating).ti,ab,kf. 13225
83. formula diet$.ti,ab,kf. 716
84. (weightwatcher$ or weight watcher$).ti,ab,kf. 157
85. or/74-84 330707
86. Case management/ 10489
87. Patient care team/ 68939
88. Cooperative behavior/ 45705
89. Interprofessional Relations/ 52927
90. Continuity of patient care/ 20415
91. Patient-centered care/ 22291
92. Patient care management/ 4742
93. Delivery of Health Care, Integrated/ 14000
94. collaborat$.ti,ab,kf. 182560
95. (interdisciplinary or inter disciplinary).ti,ab,kf. 45755
96. (multidisciplinary or multi disciplinary).ti,ab,kf. 114836
97. (integrated adj5 (healthcare or care)).ti,ab,kf. 19527
98. care manag$.ti,ab,kf. 12311
99. case manag$.ti,ab,kf. 14828
100. cooperative care.ti,ab,kf. 103
101. coordinated care.ti,ab,kf. 1554
102. patient centered care.ti,ab,kf. 6879
103. stepped care.ti,ab,kf. 1551
104. telemedicine/ 34465
105. or/86-104 553153
106. Anti-Obesity Agents/ 5630
107. pharmacotherap$.ti,kf. 12269
108. Lactones/ 19481
109. Orlistat/ 1332
110. Orlistat.ti,ab,kf. 1847
111. tetrahydrolipstatin.ti,ab,kf. 212
112. Xenical.ti,ab,kf. 105
113. Alli.ti,ab,kf. 109
114. glucagon-like peptide 1/ 8986
115. liraglutide/ 2277
116. liraglutide.ti,ab,kf. 3451
117. Saxenda.ti,ab,kf. 38
118. (setmelanotide or imcivree).ti,ab,kf. 57
119. or/106-118 48475
120. Weight Reduction Programs/ 2752
121. ((weight loss or weight reduction) adj3 (intervention$ or promot$ or program$)).ti,ab,kf. 8899
122. 24 and (63 or 73 or 85 or 105 or 119 or 120 or 121) 41596
123. Pediatric Obesity/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy] 5026
124. Obesity/dh, dt, pc, rh, th 51954
125. Obesity, Morbid/dh, dt, pc, rh, th 1909
126. Obesity, Abdominal/dh, dt, pc, rh, th 521
127. Overweight/dh, dt, pc, rh, th 6813
128. or/124-127 57214
129. 128 and (18 or 19 or 21) 15327
130. 122 or 123 or 129 47070
131. (randomized controlled trial or controlled clinical trial or clinical trial or meta analysis).pt. or clinical trials as topic.sh. or exp Randomized Controlled Trials as Topic/ or (randomized or randomised or placebo or randomly or phase iii or phase 3 or clinical trial or controlled trial).ti,ab,kf. or trial.ti,kf. 1939010
132. control groups/ or double-blind method/ or single-blind method/ or random allocation/ or placebos/ 322738
133. (RCT or placebo or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or random$).ti,ab,kf. not medline.st. 220278
134. or/131-133 2084987
135. 130 and 134 10392
136. limit 135 to (english language and yr="2016 -Current") 4642
137. 24 and 119 917
138. Pediatric Obesity/dt 102
139. Obesity/dt or Obesity, Morbid/dt or Obesity, Abdominal/dt or Overweight/dt 12207
140. 139 and (18 or 19 or 21) 1331
141. 137 or 138 or 140 2035
142. limit 141 to (english language and yr="2016 -Current") 654
143. 136 or 142 4934
144. 143 not (animals/ not humans/) 4924
145. (Phentermine/ or (Phentermine or adipex-p or Lomaira or Suprenza or sentis).ti,ab,kf.) and (Topiramate/ or (Topiramate or Trokendi XR or Qudexy XR or Topamax or eprontia or Topiramic acid).ti,ab,kf.) 295
146. “PHEN/TPM”.ti,ab,kf. 16
147. 145 or 146 296
148. 24 and 147 24
149. limit 148 to (english language and yr="2012 -Current") 23
150. 149 not (animals/ not humans/) 23
151. 150 not 144 7

Phen/TPM

APA PsycInfo <1806 to July Week 4 2022>

1. obesity/ 27306
2. overweight/ 5063
3. weight gain/ 3426
4. weight control/ 5290
5. weight loss/ 4342
6. (Obesity or Obesity, Morbid or Obesity, Abdominal or Overweight).mh. 17947
7. Weight Cycling.mh. 0
8. obesity.ti,ab,id. 39147
9. obese.ti,ab,id. 17144
10. overweight.ti,ab,id. 16830
11. over weight.ti,ab,id. 124
12. (weight adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,id. 26887
13. ((bmi or body mass ind$) adj2 (gain$ or loss$ or change$ or reduc$)).ti,ab,id. 1885
14. weight maintenance.ti,ab,id. 593
15. weight control.ti,ab,id. 2964
16. weight manag$.ti,ab,id. 2642
17. or/1-16 69572
18. limit 17 to (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>) 16967
19. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or young adult$ or pediatric$ or paediatric$ or schoolchildren or school children or preschool$ or pre school$ or toddler$).ti,ab,id. 1026546
20. 17 and 19 21024
21. 18 or 20 23423
22. Behavior Therapy/ 15299
23. Cognitive Behavior Therapy/ 22693
24. Cognitive Therapy/ 13857
25. Cognitive Techniques/ 1720
26. Behavior Modification/ 10657
27. Behavior Change/ 13191
28. Lifestyle Changes/ 1460
29. Lifestyle/ 11633
30. School Counseling/ 6416
31. Psychotherapeutic Counseling/ 1606
32. Peer Counseling/ 1204
33. Group Counseling/ 5136
34. Community Counseling/ 110
35. Motivational Interviewing/ 2899
36. Feedback/ 20494
37. Biofeedback/ 2544
38. Health Education/ 14296
39. Health Promotion/ 27389
40. Client Education/ 4417
41. Self Regulation/ 11344
42. Intervention/ 79834
43. School Based Intervention/ 21323
44. Family Intervention/ or Family Therapy/ 25723
45. Early Intervention/ 11992
46. aversion therapy/ 584
47. “Acceptance and commitment therapy”/ 2348
48. Mindfulness/ 11737
49. Social Support/ 41097
50. support groups/ 4516
51. ((psychological or behavio?r$) adj (therap$ or modif$ or chang$ or strateg$ or intervention$)).ti,ab,id. 100740
52. (group therap$ or family therap$ or cognitive therap$).ti,ab,id. 41665
53. cbt.ti,ab,id. 16335
54. ((lifestyle or life style) adj (chang$ or interven$ or modifi$)).ti,ab,id. 5200
55. counsel$.ti,ab,id. 119083
56. social$ support$.ti,ab,id. 57804
57. (peer adj2 support).ti,ab,id. 6318
58. ((child$ adj3 parent$) and therapy).ti,ab,id. 5962
59. (family intervention$ or parent$ intervention$).ti,ab,id. 5445
60. (parent$ adj2 (behavio?r$ or involv$ or control$ or attitude$ or educat$)).ti,ab. 45252
61. health education.ti,ab,id. 11920
62. health promotion.ti,ab,id. 21762
63. patient education.ti,ab,id. 4143
64. nonpharmacologic intervention$.ti,ab,id. 250
65. non pharmacologic intervention$.ti,ab,id. 106
66. self regulat$.ti,ab,id. 25123
67. (school$ adj5 (intervention$ or program$)).ti,ab,id. 43297
68. or/22-67 611669
69. Physical Activity/ 24164
70. Physical Fitness/ 4714
71. Exercise/ 26025
72. Aerobic Exercise/ 2192
73. Active Living/ 273
74. (exercise or physical activity).ti,id. 44979
75. aerobic$.ti,id. 2554
76. (fitness adj (class$ or regime$ or program$)).ti,id. 224
77. (physical training or physical education).ti,id. 4741
78. (sedentary behavio?r$ adj3 reduc$).ti,ab,id. 350
79. ((exercise or physical activity) adj5 (intervention$ or promot$)).ti,ab,id. 11418
80. or/69-79 60342
81. Diets/ 14620
82. Dietary Restraint/ 1832
83. Food Intake/ 15385
84. Eating Behavior/ 15602
85. Healthy Eating/ 99
86. “obesity (attitudes toward)”/ 453
87. (diet or diets or dieting or dietary).ti. 11141
88. (diet$ adj (modif$ or therapy or intervention$ or strateg$)).ti,ab,id. 1608
89. (low calorie or calori$ control$ or healthy eating or formula diet$).ti,ab,id. 4261
90. (weightwatcher$ or weight watcher$).ti,ab,id. 68
91. or/81-90 46469
92. Interdisciplinary Treatment Approach/ 7778
93. Collaboration/ 13746
94. Cooperation/ 15925
95. Case Management/ 3387
96. Work Teams/ 5771
97. Community Mental Health Services/ 7979
98. Health Care Delivery/ 21995
99. Community Psychology/ 2449
100. Community Psychiatry/ 904
101. client centered therapy/ 3568
102. “continuum of care”/ 2136
103. collaborat$.ti,ab,id. 96686
104. (interdisciplinary or inter disciplinary).ti,ab,id. 26834
105. (multidisciplinary or multi disciplinary).ti,ab,id. 23506
106. (integrated adj5 (healthcare or care)).ti,ab,id. 6248
107. care manag$.ti,ab,id. 3017
108. case manag$.ti,ab,id. 7285
109. cooperative care.ti,ab,id. 45
110. coordinated care.ti,ab,id. 438
111. patient centered care.ti,ab,id. 1972
112. or/92-111 205848
113. ((weight loss or weight reduction or weight control or weight maintenance or weight management) adj3 (intervention$ or promot$ or program$)).ti,ab,id. 3872
114. 21 and (68 or 80 or 91 or 112 or 113) 12507
115. random$.ti,ab,id,hw. 228121
116. placebo$.ti,ab,hw,id. 43245
117. (controlled trial$ or control group$).ti,ab,id,hw,md. 131751
118. clinical trial$.ti,ab,id,hw. 43475
119. meta analy$.ti,ab,hw,id. 46548
120. treatment outcome.md. 22707
121. (sham or dummy).ti,ab,id. 15434
122. (single blind$ or double blind$ or triple blind$ or treble blind$).ti,ab,id. 28058
123. (allocated or allocation).ti,ab,id. 30101
124. (phase iii or phase 3).ti,ab,id. 3751
125. or/115-124 415291
126. 114 and 125 2205
127. (exp Overweight/ or weight loss/ or weight control/) and exp Drug Therapy/ 1007
128. Orlistat.ti,ab,id. 105
129. tetrahydrolipstatin.ti,ab,id. 16
130. Xenical.ti,ab,id. 3
131. Alli.ti,ab,id. 40
132. liraglutide.ti,ab,id. 106
133. Saxenda.ti,ab,id. 1
134. (setmelanotide or imcivree).ti,ab,id. 2
135. or/127-134 1206
136. 21 and 135 153
137. 126 or 136 2338
138. limit 137 to (english language and yr="2016 -Current") 900
139. ((Phentermine or adipex-p or Lomaira or Suprenza or sentis) and (Topiramate or Trokendi XR or Qudexy XR or Topamax or eprontia or Topiramic acid)).ti,ab,id. 25
140. “PHEN/TPM”.ti,ab,id. 2
141. 139 or 140 25
142. 21 and 141 0

Phen/TPM

Cochane via Wiley

Date Run: 06/08/2022 03:08:18

ID Search Hits
#1 (child* or teen or teens or teenage* or adolescen* or youth or youths or young people or (young next adult*) or pediatric* or paediatric* or schoolchildren or school children or preschool* or (pre next school*) or toddler*):ti,ab,kw 334893
#2 (obese or obesity or overweight or “over weight”):ti,ab,kw 51655
#3 (weight next gain*):ti,ab,kw or (weight next loss*):ti,ab,kw 34377
#4 ((weight next change*) or (weight next reduc*)):ti,ab,kw 11022
#5 (bmi or body mass index):ti,ab,kw near/2 (gain* or loss* or change* or reduc*):ti,ab,kw 24845
#6 “weight maintenance”:ti,ab,kw 1288
#7 “weight control”:ti,ab,kw 1821
#8 “weight management”:ti,ab,kw 2654
#9 {or #2-#8} 81090
#10 (psychological or behavior* or behaviour*):ti,ab,kw next (therap* or modif* or chang* or strateg* or intervention*):ti,ab,kw 44336
#11 psychotherapy:ti,ab,kw 13876
#12 (group or family or cognitive):ti,ab,kw next therap*:ti,ab,kw 11484
#13 cbt:ti,ab,kw 9473
#14 (lifestyle or “life style”):ti,ab,kw next (chang* or interven* or modif*):ti,ab,kw 10689
#15 counsel*:ti,ab,kw 26085
#16 (social* next support*):ti,ab,kw 9198
#17 (peer* near/2 support*):ti,ab,kw 1795
#18 (child* near/3 parent*):ti,ab,kw and therap*:ti,ab,kw 4745
#19 (family or parent*):ti,ab,kw next intervention*:ti,ab,kw 1842
#20 parent*:ti,ab,kw near/2 (behavior* or behaviour* or involv* or control* or attitude* or educat*):ti,ab,kw 6440
#21 health:ti,ab,kw next (education or promotion):ti,ab,kw 21203
#22 “patient education”:ti,ab,kw 14568
#23 (nonpharmacologic or “non pharmacologic”):ti,ab,kw next intervention*:ti,ab,kw 298
#24 (self next regulat*):ti,ab,kw 2578
#25 school*:ti,ab,kw near/5 (intervention* or program*):ti,ab,kw 8120
#26 {or #10-#25} 130896
#27 (exercise or “physical activity”):ti 50809
#28 fitness:ti,ab,kw next (class* or regime* or program*):ti 305
#29 (“physical training” or “physical education”):ti 984
#30 (sedentary next (behavior* or behaviour*)):ti,ab,kw near/3 (reduc* or mimim* or less*):ti,ab,kw 436
#31 (exercise or “physical activity”):ti,ab,kw near/5 (intervention* or promot*):ti,ab,kw 21201
#32 {or #27-#31} 60183
#33 (diet or diets or dieting or dietary):ti 22625
#34 diet*:ti,ab,kw next (modif* or therap* or intervention* or strateg*):ti,ab,kw 17251
#35 (“low calorie” or (calori* next control*) or “healthy eating”):ti,ab,kw 4361
#36 (formula next diet*):ti,ab,kw 242
#37 weightwatcher*:ti,ab,kw or (weight next watcher*):ti,ab,kw 137
#38 {or #33-#37} 35465
#39 collaborat*:ti,ab,kw 13707
#40 (interdisciplinary or “inter disciplinary”):ti,ab,kw 2398
#41 (multidisciplinary or multi-disciplinary):ti,ab,kw 7266
#42 integrated:ti,ab,kw near/5 (healthcare or care):ti,ab,kw 2881
#43 (care or case):ti,ab,kw next manag*:ti,ab,kw 5239
#44 “cooperative care”:ti,ab,kw 4
#45 “patient centered care”:ti,ab,kw 1206
#46 “stepped care”:ti,ab,kw 894
#47 “coordinated care”:ti,ab,kw 158
#48 ^335–^#^47^ 30372
#49 Orlistat:ti,ab,kw 569
#50 tetrahydrolipstatin:ti,ab,kw 93
#51 Xenical:ti,ab,kw 42
#52 Alli:ti,ab,kw 33
#53 liraglutide:ti,ab,kw 2118
#54 Saxenda:ti,ab,kw 27
#55 (setmelanotide or imcivree):ti,ab,kw 24
#56 pharmacotherap*:ti,kw 3059
#57 ^336–^#^56^ 5775
#58 ((“weight loss” or “weight reduction” or “weight control” or “weight maintenance” or “weight management”) near/3 (intervention* or promot* or program*)):ti,ab,kw 6286
#59 #26 or #32 or #38 or #48 or #57 or #58 234840
#60 #1 and #9 and #59 with Publication Year from 2016 to present, in Trials 4582
#61 (Phentermine or adipex-p or Lomaira or Suprenza or sentis) AND (Topiramate or “Trokendi XR” or “Qudexy XR” or Topamax or eprontia or “Topiramic acid”):ti,ab,kw 106
#62 “PHEN/TPM”:ti,ab,kw 47
#63 #61 or #62 108
#64 #1 and #9 and #63 with Publication Year from 2012 to present, in Trials 15
#65 #64 not #60 10

Appendix A Table 1 Inclusion and Exclusion Criteria

| Include | Exclude
Condition definition | Studies identifying children with higher BMI, using measures such as BMI percentile (e.g., ≥85th percentile or ≥95th percentile), BMI z-score, percent overweight, or waist circumference
Aim | Studies with a primary aim of promoting weight reduction or stabilization, or maintenance of previous weight reduction or stabilization | Healthy lifestyle counseling with no weight-related aim
Population | Children and adolescents ages 2 to 18 years; - Age- and sex-specific BMI ≥85th percentile or meets other similar criteria for higher BMI; - Previously had higher BMI and is now engaged in maintenance of weight loss or improved weight trajectory | - Studies with an average age younger than 2 years or older than 18 years; - Populations limited exclusively to youth who:; ○ Have an eating disorder; ○ Are pregnant or postpartum; ○ Have medical conditions, such as diabetes (type 1 or 2), polycystic ovarian syndrome, hypothyroidism, Cushing’s syndrome, growth hormone deficiency, insulinoma, hypothalamic disorders (e.g., Froelich syndrome, Bardet-Biedl syndrome, or Prader-Willi syndrome), asthma, or intellectual and developmental disabilities, or who are using medication associated with weight gain (e.g., antipsychotics); ○ Are in college (unless primarily includes persons age 18 years and younger)
Intervention | - Weight management interventions include behavioral counseling, pharmacotherapy, and healthcare system–level approaches; - Designed to promote weight reduction or stabilization, or maintenance of previous weight reduction or stabilization; - May include the following, alone or in combination:; ○ Behavioral-based interventions (e.g., behavior modification, cognitive behavioral therapy, mindfulness interventions, or health-behavior change counseling and coaching); ○ Pharmacologic interventions approved by the FDA for weight loss (i.e., orlistat and liraglutide); ○ Health system–level interventions (e.g., stepped care or collaborative care); - Must be either conducted in a primary care setting, feasible in “usual” primary care, or referable from primary care. Must at least involve the healthcare system in some way (may be limited to recruitment) | - Primary prevention in children who are normal weight; - Surgical interventions; - Studies that include elements that cannot be implemented in the healthcare setting (e.g., changes in the physical/built environment or legislation); - Complementary and alternative medicine approaches (e.g., herbal supplements, acupuncture, Chinese medicine, or yoga); - Studies that provide all or most of participants’ food; - Pharmacologic interventions not approved for weight loss by the FDA (e.g., metformin)
Comparator | Control groups with:; - No intervention (e.g., wait-list control or usual care); - Minimal intervention (e.g., pamphlets or single annual session presenting information similar to what intervention groups receive through usual care in a primary care setting); - Attention control (e.g., similar format and intensity of intervention on a different content area); - Weight-neutral healthy lifestyle intervention; - Placebo or no medication control for medication trials (both groups may include a behavioral weight management component) | Comparative effectiveness studies; the following components are too intensive to be considered usual care, so would be considered active comparators, including:; - Personalized prescription for weight loss and exercise based on standardized dietary assessment; - Homework, such as study-provided self-help workbooks with a weight loss focus; - More than two annual intervention contacts (unless content not related to weight loss)
Outcomes | Health outcomes:; - Cardiovascular or weight-related morbidity or mortality; - Quality of life or functioning; - Depression; Intermediate outcomes:; - Reduction or stabilization of weight or adiposity (required outcome). Acceptable measures include weight (kilograms or pounds), age- and sex-normative weight (BMI percentile, percent of the median BMI, percent of the 95th percentile BMI, or z-score for age and sex), relative weight (BMI or percent overweight), total adiposity (e.g., dual-energy x-ray absorptiometry, underwater weight, or comparable), other similar measures, or change in any of these measures; - Weight maintenance after an intervention has ended; - Cardiometabolic measures (included only when weight-related measures are also reported): insulin resistance/blood glucose/diabetes, blood pressure/hypertension, lipid levels/dyslipidemia, or metabolic syndrome; - Liver dysfunction/nonalcoholic fatty liver disease; - Physical fitness capacity or performance; Behavioral Outcomes:; - Dietary pattern score; - Minutes per week of moderate-to-vigorous physical activity or MET-minutes per week; - Percent meeting physical activity goals; - Sedentary behavior or screen time; Harms:; - Harms associated with labeling; - Stigma or increased body image concerns or negative mental health effects; - Negative impacts on provider-patient relationship (e.g., care avoidance or dissatisfaction with care); - Unhealthy weight management efforts (e.g., using laxatives or self-induced vomiting) or eating patterns (excessive fasting, overly restrictive eating, or binging); - Suppressed growth; - Exercise-induced injury; - Serious treatment-related harms at any time after initiation of intervention (i.e., death or medical issue requiring hospitalization or urgent medical treatment) or other treatment-related harms reported in trials meeting inclusion criteria for intermediate or health outcomes | - Individual dietary intake components (e.g., fats, fiber, fruits, and vegetables); - Kilocalories/day
Timing of outcome assessment | All KQs (except serious harms of pharmacotherapy): ≥6 months after baseline or beginning of weight loss phase; KQ 4 (serious harms of pharmacotherapy): No minimum followup. Serious harms are events resulting in death, hospitalization, or the need for urgent medical treatment
Setting | - Primary care settings (e.g., pediatrics, family medicine, or school-based health clinics); - Other outpatient healthcare settings; - Phone, mobile, or virtual settings (e.g., online intervention, if there is some connection to a health setting, such as recruitment from a healthcare setting); - Community or research settings, if there is some connection to a health setting (e.g., recruitment from a healthcare setting) | - Community/university research laboratories or other nonmedical centers; - College settings; - Mental health clinics (unless recruitment is through primary care screening); - Correctional facilities; - School classrooms; - Worksites; - Inpatient/residential facilities; - Emergency departments
Study design | All KQs: Randomized, controlled trials; KQ 4 (serious harms of pharmacotherapy): Large nonrandomized studies of interventions, defined as quantitative studies estimating the harms of an intervention that does not use randomization to allocate units to intervention groups. Such studies include those in which allocation occurs in the course of usual treatment decisions or according to patients’ choices | All other study designs
Country | Studies that take place in countries categorized as “Very High” on the 2019 Human Development Index (as defined by the United Nations Development Programme) | Primary studies that are conducted in countries that are not categorized as “Very High” on the Human Development Index
Language | English | Languages other than English
Study quality | Fair or good | Poor, according to design-specific USPSTF criteria

Appendix A Table 2 Study-Specific Quality Rating Criteria^*^

Study Design | Adapted Quality Criteria
Randomized and non-randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer

Appendix A Figure 1 Literature Flow Diagram

This figure is a flow chart that summarizes the search and selection of articles in the review. There were 11,402 citations identified through literature databases. An additional 11 citations were identified from outside sources such as reference lists and suggestions from peer reviewers, and 101 citations were from the previous review of this topic. After duplicates were removed, 6,878 unique citations were screened at the title/abstract stage. The full-text of 351 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=20), Key Question 2 (k=56), Key Question 3 (k=23), and Key Question 4 (k=27). Reasons for excluding the other articles are available in Appendix C.